# Exact Search Strings and Results

Table 1 Preliminary PubMed search strategies

Preliminary Search Terms | | Preliminary Search Results
#1 | “Nitrous Oxide”[Mesh] OR “nitrous oxide”[tw] OR “N2O”[tw] OR “laughing gas”[tw] OR “Entonox “[Substance Name] OR Entonox[tw] OR Equanox[tw] OR Kalinox[tw] OR Medimix[tw] OR “Dinitrogen Monoxide”[tw] OR Kalinox[tw] OR Medimix[tw] OR “Dinitrogen Monoxide”[tw] | 19,052
#2 | “Labor Pain”[Mesh] OR “Labor, Obstetric”[Mesh] OR labor[tw] OR “parturition”[MeSH Terms] OR “pregnancy”[MeSH Terms] OR “pregnancy”[tw] OR “Analgesia, Obstetrical”[mh] OR “obstetric”[tw] OR birth[tw] OR childbirth[tw] OR labour[tw] OR intrapartum[tw] OR delivery, obstetric[mh] | 867,187
#3 | #1 AND #2 AND eng[la] AND humans[mh] | 646
#4 | #3 AND letter[pt] | 27
#5 | #3 AND comment[pt] | 14
#6 | #3 AND case reports[pt] | 50
#7 | #3 AND review[pt] | 72
#8 | #3 AND news[pt] | 2
#9 | #3 AND editorial[pt] | 5
#10 | #3 AND historical article[pt] | 6
#11 | #3 AND meta-analysis[pt] | 1
#12 | #3 NOT (#4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11) | 495*

Table 2 EMBASE search strategies

Preliminary Search Terms | | Preliminary Search Results
#1 | nitrous oxide.mp. or nitrous oxide/ or entonox.mp. or nitrous oxide plus oxygen/ or n20.mp. or laughing gas.mp. or equanox.mp. or kalinox.mp. or medimix.mp. or dinitrogen monoxide.mp. | 30,451
#2 | pregnancy/ or pregnancy.mp. or CHILDBIRTH/ or childbirth.mp. or labor pain.mp. or labor pain/ or obstetric analgesia.mp. or obstetric analgesia/ or delivery/ or delivery.mp. or INTRAPARTUM CARE/ or intrapartum.mp. or LABOR/ or labor.mp. | 537,234
#3 | #1 AND #2 | 1,789
#4 | Limit #3 to (human and english language) | 1,178
#5 | Limit #4 to (editorial or letter or “review”) | 319
#6 | #4 NOT #5 | 859*

Table 3 CINAHL search strategies

Preliminary Search Terms | | Preliminary Search Results
#1 | (MH “Nitrous Oxide”) OR “nitrous oxide” OR “N2O” OR “laughing gas” OR Entonox OR Equanox OR Kalinox OR Medimix OR “Dinitrogen Monoxide” | 925
#2 | (MH “Pregnancy”) OR (MH “Childbirth”) OR (MH “Labor”) OR (MH “Labor Pain”) OR “labor pain” OR pregnancy OR childbirth OR birth OR labour OR intrapartum OR (MH “Analgesia, Obstetrical”) OR (MH “Delivery”) | 100,226
#3 | #1 AND #2 | 90
#4 | #3 AND PT ( Commentary OR Editorial OR Letter OR Review ) | 21
#5 | #3 NOT #4 | 69