# Acronyms/Abbreviations/Symbols

±: plus or minus
≤: less than or equal to
≥: greater than or equal to
%: percent
ACGIH: American Conference of Governmental Industrial Hygienists
AE: adverse events
AHRQ: Agency for Healthcare Research and Quality
ANSI: American National Standard Institute
BUN: blood urea nitrogen
CGA: Compressed Gas Association
CI: confidence interval(s)
CINAHL: Cumulative Index to Nursing and Allied Health Literature
cm: centimeter
DHHS: Department of Health and Human Services
etc.: et cetera
EPA: United States Environmental Protection Agency
EPC: Evidence-based Practice Center
FDA: United States Food and Drug Administration
fl: fluid liter
g: gram(s)
g/dl: gram per decaliter
g/ml: grams per milliliter
Hb: hemoglobin
IM: intramuscular
Kg: kilogram
KQ: Key Question
mcM/L: micrometer per liter
mcmol/L: micromolar
mEq/L: milliequivalents per liter
Mg: milligram
mg/dl: milligrams per deciliter
min: minute(s)
ml: milliliter
mm: millimeter
mmHg: millimeters of mercury
mOsm/kg: milliosmoles per kilogram of water
mU/min: milliunits per minute
n, N: number
NACS: Neonatal Adaptive Capacity Scores
NFPA: National Fire Protection Association
NIOSH: National Institute for Occupational Health and Safety
NR: not reported
NS: not significant
N_2_O: nitrous oxide
OSHA: Occupational Safety and Health Administration
O_2_: oxygen
P, p: p value
pH: power of hydrogen
PICOTS: Population(s), Intervention(s), Comparator(s), Outcome(s), Timing, Setting(s)
PCO_2_: partial pressure of carbon dioxide
PO_2_: oxygen partial pressure
ppm: parts per million
pt: patient
RCT: randomized controlled trial
REL: recommended exposure limit
RR: relative risk
SD: standard deviation
SE: standard error
SGA: small for gestational age
TENS: transcutaneous electric nerve stimulation
TEP: technical expert panel
TLV: threshold limit value
torr: non-SI unit of pressure
TSCA: Toxic Substances Control Act
UCSF: University of California, San Francisco
U.S.: United States
USP: United States Pharmacopeia
VAS: visual analogue scale
vs.: versus
w/: with
wk(s): week(s)
yr(s): year(s)
μg/l: micrograms per liter