# Methods

## Topic Development and Refinement

During the topic refinement stage, the Key Questions (KQs) were refined with the help of an eight-person Key Informant group representing clinicians (cardiology, primary care, cardiac surgery), patients, scientific experts, and Federal agencies. We solicited input from the Task Order Officer and an eight-person Technical Expert Panel (TEP) with experts knowledgeable in CAD, PCI, and CABG throughout our evidence review and followed, based on an a priori research protocol, the Effective Health Care Program’s Methods Guide for Effectiveness and Comparative Effectiveness Reviews33 (hereafter referred to as Methods Guide) for literature search strategies, inclusion/exclusion of studies, abstract screening, data abstraction and management, assessment of methodological quality of individual studies, data synthesis, and grading of evidence for each KQ. All Key Informant and TEP participants were screened for conflicts of interest, and any potential conflicts were balanced or mitigated.

### Analytic Framework

Figure 1 shows the analytic framework for the systematic review of the comparative effectiveness of treatment strategies for women with CAD.

Figure 1 Analytic framework

CABG = coronary artery bypass graft; CAD = coronary artery disease; KQ = Key Question; MACE = major adverse cardiovascular events; MI = myocardial infarction; NSTEMI = non-ST elevation myocardial infarction; PCI = percutaneous coronary intervention; STEMI = ST elevation myocardial infarction

Figure 1 depicts the key questions (KQs) within the context of the PICO (population, interventions, comparators, and outcomes) described elsewhere in this document. In general, the figure shows that KQ 1 focuses on the population of women presenting with ST elevation myocardial infarction. KQ 1a considers the effectiveness of optimal medical therapy (i.e., fibrinolytics) versus percutaneous coronary intervention (PCI) on clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, unstable angina, heart failure, repeat hospitalization, length of hospital stay, angina relief, quality of life, or cognitive effects). KQ 1b considers the modifiers of effectiveness (e.g., age, race, demographic and socioeconomic risk factors; coronary disease risk factors; angiography-specific factors; and hospital characteristics). KQ 1c considers the safety concerns associated with each treatment strategy (e.g., adverse drug reactions, radiation exposure, access site complications, renal dysfunction, anaphylaxis, arrhythmias, stent thrombosis, bleeding, infections). KQ 2 focuses on the population of women presenting with unstable angina or non-ST elevation myocardial infarction. KQ 2a considers the effectiveness of initial conservative therapy versus early invasive therapy (PCI or CABG) on clinical outcomes. KQ 2b considers the associated modifiers of effectiveness, and KQ 2c considers the associated safety concerns. KQ 3 focuses on the population of women presenting with stable angina or unstable angina. KQ 3a considers the effectiveness of two treatment strategies on clinical outcomes: (1) optimal medical therapy versus mechanical revascularization (PCI or CABG) in women with stable angina and (2) PCI versus CABG in women with stable or unstable angina. KQ 3b considers the associated modifiers of effectiveness, and KQ 3c considers the associated safety concerns.

## Literature Search Strategy

### Sources Searched

We included studies published in English from January 1, 2001, through December 12, 2011. Search strategies were specific to each database in order to retrieve the articles most relevant to the KQs. Our search strategy used the National Library of Medicine’s medical subject headings (MeSH) keyword nomenclature developed for MEDLINE^®^ and adapted for use in other databases. In consultation with our research librarians, we used PubMed^®^, Embase^®^, the Cochrane Database of Systematic Reviews, and the Cochrane Central Registry of Controlled Trials for our literature search. We also searched the grey literature of study registries and conference abstracts for relevant articles from completed RCTs. Grey literature databases included Clinicaltrials.gov; metaRegister of Controlled Trials; ClinicalStudyResults.org; WHO: International Clinical Trials Registry Platform Search Portal; and ProQuest COS Conference Papers Index. The exact search strings used in our strategy are given in Appendix A. The reference list of articles applicable to the relevant KQs of two previous AHRQ reports related to this topic34,35 and from identified systematic reviews and meta-analyses was manually hand-searched and cross-referenced against our library, and additional manuscripts were retrieved. All citations were imported into an electronic bibliographic database (EndNote^®^ Version X4; Thomson Reuters, Philadelphia, PA).

## Process for Study Selection

### Screening for Inclusion and Exclusion

We developed a list of article inclusion and exclusion criteria for the KQs (Table 2). This review focused on randomized controlled studies since this is the strongest study design for evaluating treatment effectiveness and since observational studies contain potential biases (e.g., patient selection bias, intervention bias) that could affect the clinical outcome. The TEP approved this approach given that the number of abstracts identified in PubMed exceeded 5,000. This review focused on comparisons of treatment strategies; therefore, differences in specific drugs or devices were not investigated and were considered beyond the scope. Using the prespecified inclusion and exclusion criteria, titles and abstracts were examined independently by two reviewers for potential relevance to the KQs. Articles included by any reviewer underwent full-text screening. At the full-text screening stage, two independent reviewers read each article to determine if it met eligibility criteria. At the full-text review stage, paired researchers independently reviewed the articles and indicated a decision to “include” or “exclude” the article for data abstraction. When the paired reviewers arrived at different decisions about whether to include or exclude an article, they reconciled the difference through a third-party arbitrator. Articles meeting our eligibility criteria were included for data abstraction. Relevant review articles, meta-analyses, and methods articles were flagged for manual searching and cross-referencing against the library of citations identified through electronic database searching.

Table 2 Summary of inclusion and exclusion criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | Adult women (≥18 years of age) with CAD and angiographically proven single- or multiple-vessel disease including STEMI, NSTEMI, and stable angina | - Study population was composed entirely of patients without CAD, or the population also included patients with CAD but results were not reported separately for the subgroup with CAD; - Study did not include women, or results were not reported by sex; - All subjects under age 18, or some subjects under age 18, but results were not broken down by age; - Study did not report any of the primary or secondary outcomes of interest
Interventions and comparators | Article reported original data for any of the interventions compared with another treatment category; or a related methodology paper of an included article; - Optimal medical therapy alone; - PCI (bare-metal and drug-eluting stents) with optimal medical therapy; - CABG with optimal medical therapy | Intervention comparisons within the same treatment category such as:; - Medical therapy with medical therapy (e.g., one type of fibrinolysis drug compared with another fibrinolysis drug); - PCI with PCI (e.g., bare-metal stent compared with drug-eluting stent); - CABG with CABG (e.g., open sternotomy compared with minimally invasive CABG)
Outcomes and effect modifiers | - Primary outcomes: major adverse cardiovascular events such as death, nonfatal myocardial infarction, stroke, and repeat revascularization; - Other clinical outcomes: heart failure, repeat hospitalization, length of hospital stay, unstable angina, graft failure, angina relief, quality of life, cognitive effects; - Adverse effects of interventions: adverse drug reactions, radiation exposure, access site complications, renal dysfunction, anaphylaxis, arrhythmias, stent thrombosis, bleeding, infections; Effect modifiers—individual characteristics including the following:; - Age, race, or other demographic and socioeconomic risk factors; - Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease; - Angiographic-specific factors such as access site (radial or femoral), number of diseased vessels, vessel territory stenoses, left ventricular function, or prior PCI or CABG revascularization procedure; - CABG-specific factors such as type of surgery performed (traditional or robot-assisted), cardiopulmonary bypass mode (normothermic vs. hypothermic), on-pump vs. off-pump, type of cardioplegia used (blood vs. crystalloid), or use of saphenous vein grafts, single or bilateral internal mammary artery grafts, or other types of bypass grafts; - Hospital characteristics (hospital patient volume, setting, guideline-based treatment protocols) | - Outcomes of women not reported separately from total population; - Study did not report any of the primary or secondary outcomes of interest; Outcomes of women not reported separately from total population
Timing | Short-term (≤30 days), intermediate-term (1 year), or long-term (>1 year) | None
Setting | Inpatient or outpatient, primarily primary care and cardiology clinics | None
Study design | Randomized controlled trial (strongest study design for evaluating treatment effectiveness) | - Observational (retrospective or prospective cohort) studies, due to potential biases that could affect the clinical outcome (e.g., patient selection bias, intervention bias); - Not a clinical study (e.g., editorial, nonsystematic review, letter to the editor, case series). Systematic reviews and meta-analyses were excluded from abstraction but hand-searched as potential sources of additional material if relevant to the topic.
Publication languages | English only | Given the high volume of English-language publications (including the majority of known important studies), non-English articles were excluded

CABG = coronary artery bypass grafting; CAD = coronary artery disease; NSTEMI = non-ST elevation myocardial infarction; PCI = percutaneous coronary intervention; STEMI = ST elevation myocardial infarction

## Data Extraction and Data Management

The investigative team created forms for abstracting the data elements for the KQs. The abstraction forms were pilot tested with a sample of included articles to ensure that all relevant data elements were captured and that there was consistency and reproducibility between abstractors for accuracy. Based on their clinical and methodological expertise, two researchers were assigned to abstract data from the eligible articles pertaining to the research questions. One researcher abstracted the data, and the second overread the article and the accompanying abstraction form to check for accuracy and completeness. Disagreements were resolved by consensus or by obtaining a third reviewer’s opinion if consensus was not reached by the first two researchers. Guidance documents were drafted and given to the researchers as reference material to perform data abstraction, thus aiding in both reproducibility and standardization of data collection.

To aid in both reproducibility and standardization of data collection, researchers received data abstraction instructions directly on each form created specifically for this project with the DistillerSR data synthesis software program (Evidence Partners Inc., Manotick, ON, Canada). We designed the data abstraction forms for this project to collect the data required to evaluate the specified eligibility criteria for inclusion in this review as well as to collect demographics and outcomes. The safety outcomes abstracted included adverse drug reactions, radiation exposure, access-site complications, renal dysfunction, anaphylaxis, arrhythmias, stent thrombosis, bleeding, and infections—which are the more common adverse events resulting from medical therapy and revascularization.

Appendix B lists the elements used in the data abstraction form. Appendix C contains a bibliography of all studies included in this review, organized alphabetically by author. When appropriate, methods articles providing additional detail were considered when abstracting data for an included study. If a methods article was used as a source for information in the abstraction of a study, it was included in the review and is listed in the bibliography in Appendix C.

## Individual Study Quality Assessment

Study quality was assessed on the basis of the reported methods and results and performed by two reviewers. We evaluated the quality of individual studies using the approach described in the Methods Guide.33 To evaluate methodological quality, we applied criteria for RCTs that were derived from the core elements described in the Methods Guide. To indicate the summary judgment of the quality of the individual studies, we used the summary ratings of Good, Fair, and Poor based on the study’s adherence to well-accepted standard methodologies and adequate reporting.

We used data abstracted on the population studied, the intervention and comparator, the outcomes measured, settings, and timing of assessments to identify specific issues that may have limited the applicability of individual studies or a body of evidence as recommended in the Methods Guide.33 We used these data to evaluate the applicability to clinical practice, paying special attention to study eligibility criteria, demographic features of the enrolled population (e.g., age, race/ethnicity, sex) in comparison with the target population, version or characteristics of the intervention used in comparison with therapies currently in use (e.g., specific components of treatments considered to be “optimal medical therapy,” plus advancements in PCI or CABG techniques that have changed over time), and clinical relevance and timing of the outcome measures. We summarized issues of applicability qualitatively. Appendix D summarizes our assessment of the quality and applicability for each included study.

## Data Synthesis

We synthesized the primary literature by continuous (e.g., age, event rates) and categorical data (e.g., race/ethnicity, presence of coronary disease risk factors). We determined the feasibility of completing a quantitative synthesis (i.e., meta-analysis). The feasibility of a meta-analysis depended on the volume of relevant literature (2 or more studies), and clinical and methodological homogeneity of the studies. When a meta-analysis was appropriate, we used random-effects models to quantitatively synthesize the available evidence (Review Manager software Version 5.1.; Copenhagen: The Nordic Cochrane Centre, The Cochrane Collaboration, 2011). We tested for heterogeneity while recognizing that the ability of statistical methods to detect heterogeneity may be limited. When feasible, we used similar composite outcomes in the meta-analysis for two reasons: (1) a majority of studies reported a composite outcome (e.g., death,/MI/stroke/revascularization) as their primary endpoint and (2) many of the studies reported results for women for the primary composite outcome but not for each individual (secondary) outcome. We presented summary odds ratio estimates, standard errors, and confidence intervals.

The majority of outcomes within this report were binary or categorical; therefore, we summarized these outcomes by proportions. We summarized inherently continuous variables, such as age, by mean, median, and standard deviation.

## Grading the Body of Evidence

The strength of evidence for each KQ was assessed by using the approach described in the Methods Guide.33 The evidence was evaluated by using the four required domains: risk of bias (low, medium, or high), consistency (consistent, inconsistent, or unknown/not applicable), directness (direct or indirect), and precision (precise or imprecise). All the studies were randomized controlled trials and most were of good quality, resulting in a low risk of bias. To rate consistency, we looked at the test of heterogeneity and the I^2^ value; any significant test of heterogeneity or I^2^ value greater than 50 percent was rated as inconsistent. To rate directness, we looked at the composite outcome used in the meta-analysis; any inclusion of softer endpoints (e.g., revascularization or heart failure) in the composite outcome, or differences in the composite endpoint between studies, was rated as indirect. To rate precision, we looked at the effect sizes used in the power calculations of the trials to determine a clinically meaningful reduction in odds. For a negative finding, a confidence interval narrow enough to exclude a less than 30 percent reduction (or increase) was rated as precise. Additionally, when appropriate, the studies were evaluated for the presence of confounders that would diminish an observed effect, the strength of association (magnitude of effect), and publication bias.

The strength of evidence was assigned an overall grade of High, Moderate, Low, or insufficient according to the following four-level scale:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence either is unavailable or does not permit estimation of effect.

## Peer Review and Public Commentary

The peer review process was our principal external quality-monitoring device. Nominations for peer reviewers were solicited from several sources, including the TEP and interested Federal agencies. The list of nominees was forwarded to AHRQ for vetting and approval. A list of reviewers submitting comments on the draft report is included in the Preface.