# Introduction

## Background

Cardiovascular disease remains the leading cause of death among women in the United States.1 More than 500,000 women die of cardiovascular disease each year, exceeding the number of deaths in men and the next seven causes of death in women combined. This translates into approximately one death every minute.1,2 Coronary artery disease (CAD)—which includes coronary atherosclerotic disease, myocardial infarction, acute coronary syndrome, and angina—is the most prevalent form of cardiovascular disease and is the largest subset of this mortality. An estimated 16.3 million Americans 20 years of age and older have CAD, and the overall CAD prevalence is 7 percent in adults in the United States (8.3% for men, 6.1% for women). The prevalence of CAD is higher in men than in women across different age groups until they reach 75 years of age, thus giving the perception that CAD is a male-specific disease.1

The morbidity associated with this disease is also considerable. The estimated annual incidence of myocardial infarction is 610,000 new heart attacks; the average age at first myocardial infarction is 64.5 years for men and 70.3 for women. Many more individuals are hospitalized for unstable angina and for evaluation and treatment of stable chest pain syndromes. Recent data have shown a decrease in mortality rate in women, but reductions are well behind those obtained in men and are mainly in older women—still leaving the greater discrepancy in mortality rate limited to younger patients.3–5

This report focuses on women because of the differences in clinical presentation and coronary anatomy, which affect the treatment options for CAD.6–8 Currently available guidelines and systematic reviews provide specific treatment recommendations for women only among a subset of treatment options and overall assume that treatment options are equally effective for both sexes when gender data are not available. However, women have a worse prognosis than men for manifestations of CAD such as acute myocardial infarction, and some data suggest that women and men do not respond equally to the same treatments. Further, women are more likely than men to experience bleeding complications.9–12

In women, CAD is misdiagnosed or not treated as aggressively as in men or is underresearched.4,13,14 Multiple factors15 are likely to contribute to the lower use of evidence-based medicine (medical therapy and/or coronary revascularization) and the higher rate of cardiovascular complications among women with CAD.6 These factors include:

- Cardiovascular disease affects women later in life.1,15–17
- At the time CAD is diagnosed, women are more likely to have comorbid factors such as diabetes mellitus, hypertension, hypercholesterolemia, peripheral vascular disease, and heart failure.13
- Women present with angina-equivalent symptoms such as dyspnea or atypical symptoms more often than men.18,19
- The coronary vessels in women tend to be smaller than those of men, which makes them more difficult to revascularize percutaneously and surgically,20 and microvascular disease of the coronary arteries is more common in women than in men.21
- Women tend to have less extensive CAD and a higher proportion of nonobstructive CAD.22,23
- Delay in hospitalization, symptom pattern and recognition, and higher frequency of nonobstructive CAD ultimately results in delay in diagnosis and effective treatment.15,16,24,25
- Because of underrepresentation of women in RCTs, a lack of solid data on cardiovascular disease in women leaves uncertainty about the risk-benefit ratio of treatment.26,27

Thus, a better understanding of the evidence for the effectiveness of medical treatment and revascularization therapies specifically in women is needed in order to reduce cardiovascular events in women.

### Clinical Presentations of CAD

Coronary artery disease is the presence of atherosclerosis in the epicardial coronary arteries. Atherosclerotic plaques may either rupture and cause acute ischemia or progressively narrow the coronary artery lumen, resulting in chronic stable angina. Acute myocardial ischemia occurs when an atheromatous plaque ruptures or splits. The reasons for why a specific plaque ruptures when it does are unclear but probably relate to plaque morphology, plaque calcium content, and plaque softening due to an inflammatory process. Rupture exposes collagen and other thrombogenic material, which activates platelets and the coagulation cascade, resulting in an acute thrombus that interrupts coronary blood flow and causes some degree of myocardial ischemia. The consequences of acute ischemia depend on the location and degree of obstruction and range from reversible ischemia (unstable angina) through partial obstruction and tissue damage (non-ST elevation myocardial infarction [NSTEMI]) to complete epicardial occlusions leading to possible transmural infarction of the heart muscle (ST elevation myocardial infarction [STEMI]). The constellation of clinical symptoms that are compatible with acute myocardial ischemia is usually referred to as acute coronary syndrome.28,29

Angina resulting from progressive narrowing of the coronary arteries is the initial manifestation of ischemic heart disease in approximately one-half of patients.30 Angina is a clinical syndrome characterized by discomfort in the chest, jaw, shoulder, back, or arm. It is typically aggravated by exertion or emotional stress and relieved by nitroglycerin. Angina usually occurs in patients with CAD that involves at least one large epicardial artery. However, angina can also occur in patients with valvular heart disease, hypertrophic cardiomyopathy, and uncontrolled hypertension. It can also be present in patients with normal coronary arteries and myocardial ischemia related to spasm or endothelial dysfunction. Most angina is a sign of significant CAD—defined angiographically as a stenosis with greater than 70 percent diameter in at least one major epicardial artery segment or with greater than 50 percent diameter in the left main coronary artery. However, some angina is caused by stenotic lesions of lesser diameters, which have much less prognostic significance.30

Unstable angina (UA) is defined as angina with at least one of three features: (1) it occurs at rest or with minimal exertion, (2) it is severe and of recent onset (within the past 4 to 6 weeks), and/or (3) it occurs in a crescendo pattern (i.e., more severe, more prolonged, or more frequent than previously experienced). UA and NSTEMI have a fairly similar pathophysiology, mortality rate, and management strategy when compared with STEMI; therefore they are often grouped together as UA/NSTEMI in clinical guidelines and trial populations. Chronic stable angina is classified as pain that typically occurs with moderate to severe exertion, is milder in nature, and relieved with rest or sublingual nitroglycerin.

### Treatment Options for Patients With CAD

#### Optimal Medical Therapy

All patients with CAD—regardless of clinical presentation—should receive aggressive management of risk factors for progression of atherosclerosis (smoking, hypertension, hyperlipidemia, and diabetes) combined with pharmacological treatment (antiplatelets, antianginals, beta-blockers, angiotensin-converting enzyme inhibitors, angiotensin II receptor antagonists, and lipid-lowering drugs).31 Optimal medical therapy of CAD comprises the combinations of these treatments to reduce future cardiovascular events for all the clinical presentations outlined in the previous section. However, patients may not be able to receive optimal medical therapy if they have allergies to, or adverse effects from, individual medications (e.g., aspirin, beta blockers, or cholesterol-lowering drugs) or the combination of medications. Also, the definition of optimal medical therapy continues to evolve as new drugs are developed and as studies are conducted to assess the optimal blood pressure, blood sugar, and lipid goals needed to reduce future cardiovascular events. For medical therapy to be optimized, patients should be prescribed appropriate therapy to reach their therapeutic goal. The effectiveness of medical therapy is also affected by how adherent the patient is to the prescribed therapy.

#### Coronary Revascularization

Coronary revascularization falls broadly into two categories: coronary artery bypass grafting (CABG) and catheter-based percutaneous coronary intervention (PCI). Together, these coronary revascularization techniques are among the most common major medical procedures performed in North America and Europe. Since the introduction of bypass surgery in 1967 and PCI in 1977, it has become clear that both strategies can contribute to the effective treatment of patients with CAD. CABG and PCI (with or without stents) are alternative approaches in coronary revascularization, so their comparative effectiveness in terms of patient outcomes has been of great interest. The comparative effectiveness of CABG and PCI is an open question primarily for those patients for whom either procedure would be technically feasible or whose CAD is neither too limited nor too extensive.

CABG is generally preferred for patients with very high CAD burden—often described as left main CAD or severe triple-vessel disease with reduced left ventricular function—because CABG has previously been shown in randomized controlled trials (RCTs) to improve survival when compared with medical therapy. In contrast, PCI is generally preferred for patients with milder CAD burden—described as single-or double-vessel disease—when symptoms warrant coronary revascularization, in light of its lower procedural risk and evidence that PCI reduces angina and myocardial ischemia in this subset of patients. Uncertainty exists about the choice between PCI or CABG for patients with moderate CAD burden; namely, patients with disease of the proximal left anterior descending artery and less extensive forms of triple-vessel CAD. Most RCTs of PCI and CABG have been conducted in this middle segment of the patient population with CAD. The major advantage of PCI is its relative ease of use and avoidance of general anesthesia, thoracotomy, extracorporeal circulation, central nervous system complications, and prolonged convalescence. Repeat PCI can be performed more easily than repeat bypass surgery, and revascularization can be achieved more quickly in emergency situations. The disadvantages of PCI are early restenosis and the inability to relieve many totally occluded arteries or vessels with extensive atherosclerotic disease. CABG has the advantages of greater durability (graft patency rates exceeding 90% at 10 years with arterial conduits) and more complete revascularization regardless of the morphology of the obstructing atherosclerotic lesion.32

Therefore, patients and clinicians have two or more major treatment approaches to consider for each presentation of CAD. In general, these fall into less invasive (i.e., more medical) approaches and more invasive approaches. Table 1 summarizes the major treatment options for each clinical scenario described in the sections that follow.

Table 1 Comparisons of treatment strategies for women with CAD

CAD Presentation | Treatment Choices
STEMI | PCI vs. fibrinolysis PCI vs. conservative/supportive medical management
NSTEMI/unstable angina | Early invasive management (with PCI or CABG) vs. initial conservative management
Stable/unstable angina | PCI vs. CABG vs. optimal medical therapy

CABG = coronary artery bypass grafting; CAD = coronary artery disease; NSTEMI = non-ST elevation myocardial infarction; PCI = percutaneous coronary intervention; STEMI = ST elevation myocardial infarction

#### STEMI

Treatment for patients with ST-segment elevation is well established. Patients with STEMI are candidates for reperfusion therapy (either pharmacological or catheter based) to restore blood flow promptly in the occluded epicardial infarct-related artery. Pharmacological therapy consists of fibrinolysis or conservative/supportive therapy with facilitated antithrombotic medications.29 Multiple randomized trials have demonstrated the benefit of PCI in reducing major cardiovascular adverse events when compared with fibrinolysis or conservative therapy; therefore, immediate revascularization with PCI is the preferred strategy when patients have close access to a catheterization facility. Otherwise, fibrinolysis is recommended (in facilities without access) since it also has been shown to improve cardiovascular outcomes. In older or unstable patients, the use of fibrinolytics can increase bleeding complications; therefore trials comparing conservative medical therapy with PCI have been performed. In general, patients with STEMI are not treated with CABG (unless emergent from PCI complications) but do receive optimal medical therapy.

#### UA/NSTEMI

Patients with UA/NSTEMI are not candidates for immediate pharmacological reperfusion. The optimal management of UA/NSTEMI has the twin goals of the immediate relief of ischemia and the prevention of serious adverse outcomes (i.e., death or MI). Optimal management is best accomplished with an approach that includes anti-ischemic therapy, antithrombotic therapy, ongoing risk stratification, and in some cases the use of invasive procedures. In addition to aggressive medical therapy, two treatment pathways have emerged for treating patients without ST-segment elevation.28 An initial conservative strategy (also referred to as selective invasive management) calls for proceeding with an invasive evaluation only for those patients whose medical therapy fails (refractory angina or angina at rest or with minimal activity despite vigorous medical therapy) or in whom objective evidence of ischemia (dynamic electrocardiographic changes, high-risk stress test) is identified. The early invasive strategy triages patients to undergo an invasive diagnostic evaluation without first getting a noninvasive stress test or having medical treatment fail. Patients treated with an early invasive strategy generally will undergo coronary angiography within 4 to 24 hours of admission; however, these patients also are treated with the usual UA/NSTEMI medications, including appropriate anti-ischemic, antiplatelet, and anticoagulant therapy. Several RCTs have demonstrated improved clinical outcomes in patients with an invasive strategy, leading to guideline recommendations for invasive approaches to treat patients with NSTEMI and high-risk acute coronary syndrome. Patients with UA/NSTEMI also receive optimal medical therapy.

#### Angina

The treatment of stable angina has two major purposes. The first is to prevent MI and death and thereby increase the quantity of life. The second is to reduce symptoms of angina and occurrence of ischemia, which should improve the quality of life.30 All patients with stable angina are candidates for optimal medical therapy and may be candidates for PCI or CABG based on findings from coronary angiography and if symptoms persist despite optimal medical therapy.

## Scope and Key Questions

Although CAD is the leading cause of death for women in the United States, treatment studies to date have primarily enrolled men and may not reflect the benefits and risks that women experience. We conducted a systematic review of the medical literature to assess the comparative effectiveness of the major treatment options for CAD specifically in women, evaluating these comparisons:

1. PCI versus fibrinolysis or PCI versus conservative/supportive medical management in women with STEMI
2. Early invasive versus initial conservative management in women with UA/NSTEMI
3. PCI versus CABG versus optimal medical therapy in women with stable or unstable angina

The endpoints assessed were clinical outcomes, modifiers of effectiveness by demographic and clinical factors, and safety outcomes. The following Key Questions (KQs) were considered in this review:

KQ 1. In women presenting with ST elevation myocardial infarction (STEMI):

a. What is the effectiveness of percutaneous coronary intervention (PCI) versus fibrinolysis/supportive therapy on clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, angina relief, quality of life, or cognitive effects)?
b. Is there evidence that the comparative effectiveness of PCI versus fibrinolysis/supportive therapy varies based on characteristics such as:
  - Age, race, or other demographic and socioeconomic risk factors?
  - Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease?
  - Angiographic-specific factors (number of diseased vessels, vessel territory stenoses, left ventricular function, access site, or prior PCI or coronary artery bypass graft surgery [CABG] revascularization procedure)?
  - Hospital characteristics (hospital volume, setting, guideline-based treatment protocols)?
c. What are the significant safety concerns associated with each treatment strategy (i.e., adverse drug reactions, radiation exposure, access site complications, renal dysfunction, anaphylaxis, arrhythmias, stent thrombosis, bleeding, infections)?

KQ 2. In women presenting with unstable angina or non-ST elevation myocardial infarction (UA/NSTEMI):

a. What is the effectiveness of early invasive (PCI or CABG) versus initial conservative therapy on clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)?
b. Is there evidence that the comparative effectiveness of early invasive versus initial conservative therapy varies based on characteristics such as:
  - Age, race, or other demographic and socioeconomic risk factors?
  - Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease?
  - Angiographic-specific factors (number of diseased vessels, vessel territory stenoses, left ventricular function, access site, or prior PCI or CABG revascularization procedure)?
  - Hospital characteristics (hospital volume, setting, guideline-based treatment protocols)?
c. What are the significant safety concerns associated with each treatment strategy (i.e., adverse drug reactions, radiation exposure, access site complications, renal dysfunction, anaphylaxis, arrhythmias, stent thrombosis, bleeding, infections)?

KQ 3. In women presenting with stable or unstable angina:

a. What is the effectiveness of the following treatment strategies on clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)?
  - Revascularization (PCI or CABG) versus optimal medical therapy in women with stable angina
  - PCI versus CABG in women with stable or unstable angina
b. Is there evidence that the comparative effectiveness of revascularization versus optimal medical therapy varies based on characteristics such as:
  - Age, race, or other demographic and socioeconomic risk factors?
  - Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease?
  - Angiographic-specific factors (number of diseased vessels, vessel territory stenoses, left ventricular function, access site, or prior PCI or CABG revascularization procedure)?
  - CABG-specific factors such as type of surgery performed, cardiopulmonary bypass mode (normothermic versus hypothermic), on-pump versus off-pump, type of cardioplegia used (blood versus crystalloid), or use of saphenous vein grafts, single or bilateral internal mammary artery grafts, or other types of bypass grafts?
  - Hospital characteristics (hospital volume, setting, guideline-based treatment protocols)?
c. What are the significant safety concerns associated with each treatment strategy (i.e., adverse drug reactions, radiation exposure, access site complications, renal dysfunction, anaphylaxis, arrhythmias, stent thrombosis, bleeding, infections)?