# Peer Reviewers

Indira Jevaji, M.D., M.S.L.

Senior Medical Officer

Office of Research on Women’s Health

Bethesda, MD

Michael Mack, M.D.

Medical Director, Cardiovascular Services

Medical City Dallas Hospital

Dallas, TX

Lori Mosca, M.D., Ph.D., M.P.H.

Professor of Medicine

Director of Preventive Cardiology

Columbia University Medical Center

New York, NY

John Puskas, M.D., M.Sc.

Associate Chief, Division of Cardiothoracic Surgery

Emory University School of Medicine

Atlanta, GA

William S. Weintraub, M.D.

Chief of Cardiology

Director, Christiana Center for Outcomes Research

Christiana Care Health System

Newark, DE