# Technical Expert Panel

Noel Bairey Merz, M.D.

Director, Women’s Heart Center

Professor of Medicine

Cedars-Sinai Medical Center

Los Angeles, CA

Patricia Best, M.D.

Assistant Professor of Medicine

Mayo Clinic College of Medicine

Rochester, MN

Javed Butler, M.D., M.P.H.

Associate Professor of Medicine

Emory University

Atlanta, GA

Lily Chaput, M.D., M.P.H.

Chief, California Heart Disease and Stroke Prevention Program

Sacramento, CA

Nakela L. Cook, M.D., M.P.H.

Division of Cardiology

Washington Hospital Center

Washington, DC

Linda Humphrey, M.D., M.P.H.

Clinical Director, Evidence-based Synthesis Program

Portland Veterans Affairs Medical Center

Portland, OR

Frank V. Lefevre, M.D.

Associate Professor

Northwestern University Feinberg School of Medicine

Chicago, IL