# Key Informants

Noel Bairey Merz, M.D.

Professor of Medicine

Director, Women’s Heart Center

Cedars-Sinai Medical Center

Los Angeles, CA

Patricia Best, M.D.

Assistant Professor of Medicine

Mayo Clinic College of Medicine

Rochester, MN

Javed Butler, M.D., M.P.H.

Associate Professor of Medicine

Emory University

Atlanta, GA

Lily Chaput, M.D., M.P.H.

Chief, California Heart Disease and Stroke

Prevention Program

Sacramento, CA

Brenda J. Clark

Go Red for Women

American Heart Association

San Francisco, CA

Linda Humphrey, M.D., M.P.H.

Clinical Director, Evidence-based Synthesis Program

Portland Veterans Affairs Medical Center

Portland, OR

Michael Lauer, M.D.

Director, Division of Cardiovascular Sciences

National Heart, Lung, and Blood Institute

Bethesda, MD

Peter K. Smith, M.D.

Chief, Cardiothoracic Surgery

Duke University Medical Center

Durham, NC