# Acknowledgments

The authors thank Megan von Isenburg, M.L.S., for help with the literature search and retrieval, and Dr. Douglas McCrory for comments on the final draft of the report.