# Summary Table for Safety Concerns

Table H-1 Summary of RCTs reporting safety concerns (harms)

Study Author/Year Related Articles | Population | Comparison | # Subjects | Harms | Quality
ARTS I Vaina et al., 2009 1 and van den Brand, et al., 2002 2 Serruys et al., 1999 3 Voudris et al., 2006 4 Anonymous, 1999 5 | UA/NSTEMI | PCI vs. CABG | Total: 1,205 Women: 283 (23%) | [underlined: Major bleeding] PCI (men vs. women): OR (95% CI) 29.4 (5.3 to 500); p = 0.001 CABG (men vs. women): OR (95%CI) 1.5 (0.4 to 10.1); p = 0.58 | Good
GUSTO II-B Tamis-Holland et al., 2004 6 | STEMI | PCI vs. fibrinolysis (accelerated t-PA) | Total: 1,137 Women: 260 (23%) | [underlined: Intracranial hemorrhage] Women PCI: 0 Optimal medical therapy: 4.1% Men PCI: 0 Optimal medical therapy: 0.7% | Good
PAMI Stone et al., 1995 7 | STEMI | PCI vs. fibrinolysis (t-PA) | Total: 395 Women: 107 (27%) | [underlined: Nadir HCT (PCI vs. fibrinolysis)] Women: 30 ± 5% vs. 33 ± 5%; p = 0.002 Men: 35 ± 6% vs. 35 ± 6%; p = 0.17 [underlined: Requirement for blood transfusion (PCI vs. fibrinolysis)] Women: 18% vs. 8.8%; p = 0.16 Men: 9.7% vs. 8.4%; p = 0.71 | Good
TACTICS TIMI-18 Cannon et al., 2001 8 and Glaser et al., 2002 9 Cannon et al., 1998 10 | UA/NSTEMI | Early invasive vs. initial conservative | Total: 2,220 Women: 757 (34%) | Bleeding in women undergoing PTCA was higher compared to men; adjusted OR (95% CI) 3.6 (1.6 to 8.3). Bleeding related to CABG was similar in women and men (12.6% vs. 15%). Occurrence of stroke at 30 days related to CABG also was similar in women and men (2.1% vs. 1.5%). | Good

Abbreviations: BMS = bare metal stent; CABG = coronary artery bypass graft; CAD = coronary artery disease; CI = confidence interval; DES = drug-eluting stent; HCT = hematocrit; NSTEMI = non-ST elevation myocardial infarction; OR = odds ratio; PCI = percutaneous coronary intervention; PTCA = percutaneous transluminal coronary angioplasty; RCT = randomized controlled trial; t-PA = tissue plasminogen activator; UA = unstable angina

## References Cited in Appendix H

1 Vaina S, Voudris V, Morice MC, et al. Effect of gender differences on early and mid-term clinical outcome after percutaneous or surgical coronary revascularisation in patients with multivessel coronary artery disease: insights from ARTS I and ARTS II. EuroIntervention. 2009;4(4):492-501. [pmid: 19284072].
2 van den Brand MJ, Rensing BJ, Morel MA, et al. The effect of completeness of revascularization on event-free survival at one year in the ARTS trial. J Am Coll Cardiol. 2002;39(4):559-64. [pmid: 11849851].
3 Serruys PW, Unger F, van Hout BA, et al. The ARTS study (Arterial Revascularization Therapies Study). Semin Interv Cardiol. 1999;4(4):209-19. [pmid: 10738354].
4 Voudris V, Ong AT, Serruys PW, et al. Sex differences and their impact on clinical outcome after percutaneous or surgical revascularisation: a report from the Arterial Revascularisation Therapies Study (ARTS). EuroIntervention. 2006;2(2):175-80. [pmid: 19755257].
5 The ARTS (Arterial Revascularization Therapies Study): Background, goals and methods. Int J Cardiovasc Intervent. 1999;2(1):41-50. [pmid: 12623386].
6 Tamis-Holland JE, Palazzo A, Stebbins AL, et al. Benefits of direct angioplasty for women and men with acute myocardial infarction: results of the Global Use of Strategies to Open Occluded Arteries in Acute Coronary Syndromes Angioplasty (GUSTO II-B) Angioplasty Substudy. Am Heart J. 2004;147(1):133-9. [pmid: 14691431].
7 Stone GW, Grines CL, Browne KF, et al. Comparison of in-hospital outcome in men versus women treated by either thrombolytic therapy or primary coronary angioplasty for acute myocardial infarction. Am J Cardiol. 1995;75(15):987-92. [pmid: 7747700].
8 Cannon CP, Weintraub WS, Demopoulos LA, et al. Comparison of early invasive and conservative strategies in patients with unstable coronary syndromes treated with the glycoprotein IIb/IIIa inhibitor tirofiban. N Engl J Med. 2001;344(25):1879-87. [pmid: 11419424].
9 Glaser R, Herrmann HC, Murphy SA, et al. Benefit of an early invasive management strategy in women with acute coronary syndromes. JAMA. 2002;288(24):3124-9. [pmid: 12495392].
10 Cannon CP, Weintraub WS, Demopoulos LA, et al. Invasive versus conservative strategies in unstable angina and non-Q-wave myocardial infarction following treatment with tirofiban: rationale and study design of the international TACTICS-TIMI 18 Trial. Treat Angina with Aggrastat and determine Cost of Therapy with an Invasive or Conservative Strategy. Thrombolysis In Myocardial Infarction. Am J Cardiol. 1998;82(6):731-6. [pmid: 9761082].