# Summary Tables for Sex-Specific Clinical Outcomes

Table F-1 Summary of RCTs reporting clinical outcomes for STEMI (KQ 1)

Study Author/Year Related Articles | Population | Comparison | # Subjects | Outcomes | Quality
CARESS-in-AMI Di Mario et al., 2008 1 and Di Mario et al., 2004 2 | STEMI | Fibrinolysis (reteplase) plus immediate PCI vs. fibrinolysis (reteplase) plus rescue PCI | Total: 600 Women: 128 (21%) | [underlined: 1) Composite outcome] (total mortality/reinfarction/refractory MI within 30 days) HR (95%CI) Women: 0.4 (0.12 to 1.31) Men: 0.39 (0.18 to 0.85) Overall: 0.40 (0.21 to 0.76) [underlined: 2) Cumulative event rate] (total mortality/reinfarction/refractory MI within 30 days) Women: 6.2 vs. 14.5 Men: 3.9 vs. 9.7 Overall: 4.4 vs. 10.7 | Good
DANAMI-2 Andersen et al., 2003 3 and Mortensen et al., 2007 4 Nielsen et al., 2010 5 Busk et al., 2009 6 Busk et al., 2008 7 | STEMI | Primary PCI vs. fibrinolysis (accelerated t-PA) | Total: 1,572 Women: 417 (27%) | [underlined: 1) Composite outcome] (total mortality/nonfatal MI/stroke) 30 days OR (95% CI) Women: 0.47 (0.27 to 0.81) Men: 0.59 (0.39 to 0.90) Overall: 0.55 (0.39 to 0.76) 3 years HR (95% CI) Women: 0.62 (0.42 to 0.90) Men: 0.81 (0.63 to 1.04) Overall: 0.74 (0.60 to 0.92) Median 7.8 years HR (95% CI) Women: 0.73 (0.53 to 0.99) Men: 0.80 (0.66 to 0.97) Overall: 0.78 (0.66 to 0.92) [underlined: 2) Angina] (angina/recurrent symptoms/refractory angina/refractory MI) 30 days Women: 25.3% vs. 30.7% Men: 18.8% vs. 26.4% 1 year Women: 18.5% vs. 21.3% Men: 15.5% vs. 17.6% [underlined: 3) General health SF-36] 30 days Women: 62 vs. 61.1 Men: 69.2 vs. 65.1 1 year Women: 61.5 vs. 66.4 Men: 68.2 vs. 63.1 | Good
Dobrzycki et al., 2007 8 | STEMI | Fibrinolysis (streptokinase) onsite vs. tirofiban plus transfer for primary PCI | Total: 401 Women: 105 (26%) | [underlined: 1) Composite outcome] (total mortality/nonfatal MI/stroke): 30 days RR (95% CI) Women: 2.04 (0.85 to 4.90) Men: 1.79 (0.85 to 3.79) Overall: 1.95 (1.1 to 3.45) 1 year Women: 2.48 (1.06 to 5.79) Men: 1.61 (0.92 to 2.85) Overall: 1.88 (1.18 to 3.00) [underlined: 2) Total mortality] 30 days RR (95% CI) Women: 2.19 (0.73 to 6.53) Men: 1.41 (0.50 to 3.96) Overall: 1.81 (0.86 to 3.82) 1 year Women: 2.41 (0.82 to 7.07) Men: 1.48 (0.68 to 3.22) Overall: 1.79 (0.96 to 3.35) | Good
GUSTO II-B Tamis-Holland et al., 2004 9 | STEMI | PCI vs. fibrinolysis (accelerated t-PA) | Total: 1,137 Women: 260 (23%) | [underlined: 1) Composite outcome (30-day):] (total mortality/nonfatal MI/nonfatal disabling stroke) OR (95% CI) Women: 0.685 (0.36 to 1.32) Men: 0.562 (0.35 to 0.91) Overall: 0.67 (0.47 to 0.97) [underlined: 2) Total mortality (30-day)] Women: 10.9% vs. 11.6% Men: 4% vs. 5.8% [underlined: 3) Nonfatal MI (30-day):] Women: 6.5% vs. 6.6% Men: 3.8% vs. 6.4% [underlined: 4) Nonfatal disabling stroke (30-day):] Women: 0 vs. 2.5% Men: 0.2% vs. 0.4% | Good
Minai et al., 2002 10 | STEMI age ≥ 80 years | PCI vs. conservative/supportive medical therapy (without fibrinolysis) | Total: 120 Women: 60 (50%) | [underlined: Composite outcome] (total mortality/heart failure/repeat MI/stroke) 3 years 46 of the PCI subjects vs. 31 of the no PCI subjects; p = 0.06 Multivariate analysis was done to look at factors associated with the composite endpoint in the overall study (i.e., not treatment specific) and found that male gender was NOT a factor significantly associated with outcome in the overall population. | Fair
PAMI Stone et al., 1995 11 | STEMI | PCI vs. fibrinolysis (t-PA) | Total: 395 Women: 107 (27%) | [underlined: 1) In-hospital death or reinfarction] Women: 6% vs. 17.5%; p = 0.07 Men: 4.8% vs. 9.8%; p = 0.11 Overall: 5.1% vs. 12%; p=0.02 [underlined: 2) In-hospital total mortality] Women: 4.0% vs. 14%; p = 0.07 Men: 2.1% vs. 3.5%; p = 0.46 [underlined: 3) In-hospital nonfatal MI] Women: 2.0% vs. 3.5%; p = 0.64 Men: 2.8% vs. 7.7%; p = 0.06 [underlined: 4) In-hospital recurrent ischemia] Women: 16% vs. 28.1%; p = 0.14 Men: 8.2% vs. 28%; p = 0.001 [underlined: 5) In-hospital stroke] Women: 0 vs. 5.3%; p = 0.10 Men: 0 vs. 2.8%; (p = 0.04 [underlined: 6) Length of stay] Women: 7.8 ± 3.4 days vs. 8.5 ± 4.1 days; p = 0.34 Men: 7.4 ± 3.3 days vs. 8.3 ± 4.8 days; p = 0.05 | Good
SHOCK Hochman et al., 2001 12 and Hochman et al., 2006 13 Hochman et al., 1999 14 Hochman et al., 1999 15 | STEMI | Early revascularization (PCI or CABG within 6 hours) vs. initial medial stabilization (thrombolysis, IABP) | Total: 302 Women: 97 (32%) | Relative risk (95% CI) for death at 1 year with early revascularization vs. initial medical stabilization: 0.72 (0.54 to 0.95) There was no interaction between treatment effect and sex. | Good

Abbreviations: BMS = bare metal stent; CABG = coronary artery bypass graft; CAD = coronary artery disease; CI = confidence interval; DES = drug-eluting stent; HR = hazard ratio; IABP = intra-aortic balloon pump; MI = myocardial infarction; NSTEMI = non-ST elevation myocardial infarction; OR = odds ratio; PCI = percutaneous coronary intervention; PTCA = percutaneous transluminal coronary angioplasty; RCT = randomized controlled trial; RR = relative risk; UA = unstable angina

Table F-2 Summary of RCTs reporting clinical outcomes for UA/NSTEMI (KQ 2)

Study Author/Year Related Articles | Population | Comparison | # Subjects | Outcomes | Quality
FRISC II Lagerqvist et al., 2001 16 and Lagerqvist et al., 2006 17 Wallentin et al., 2000 18 Anonymous, 1999 19 | UA/NSTEMI | Early invasive treatment with revascularization vs. initial conservative strategy | Total: 2,457 Women: 749 (30%) | [underlined: Primary endpoint] (death/MI or both) 6 months RR (95% CI) Invasive vs. conservative Women: 1.26 (0.80 to 1.97) Men: 0.64 (0.49 to 0.84) Overall: 0.78 (0.62 to 0.98); p = 0.031 1 year Women: 12.4% vs. 10.5%; p = not significant Men: 9.6% vs. 15.8%; p < 0.001 Overall: 0.74 (0.60 to 0.92); p = 0.005 Interaction by sex: p = 0.008 (significant) OR (95% CI) 0.91 (0.68 to 1.22) for effect of women on primary endpoint adjusted for treatment group Women did not benefit from early invasive strategy partly because of higher mortality related to CABG. 5 years OR (95% CI) Women: 1.12 (0.83 to 1.50) Men: 0.70 (0.59 to 0.86) Overall: 0.81 (0.69 to 0.95); p = 0.009 Interaction by sex p = 0.010 (significant) | Good
GUSTO IV-ACS Ottervanger et al., 2004 20 | NSTEMI Acute coronary syndrome | Revascularization within 30 days (early invasive) vs. initial conservative strategy | Total: 7,800 Women: 2896 (37%) | [underlined: Death, 1 year] Women: adjusted HR (95% CI) 0.53 (0.28 to 1.00) Men: adjusted HR (95% CI) 0.55 (0.35 to 0.85) Overall: adjusted RR (95% CI) 0.53 (0.37 to 0.77) | Good
ICTUS de Winter et al., 2005 21 and Damman et al., 2010 22 | NSTEMI-acute coronary syndrome | Early invasive therapy with revascularization vs. selective invasive strategy (initial conservative) | Total: 1,200 Women: 320 (27%) | [underlined: 1) Death/MI/rehospitalization for angina] 1 year Early invasive vs. selective Total: RR (95% CI) 1.07 (0.87 to 1.33); p = 0.33 No significant difference among sex groups [underlined: 2) Death/spontaneous MI] 5 years HR (95% CI) Women: 0.87 (0.53 to 1.43); p = 0.59 Men: 1.22 (0.87 to 1.71); p = 0.24 Overall: 1.10 (0.83 to 1.45); p = 0.52 | Good
RITA-2 Anonymous, 1997 23 | UA/stable CAD (no recent MI) | Early invasive therapy with PCI (PTCA) vs. initial conservative | Total: 1,018 Women: 183 (8%) | [underlined: 1) Death/MI] Median followup of 2.7 years PTCA vs. optimal medical therapy Total: RR (95% CI) 1.92 (1.08 to 3.41); p = 0.02 No significant interaction by sex [underlined: 2) Secondary outcomes] Angina grade 2+ at 6 months Women: 22.8% vs. 39.8% Men: 20.5% vs. 31.4% [underlined: 3) Exercise time] 6 months mean (SE) Women: 6.72 (0.25) vs. 6.52 (0.26); Men: 9.34 (0.13) vs. 8.90 (0.15) | Fair
RITA-3 Clayton et al., 2004 24 and Fox et al., 2002 25 | UA/NSTEMI | Early invasive (PCI) vs. initial conservative | Total: 1,810 Women: 682 (38%) | [underlined: 1) Primary outcome] (death/MI/refractory angina) Early invasive vs. initial conservative 4 months Women: 10.9% vs. 9.6% (similar) Men: 8.8% vs. 17.3% Overall: 9.6% vs. 14.5% p = 0.001 RR (95% CI) 0.66 (0.51 to 0.85) Significant interaction by sex: p = 0.004 1 year Women: adjusted OR (95% CI) 1.14 (0.74 to 1.76) Men: adjusted OR (95% CI) 0.48 (0.34 to 0.67) Overall: RR (95% CI) 0.72 (0.58 to 0.90); p = 0.003 [underlined: 2) Secondary outcomes] (death/MI) Early invasive vs. initial conservative 1 year Women: adjusted OR (95% CI) 1.79 (0.95 to 3.35) Men: adjusted OR (95% CI) 0.63 (0.41 to 0.98) Overall: RR (95% CI) 0.91 (0.67 to 1.25); p = 0.58 [underlined: 3) Death] 1 year Women: adjusted OR (95% CI) 2.43 (1.01 to 5.84) Men: adjusted OR (95% CI) 0.78 (0.44 to 1.41) Overall: RR (95% CI) 1.16 (0.75 to 1.80); p = 0.50 Significant interaction by sex for all 3 outcomes 4) Risk stratification by TIMI risk score (death/MI/refractory angina) Early invasive vs. initial conservative Low risk Women: 2.3% vs. 3.8% Men: 6.1% vs. 5.1% Moderate risk Women: 13.4% vs. 3.4% Men: 5.4% vs. 9.5% High risk Women: 11.7% vs. 8.2% Men: 10.3% vs. 17.9% Women in moderate- or high-risk TIMI groups had higher event rate in early invasive arm Men in moderate- or high-risk TIMI groups had benefit from early invasive therapy | Good
TACTICS TIMI-18 Cannon et al., 2001 26 and Glaser et al., 2002 27 Cannon et al., 1998 28 | UA./NSTEMI | Early invasive (PCI) vs. initial conservative | Total: 2,220 Women: 757 (34%) | [underlined: 1) Primary endpoint] (death/MI/rehospitalization for acute coronary syndrome) Early invasive vs. initial conservative 6 months Adjusted OR (95% CI) Women: 0.72 (0.47 to 1.11) Men: 0.64 (0.47 to 0.88) Overall: 0.78 (0.62 to 0.97) [underlined: 2) Secondary outcomes] (death/MI) Early invasive vs. initial conservative 6 months Adjusted OR (95% CI) Women: 0.45 (0.24 to 0.88) Men: 0.68 (0.43 to 1.05) Overall: 0.74 (0.54 to 1.00); p < 0.05 [underlined: 3) Death] Early invasive vs. initial conservative 6 months Adjusted OR (95% CI) Women: 0.94 (0.37 to 2.44) Men: 0.75 (0.36 to 1.56) Women less likely to undergo CABG even after adjustment for 3-vessel and left main disease | Good
TIMI III-B Anonymous, 1994 29 and Anderson et al., 1995 30 | UA/NSTEMI | Early invasive vs. initial conservative | Total: 1,425 Women: 497 (35%) | [underlined: 1) Primary endpoint] (death/MI/failed symptom-limited exercise treadmill test) 6 weeks Overall: 16.2% vs. 18.1%; p = 0.33 [underlined: 2) Secondary outcomes] (death/MI) Early invasive vs. initial conservative 6 weeks Women: 6.1% vs. 8.9%; p = 0.24 Men: 7.8% vs. 7.3%; p = 0.73 1 year Women: 9.7% vs. 15.4%; p = 0.06 Men: 11.3% vs. 10.6%; p = 0.68 Overall: 10.8% vs. 12.2%; p = 0.42 No interaction by sex | Good

Abbreviations: CABG = coronary artery bypass graft; CAD = coronary artery disease; CI = confidence interval; HR = hazard ratio; MI = myocardial infarction; NSTEMI = non-ST elevation myocardial infarction; OR = odds ratio; PCI = percutaneous coronary intervention; PTCA = percutaneous transluminal coronary angioplasty; RCT = randomized controlled trial; RR = risk ratio; SD = standard deviation; SE = standard error; t-PA = tissue plasminogen activator; UA = unstable angina

Table F-3 Summary of RCTs reporting clinical outcomes for stable angina (KQ 3 Strategy 1—revascularization vs. optimal medical therapy)

Study Author/Year Related Articles | Population | Comparison | # Subjects | Outcomes | Quality
Allen et al., 2004 31 and Allen et al., 1999 32 | Stable angina | Surgical revascularization (CABG with transmyocardial revascularization) vs. optimal medical therapy | Total: 222 Women: 61 (27%) | [underlined: 1) Death] 5.7 years (SD 0.8) Men: OR (95% CI) 1.4 (0.4 to 5.0); p = 0.63 [underlined: 2) Angina relief] 5.7 years (SD 0.8) Men: OR (95% CI) 1.1 (0.7 to 1.8); p = 0.41 | Good
COURAGE Boden et al., 2007 33 and Mancini et al., 2009 34 Boden et al., 2006 35 | Stable angina | PCI (type not specified) or CABG if PCI failed vs. optimal medical therapy | Total: 2,287 Women: 338 (15%) | [underlined: 1) Death/MI] 4.6 years (median followup) PCI vs. optimal medical therapy: Women: 18% vs. 26% Men: 19% vs. 18% p = 0.03 Women: HR (95% CI) 0.65 (0.40 to 1.06) Men: HR (95% CI) 1.15 (0.93 to 1.42) Overall: HR (95%CI) 1.05 (0.87 to 1.27) | Good
MASS II Hueb et al., 2010 36 and Hueb et al., 2004 37 Hueb et al., 2007 38 | Stable angina with multiple-vessel CAD | PCI vs. Optimal medical therapy CABG vs. optimal medical therapy | Total: 611 Women: 196 (32%) | [underlined: Primary endpoint] (death/MI/angina requiring mechanical revascularization) 10 years Adjusted HR (95% CI) Women: Optimal medical therapy vs. PCI: 1.57 (1.01 to 2.46); p = 0.047(favoring PCI) CABG vs. optimal medical therapy: 0.43 (0.26 to 0.72); p = 0.001 Men: Optimal medical therapy vs. PCI: 1.13 (0.84 to 1.53); p = 0.410 CABG vs. optimal medical therapy: 0.43 (0.31 to 0.60); p = 0.001 Overall: PCI vs. optimal medical therapy: 0.79 (0.62–1.01) CABG vs. optimal medical therapy: 0.43 (0.32 to 0.58) p < 0.001 | Good
OAT Hochman et al., 2006 39 and Hochman et al., 2005 40 Hochman et al., 2011 41 | Stable angina | PCI (or CABG if PCI failed) vs. optimal medical therapy | Total: 2,166 Women: 476 (22%) | [underlined: Primary endpoint] (death/MI/heart failure) 4 years PCI vs. optimal medical therapy: Women: 18.3% vs. 22.9% Men: 16.8% vs. 13.5% p = 0.13 Women: HR < 1.0 (favoring PCI, but not significant) Men: HR > 1.0 (favoring optimal medical therapy, but not significant) Overall: HR 0.43 (0.32 to 0.56) 7 years PCI vs. optimal medical therapy: Women: 25.5% vs. 28.6%; HR 0.89 (0.62 to 1.28) Men: 21.3% vs. 21.3%; HR 1.11 (0.89 to 1.39) p = 0.31 | Good
STICH Velazquez et al., 2011 42 and Velazquez et al., 2007 43 | Stable angina | CABG vs. optimal medical therapy | Total: 1,212 Women: 148 (12%) | [underlined: Death] 5 years HR (95% CI) Women: 0.75 (0.42 to 1.31) Men: 0.87 (0.72 to 1.06) Overall: 0.86 (0.72 to 1.04) p = 0.61 | Good

Abbreviations: BMS = bare metal stent; CABG = coronary artery bypass graft; CAD = coronary artery disease; CI = confidence interval; DES = drug-eluting stent; HR = hazard ratio; MI = myocardial infarction; NSTEMI = non-ST elevation myocardial infarction; OR = odds ratio; PCI = percutaneous coronary intervention; PTCA = percutaneous transluminal coronary angioplasty; RCT = randomized controlled trial; SD = standard deviation; UA = unstable angina

Table F-4 Summary of RCTs reporting clinical outcomes for stable/unstable angina (KQ 3 Strategy 2–PCI vs. CABG)

Study Author/Year Related Articles | Population | Comparison | # Subjects | Outcomes | Quality
ARTS I Vaina et al., 2009 44 and van den Brand, et al., 2002 45 Serruys et al., 1999 46 Voudris et al., 2006 47 Anonymous, 1999 48 | Unstable angina | PCI (BMS) vs. CABG | Total: 1,205 Women: 283 (23%) | [underlined: 1) Composite outcome] (death/CVA/MI/CABG/repeat PCI) 30 days Women: PCI 13.0% vs. CABG 8.3% Men: PCI 8.0% vs. CABG 5.7% 1 year Women: PCI 29.0% vs. CABG 14.5% Men: PCI 25.8% vs. CABG 10.7% 3 years Women: PCI 35.5% vs. CABG 19.3% Men: PCI 33.5% vs. CABG 15.1% [underlined: 2) Composite death/CVA] 30 days Women: PCI 4.3% vs. CABG 4.8% Men: PCI 1.9% vs. CABG 1.5% 1 year Women: PCI 8.0% vs. CABG 7.6% Men: PCI 3.5% vs. CABG 3.5% 3 years Women: PCI 10.9% vs. CABG 9.7% Men: PCI 5.8% vs. 5.9% [underlined: 3) Composite death/MI/CVA] 30 days Women: PCI 7.2% vs. 6.9% Men: PCI 4.5% vs. 5.0% 1 year Women: PCI 11.6% vs. 11.0% Men: PCI 8.9% vs. CABG 7.0% 3 years Women: PCI 14.5% vs. CABG 14.5% Men: PCI 12.3% vs. CABG 9.6% [underlined: 4) Death—5 years] PCI: women 7.4% vs. men 9.0%; p = 0.29 CABG: women 7.2% vs. men 10.1%; p = 0.48 PCI: OR (95% CI) 1.1 (0.5 to 2.8); p = 0.86 CABG: OR (95% CI) 1.4 (0.5 to 4.1); p = 0.54 [underlined: 5) MI—5 years] PCI: OR (95% CI) 1.4 (0.7 to 3.2); p = 0.44 CABG: OR (95%CI) 0.6 (0.3 to 1.3); p = 0.17 [underlined: 6) CVA—5 years] PCI: OR (95% CI) 0.8 (0.3 to 2.2); p = 0.58 CABG: OR (95%CI) 0.6 (0.3 to 1.9); p = 0.39 [underlined: 7) Revascularization—5 years] PCI: OR (95% CI) 1.0 (0.6 to 1.5); p = 0.92 CABG: OR (95%CI ) 0.7 (0.4 to 1.4); p = 0.32 [underlined: 8) Composite death/MI/CVA] Men vs. women PCI: OR (95% CI) 1.2 (0.7 to 1.2); p = 0.57 CABG: OR (95%CI) 0.8 (0.5 to 1.5); p = 0.57 [underlined: 9) Composite MI/CVA/PTCA] Men vs. women PCI : OR (95% CI) 0.9 (0.6 to 1.4); p = 0.77 CABG : OR (95% CI) 0.8 (0.5 to 1.3); p = 0.38 [underlined: 10) In-hospital outcomes] PCI: OR 95% CI 0.6 (0.3 to 1.2); p = 0.14 CABG: OR 95%CI 1.8 (0.7 to 6.2); p = 0.29 [underlined: 11) In-hospital MI] PCI: OR 95% CI 0.7 (0.2 to 2.6); p = 0.58 CABG: OR 95%CI 1.2 (0.4 to 4.3); p = 0.72 [underlined: 12) In-hospital CVA] PCI: OR 95% CI 0.6 (0.1 to 12.5); p = 0.65 CABG: OR 95%CI 1.8 (0.3 to 34.9); p = 0.57 [underlined: 13) Quality of life—3 years] Euro-QoL summary: PCI: Men 86 ± 16 vs. women 83 ± 19 P = 0.08 CABG: Men 86 ± 20 vs. women 82 ± 20 P = 0.02 [underlined: 14) Composite outcome] (death/CVA/MI/CABG/repeat CABG) 5 years Men vs. women PCI: OR (95%CI) 0.9 (0.6 to 1.4); p = 0.77 CABG: OR (95%CI) 0.8 (0.5 to 1.3) p = 0.38 [underlined: 15) Individual outcomes] 30 days Death: Women: PCI 2.9% vs. CABG 4.1% Men: PCI 1.3% vs. CABG 0.4% CVA: Women: PCI 2.2% vs. CABG 0.7% Men: PCI 0.6% vs. CABG 1.1% MI: Women: PCI 3.6% vs. CABG 4.1% Men: PCI 3.2% vs. CABG 3.7% Revascularization: Women: PCI 7.2% vs. CABG 1.4% Men: PCI 5.2% vs. CABG 0.7% Major cardiovascular adverse event-free survival: Women: PCI 87.0% vs. CABG 91.7% Men: PCI 92.0% vs. CABG 94.3% 1 year Death: Women: PCI 5.8% vs. CABG 6.2% Men: PCI 1.7% vs. CABG 1.5% CVA: Women: PCI 2.9% vs. CABG 2.1% Men: PCI 1.7% vs. CABG 2.0% MI: Women: PCI 5.1% vs. CABG 5.5% Men: PCI 6.1% vs. CABG 3.7% Revascularization: Women: PCI 20.3% vs. CABG 4.1% Men: PCI 21.2% vs. CABG 4.2% Major cardiovascular adverse event-free survival: Women: PCI 71.0% vs. CABG 85.5% Men: PCI 74.2% vs. CABG 89.3% 3 years Death: Women: PCI 7.2% vs. CABG 6.9% Men: PCI 3.0% vs. CABG 3.5% CVA: Women: PCI 4.3% vs. CABG 4.1% Men: PCI 3.0% vs. CABG 2.8% MI: Women: PCI 5.8% vs. CABG 7.6% Men: PCI 7.1% vs. CABG 4.2% Revascularization: Women: PCI 24.6% vs. CABG 6.2% Men: PCI 26.8% vs. CABG 6.6% Major cardiovascular adverse event-free survival: Women: PCI 64.5% vs. CABG 80.7% Men: PCI 66.5% vs. CABG 84.9% | Good
BARI Jacobs et al., 1998 49 and Gibbons et al., 2001 50 Anonymous, 2007 51 Lombardero et al., 2002 52 Anonymous, 2000 53 Hlatky et al., 1995 54 Rogers et al., 1995 55 Sutton-Tyrrell et al., 1998 56 Mullany et al., 1999 57 Anonymous, 1996 58 | Stable/unstable angina Diabetics | PCI (type not specified) vs. CABG | Total: 915 Women: 249 (27%) | [underlined: 1) 5-year cumulative survival rate] Women: PCI 86.3% vs. CABG 89.3% Men: PCI 86% vs. CABG 89% Survival free of MI: Women: PCI 74% vs. CABG 76% In-hospital death: PCI 1.1% vs. CABG 1.3% Women: PCI 0.8% vs. CABG 1.3% Men: PCI 1.2% vs. CABG 1.4% Q-waves MI: Women : PCI 1.2% vs. CABG 4.7% Men : PCI 2.4% vs. CABG 4.6% Congestive heart failure: Women: PCI 4.8% vs. CABG 9.8% Men: PCI 1.4% vs. CABG 1.8% [underlined: 2) 7-year survival rate] Women: PCI 79.2% vs. CABG 82.6% Men: PCI 81.6% vs. CABG 85.1% [underlined: 3) 10-year survival rate] Women: PCI 70.2% vs. CABG 67.8% Men: PCI 71.3% vs. CABG 75.5% [underlined: 4) 4-year angina status] Women: PCI 23.3% vs. CABG 18.8% Men: PCI 19.7% vs. CABG 13.2% At 5 years, anginal status was not significantly different between men and women [underlined: 5) Repeat revascularization] CABG: Women RR 1.74 p = 0.043 PCI: Women RR 0.74 p = 0.011 Women were less likely than men to undergo repeat revascularization with an initial strategy of CABG compared with PTCA (11.2% vs. 51.9%, respectively; p < 0.001) | Good
CABRI Anonymous, 1995 59 | Stable/unstable angina with multiple-vessel disease | PCI (PTCA) vs. CABG | Total: 1,054 Women: 234 (22%) | [underlined: 1) Primary endpoint of mortality, 1 year] PTCA 3.9% vs. CABG 2.7% RR 95%CI 1.42 (0.731 to 2.74); p = 0.297 Women had higher risk of 1-year mortality RR (95% CI) 2.07 (1.07 to 4.01); p=0.031 [underlined: 2) Angina, 1 year] PTCA 13.9% vs. CABG 10.1% RR (95% CI) 1.54 (1.09 to 2.16) Women: 3.12 (1.41 to 6.54) p = 0.002 Men: 1.25 (0.85 to 1.85); p = 0.256 [underlined: 3) Crude absolute risk of angina, 1 year] PTCA Women: 0.214 Men: 0.131 CABG Women: 0.069 Men: 0.104 | Good
CARDia Kapur et al., 2010 60 and Kapur et al., 2005 61 | UA/NSTEMI Stable angina Diabetic Multiple-vessel disease or complex single lesion | PCI (BMS or DES) vs. CABG | Total: 510 Women: 132 (26%) | [underlined: 1) Primary endpoint, 1 year] (death/MI/stroke) HR (95%CI) Women: 2.13 (0.68 to 6.68) Men: 1.07 (0.59 to 1.93) Overall: 1.25 (0.75 to 2.09) [underlined: 2) Secondary endpoint, 1 year] (death/MI/stroke/repeat revascularization) HR (95%CI) Women: 2.4 (0.87 to 6.61) Men: 1.62 (0.95 to 2.74) Overall: 1.77 (1.11 to 2.09) | Good
EAST King et al., 2000 62 and King et al., 1995 63 King et al., 1994 64 Zhao et al., 1996 65 | Stable angina with multiple-vessel disease | PCI (type not specified) vs. CABG | Total: 392 Women: 103 (26%) | [underlined: Single outcome survival] 3 years CABG 93.8% vs. PTCA 92.9% 8 years CABG 82.7% vs. PTCA 79.3% Comparisons were made for other baseline variables including sex, and no survival differences by treatment assignment were seen | Good
GABI Kaehler et al., 2005 66 and Hamm et al., 1994 67 | Stable angina | PCI (type not specified) vs. CABG | Total: 359 Women: 66 (18%) | [underlined: Death] 13 years No significant sex differences in hazard ratio for death | Good
MASS II Hueb et al., 2010 36 and Hueb et al., 2004 37 Hueb et al., 2007 38 | Stable angina with multiple-vessel coronary artery disease | PCI (type not specified) vs. CABG | Total: 611 Women: 196 (32%) | [underlined: Primary endpoint] (death/MI/angina requiring mechanical revascularization) 10 years Adjusted HR (95% CI) Women: CABG vs. PCI: 0.68 (0.40 to 1.15); p = 0.015 Men: CABG vs. PCI: 0.49 (0.34 to 0.69); p = 0.001 Overall: CABG vs. PCI: 0.53 (0.39 to 0.72); p < 0.001 | Good
PRECOMBAT Park et al., 2011 68 | Stable/unstable angina | PCI (DES) vs. CABG | Total: 600 Women: 141 (24%) | [underlined: 1) Composite endpoint, 1 year] (death/MI/stroke/ischemia-driven target-vessel revascularization) PCI 8.7% vs. CABG 6.7% [underlined: 2) Composite endpoint, 2 years] PCI 12.2% vs. CABG 8.1% HR (95% CI) 1.50 (0.90 to 2.52); p = 0.12 Women: PCI 13.9% vs. CABG 11.7 % HR (95% CI) 1.22 (0.48 to 3.08); p = 0.68 Men: PCI 11.7% vs. CABG 7.0% HR (95%CI) 1.65 (0.88 to 3.07); p = 0.12 Overall: HR 1.50 (0.90 to 2.52) | Good
SOS Zhang et al., 2004 69 and Zhang et al., 2003 70 Stables et al., 1999 71 | Stable angina | PCI (BMS) vs. CABG | Total: 908 Women: 206 (23%) | [underlined: 1) Quality of life] (adjusted relative difference of CABG vs. PCI) 6 months Women: 39.3 Men: 18.3 1 year Women: 0.6 Men: 15.3 [underlined: 2) Angina frequency] (adjusted relative difference of CABG vs. PCI) 6 months Women: 43.2 Men: 31.3 1 year Women: 11.1 Men: 19.7 [underlined: 3) Physical limitation] (adjusted relative difference of CABG vs. PCI) 6 months Women: 11.6 Men: 54.7 1 year Women: 1.6 Men: 50.6 | Fair
SYNTAX Morice et al., 2010 72 | Triple-vessel or left main coronary artery disease | PCI (type not specified) vs. CABG | Total: 705 Women: 185 (26%) | [underlined: 1) Primary endpoint, 1 year] (death/MI/stroke/repeat revascularization) CABG vs. PCI 13.6% vs. 15.8% OR (95% CI) 2.1 (−3.2 to 7.4); p = 0.44 [underlined: 2) Predictors of 1-year major adverse cardiovascular events] OR (95% CI) Women: 0.50 (0.27 to 0.91); p = 0.02 | Fair

Abbreviations: BMS = bare metal stent; CABG = coronary artery bypass graft; CAD = coronary artery disease; CI = confidence interval; CVA = cerebrovascular accident; DES = drug-eluting stent; HR = hazard ratio; MI = myocardial infarction; NSTEMI = non-ST elevation myocardial infarction; OR = odds ratio; PCI = percutaneous coronary intervention; PTCA = percutaneous transluminal coronary angioplasty; RCT = randomized controlled trial; UA = unstable angina

## References Cited in Appendix F

1 Di Mario C, Dudek D, Piscione F, et al. Immediate angioplasty versus standard therapy with rescue angioplasty after thrombolysis in the Combined Abciximab REteplase Stent Study in Acute Myocardial Infarction (CARESS-in-AMI): an open, prospective, randomised, multicentre trial. Lancet. 2008;371(9612):559-68. [pmid: 18280326].
2 Di Mario C, Bolognese L, Maillard L, et al. Combined Abciximab REteplase Stent Study in acute myocardial infarction (CARESS in AMI). Am Heart J. 2004;148(3):378-85. [pmid: 15389222].
3 Andersen HR, Nielsen TT, Rasmussen K, et al. A comparison of coronary angioplasty with fibrinolytic therapy in acute myocardial infarction. N Engl J Med. 2003;349(8):733-42. [pmid: 12930925].
4 Mortensen OS, Bjorner JB, Newman B, et al. Gender differences in health-related quality of life following ST-elevation myocardial infarction: women and men do not benefit from primary percutaneous coronary intervention to the same degree. Eur J Cardiovasc Prev Rehabil. 2007;14(1):37-43. [pmid: 17301625].
5 Nielsen PH, Maeng M, Busk M, et al. Primary angioplasty versus fibrinolysis in acute myocardial infarction: long-term follow-up in the Danish acute myocardial infarction 2 trial. Circulation. 2010;121(13):1484-91. [pmid: 20308618].
6 Busk M, Maeng M, Kristensen SD, et al. Timing, causes, and predictors of death after three years’ follow-up in the Danish Multicenter Randomized Study of Fibrinolysis versus Primary Angioplasty in Acute Myocardial Infarction (DANAMI-2) trial. Am J Cardiol. 2009;104(2):210-5. [pmid: 19576349].
7 Busk M, Maeng M, Rasmussen K, et al. The Danish multicentre randomized study of fibrinolytic therapy vs. primary angioplasty in acute myocardial infarction (the DANAMI-2 trial): outcome after 3 years follow-up. Eur Heart J. 2008;29(10):1259-66. [pmid: 17956874].
8 Dobrzycki S, Kralisz P, Nowak K, et al. Transfer with GP IIb/IIIa inhibitor tirofiban for primary percutaneous coronary intervention vs. on-site thrombolysis in patients with ST-elevation myocardial infarction (STEMI): a randomized open-label study for patients admitted to community hospitals. Eur Heart J. 2007;28(20):2438-48. [pmid: 17884846].
9 Tamis-Holland JE, Palazzo A, Stebbins AL, et al. Benefits of direct angioplasty for women and men with acute myocardial infarction: results of the Global Use of Strategies to Open Occluded Arteries in Acute Coronary Syndromes Angioplasty (GUSTO II-B) Angioplasty Substudy. Am Heart J. 2004;147(1):133-9. [pmid: 14691431].
10 Minai K, Horie H, Takahashi M, et al. Long-term outcome of primary percutaneous transluminal coronary angioplasty for low-risk acute myocardial infarction in patients older than 80 years: a single-center, open, randomized trial. Am Heart J. 2002;143(3):497-505. [pmid: 11868057].
11 Stone GW, Grines CL, Browne KF, et al. Comparison of in-hospital outcome in men versus women treated by either thrombolytic therapy or primary coronary angioplasty for acute myocardial infarction. Am J Cardiol. 1995;75(15):987-92. [pmid: 7747700].
12 Hochman JS, Sleeper LA, White HD, et al. One-year survival following early revascularization for cardiogenic shock. JAMA. 2001;285(2):190-2. [pmid: 11176812].
13 Hochman JS, Sleeper LA, Webb JG, et al. Early revascularization and long-term survival in cardiogenic shock complicating acute myocardial infarction. JAMA. 2006;295(21):2511-5. [pmid: 16757723].
14 Hochman JS, Sleeper LA, Godfrey E, et al. SHould we emergently revascularize Occluded Coronaries for cardiogenic shocK: an international randomized trial of emergency PTCA/CABG-trial design. The SHOCK Trial Study Group. Am Heart J. 1999;137(2):313-21. [pmid: 9924166].
15 Hochman JS, Sleeper LA, Webb JG, et al. Early revascularization in acute myocardial infarction complicated by cardiogenic shock. SHOCK Investigators Should We Emergently Revascularize Occluded Coronaries for Cardiogenic Shock. N Engl J Med. 1999;341(9):625-34. [pmid: 10460813].
16 Lagerqvist B, Safstrom K, Stahle E, et al. Is early invasive treatment of unstable coronary artery disease equally effective for both women and men? FRISC II Study Group Investigators. J Am Coll Cardiol. 2001;38(1):41-8. [pmid: 11451294].
17 Lagerqvist B, Husted S, Kontny F, et al. 5-year outcomes in the FRISC-II randomised trial of an invasive versus a non-invasive strategy in non-ST-elevation acute coronary syndrome: a follow-up study. Lancet. 2006;368(9540):998-1004. [pmid: 16980115].
18 Wallentin L, Lagerqvist B, Husted S, et al. Outcome at 1 year after an invasive compared with a non-invasive strategy in unstable coronary-artery disease: The FRISC II invasive randomised trial. Lancet. 2000;355(9223):9-16. [pmid: 10615884].
19 Invasive compared with non-invasive treatment in unstable coronary-artery disease: FRISC II prospective randomised multicentre study. FRagmin and Fast Revascularisation during InStability in Coronary artery disease Investigators. Lancet. 1999;354(9180):708-15. [pmid: 10475181].
20 Ottervanger JP, Armstrong P, Barnathan ES, et al. Association of revascularisation with low mortality in non-ST elevation acute coronary syndrome, a report from GUSTO IV-ACS. Eur Heart J. 2004;25(17):1494-501. [pmid: 15342168].
21 de Winter RJ, Windhausen F, Cornel JH, et al. Early invasive versus selectively invasive management for acute coronary syndromes. N Engl J Med. 2005;353(11):1095-104. [pmid: 16162880].
22 Damman P, Hirsch A, Windhausen F, et al. 5-year clinical outcomes in the ICTUS (Invasive versus Conservative Treatment in Unstable coronary Syndromes) trial a randomized comparison of an early invasive versus selective invasive management in patients with non-ST-segment elevation acute coronary syndrome. J Am Coll Cardiol. 2010;55(9):858-64. [pmid: 20045278].
23 Coronary angioplasty versus medical therapy for angina: the second Randomised Intervention Treatment of Angina (RITA-2) trial. RITA-2 trial participants. Lancet. 1997;350(9076):461-8. [pmid: 9274581].
24 Clayton TC, Pocock SJ, Henderson RA, et al. Do men benefit more than women from an interventional strategy in patients with unstable angina or non-ST-elevation myocardial infarction? The impact of gender in the RITA 3 trial. Eur Heart J. 2004;25(18):1641-50. [pmid: 15351164].
25 Fox KA, Poole-Wilson PA, Henderson RA, et al. Interventional versus conservative treatment for patients with unstable angina or non-ST-elevation myocardial infarction: the British Heart Foundation RITA 3 randomised trial. Randomized Intervention Trial of unstable Angina. Lancet. 2002;360(9335):743-51. [pmid: 12241831].
26 Cannon CP, Weintraub WS, Demopoulos LA, et al. Comparison of early invasive and conservative strategies in patients with unstable coronary syndromes treated with the glycoprotein IIb/IIIa inhibitor tirofiban. N Engl J Med. 2001;344(25):1879-87. [pmid: 11419424].
27 Glaser R, Herrmann HC, Murphy SA, et al. Benefit of an early invasive management strategy in women with acute coronary syndromes. JAMA. 2002;288(24):3124-9. [pmid: 12495392].
28 Cannon CP, Weintraub WS, Demopoulos LA, et al. Invasive versus conservative strategies in unstable angina and non-Q-wave myocardial infarction following treatment with tirofiban: rationale and study design of the international TACTICS-TIMI 18 Trial. Treat Angina with Aggrastat and determine Cost of Therapy with an Invasive or Conservative Strategy. Thrombolysis In Myocardial Infarction. Am J Cardiol. 1998;82(6):731-6. [pmid: 9761082].
29 Effects of tissue plasminogen activator and a comparison of early invasive and conservative strategies in unstable angina and non-Q-wave myocardial infarction. Results of the TIMI IIIB Trial Thrombolysis in Myocardial Ischemia. Circulation. 1994;89(4):1545-56. [pmid: 8149520].
30 Anderson HV, Cannon CP, Stone PH, et al. One-year results of the Thrombolysis in Myocardial Infarction (TIMI) IIIB clinical trial. A randomized comparison of tissue-type plasminogen activator versus placebo and early invasive versus early conservative strategies in unstable angina and non-Q wave myocardial infarction. J Am Coll Cardiol. 1995;26(7):1643-50. [pmid: 7594098].
31 Allen KB, Dowling RD, Angell WW, et al. Transmyocardial revascularization: 5-year follow-up of a prospective, randomized multicenter trial. Ann Thorac Surg. 2004;77(4):1228-34. [pmid: 15063241].
32 Allen KB, Dowling RD, Fudge TL, et al. Comparison of transmyocardial revascularization with medical therapy in patients with refractory angina. N Engl J Med. 1999;341(14):1029-36. [pmid: 10502592].
33 Boden WE, O’Rourke RA, Teo KK, et al. Optimal medical therapy with or without PCI for stable coronary disease. N Engl J Med. 2007;356(15):1503-16. [pmid: 17387127].
34 Mancini GB, Bates ER, Maron DJ, et al. Quantitative results of baseline angiography and percutaneous coronary intervention in the COURAGE trial. Circ Cardiovasc Qual Outcomes. 2009;2(4):320-7. [pmid: 20031857].
35 Boden WE, O’Rourke RA, Teo KK, et al. Design and rationale of the Clinical Outcomes Utilizing Revascularization and Aggressive DruG Evaluation (COURAGE) trial Veterans Affairs Cooperative Studies Program no. 424. Am Heart J. 2006;151(6):1173-9. [pmid: 16781214].
36 Hueb W, Lopes N, Gersh BJ, et al. Ten-year follow-up survival of the Medicine, Angioplasty, or Surgery Study (MASS II): a randomized controlled clinical trial of 3 therapeutic strategies for multivessel coronary artery disease. Circulation. 2010;122(10):949-57. [pmid: 20733102].
37 Hueb W, Soares PR, Gersh BJ, et al. The medicine, angioplasty, or surgery study (MASS-II): a randomized, controlled clinical trial of three therapeutic strategies for multivessel coronary artery disease: one-year results. J Am Coll Cardiol. 2004;43(10):1743-51. [pmid: 15145093].
38 Hueb W, Lopes NH, Gersh BJ, et al. Five-year follow-up of the Medicine, Angioplasty, or Surgery Study (MASS II): a randomized controlled clinical trial of 3 therapeutic strategies for multivessel coronary artery disease. Circulation. 2007;115(9):1082-9. [pmid: 17339566].
39 Hochman JS, Lamas GA, Buller CE, et al. Coronary intervention for persistent occlusion after myocardial infarction. N Engl J Med. 2006;355(23):2395-407. [pmid: 17105759].
40 Hochman JS, Lamas GA, Knatterud GL, et al. Design and methodology of the Occluded Artery Trial (OAT). Am Heart J. 2005;150(4):627-42. [pmid: 16209957].
41 Hochman JS, Reynolds HR, Dzavik V, et al. Long-term effects of percutaneous coronary intervention of the totally occluded infarct-related artery in the subacute phase after myocardial infarction. Circulation. 2011;124(21):2320-2328. [pmid: 22025606].
42 Velazquez EJ, Lee KL, Deja MA, et al. Coronary-Artery Bypass Surgery in Patients with Left Ventricular Dysfunction. N Engl J Med. 2011. [pmid: 21463150].
43 Velazquez EJ, Lee KL, O’Connor CM, et al. The rationale and design of the Surgical Treatment for Ischemic Heart Failure (STICH) trial. J Thorac Cardiovasc Surg. 2007;134(6):1540-7. [pmid: 18023680].
44 Vaina S, Voudris V, Morice MC, et al. Effect of gender differences on early and mid-term clinical outcome after percutaneous or surgical coronary revascularisation in patients with multivessel coronary artery disease: insights from ARTS I and ARTS II. EuroIntervention. 2009;4(4):492-501. [pmid: 19284072].
45 van den Brand MJ, Rensing BJ, Morel MA, et al. The effect of completeness of revascularization on event-free survival at one year in the ARTS trial. J Am Coll Cardiol. 2002;39(4):559-64. [pmid: 11849851].
46 Serruys PW, Unger F, van Hout BA, et al. The ARTS study (Arterial Revascularization Therapies Study). Semin Interv Cardiol. 1999;4(4):209-19. [pmid: 10738354].
47 Voudris V, Ong AT, Serruys PW, et al. Sex differences and their impact on clinical outcome after percutaneous or surgical revascularisation: a report from the Arterial Revascularisation Therapies Study (ARTS). EuroIntervention. 2006;2(2):175-80. [pmid: 19755257].
48 The ARTS (Arterial Revascularization Therapies Study): Background, goals and methods. Int J Cardiovasc Intervent. 1999;2(1):41-50. [pmid: 12623386].
49 Jacobs AK, Kelsey SF, Brooks MM, et al. Better outcome for women compared with men undergoing coronary revascularization: a report from the bypass angioplasty revascularization investigation (BARI). Circulation. 1998;98(13):1279-85. [pmid: 9751675].
50 Gibbons RJ, Miller DD, Liu P, et al. Similarity of ventricular function in patients alive 5 years after randomization to surgery or angioplasty in the BARI trial. Circulation. 2001;103(8):1076-82. [pmid: 11222469].
51 The final 10-year follow-up results from the BARI randomized trial. J Am Coll Cardiol. 2007;49(15):1600-6. [pmid: 17433949].
52 Lombardero MS. Seven-year outcome in the bypass angioplasty revascularization investigation (BARI), by treatment and presence of diabetes. Cardiovasc Rev Rep. 2002;23(1):14-18.
53 Seven-year outcome in the Bypass Angioplasty Revascularization Investigation (BARI) by treatment and diabetic status. J Am Coll Cardiol. 2000;35(5):1122-9. [pmid: 10758950].
54 Hlatky MA, Charles ED, Nobrega F, et al. Initial functional and economic status of patients with multivessel coronary artery disease randomized in the Bypass Angioplasty Revascularization Investigation (BARI). Am J Cardiol. 1995;75(9):34C-41C. [pmid: 7801861].
55 Rogers WJ, Alderman EL, Chaitman BR, et al. Bypass Angioplasty Revascularization Investigation (BARI): baseline clinical and angiographic data. Am J Cardiol. 1995;75(9):9C-17C. [pmid: 7892823].
56 Sutton-Tyrrell K, Rihal C, Sellers MA, et al. Long-term prognostic value of clinically evident noncoronary vascular disease in patients undergoing coronary revascularization in the Bypass Angioplasty Revascularization Investigation (BARI). Am J Cardiol. 1998;81(4):375-81. [pmid: 9485122].
57 Mullany CJ, Mock MB, Brooks MM, et al. Effect of age in the Bypass Angioplasty Revascularization Investigation (BARI) randomized trial. Ann Thorac Surg. 1999;67(2):396-403. [pmid: 10197660].
58 Comparison of coronary bypass surgery with angioplasty in patients with multivessel disease. The Bypass Angioplasty Revascularization Investigation (BARI) Investigators. N Engl J Med. 1996;335(4):217-25. [pmid: 8657237].
59 First-year results of CABRI (Coronary Angioplasty versus Bypass Revascularisation Investigation). CABRI Trial Participants. Lancet. 1995;346(8984):1179-84. [pmid: 7475656].
60 Kapur A, Hall RJ, Malik IS, et al. Randomized comparison of percutaneous coronary intervention with coronary artery bypass grafting in diabetic patients. 1-year results of the CARDia (Coronary Artery Revascularization in Diabetes) trial. J Am Coll Cardiol. 2010;55(5):432-40. [pmid: 20117456].
61 Kapur A, Malik IS, Bagger JP, et al. The Coronary Artery Revascularisation in Diabetes (CARDia) trial: background, aims, and design. Am Heart J. 2005;149(1):13-9. [pmid: 15660030].
62 King SB 3rd, Kosinski AS, Guyton RA, et al. Eight-year mortality in the Emory Angioplasty versus Surgery Trial (EAST). J Am Coll Cardiol. 2000;35(5):1116-21. [pmid: 10758949].
63 King SB 3rd, Lembo NJ, Weintraub WS, et al. Emory Angioplasty Versus Surgery Trial (EAST): design, recruitment, and baseline description of patients. Am J Cardiol. 1995;75(9):42C-59C. [pmid: 7892822].
64 King SB 3rd, Lembo NJ, Weintraub WS, et al. A randomized trial comparing coronary angioplasty with coronary bypass surgery. Emory Angioplasty versus Surgery Trial (EAST). N Engl J Med. 1994;331(16):1044-50. [pmid: 8090163].
65 Zhao XQ, Brown BG, Stewart DK, et al. Effectiveness of revascularization in the Emory angioplasty versus surgery trial. A randomized comparison of coronary angioplasty with bypass surgery. Circulation. 1996;93(11):1954-62. [pmid: 8640968].
66 Kaehler J, Koester R, Billmann W, et al. 13-year follow-up of the German angioplasty bypass surgery investigation. Eur Heart J. 2005;26(20):2148-53. [pmid: 15975991].
67 Hamm CW, Reimers J, Ischinger T, et al. A randomized study of coronary angioplasty compared with bypass surgery in patients with symptomatic multivessel coronary disease. German Angioplasty Bypass Surgery Investigation (GABI). N Engl J Med. 1994;331(16):1037-43. [pmid: 8090162].
68 Park SJ, Kim YH, Park DW, et al. Randomized trial of stents versus bypass surgery for left main coronary artery disease. N Engl J Med. 2011;18:1718-27. [pmid: 21463149].
69 Zhang Z, Weintraub WS, Mahoney EM, et al. Relative benefit of coronary artery bypass grafting versus stent-assisted percutaneous coronary intervention for angina pectoris and multivessel coronary disease in women versus men (one-year results from the Stent or Surgery trial). Am J Cardiol. 2004;93(4):404-9. [pmid: 14969611].
70 Zhang Z, Mahoney EM, Stables RH, et al. Disease-specific health status after stent-assisted percutaneous coronary intervention and coronary artery bypass surgery: one-year results from the Stent or Surgery trial. Circulation. 2003;108(14):1694-700. [pmid: 12975252].
71 Stables RH. Design of the ‘Stent or Surgery’ trial (SoS): a randomized controlled trial to compare coronary artery bypass grafting with percutaneous transluminal coronary angioplasty and primary stent implantation in patients with multi-vessel coronary artery disease. Semin Interv Cardiol. 1999;4(4):201-7. [pmid: 10738353].
72 Morice MC, Serruys PW, Kappetein AP, et al. Outcomes in patients with de novo left main disease treated with either percutaneous coronary intervention using paclitaxel-eluting stents or coronary artery bypass graft treatment in the Synergy Between Percutaneous Coronary Intervention with TAXUS and Cardiac Surgery (SYNTAX) trial. Circulation. 2010;121(24):2645-53. [pmid: 20530001].