# Quality and Applicability of Included Studies

Table D-1 Quality and applicability for RCTs evaluating women with STEMI (KQ 1)

Study Name | Study Author/Year | Comparator | Quality | Limitations to Applicability
CARESS-in-AMI | Di Mario et al., 2008^1^ | Immediate PCI with fibrinolysis (reteplase) vs. fibrinolysis (reteplase) with rescue PCI | Good | - None
DANAMI-2 | Andersen et al., 2003^2^ | PCI vs. fibrinolysis (accelerated t-PA) | Good | - None
Dobrzycki | Dobrzycki et al., 2007^3^ | Transfer with tirofiban for primary PCI vs. onsite fibrinolysis (streptokinase) | Good | - Comparability of care in international settings unclear
GUSTO II-B | Tamis-Holland et al., 2004^4^ | PCI vs. fibrinolysis (accelerated t-PA) | Good | - Comparability of care in international settings unclear
Minai | Minai et al., 2002^5^ | PCI vs. optimal medical therapy (without fibrinolysis) | Fair | - Comparability of care in international settings unclear
PAMI | Stone et al., 1995^6^ | PCI vs. fibrinolysis (t-PA) | Good | - Comparability of care in international settings unclear
SHOCK | Hochman et al., 2001^7^ | Early invasive revascularization (PCI or CABG within 6 hours) vs. initial medical stabilization (thrombolysis, IABP) | Good | - None

Abbreviations: CABG = coronary artery bypass grafting; PCI = percutaneous coronary revascularization; STEMI = ST elevation myocardial infarction

Table D-2 Quality and applicability for RCTs evaluating women with UA/NSTEMI (KQ 2)

Study Name | Study Author/Year | Comparator | Quality | Limitations to Applicability
FRISC II | Lagerqvist et al., 2001^8^ | Early invasive treatment with revascularization vs. initial conservative strategy | Good | - Comparability of care in international settings unclear
GUSTO IV-ACS | Ottervanger et al., 2004^9^ | Early invasive management vs. initial conservative treatment within 30 days. | Good | - Older versions of an intervention no longer in common use; - Resources available to providers for diagnosis and treatment of condition varied widely; - Comparability of care in international settings unclear
ICTUS | de Winter et al., 2005^10^ | Early invasive therapy with revascularization vs. selective invasive strategy | Good | - Comparability of care in international settings unclear
RITA-2 | Anonymous, 1997^11^ | Early invasive therapy with PCI vs. initial conservative | Fair | - Provider type/specialty varied across settings; - Comparability of care in international settings unclear
RITA-3 | Clayton et al., 2004^12^ | Early invasive with PCI vs. initial conservative | Good | - None
TACTICS TIMI-18 | Cannon et al., 2001^13^ | Early invasive with PCI vs. initial conservative | Good | - None
TIMI III-B | Anonymous, 1994^14^ | Early invasive with PCI vs. initial conservative | Good | - Older versions of an intervention no longer in common use

Abbreviations: CABG = coronary artery bypass grafting; PCI = percutaneous coronary revascularization

Table D-3 Quality and applicability for RCTs evaluating women with stable angina (KQ 3 Strategy 1)

Study Name | Study Author/Year | Comparator | Quality | Limitations to Applicability
Allen | Allen et al., 2004^15^ | Surgical revascularization vs. optimal medical therapy | Good | - Older versions of an intervention no longer in common use; - Cointerventions that were likely to modify effectiveness of therapy
COURAGE | Boden et al., 2007^16^ | PCI (or CABG if PCI failed) vs. optimal medical therapy | Good | - None
MASS II | Hueb et al., 2010^17^ | PCI vs. optimal medical therapy CABG vs. optimal medical therapy | Good | - Study population not representative of community patients; - Cointerventions that were likely to modify effectiveness of therapy
OAT | Hochman et al., 2006^18^ | PCI (or CABG if PCI failed) vs. optimal medical therapy | Good | - None
STICH | Velazquez et al., 2011^19^ | CABG vs. optimal medical therapy | Good | - Cointerventions that were likely to modify effectiveness of therapy; - Comparability of care in international settings unclear

Abbreviations: CABG = coronary artery bypass grafting; PCI = percutaneous coronary revascularization

Table D-4 Quality and applicability for RCTs evaluating women with stable/unstable angina (KQ 3 Strategy 2)

Study Name | Study Author/Year | Comparator | Quality | Limitations to Applicability
ARTS I | Vaina et al., 2009^20^ | PCI vs. CABG | Good | - None
BARI | Jacobs et al., 1998^21^ | PCI vs. CABG | Good | - Study population not representative of community patients; - Older versions of an intervention no longer in common use; - Cointerventions that were likely to modify effectiveness of therapy
CABRI | Anonymous, 1995^22^ | PCI vs. CABG | Good | - None
CARDia | Kapur et al., 2010^23^ | PCI vs. CABG | Good | - Key characteristics not reported; - Provider type/specialty varied across settings
EAST | King et al., 2000^24^ | PCI vs. CABG | Good | - Study population not representative of community patients; - Older versions of an intervention no longer in common use; - Cointerventions that were likely to modify effectiveness of therapy
GABI | Kaehler et al., 2005^25^ | PCI vs. CABG | Good | - Cointerventions that were likely to modify effectiveness of therapy
MASS II | Hueb et al., 2010^17^ | PCI vs. CABG | Good | - Study population not representative of community patients; - Cointerventions that were likely to modify effectiveness of therapy
PRECOMBAT | Park et al., 2011^26^ | PCI vs. CABG | Good | - Comparability of care in international settings unclear
SOS | Zhang et al., 2004^27^ | PCI vs. CABG | Fair | - Study population not representative of community patients; - Cointerventions that were likely to modify effectiveness of therapy
SYNTAX | Morice et al., 2010^28^ | PCI vs. CABG | Fair | - Data not stratified or adjusted for key predictors; - Comparability of care in international settings unclear

Abbreviations: CABG = coronary artery bypass grafting; PCI = percutaneous coronary revascularization

## References Cited in Appendix D

1 Di Mario C, Dudek D, Piscione F, et al. Immediate angioplasty versus standard therapy with rescue angioplasty after thrombolysis in the Combined Abciximab REteplase Stent Study in Acute Myocardial Infarction (CARESS-in-AMI): an open, prospective, randomised, multicentre trial. Lancet. 2008;371(9612):559-68. [pmid: 18280326].
2 Andersen HR, Nielsen TT, Rasmussen K, et al. A comparison of coronary angioplasty with fibrinolytic therapy in acute myocardial infarction. N Engl J Med. 2003;349(8):733-42. [pmid: 12930925].
3 Dobrzycki S, Kralisz P, Nowak K, et al. Transfer with GP IIb/IIIa inhibitor tirofiban for primary percutaneous coronary intervention vs. on-site thrombolysis in patients with ST-elevation myocardial infarction (STEMI): a randomized open-label study for patients admitted to community hospitals. Eur Heart J. 2007;28(20):2438-48. [pmid: 17884846].
4 Tamis-Holland JE, Palazzo A, Stebbins AL, et al. Benefits of direct angioplasty for women and men with acute myocardial infarction: results of the Global Use of Strategies to Open Occluded Arteries in Acute Coronary Syndromes Angioplasty (GUSTO II-B) Angioplasty Substudy. Am Heart J. 2004;147(1):133-9. [pmid: 14691431].
5 Minai K, Horie H, Takahashi M, et al. Long-term outcome of primary percutaneous transluminal coronary angioplasty for low-risk acute myocardial infarction in patients older than 80 years: a single-center, open, randomized trial. Am Heart J. 2002;143(3):497-505. [pmid: 11868057].
6 Stone GW, Grines CL, Browne KF, et al. Comparison of in-hospital outcome in men versus women treated by either thrombolytic therapy or primary coronary angioplasty for acute myocardial infarction. Am J Cardiol. 1995;75(15):987-92. [pmid: 7747700].
7 Hochman JS, Sleeper LA, White HD, et al. One-year survival following early revascularization for cardiogenic shock. JAMA. 2001;285(2):190-2. [pmid: 11176812].
8 Lagerqvist B, Safstrom K, Stahle E, et al. Is early invasive treatment of unstable coronary artery disease equally effective for both women and men? FRISC II Study Group Investigators. J Am Coll Cardiol. 2001;38(1):41-8. [pmid: 11451294].
9 Ottervanger JP, Armstrong P, Barnathan ES, et al. Association of revascularisation with low mortality in non-ST elevation acute coronary syndrome, a report from GUSTO IV-ACS. Eur Heart J. 2004;25(17):1494-501. [pmid: 15342168].
10 de Winter RJ, Windhausen F, Cornel JH, et al. Early invasive versus selectively invasive management for acute coronary syndromes. N Engl J Med. 2005;353(11):1095-104. [pmid: 16162880].
11 Coronary angioplasty versus medical therapy for angina: the second Randomised Intervention Treatment of Angina (RITA-2) trial. RITA-2 trial participants. Lancet. 1997;350(9076):461-8. [pmid: 9274581].
12 Clayton TC, Pocock SJ, Henderson RA, et al. Do men benefit more than women from an interventional strategy in patients with unstable angina or non-ST-elevation myocardial infarction? The impact of gender in the RITA 3 trial. Eur Heart J. 2004;25(18):1641-50. [pmid: 15351164].
13 Cannon CP, Weintraub WS, Demopoulos LA, et al. Comparison of early invasive and conservative strategies in patients with unstable coronary syndromes treated with the glycoprotein IIb/IIIa inhibitor tirofiban. N Engl J Med. 2001;344(25):1879-87. [pmid: 11419424].
14 Effects of tissue plasminogen activator and a comparison of early invasive and conservative strategies in unstable angina and non-Q-wave myocardial infarction. Results of the TIMI IIIB Trial Thrombolysis in Myocardial Ischemia. Circulation. 1994;89(4):1545-56. [pmid: 8149520].
15 Allen KB, Dowling RD, Angell WW, et al. Transmyocardial revascularization: 5-year follow-up of a prospective, randomized multicenter trial. Ann Thorac Surg. 2004;77(4):1228-34. [pmid: 15063241].
16 Boden WE, O’Rourke RA, Teo KK, et al. Optimal medical therapy with or without PCI for stable coronary disease. N Engl J Med. 2007;356(15):1503-16. [pmid: 17387127].
17 Hueb W, Lopes N, Gersh BJ, et al. Ten-year follow-up survival of the Medicine, Angioplasty, or Surgery Study (MASS II): a randomized controlled clinical trial of 3 therapeutic strategies for multivessel coronary artery disease. Circulation. 2010;122(10):949-57. [pmid: 20733102].
18 Hochman JS, Lamas GA, Buller CE, et al. Coronary intervention for persistent occlusion after myocardial infarction. N Engl J Med. 2006;355(23):2395-407. [pmid: 17105759].
19 Velazquez EJ, Lee KL, Deja MA, et al. Coronary-Artery Bypass Surgery in Patients with Left Ventricular Dysfunction. N Engl J Med. 2011. [pmid: 21463150].
20 Vaina S, Voudris V, Morice MC, et al. Effect of gender differences on early and mid-term clinical outcome after percutaneous or surgical coronary revascularisation in patients with multivessel coronary artery disease: insights from ARTS I and ARTS II. EuroIntervention. 2009;4(4):492-501. [pmid: 19284072].
21 Jacobs AK, Kelsey SF, Brooks MM, et al. Better outcome for women compared with men undergoing coronary revascularization: a report from the bypass angioplasty revascularization investigation (BARI). Circulation. 1998;98(13):1279-85. [pmid: 9751675].
22 First-year results of CABRI (Coronary Angioplasty versus Bypass Revascularisation Investigation). CABRI Trial Participants. Lancet. 1995;346(8984):1179-84. [pmid: 7475656].
23 Kapur A, Hall RJ, Malik IS, et al. Randomized comparison of percutaneous coronary intervention with coronary artery bypass grafting in diabetic patients. 1-year results of the CARDia (Coronary Artery Revascularization in Diabetes) trial. J Am Coll Cardiol. 2010;55(5):432-40. [pmid: 20117456].
24 King SB 3rd, Kosinski AS, Guyton RA, et al. Eight-year mortality in the Emory Angioplasty versus Surgery Trial (EAST). J Am Coll Cardiol. 2000;35(5):1116-21. [pmid: 10758949].
25 Kaehler J, Koester R, Billmann W, et al. 13-year follow-up of the German angioplasty bypass surgery investigation. Eur Heart J. 2005;26(20):2148-53. [pmid: 15975991].
26 Park SJ, Kim YH, Park DW, et al. Randomized trial of stents versus bypass surgery for left main coronary artery disease. N Engl J Med. 2011;18:1718-27. [pmid: 21463149].
27 Zhang Z, Weintraub WS, Mahoney EM, et al. Relative benefit of coronary artery bypass grafting versus stent-assisted percutaneous coronary intervention for angina pectoris and multivessel coronary disease in women versus men (one-year results from the Stent or Surgery trial). Am J Cardiol. 2004;93(4):404-9. [pmid: 14969611].
28 Morice MC, Serruys PW, Kappetein AP, et al. Outcomes in patients with de novo left main disease treated with either percutaneous coronary intervention using paclitaxel-eluting stents or coronary artery bypass graft treatment in the Synergy Between Percutaneous Coronary Intervention with TAXUS and Cardiac Surgery (SYNTAX) trial. Circulation. 2010;121(24):2645-53. [pmid: 20530001].