# Data Abstraction Elements

## I Study Characteristics

- Study name and acronym
- Other articles used in this abstraction
- Study dates
- Date enrollment started (Mon and YYYY)
- Date enrollment ended (Mon and YYYY)
- Number of subjects screened/approached for study participation: Total. Female, Male
- Study site
- Single center, Multicenter, Not reported/Unclear
- Geographic location
- If single center, enter City and State (if US) or City and Country (if outside US). If multicenter, enter number of sites. Enter NR if not reported.
- If multicenter, specify applicable geographic regions
- Funding source: Government, Private foundation, Industry, Not reported, Other.
- Setting: Academic centers, Community hospitals, Outpatient, VA, Not reported/unclear, Other
- Were patients transported from the site of presentation to another location to receive PCI?
- Were patients transported from the site of presentation to another location to receive CABG?
- Qualifications of the study surgeons: Not specified, Minimum case volume (specify), Maximum mortality (specify), Other (specify)
- Qualifications of the study interventional cardiologists: Not specified, Minimum case volume (specify), Maximum mortality (specify), Minimum success rates (specify), Other (specify)
- Qualifications of the sites involved in the trial: Not specified, Minimum case volume (specify), Maximum mortality (specify), Minimum success rates (specify), Other (specify)
- Were guideline-based treatment protocols followed?
- Briefly describe use of guideline-based protocols.
- Length of followup
- Inclusion and exclusion criteria; Copy/paste criteria as reported in the article.
- Clinical presentation: STEMI NSTEMI/Unstable angina Stable CAD
- Method for interpretation of angiograms: Central laboratory, Local site interpretation, Quantitative angiography, Unclear/Not reported Other
- Were study patients systematically enrolled in cardiac rehabilitation?
- Does the study report a composite primary endpoint?
- Indicate the components of the composite primary endpoint (check all that apply): Total mortality, Cardiac mortality, Nonfatal myocardial infarction, Stroke, TIA, Unstable angina, Angina/recurrent symptoms, Angina class, Angina relief, Repeat revascularization, Heart failure, Graft failure, Hospitalization, Length of hospital stay, Bleeding, Quality of life, Cognitive effects, Adverse drug reactions, Radiation exposure, Access site complications, Renal dysfunction, Anaphylaxis, Arrhythmias, Stent thrombosis, Infections, Cost, Employment/productivity, Other (specify )
- Indicate timing of the components of the composite primary endpoint: Short-term (less than or equal to 30 days), Long-term (greater than 30 days), Mixture of short- and long-term outcomes
- Indicate all short-term (<30 days) primary and secondary endpoints separately reported (i.e. reported singly, rather than only reported as part of a composite primary endpoint): Total mortality, Cardiac mortality, Nonfatal myocardial infarction, Stroke, TIA, Unstable angina, Angina/recurrent symptoms, Angina class, Angina relief, Repeat revascularization, Heart failure, Graft failure, Hospitalization, Length of hospital stay, Bleeding, Quality of life, Cognitive effects, Adverse drug reactions, Radiation exposure, Access site complications, Renal dysfunction, Anaphylaxis, Arrhythmias, Stent thrombosis, Infections, Cost, Employment/productivity, Other (specify )
- Indicate all long-term (>30 days) primary and secondary endpoints separately reported (i.e. reported singly, rather than only reported as part of a composite primary endpoint): Total mortality, Cardiac mortality, Nonfatal myocardial infarction, Stroke, TIA, Unstable angina, Angina/recurrent symptoms, Angina class, Angina relief, Repeat revascularization, Heart failure, Graft failure, Hospitalization, Length of hospital stay, Bleeding, Quality of life, Cognitive effects, Adverse drug reactions, Radiation exposure, Access site complications, Renal dysfunction, Anaphylaxis, Arrhythmias, Stent thrombosis, Infections, Cost, Employment/productivity, Other (specify )
- Describe how the short- and long-term outcome data is reported (e.g. Kaplan-Meier plots, Cox proportional hazards, hazard ratios, risk ratios, odds ratios, raw numbers, percentages, other methods), including whether p values, confidence intervals, etc. are provided.
- Include timing of outcomes (e.g. 1 yr, 5 yr)
- Comments (if needed)

## II Intervention characteristics

- Briefly indicate which population/intervention combination is reflected by the data abstracted on this instance of the form.
- PCI Procedural Characteristics
  ○ Describe the PCI intervention
  ○ Complete the below for Total, Female, and Male
    ■ Complete revascularization achieved
    ■ Vessels treated (mean): 1, 2, 3, or Unclear/Not specified
    ■ Access site
      - Radial
      - Femoral
      - Unclear/Not specified
    ■ Stents used (mean)
      - 0 stents
      - Bare metal stents
        ○ 1
        ○ 2
        ○ 3
        ○ More than 3
        ○ Unclear/Not specified
      - Drug-eluting stents
        ○ 1
        ○ 2
        ○ 3
        ○ More than 3
        ○ Unclear/Not specified
    ■ Interventional approach
      - Balloon
      - Atherectomy
      - Unclear/Not specified
    ■ Timing
      - Initial conservative strategy
      - Invasive strategy
      - Unclear/Not specified
  ○ If applicable, specify type of bare metal stent used
  ○ If applicable, specify type of drug-eluting stent used:
- CABG Procedural Characteristics
  ○ Describe the CABG intervention:
  ○ Complete the below for Total, Female, and Male
    ■ Bypass mode
      - None (beating heart)
      - Normothermic
      - Hypothermic
      - Unclear/Not specified
    ■ Cardioplegia type
      - Blood
      - Crystalloid
      - Other
      - Mixed
      - Unclear/Not specified
    ■ Incision type
      - Median sternotomy
      - Minimally invasive direct coronary bypass (Midcab)
      - Unclear/Not specified
    ■ Grafts used
      - 0 grafts
      - Saphenous vein (mean)
        ○ 1
        ○ 2
        ○ Greater than 2
        ○ Unclear/Not specified
      - Mammary arteries (mean)
        ○ Left internal mammary artery
        ○ Right internal mammary artery
        ○ Both mammary arteries
        ○ Unclear/Not specified
      - Radial artery (mean)
        ○ 1
        ○ 2
        ○ Unclear/Not specified
    ■ Transmyocardial laser revascularization (TMR)
      - Received
      - Not received
      - Unclear/Not specified
  ○ If applicable, specify type of crystalloid cardioplegia agent used
  ○ If applicable, specify type of vein harvest (check all that apply): Endoscopic, Open, Unclear/Not reported, Other (specify)
  ○ Mean cardiopulmonary bypass time
  ○ Mean cross-clamp time
  ○ Were concomitant procedures performed at the time of CABG surgery?
    ■ If yes, describe the concomitant procedures
- Medical Therapy Intervention Characteristics
  ○ Describe the medical therapy intervention received by patients in the PCI arm (if applicable)
  ○ Describe the medical therapy intervention received by patients in the CABG arm (if applicable)
  ○ Describe the medical therapy intervention received by patients in the OMT arm (if applicable)
  ○ Medications received in-hospital: record for PCI Subjects, CABG Subjects, and OMT Subjects; If ‘yes’ list drug name(s)/dosage(s)
    ■ Acetylsalicylic acid (ASA)
    ■ Additional antiplatelet agents (e.g. clopidogrel, prasugrel, ticagrelor)
    ■ Antithrombin drugs (e.g. LMWH, unfractionated heparin, bivalirudin)
    ■ Glycoprotein IIb/IIIa inhibitors
    ■ Thrombolytic/fibrinolytic drugs
    ■ Statins/lipid-lowering drugs
    ■ Beta-blockers
    ■ ACEIs/ARBs
    ■ Calcium channel blockers
    ■ Nitrates
    ■ Other #1 (specify)
    ■ Other #2 (specify)
    ■ Other #3 (specify)
- Discharge medications
  ○ Record for PCI Subjects, CABG Subjects, and OMT Subjects; If ‘yes’ list drug name(s)/dosage(s)
    ■ Acetylsalicylic acid (ASA)
    ■ Additional antiplatelet agents (e.g. clopidogrel, prasugrel, ticagrelor)
    ■ Antithrombin drugs (e.g. LMWH, unfractionated heparin, bivalirudin)
    ■ Glycoprotein IIb/IIIa inhibitors
    ■ Thrombolytic/fibrinolytic drugs
    ■ Statins/lipid-lowering drugs
    ■ Beta-blockers
    ■ ACEIs/ARBs
    ■ Calcium channel blockers
    ■ Nitrates
    ■ Other #1 (specify)
    ■ Other #2 (specify)
    ■ Other #3 (specify)
- Lifestyle modification
  ○ Indicate the components of lifestyle modification recommended to patients in the study (check all that apply): Smoking cessation, Diet modification, Exercise, Other (specify)
  ○ If lifestyle modifications recommended were not consistent across all patients in the study, specify which groups received these recommendations and which did not.
- Therapeutic targets
  ○ Did the study include consideration of therapeutic target goals?
    ■ If yes, describe the therapeutic targets considered and whether interventions were adjusted for the purpose of meeting those specific goals.
- Compliance
  ○ If reported, provide data on in-hospital medication compliance (and lifestyle modification compliance, if available)
  ○ If reported, provide data on post-discharge medication compliance (and lifestyle modification compliance, if available) at the first followup visit after discharge. Include the time point of this followup visit (including units)
- Comments (if needed)

## III Outcomes

- Outcomes definitions
  ○ Authors’ definition of procedure-related outcomes
  ○ Authors’ definition of post-CABG MI
  ○ Authors’ definition of post-PCI MI
  ○ Check all outcomes for which gender-specific data is provided. Include an outcome if (1) data is reported specifically for women, or if (2) data is reported for men that can be used to calculate values for women (Total mortality, Cardiac mortality, Nonfatal myocardial infarction, Stroke, TIA, Unstable angina, Angina/recurrent symptoms/refractory angina/refractory myocardial infarction, Angina class, Angina relief, Repeat revascularization (PCI or CABG), Heart failure, Graft failure, Hospitalization/Re-hospitalization, Length of hospital stay, Bleeding, Quality of life, Cognitive effects, Adverse drug reactions, Radiation exposure, Access site complications, Renal dysfunction, Anaphylaxis, Arrhythmias, Stent thrombosis, Infections, Cost, Employment/productivity, Other individual outcome #1 (e.g. CPR, cardioversion, respiratory failure, pulmonary edema), Other individual outcome #2, Other individual outcome #3.)
  ○ Comments (if needed)
- Composite outcome data
  ○ Are one or more composite outcomes reported in such a way that data for women can be abstracted or derived?
  ○ Is this a Primary or Secondary composite outcome?
  ○ Refer to the Intervention Characteristics forms completed; indicate which one applies to the outcome data recorded on this form:
  ○ Indicate the components that make up this composite outcome (check all that apply): Total mortality, Cardiac mortality, Nonfatal myocardial infarction, Stroke, TIA, Unstable angina, Angina/recurrent symptoms/refractory angina/refractory myocardial infarction, Angina class, Angina relief, Repeat revascularization (PCI or CABG), Heart failure, Graft failure, Hospitalization/Re-hospitalization, Length of hospital stay, Bleeding, Quality of life, Cognitive effects, Adverse drug reactions, Radiation exposure, Access site complications, Renal dysfunction, Anaphylaxis, Arrhythmias, Stent thrombosis, Infections, Cost, Employment/productivity, Other individual outcome #1 (e.g. CPR, cardioversion, respiratory failure, pulmonary edema), Other individual outcome #2, Other individual outcome #3.
  ○ Complete tables to provide data for this outcome/time point(s).
    ■ Timing of the outcome data reported in the table: Short term ≤ 30 days, Long-term > 30 days,
      - Specify timing of short-term outcome: 30 days, Other (specify)
      - Specify timing of long-term outcome: 6 weeks, 6 months, 1 year, 2 years, 3 years, 4 years, 5 years, Other (specify)
    ■ Indicate whether/how the results reported were adjusted (check all that apply):Results are not adjusted, RCT that did not adjust for any baseline difference, Age, Sex, Race, Comorbidity(ies) (specify), Other (specify all)
    ■ For each reported group (OMT, PCI, CABG, and/or Mixed Revascularization) record the following for Total, Female, and Male:
      - N for Analysis
      - Result
        ○ Mean
        ○ Median
        ○ Number of patients with outcome
        ○ % of patients with outcome
        ○ Relative risk
        ○ Relative hazard
        ○ Odds ratio
        ○ Risk difference
        ○ Other (specify)
      - Variability
        ○ Standard Error (SE)
        ○ Standard Deviation (SD)
        ○ Other (specify)
      - Confidence Interval (CI) or Interquartile Range (IQR)
        ○ 95% CI
        ○ Other %CI
        ○ IQR
      - p-value between female and male data (within tx group)
      - p-value between tx groups
      - Reference group (for comparisons between tx groups)
  ○ Comments (if needed)
- Individual outcome data
  ○ Select the outcome reported: Total mortality, Cardiac mortality, Nonfatal myocardial infarction, Stroke, TIA, Unstable angina, Angina/recurrent symptoms/refractory angina/refractory myocardial infarction, Angina class, Angina relief, Repeat revascularization (PCI or CABG), Heart failure, Graft failure, Hospitalization/Re-hospitalization, Length of hospital stay, Bleeding, Quality of life, Cognitive effects, Adverse drug reactions, Radiation exposure, Access site complications, Renal dysfunction, Anaphylaxis, Arrhythmias, Stent thrombosis, Infections, Cost, Employment/productivity, Other individual outcome #1 (e.g. CPR, cardioversion, respiratory failure, pulmonary edema), Other individual outcome #2, Other individual outcome #3.
  ○ Complete tables to provide data for this outcome/time point(s).
    ■ Timing of the outcome data reported in the table: Short term ≤ 30 days, Long-term > 30 days,
      - Specify timing of short-term outcome: 30 days, Other (specify)
      - Specify timing of long-term outcome: 6 weeks, 6 months, 1 year, 2 years, 3 years, 4 years, 5 years, Other (specify)
    ■ Indicate whether/how the results reported were adjusted (check all that apply):Results are not adjusted, RCT that did not adjust for any baseline difference, Age, Sex, Race, Comorbidity(ies) (specify), Other (specify all)
    ■ For each reported group (OMT, PCI, CABG, and/or Mixed Revascularization) record the following for Total, Female, and Male:
      - N for Analysis
      - Result
        ○ Mean
        ○ Median
        ○ Number of patients with outcome
        ○ % of patients with outcome
        ○ Relative risk
        ○ Relative hazard
        ○ Odds ratio
        ○ Risk difference
        ○ Other (specify)
      - Variability
        ○ Standard Error (SE)
        ○ Standard Deviation (SD)
        ○ Other (specify)
      - Confidence Interval (CI) or Interquartile Range (IQR)
        ○ 95% CI
        ○ Other %CI
        ○ IQR
      - p-value between female and male data (within tx group)
      - p-value between tx groups
      - Reference group (for comparisons between tx groups)
  ○ Comments (if needed)

## IV Subgroup Analyses

- Does the article include subgroup analyses reported in a gender-specific way such that data for women can be abstracted or derived for any outcomes of interest?
- For each outcome record for Total, Female, and Male
- Indicate the nature of the subgroup analysis (i.e. the characteristic factor being considered): Age, Race, Other demographic or socioeconomic factor (specify), Diabetes, Chronic kidney disease, Other comorbid disease (specify), Angiographic-specific factor (specify), CABG-specific factor (specify), Hospital characteristic (specify)
- Specify the categories for this subgroup analysis. Columns are provided to capture up to 5 categories. Complete only the number needed to capture the data presented in the study.
  ○ Define the categories, then complete the tables with as much information as is provided in the study.
  ○ Provide data for each outcome. Clearly indicate units (number of patients, %, hazard ratio, etc.). Include values for confidence intervals, p values, standard error, standard deviation, etc. when available.
- Comments (if needed):

## V Quality Assessment

- Selection Bias
  ○ Was treatment adequately randomized (e.g. random number table, computer-generated randomization)?
  ○ Was the allocation of treatment adequately concealed (e.g. pharmacy-controlled randomization or use of sequentially numbered sealed envelopes)?
  ○ Did the strategy for recruiting participants into the study differ across study groups?
  ○ Are baseline characteristics similar between groups? If not, did the analysis control for differences?
- Performance Bias
  ○ Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results?
  ○ Did variation from the study protocol compromise the conclusions of the study?
- Attrition Bias
  ○ Was there a high rate of differential or overall attrition?
  ○ Did attrition result in a difference in group characteristics between baseline (or randomization) and followup?
  ○ Is the analysis conducted on an intention-to-treat (ITT) basis?
- Detection Bias
  ○ Were the outcome assessors blinded to the intervention status of participants?
  ○ Are the inclusion/exclusion criteria measured using valid and reliable measures?
  ○ Are the inclusion/exclusion criteria implemented consistently across all study participants?
  ○ Are interventions/exposures assessed using valid and reliable measures?
  ○ Are interventions/exposures implemented consistently across all study participants?
  ○ Are primary outcomes assessed using valid and reliable measures?
  ○ Are primary outcomes implemented consistently across all study participants?
- Reporting Bias
  ○ Are the potential outcomes pre-specified by the researchers? Are all pre-specified outcomes reported?
- Additional Comments
- Summary Judgment. Assign the study an overall quality rating based on the following definitions:
  ○ Good (low risk of bias). These studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; low dropout rate; and clear reporting of dropouts.
  ○ Fair. These studies are susceptible to some bias, but it is not sufficient to invalidate the results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
  ○ Poor (high risk of bias). These studies have significant flaws that imply biases of various types that may invalidate the results. They have serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.

## VI Applicability

- Population (P) (select all that apply)
  ○ Study population not representative of community patients
  ○ Study population poorly specified
  ○ Key characteristics not reported
- Intervention (I) (select all that apply)
  ○ Monitoring practices or visit frequency not used in typical practice
  ○ Older versions of an intervention no longer in common use
  ○ Cointerventions that are likely to modify effectiveness of therapy
  ○ Highly selected intervention team or level of training/proficiency not widely available
- Comparator (C) (select all that apply)
  ○ Inadequate comparison therapy
- Outcomes (O) (select all that apply)
  ○ Composite outcomes that mix outcomes of different significance
  ○ Data not stratified or adjusted for key predictors
  ○ Only short-term or surrogate outcomes reported
- Timing (T) (n/a)
- Setting (S) (select all that apply)
  ○ Resources available to providers for diagnosis and treatment of condition vary widely
  ○ Provider type/specialty varies across settings
  ○ Comparability of care in international settings unclear
  ○ Standards of care differ markedly from setting of interest
  ○ Specialty population or level of care differs from that seen in community
- Comments (if needed)