# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BMS: bare-metal stent
CABG: coronary artery bypass graft
CAD: coronary artery disease
CI: confidence interval
CVA: cerebrovascular accident
DES: drug-eluting stent
EF: ejection fraction
HCT: Hematocrit
HR: hazard ratio
IABP: intra-aortic balloon pump
ICH: intracranial hemorrhage
IV: Intravenous
KQ: Key Question
MACE: major adverse cardiovascular events
MI: myocardial infarction
NSTEMI: non-ST elevation myocardial infarction
OR: odds ratio
PCI: percutaneous coronary intervention
PTCA: percutaneous transluminal coronary angioplasty
RCT: randomized controlled trial
RR: risk ratio
SOE: strength of evidence
STEMI: ST elevation myocardial infarction
TEP: Technical Expert Panel
TIMI: thrombolysis in myocardial infarction
TMR: transmyocardial revascularization
t-PA: tissue plasminogen activator
UA: unstable angina