# Results

## Article Selection

We identified few studies addressing interventions for adolescents and young adults with autism spectrum disorders (ASD). Of the entire group of 4,855 citations identified, 1,035 required full text review (Figure 2). Of these 1,035 full-text articles reviewed, we retained 32 papers (comprising 32 unique studies) and excluded 1,003 papers. Reasons for article exclusion are listed in Appendix F.

Figure 2 Disposition of studies identified for this review

KQ = Key Question; n = number

^a^ One paper47 reports two unique studies.

^b^ Numbers do not tally as studies could be excluded for multiple reasons.

This figure outlines the flow of articles identified for the review. We located a total of 4,855 citations. Of these, 1,035 required full-text review. Of the 1,035 full text articles reviewed, we retained 32 papers (comprising 32 unique studies) and excluded 1,003 papers. Papers could be excluded for multiple reasons, and a number were excluded because they were not relevant to the Key Questions (n=840), did not include individuals with ASD in our target age range of 13 to 30 years (n=834), did not include at least 20 adolescents or young adults with ASD or their family members (n=845), or were not original research (n=156).

## Organization of Results

As noted, we classified studies by broad category of intervention (behavioral, educational, vocational, adaptive/life skills, medical, and allied health). With the exceptions of studies of behavioral, medical, and vocational interventions, which included at least two studies addressing the same intervention, the other categories of interventions comprise single studies of unique interventions. Most studies (n=14) also targeted core symptoms of ASD (Key Question 1) or functional behavior/independent living skills (n=10) (Key Question 3). Nine studies, eight of which addressed medical interventions, examined comorbidities commonly occurring with ASD, which we defined broadly to encompass associated symptoms such as irritability (Key Question 2). Only studies of medical interventions addressed harms (Key Question 5).

One study addressed interventions targeting the transition process (Key Question 4), and two assessed effects of an intervention on family outcomes (Key Question 6). Because questions were addressed by a number of small, single studies of any given intervention, we discuss all studies together in the following sections instead of divided by Key Question. This approach allows us to present the findings of this disparate literature more clearly. We use headings to indicate the outcomes (e.g., core symptoms, functional behavior, harms, etc.) targeted in each study. It is nonetheless important to note that the studies in these categories typically assessed different interventions, and therefore could not be combined for an assessment of strength of evidence beyond insufficient for any specific intervention at this time.

We present findings beginning with an overview of the content of the literature as a whole, including the range of study designs used, approaches assessed and participants included. The detailed analysis of the literature provides further discussion and analysis of studies presented by broad category of intervention. Studies also are described in more detailed summary tables in the relevant section of text. For information on studies not included in the summary tables, please see the evidence tables in Appendix D; for information on quality scores for each study, see Appendix G.

## Overview of the Literature

The 32 unique studies described in this review included 10 randomized controlled trials (RCTs). Table 4 provides an overview of the characteristics of the literature overall.

Table 4 Overview of the literature addressing interventions for adolescents and young adults with ASD

Characteristic | RCTs | Nonrandomized Trials | Prospective Cohort Studies | Prospective Case Series | Retrospective Case Series | Cross-sectional Studies | Total Literature
Total n: | 10 | 3 | 5 | 9 | 4 | 1 | 32
Intervention Category
Behavioral | 2 | 1 | 2 | 3 | 0 | 0 | 8
Educational | 1 | 1 | 0 | 0 | 0 | 0 | 2
Adaptive/Life Skills | 1 | 0 | 1 | 1 | 1 | 0 | 4
Vocational | 0 | 2 | 1 | 0 | 1 | 1 | 5
Medical | 5 | 0 | 0 | 2 | 1 | 0 | 8
Allied Health | 1 | 0 | 0 | 3 | 1 | 0 | 5
Treatment Duration
<1 month | 3 | 0 | 0 | 2 | 0 | 0 | 5
>1 to ≤3 months | 5 | 1 | 2 | 4 | 0 | 0 | 12
>3 to ≤6 months | 0 | 1 | 0 | 0 | 1 | 0 | 2
>6 to ≤12 months | 2 | 0 | 1 | 2 | 0 | 0 | 5
>12 months | 0 | 1 | 2 | 1 | 2 | 0 | 6
Not specified | 0 | 0 | 0 | 0 | 1 | 1 | 2
Study Population
United States | 5 | 1 | 2 | 5 | 3 | 1 | 17
Europe | 3 | 2 | 3 | 2 | 1 | 0 | 11
Asia | 2 | 0 | 0 | 2 | 0 | 0 | 4
Total N participants with ASD | 341 | 114 | 200 | 296 | 233 | 1707^a^ | 2891

ASD = autism spectrum disorders; n = number; RCT = randomized controlled trial

a 1,707 individuals with ASD included in one study reporting data from an administrative database48

We did not rate any study as good quality. Five studies were fair quality,49–53 and most studies were poor quality.17, 47, 48, 54–77 Eighteen studies included comparison groups, and ten of these studies were randomized. Most studies were conducted in the United States or Europe, and participant ages across all studies ranged from 2 years to over 45 years. Only studies of medical interventions reported harms data.

## Studies of Behavioral Interventions

### Key Points

- Eight behavioral studies examined different social skills and intensive behavioral interventions and included individuals with ASD both with and without concomitant intellectual disability or language deficiencies. All studies were of poor quality.
- Most studies reported short-term gains in social skills as reported by parents or within study measures, but the diversity of the interventions precludes drawing a conclusion about effectiveness across the studies for behavioral interventions as a whole.
- Few studies reported evidence of generalization of skills beyond the treatment context.

### Overview of the Literature

We identified eight studies47, 61–64, 76, 77 of behavioral interventions in seven unique populations (Table 5). Studies included two RCTs conducted in the United States61 and United Kingdom,63 one nonrandomized controlled trial conducted in the United States,76 and three case series conducted in Canada,62 the Netherlands,77 and Italy.64 One paper presented data from two separate studies conducted in the United Kingdom and involving two unique groups of participants.47 Individuals in both studies received the same computer-based social skills software intervention, but comparators differed, and participants were randomized to intervention or control groups in only one study.47 Five studies examined either individual or group61, 62, 76 or computer-based intervention approaches47, 63 focused on social skill development, including recognizing emotions, for individuals with ASD. One study conducted in Italy examined the impact of intensive behavioral treatment from a semi-residential rehabilitation center on adaptive behavior64 while another examined social and adaptive outcomes from an individualized treatment program in the Netherlands.77

Table 5 Key outcomes of behavioral studies addressing the core symptoms of ASD

Author, Year, Country Groups, N Enrollment/N Final Study Quality | Age, Mean/Yrs ± SD IQ, Mean ± SD | Key Outcomes
Individual/Group-Based Social Skills Training
Lagueson et al.,76 2011 United States G1: Immediate socials skills training, 14/12 (28 week followup) G2: Delayed treatment control, 14/14 (14 week followup) Quality: Poor | G1: 15.0 ± 1.0 G2: 14.3 ± 1.4 IQ (KBIT2) G1: 94.1 ± 20.2 G2: 104.5 ± 18.8 | - 14-week manualized intervention: Program for the Education and Enrichment of Relational Skills with followup 14 weeks postintervention for treatment group participants.; - Adolescents with high-functioning ASD (diagnoses not confirmed within study), ranging in age from 12 to 17 (mean = 14.6).; - Treatment group showed improvements on parent-reported measures of social skills and interactions compared with control group; limited teacher reports showed no significant differences between groups.; - At 14-week followup, most gains maintained for treatment participants; overall social skills continued to improve based on parent-rated measures. Some teacher-rated domains improved also.; - Quality considerations: nonrandom assignment to groups; systematic diagnostic approach not reported within study; attrition and treatment fidelity not reported; differences in concomitant interventions not reported; outcomes not coded by masked assessors.
Laugeson et al.,61 2009 United States G1: Immediate social skills training, 35 (total)/17 G2: Wait list, 35 (total)/16 Quality: Poor | G1: 14.6 ± 1.3 G2: 14.6 ±1.6 IQ (KBIT2): G1: 96 ± 16.1 G2: 88.3 ± 21.1 | - 12-week manualized intervention: Program for the Education and Enrichment of Relational Skills.; - School-aged children of average intelligence. demonstrated short-term improvements in social skills knowledge, parent rated skills, and reported engagement in social activity.; - Teacher-rated outcomes were not different for delayed treatment control.; - Quality considerations: randomization method not clearly described; systematic diagnostic approach not reported within study; outcomes not coded by masked assessors.
Verhoeven et al.,77 2011 Netherlands G1: Social skills intervention, 28/28 Quality: Poor | G1: 17.68 ± 3.14 IQ (WAIS/WISC): G1: 102.82 ± 13.33 (verbal) 98.36 ± 12.02 (performance) | - 12-month intervention associated with psychiatric hospitals, focusing on fostering development, improving behavioral functioning, well-being, and reducing ASD symptoms and understanding role of self-awareness in influencing treatment.; - Social and behavioral functioning improved in teacher -and parent-reported measures.; - Participants reported decrease in ASD symptoms, but no change in problems of daily behavioral functioning.; - Positive correlation between initial self-awareness and improved social functioning; improved self-awareness associated with parent-reported decrease in problems in daily functioning but self-reported increase in problems.; - Quality considerations: no comparison group; intervention not fully described; measure of treatment fidelity not reported; outcomes not coded by masked assessors.
Tse et al.,62 2007 Canada G1: Social skills training with emphasis on learning through role play, 46/32 Quality: Poor | G1: 14.6 ±1.7 NR | - 12-week intervention for adolescents with substantial verbal ability.; - Improvement in parent rated skill outcomes.; - Nonmanualized intervention, only parent report outcomes noted.; - Quality considerations: no comparison group; systematic diagnostic approach not reported within study; participants not clearly characterized (no cognitive or developmental measures); measure of treatment fidelity not reported; differences in concomitant interventions not reported; outcomes not coded by masked assessors.
Computer-based social skills training
Golan et al.,47 2006 United Kingdom Study 1 G1: Home software users, 19/NR (21% drop out rate) G2: Control, 22/NR Quality: Poor | G1: 30.5 ± 10.3 G2: 30.9 ± 11.2 IQ (WASI, verbal): G1: 108.3 ± 13.3 G2: 109.7 ± 10.0 | - Individuals participating in home-based program demonstrated improvement related to emotion recognition of faces and voices within the study relative to controls.; - Individuals did not perform differently on measures assessing generalization of emotion recognition.; - Quality considerations: randomization method not clearly described; systematic diagnostic approach not reported within study; measure of treatment fidelity not reported.
Golan et al.,47 2006 United Kingdom Study 2 G1: Software and tutor, 18/13 G2: Social skills course, 18/13 Quality: Poor | G1: 25.5 ± 9.3 G2: 24.4 ± 6.4 IQ (WASI, verbal): G1: 105.7 ± 16.1 G2: 96.5 ± 15.5 | - Individuals participating in home-based program plus group intervention demonstrated improvement related to emotion recognition of faces and voices within the study relative to controls.; - Individuals did not perform differently on measures assessing generalization of emotion recognition.; - Verbal IQ was significantly associated with improvement.; - Quality considerations: nonrandom assignment to groups; systematic diagnostic approach not reported within study; inclusion/exclusion criteria not clearly stated; measure of treatment fidelity not reported; differences in concomitant interventions not reported.
Silver et al.,63 2001 United Kingdom G1: Computer sessions + standard lessons, 12/10 G2: Standard lessons only, 12/11 Quality: Poor | G1: 13.9 ± 0.9 G2: 14.75 ± 2.0 IQ (BPVS): G1: 10.67 ± 2.25 G2: 12.0 ± 3.33 | - School-aged children and adolescents with substantial verbal abilities demonstrated improvement in emotion recognition after 10 half hour sessions over 2 weeks.; - No measures of generalization or outcomes apart from the study session were included.; - Quality considerations: randomization method not clearly described; systematic diagnostic approach not reported within study; differences in concomitant interventions not reported; outcomes data not collected from appropriate sources (self-report only).
Intensive Behavioral Treatment
Valenti et al.,64 2010 Italy G1: ABA-based intensive behavioral therapy, 34/34 Quality: Poor | G1: NR, 34 identified as postpubertal adolescents 25/34 identified as having intellectual disability | - Study of treatment received within context of semi-residential facility indexed gains related to adaptive behavior.; - No control group was included, the participants were very diverse, and the specific intervention components were not well described.; - Parent satisfaction with the treatment program was high on all measures.; - Quality considerations: no comparison group; measure of treatment fidelity not reported; differences in concomitant interventions not reported; outcomes not coded by masked assessors

BPVS = British Picture Vocabulary Scale; G = group; IQ = intelligence quotient; KBIT2 = Kaufman Brief Intelligence Test-Second Edition; n = number; NR = not reported; SD = standard deviation; WASI = Wechsler Abbreviated Scale of Intelligence

Participants ranged in age from 13 to 43 in the studies. One study64 did not provide precise age data but notes that 34 participants were categorized as adolescents. Treatment duration ranged from 2 weeks to 2 years. We rated all studies as poor quality. Appendix G provides the quality ratings for each study.

### Detailed Analysis

#### Behavioral Studies Addressing Core Symptoms of ASD

##### Individual or Group Social Skills Interventions

Most studies of behavioral interventions addressing effects on the core symptoms of ASD were short term and included a small number of individuals (Table 5). Among studies examining group-based social skills programs, one RCT examined the short-term outcome of a trial of a manualized (i.e., has a published treatment manual) outpatient social skills program, the Program for the Education and Enrichment of Relational Skills (PEERS).61 The study included 33 adolescents (mean age 14.6 years) with average cognitive abilities (mean intelligence quotient [IQ] = 96.0 in treatment group and 88.3 in control group) randomized either to a 12-week program of group social skills intervention or to a delayed treatment control group. A later 14-week, nonrandomized trial of the PEERS program involved a separate group of 28 adolescents (mean age 14.6) diagnosed with high-functioning autism.76 In both studies, participants in the treatment groups improved on parent-rated measured of social skills compared with control group participants, but limited teacher-rated measures indicated no differences between groups. The latter study assessed 12 of 14 treated participants 14 weeks after the end of intervention;76 gains were maintained on most measures.

One prospective case series examined improvements in 28 hospitalized high-functioning adolescents (mean verbal IQ = 102.98 ± 13.33, mean age = 17.68 ± 3.14) receiving individualized treatment plans focused on psychoeducation.77 At followup after 12 months of treatment, social and daily behavioral functioning improved on parent- and tutor-reported measures as did ASD symptoms on self-reported measures. Participants did not report a change in problems related to daily behavioral functioning. Another prospective case series examined the impact of a 12-week social skills group for adolescents (mean age 14.6 years) with ASD. Adolescents recruited from community clinics with verbal skills sufficient to participate in a group intervention demonstrated parent-reported improvements related to problem behaviors and autism specific social concerns.62

##### Computer-Based Social Skills Interventions

Among studies examining computer-based approaches, one RCT of a computer-based social skills training for adolescents with ASD randomized 22 children (age 12 to 18) to either training through 10 half-hour sessions with a computer program designed to train emotion recognition or to a control group.63 The intervention group demonstrated fewer errors in recognizing the emotion depicted within the program from pre- to post-training, and relative to controls demonstrated improvement regarding emotion recognition via tasks presented within cartoons and stories.

An additional publication reported on two separate studies, one nonrandomized trial and one cohort study, with unique groups of participants. Both studies assessed emotion recognition abilities following completion of the Mind Reading computer-based training program.47 In both studies, adults with ASD completing the program demonstrated improvements in recognizing faces and voices utilized in the training relative to the control group but did not demonstrate such improvements in recognizing improvements outside of the tasks.

##### Intensive Behavioral Interventions

The one study examining an intensive behavioral approach reported on the impact of intensive behavioral treatment from a semi-residential rehabilitation center on adaptive behavior.64 The study included 34 adolescents (age range not provided) receiving intervention from autism specific centers in Italy. Participants were reported to have improved on measures of socialization and adaptive behavior.

#### Behavioral Studies Addressing Comorbidities and Associated Symptoms

##### Individual/Group Social Skills Interventions

One prospective case series examined social outcomes and daily behavioral functioning in 28 high-functioning adolescents (mean verbal IQ = 102.98 ± 13.33, mean age = 17.68 ± 3.14) undergoing individualized treatment at specialized psychiatric hospitals.77 Greater self-awareness was correlated with increased social functioning; however, improvements in self-awareness after treatment were correlated with increases in reports of problems in daily behavioral functioning and psychological problems by self-report.

#### Behavioral Studies Addressing Independent Functioning

##### Intensive Behavioral Interventions

In the poor quality case series assessing the impact of intensive behavioral treatment,64 participants demonstrated modest improvements in standard measures of adaptive behavior over a 2-year period. Female participants also had improved daily living and motor skills in this uncontrolled study.

#### Behavioral Studies Addressing Family Outcomes

##### Intensive Behavioral Interventions

The same poor quality case series64 of intensive behavioral intervention reported family satisfaction. The study included both adolescents and younger children and presented satisfaction data for the two groups combined. Overall, parents were highly satisfied with most elements of the program at year 1 and year 2, with median scores in the 4.5 to 10 range on scales ranging from 1 to 6 or 1 to 10. The overall median score for the domain of “family participation” increased slightly (8.0 to 8.5) as did scores on individual domain elements (“feeling of a having a say in the matter,” 5.0 to 5.5; “involvement in school meetings,” 5.0 to 5.5). Scores in the domain of “intervention outcome” remained stable for elements including “service to help participant in facing daily problems” (5.0), “feeling confident about what to do” (5.0), and “service to help participants’ quality of life” (5.0) but declined slightly on “service to help family in coping with problems” (5.0 to 4.5).

## Studies of Educational Interventions

### Key Points

- Two poor quality studies evaluated educational approaches; the strength of the evidence for effects of educational approaches is insufficient based on few poor quality studies addressing disparate interventions.
- Strategies to increase reading comprehension were reportedly associated with some improvement in one small, poor quality study.
- Neither of two vocabulary teaching methods was more effective in increasing nouns learned by individuals with ASD and intellectual disability.

### Overview of the Literature

Two studies, both of poor quality, examined educational interventions. One nonrandomized controlled trial66 in the United States included 23 individuals ranging in age from 17 to 37 years (mean = 26) with mean mental age scores of 3.3 years and mean language scores of 3.0 years. Participants received language instruction using 2 methods of teaching over the course of 8 weeks, and investigators assessed outcomes including the number of nouns learned and retained. One RCT65 was conducted in Canada and investigated procedural strategies to promote reading comprehension and included 20 individuals with ASD (mean age = 15.1, mean Stanford-Binet IQ = 88.15 ± 16.06). Appendix G provides the quality ratings for each study.

### Detailed Analysis

#### Educational Studies Addressing Core Symptoms of ASD

One poor quality nonrandomized trial included 23 adults with ASD and intellectual disability living in a residential treatment facility (Table 6).66 Participants ranged in age from 17 to 37 (mean = 26) and had mean mental age scores of 3.3 years and mean language scores of 3.0 years. Investigators matched participants on chronological age, mental age and vocabulary scores, and duration of stays in residential treatment and assigned groups to either analog language teaching for three 15 minute individual sessions/week over 4 weeks or natural language teaching for three 45-minute group sessions/week over 4 weeks. After an assessment, participants crossed over to the alternate training condition.

Table 6 Key outcomes of educational interventions addressing core symptoms of ASD

Author, Year, Country Groups, N Enrollment/N Final Study Quality | Age, Yrs, Mean ± SD IQ, Mean ± SD | Key Outcomes
Elliott et al.,66 1991 United States G1: 23/23 Quality: poor | G1: 26 G1: NR | - Analog and natural language teaching styles had similar effects on increasing the number of nouns learned by participants.; - Quality considerations: nonrandom assignment to groups; inclusion/exclusion criteria not clearly stated; attrition not reported; differences in concomitant interventions not reported; outcomes not coded by masked assessors.

G = group; NR = not reported; SD = standard deviation

At the end of this second training phase, investigators assessed vocabulary retention. Neither teaching condition was significantly better at increasing vocabulary (mean number nouns learned in analog condition = 15.7, mean learned in natural language condition = 12.8); as expected, generalization was greater during receptive as compared with expressive testing of noun identification (p<0.001).66 Participants in both groups retained an average of 92.2 percent of items learned at the final assessment. Participants’ level of intelligence was related to the amount of generalization and to order of teaching. Participants in the upper range for mental age scores learned more nouns with analog teaching first (mean nouns learned = 64.8) than did those in the middle range (mean nouns learned = 10.3). Participants in the lowest mental age range performed more poorly than others regardless of teaching condition order.

#### Educational Studies Addressing Independent Functioning

A poor quality randomized study investigating the use of procedural strategies to promote reading comprehension included 20 individuals with high-functioning ASD (mean age = 15.1, mean Stanford-Binet IQ = 88.15 ± 16.06).65 Investigators presented participants with five stories written at a roughly sixth grade reading level in various procedural facilitation conditions or two control conditions. Procedural facilitation conditions included prereading, in which investigators asked participants questions designed to elicit common knowledge relevant to the main focus of the story; anaphoric cuing, in which a number of pronouns in each passage were underlined with choices for appropriate or inappropriate referent words appearing below them; and a cloze (fill in the blank) condition, in which blanks in sentences in each story could be completed by referring to information presented in the preceding sentences. Passages were not altered in the control condition. Investigators also asked participants questions about the stories’ main idea, facts from the stories, and for their own retelling of the stories to gauge their understanding of the content. Participants read and answered questions about all 5 stories, presented in random order for each participant, in approximately 60 minutes, scored independently by masked assessors on a 1 (low) to 25 (high) point scale. Reading comprehension scores ranged from 12.79 ± 6.33 in a control condition to 15.41 ± 6.28 in the anaphoric cuing condition.

Overall, the study reported a medium size effect for procedural facilitation (F(4,76) = 2.49, η^2^ = 0.12, p = 0.05). Post hoc analyses also revealed a significant effect of anaphoric cuing on passage comprehension with a medium effect size (F(1.19) = 5.60, η^2^ = 0.42, p = 0.03). No significant effects of prereading questions or cloze (fill in the blank) were apparent in the results. Correlation analyses showed that anaphoric cuing worked best for individuals with lower grammatical ability while prereading questions were most effective for students with high pre-existing comprehension ability (Table 7).65

Table 7 Key outcomes of educational interventions addressing independent functioning

Author, Year, Country Groups, N Enrollment/N Final Study Quality | Age, Yrs, Mean ± SD IQ, Mean ± SD | Key Outcomes
O’Connor et al.,65 2004 Canada G1: 20/20 Quality: Poor | G1: 15.11 ± 0.99 G1: 88.15 ± 16.06 | - Medium effect size for procedural facilitation and anaphoric cuing styles as compared with baseline (p = 0.05 and p = 0.03, respectively) among high functioning individuals with ASD.; - No significant effect of prereading questions or cloze style prompting.; - Quality considerations: randomization method not clearly described; differences in concomitant interventions not reported; outcomes not coded by masked assessors.

ASD = autism spectrum disorders; G = group; SD = standard deviation

## Studies of Adaptive/Life Skills Interventions

### Key Points

- Four poor quality studies reported on disparate adaptive/life skills-focused interventions; most assessed outcomes after short-term (<12 weeks) intervention, and at least two included individuals with intellectual disability and ASD.
- Each study examined a different intervention, precluding a conclusion across studies on the overall effectiveness of life skills interventions. Therefore, with four distinct, poor quality studies, our ability to generate an estimate of effect is insufficient
- Nonetheless, each study reported some improvements in very specific life skills (e.g., shoe lacing, digital device use) after specific short-term interventions.

### Overview of the Literature

We identified four studies, all of poor quality, of adaptive-focused interventions (Table 8).54–57 Each study examined a different intervention, so the studies could not be combined to assess effectiveness. Appendix G provides the quality ratings for each study. Treatment duration varied from a day-long experiment to roughly 2 years in a residential facility. All studies were conducted in the United States, and at least two included participants with intellectual disability.54, 55 One crossover RCT assessed the number of trials needed to learn to lace a color coded shoe versus a non-color coded shoe.55

Table 8 Summary of outcomes of adaptive/life-skills interventions

Author, Year, Country Groups, N Enrollment/N Final Study Quality | Age, Mean/Yrs ± SD IQ, Mean ± SD | Key Outcomes
Gentry et al.,57 2010 United States G1: PDA use, 22/22 Quality: Poor | G1: 16.5 (range 14–18) NR | - Self-rated scores on Canadian Occupational Performance Measure increased from baseline; - 22/22 participants used PDA daily and reported wanting to continue use; 16/22 could program device independently.; - Quality considerations: no comparison group; systematic diagnostic approach not reported within study; participants not clearly characterized (no cognitive or developmental measures); differences in concomitant interventions not reported; outcomes not coded by masked assessors.
Jewell et al.,56 2007 United States G1: Adolescents with rotating classroom schedule, 55/55 Quality: Poor | G1: 17.63 (14–22) NR | - Rotating classroom schedule (students change classroom throughout the day) had no significant effect on the number of crisis events (baseline mean = 2.44 ± 6.39, followup = 2.22 ± 5.88) or time in crisis (baseline mean minutes = 40.27 ± 102.08, followup = 28.96 ± 65.47).; - Quality considerations: no comparison group; no systematic diagnostic approach reported within study; participants not clearly characterized (no cognitive or developmental measures); attrition not reported; outcomes not coded by masked assessors.
Von Bourgondien et al.,54 2003 United States G1: TEACCH-based program, 6/6 G2: Family home, 10/10 G3: Group home, 10/10 G4: Institutions, 6/6 Quality: Poor | G1: 23.7 ± 4.4 G2: 26.6 ± 5.1 G3: 27.8 ± 8.5 G4: 21.5 ± 5.0 85% of all participants had moderate to severe intellectual disability | - Outcomes rated by research assistants.; - Desirability of living situation and use of programming rated more highly for TEACCH. than other conditions; group homes rated more desirable than institutions.; - Few significant changes in skills or negative behaviors reported in exploratory analyses; - Parental satisfaction higher for TEACCH than group homes (p≤0.05); no difference in parental satisfaction with institutions.; - Quality considerations: nonrandom assignment to groups; systematic diagnostic approach not reported within study; inclusion/exclusion criteria not clearly stated; attrition not reported; intervention not fully described; measure of treatment fidelity not reported; differences in concomitant interventions not reported; outcomes not coded by masked assessors.
Nelson et al.,55 1980 United States G1: Extra prompts/no extra prompts G2: No extra prompts/extra prompts G1+G2: 20/20 Quality: Poor | G1: 11.5 ± 3.0 G2: 13.1 ± 4.1 IQ (PEP developmental age) G1: 3.0 ± 0.7 G2: 3.1 v 0.9 | - G1 completed lacing successfully in mean 108.7 trials plus 81.6 trials with the non-color coded shoe.; - G2 completed lacing successfully in mean 137.2 trials plus 15.9 trials with the color coded shoe.; - Quality considerations: randomization method not clearly described; systematic diagnostic approach not reported within study; attrition not reported; measure of treatment fidelity not reported; differences in concomitant interventions not reported; outcomes not coded by masked assessors.

ASD = autism spectrum disorders; G = group; IQ = intelligence quotient; n = number; NR = not reported; PDA = personal digital assistant; PEP = PsychoEducational Profile; SD = standard deviation; TEACCH = Treatment and Education of Autistic and Communication related Handicapped Children

One cohort study assessed an implementation of the TEACCH psychoeducational model emphasizing farming and landscaping as vocational modalities and focused on teaching skills and ameliorating behavioral problems.54 Outcomes assessed included measures of participant skills and behaviors, level of environmental adaption and individualized programming, and family satisfaction with treatment.

One case series57 investigated the use of personal digital assistants (PDAs) as memory aids for high school students. Participants were all enrolled in a mainstream high school, had home computers, and could operate a PDA independently. Outcomes measured included self-reported performance of activities of daily living. A final case series addressed the transitioning process by assessing effects related to implementing a classroom process—changing classrooms throughout the school day—that individuals would be likely to encounter as they move to high school or college.56

### Detailed Analysis

#### Adaptive/Life Skills Studies Addressing Independent Functioning

A poor quality RCT55 demonstrated challenges related to utilizing highly salient, non-criterion-related prompts (i.e., color coded targets) in teaching a specific shoe lacing skill to a group of 20 young adolescents (mean age 12.3) with significant cognitive limitations (average developmental age of 3.05). Participants were randomized to attempt to lace a shoe with color coded laces and eyelets or a shoe with no color coding. Participants typically mastered the shoe lace task more quickly in the color-coded condition but were not able to complete lacing a non-color coded shoe as quickly, suggesting that participants may have concentrated more fully on the color-coded prompt than the mechanics of the task.

One poor quality cohort study compared the effects of an experimental treatment setting, a combined residential and vocational TEACCH-based training program model with three control conditions: group homes, institutions, or family homes.54 The farm-based TEACCH program emphasized farming and landscaping as vocational modalities and focused on teaching skills and ameliorating behavioral problems. All participants were applicants to the TEACCH residential program. Investigators used a part-random, part-clinical/administrative assignment procedure to assign participants, matched on cognitive ability, autism and challenging behavior severity, communication skills, and need for supervision, to the TEACCH treatment group (n = 6). The other participants were living in a control setting (group homes, n = 10; institutions, n = 6; family homes, n = 10). Participants were similar at baseline except in the case of individuals in family homes, who were less likely to have experienced residential placement before age 18. The mean age of all participants at baseline was 25 (range = 16 to 48 years). Eighty-five percent had severe to profound intellectual disability (Vineland Adaptive Behavior Composite mean = 25), and most had moderate to severe autism (mean CARS score = 36, range = 21 to 46). A majority of participants (53%) had experienced residential treatment prior to age 18.

Research assistants measured outcomes at baseline and 12 months after treatment/residence began for the TEACCH group. Outcomes assessed included measures of participant skills and behaviors, level of environmental adaption and individualized programming, and family satisfaction with treatment. The TEACCH program was rated as employing more communication adaptations, socialization programming, preventive behavior management approaches, and visual structure (all p<0.0004) than the other settings. TEACCH was also rated more highly in terms of desirability of the living situation and use of programming (p = 0.0001 for both). Researchers rated group homes as more desirable settings than institutions. Exploratory analyses of changes in skills and behaviors showed variable results with few significant changes in skills or negative behaviors over time across groups.54

One poor quality case series57 investigated the use of PDAs as memory aids for high school students with ASD. While investigators do not report measures of IQ or mental age, participants were all enrolled in a mainstream high school, had home computers, and could operate a PDA independently. All 22 participants (age range 14 to 18, mean = 16.5) reported increases in self-assessed performance of activities of daily living and satisfaction with the PDA after 8 weeks of use following a brief training session (p<0.001). The majority reported independent daily use, and examination of the PDAs showed a variable number of reminders entered. Outcome measures were administered by study investigators who had also provided training in PDA use and included one unvalidated tool.

#### Adaptive/Life Skills Studies Addressing the Transitioning Process

One poor quality case series56 investigated the effect of a rotating classroom schedule (i.e., students change classrooms throughout the day) on behavior warranting crisis intervention among 55 adolescent students at a school for individuals with ASD (mean age = 17.63, range 14 to 22). We considered this study as addressing transitional issues because it was intended to examine the effects of a process (classroom changes) that individuals with ASD are likely to encounter as they transition into high school or higher education settings.

The school used crisis management to handle violent, uncontrollable, self-abusive, or dangerous behaviors. Crisis interventions consisted of progressive behavior management techniques that could include restraint as a last resort. Investigators collected data on the number of crisis interventions and time spent in interventions for 6 months prior to and 6 months following the implementation of a rotating classroom schedule. Twenty-two of 55 adolescent participants had crisis events prior to or after the classroom change. The number of crisis events (mean prerotation = 2.44 ± 6.39, postrotation = 2.22 ± 5.88) and time in crisis were not significantly different across time periods (mean minutes prerotation = 40.27 ± 102.08, postrotation = 28.96 ± 65.47).

#### Adaptive/Life Skills Studies Addressing Family Outcomes

The cohort study54 investigating the TEACCH-based residential center54 also assessed family satisfaction with treatment. Parents were significantly more satisfied with the TEACCH program overall and with individuals’ level of community involvement compared with group homes (p≤0.05), but there was no difference in satisfaction with institutions and either the TEACCH program or group homes. Parents of individuals in the TEACCH residence were also more satisfied with the impact of the placement on the family than parents of individuals in other groups.54

## Studies of Vocational Interventions

### Key Points

- Five poor quality studies assessed vocational interventions for adolescents and young adults with ASD.
- Individual studies of different on-the job supports (broadly defined as services to promote job placement and job retention) reported increased rates of employment in the community relative to those without on-the-job supports. Because the individual studies have not been replicated and are of poor quality, the strength of evidence (confidence that future research will not change our understanding of the effect) for the effect seen is insufficient, as more research is needed to quantify the degree to which these interventions are effective, and under what circumstances.
- Despite positive results associated with other outcomes (quality of life, autism symptoms, cognitive development) reported in individual studies, the poor quality of the studies, assessment of unique outcomes in each study, and lack of replication lead to insufficient strength of evidence until further studies are conducted that may confirm the observed effects.

### Overview of the Literature

We identified six papers reporting on five unique study populations and addressing the impact of supported employment/vocational interventions on outcomes for adolescents and young adults with ASD (Table 9). One study was a nonrandomized controlled trial conducted in Spain and Germany.74, 75 Two prospective cohort studies were conducted in Spain72 and the United Kingdom,73 and one case series was conducted in the United Kingdom17 and one cross-sectional study was conducted in the United States.48 All studies were considered poor quality. Appendix G provides the quality ratings for each study.

Table 9 Key outcomes of vocational studies addressing core symptoms

Author, Year, Country Groups, N Enrollment/N Final Study Quality | Age, Yrs, Mean ± SD IQ, Mean ± SD | Key Outcomes
Garcia-Villamisar et al.,72 2007 Spain G1: Supported employment G2: Wait list Overall N: 44/44 Quality: Poor | G1: 25.52 ± 3.35 G2: 24.32 ± 4.34 IQ (Raven): G1: 41.14 ± 4.45 G2: 42.23 ± 5.43 | - Adults with ASD participating in a community work program vs. a waitlisted group who participated in non-competitive (i.e., sheltered) vocational activities.; - Followup assessment was approximately 30 months after the start of the intervention.; - Relative to the waitlisted group, the supported employment group experienced improvements over time in 8 of the 12 measures of cognitive functioning.; - Quality considerations: nonrandom assignment to groups; attrition not reported; intervention not fully described; measure of treatment fidelity not reported; differences in concomitant interventions not reported; outcomes not coded by masked assessors.
Garcia-Villamisar et al.,74, 75 2000 Spain, Germany G1: Sheltered work, 26/26 G2: Supported work, 25/21 Quality: Poor | G1: 21.07 ± 4.18 G2: 21.64 ± 3.75 IQ (Leiter): G1: 55.52 ± 14.43 G2: 57.41 ± 15.01 | - Adults with ASD participating in a community work program had lower autism symptoms and higher quality of life scores relative to those who were in a sheltered workshop.; - Followup assessment was approximately 30 months after the start of the intervention.; - Quality considerations: nonrandom assignment to groups; inclusion/exclusion criteria not clearly stated; intervention not fully described; measure of treatment fidelity not reported; differences in concomitant interventions not reported; outcomes not coded by masked assessors.

ASD = autism spectrum disorders; G = group; IQ = intelligence quotient; N = number; SD = standard deviation

Interventions addressed in the studies all involved finding and implementing on-the-job supports for young adults with ASD. Three of the studies focused on government-funded supports,17, 48, 73 and two studies conducted in Spain and/or Germany focused on privately-funded supports.72, 74, 75 Three studies included a comparison or control group that did not receive the employment/vocational intervention,72–75 and two studies examined the impact of the intervention on employment outcomes without a comparison group.17, 48

### Detailed Analysis

#### Vocational Studies Addressing Core Symptoms

A poor quality nonrandomized trial reported in two papers74, 75 examined the impact of supported employment (community-based jobs with no more than two individuals with ASD in the workplace) versus sheltered workshops (defined as “piece work being performed in segregated programs with only disabled coworkers”) on autism symptoms75 and quality of life74 of young adults with ASD (Table 9). Participants were 55 young adults who had received a clinical diagnosis of autism. The study did not report participant recruitment procedures clearly. Investigators assigned 26 participants to a sheltered workshop group and 21 to a supported work group. It is unclear why the sum of number of participants in each group does not match the total sample size.

The average age of participants was 21 years (mean = 21.07 ± 4.18, sheltered workshop group; mean = 21.64 ± 3.75, supported employment group), and their average IQ scores were in the mid-50s (mean = 55.52 ± 14.43, sheltered workshop group; mean = 57.41 ± 15.01, supported employment group). There appeared to be more males in the supported employment group (84%) than in the sheltered workshop group (69.2%), although the study did not assess group differences in gender. Although individuals were matched by gender, autism symptom scores (using the CARS), and IQ, participants were only eligible for the supported employment group if they had an absence of severe behavior problems and acceptable professional and vocational abilities. All of the jobs for those in the supported group were in the community with no more than two individuals with ASD in the same work place. Youth in the supported group worked between 15 to 30 hours a week, were paid competitive wages, and each had a job coach.

The average length of community employment at followup was 30 months. Differences between the supported and sheltered workshop groups in autism symptoms or quality of life were not significant before intervention. However, at followup, young adults who had participated in the supported work program had reduced autism symptom and higher quality of life scores relative to those who were in a sheltered workshop. Further, the autism symptom differences were due to deterioration in the sheltered group over time, whereas the supported group had no difference in autism symptoms scores from before to after intervention. In contrast, the sheltered workshop group had no difference in quality of life over time, whereas the supported group had quality of life scores that improved from before to after intervention. In sum, this study reports that for young adults with autism, supported work in the community may ameliorate increases in autism symptoms and improve quality of life relative to sheltered workshop work.74, 75

A related poor quality prospective cohort study from the same research group72 examined the impact of supported employment in the community (supported work group) versus vocational activities in a sheltered setting (no supported work group) on the cognitive development of young adults with autism (Table 9). Participants included 44 young adults (32 men, 12 women) who were diagnosed according to Diagnostic and Statistical Manual of Mental Disorders, FourthEdition (DSM-IV) criteria and who had CARS scores greater than 30. Participants were randomly selected from the Spanish Program of Employment for Autistic People. The mean age of participants was 25.52 years (SD = 3.35) for the supported work group and 24.32 (SD = 4.34) years for the no supported work group. The average years of schooling was 5.31 (range = 3 to 7 years). The study did not present standardized IQ scores for the participants, but all participants were required to score at about the 35^th^ percentile on the Standard Progressive Matrices, a non-verbal IQ test. Similar to earlier studies,74, 75 participants were eligible for the supported work group if they had an absence of severe behavior problems and acceptable professional and vocational abilities. All of the jobs for those in the supported work group were in the community, with no more than two individuals with autism in the same work place. Youth in the supported work group averaged 20 hours of work a week, were paid competitive wages, and each had a job coach. The average length of community employment at followup was 30 months.

The “no supported work” group was on a waiting list for supported work and participated in non-competitive vocational activities during the study period. It is unclear how many participants were in each group. At the start of the study, there were no significant differences between the supported work and no supported work groups in vocabulary (British Picture Vocabulary Scale), IQ (Raven’s matrices), or autism symptoms (CARS). There were also no differences between groups at this time on any of the 12 cognitive performance tasks which measured constructs such as psychomotor speed, spatial recognition memory, and executive functioning (many of the tasks were from the Cambridge Neuropsychological Tests: Automatic Battery). Results suggested that, relative to the control group, the supported employment program was associated with improvements over time in 8 of the 12 measures of cognitive functioning.72

#### Vocational Studies Addressing Independent Functioning

We identified two cohort studies17, 73 and one cross-sectional study48 examining the impact of employment/vocational interventions on outcomes for adolescents and young adults with ASD (Table 10). We rated all studies as poor quality.

Table 10 Key outcomes of vocational studies addressing independent functioning

Author, Year, Country Groups, N Enrollment/N Final Study Quality | Age, Yrs, Mean ± SD IQ, Mean ± SD | Key Outcomes
Lawer et al.,48 2009 United States G1: Vocational rehabilitation service users, 1,707/1,707 United States Quality: Poor | Age, range (%): 18–25 (73.4) 25–34 (15.5) 35–44 (8.1) 45–54 (2.5) 55–65 (0.5) IQ: NR | - Presence of on-the job supports was associated with a higher likelihood of employment in the community (competitive or supported) for adults with ASD.; - On-the job supports were as effective in promoting employment for adults with ASD as for adults with other developmental disabilities.; - Quality considerations: no comparison group; systematic diagnostic approach note reported within study; participants not clearly characterized (no cognitive or developmental measures); intervention not fully described; measure of treatment fidelity not reported; differences in concomitant interventions not reported; outcomes not coded by masked assessors.
Howlin et al.,17 2005 United Kingdom G1a: Pilot supported employment program participants (1995–1996), 30/30 G1b: Supported employment program participants (2003–2005), 117/89 Quality: Poor | G1a: 31.1 ± 9.1 G1b: 31.4 ± 9.3 IQ (Raven nonverbal): G1a: 110.2 ± 17.6 G1b:110.7 v 19.5 | - For adults in the 8-year followup (1995–1996 sample), 13 of 19 (68%) who had been previously employed remained employed.; - For adults in the additional sample (2003–2005), employment ranged from 70.5% to 54.3%, depending on regional site.; - Quality considerations: no comparison group; attrition not reported; differences in concomitant interventions not reported; outcomes not coded by masked assessors.
Mawhood et al.,73 1999 United Kingdom G1: Supported employment program, 30/30 G2: Control, 20/20 Quality: Poor | G1: 31.1 ± 9.1 G2: 28.0 ± 6.1 IQ (WAIS full scale): G1: 98.8 ± 16.3 G2: 97.7 ± 20.4 | - 2-year supported employment scheme for high-functioning adults with autism or Asperger syndrome.; - Adults in the supported work group were more likely to find paid employment (63% vs. 25%) and had higher wages per hour on average than a control group.; - No differences between groups in number of hours worked per week for those who worked.; - Quality considerations: nonrandom assignment to groups; systematic diagnostic approach not reported within study; differences in concomitant interventions not reported; outcomes not coded by masked assessors.

ASD = autism spectrum disorders; G = group; IQ = intelligence quotient; SD = standard deviation; WAIS = Wechsler Adult Intelligence Scale

In one cohort study conducted in the United Kingdom, the authors examined the outcome of a 2-year supported employment scheme for high-functioning adults with autism or Asperger syndrome.73 Participants in the supported employment scheme included 27 males and 3 females. All participants had a formal diagnosis of autism or Asperger syndrome, a performance or verbal IQ score above 70 (as measured by the Wechsler Adult Intelligence Scale), were actively seeking work and able to travel independently, were capable of eventually maintaining employment with minimal support, and had no psychiatric or physical problems that would adversely affect employment. An additional 20 individuals (all male) who met the study criteria were contacted and enrolled into a no-treatment comparison group. There were no significant differences between the supported employment and comparison groups in age (mean = 31.1 years for the supported employment group and 28.0 years for the comparison group), IQ, or vocabulary (British Picture Vocabulary Test) at the start of the study.

The supported employment scheme included job finding and work preparation, educating potential and existing employers and colleagues about ASD, and on-the-job supports. On-the-job supports included assistance from a support worker with dealing with the social and occupational requirements of a job and education about ASD for employers and work colleagues. The frequency of supports decreased over the study period. Although the total study period covered two years, and average amount of time that individuals were registered with the scheme was 17.03 months (range from 5 to 24 months). Over the 2-year evaluation period, young adults in the supported employment group were significantly more likely to find paid employment than those in the comparison group (63.3%vs. 25%), and they spent a greater amount of the study time employed (27.09% of time employed for the supported employment group and 12.35% of time employed for the comparison group). For those who were employed, the number of hours worked per week did not differ between the supported work versus comparison group, however the supported work group had higher wages per hour on average. There were no significant differences between those who were and were not able to find work in IQ, vocabulary, social understanding, or age. The investigators noted that the most important aspect of their supported work program–and also the most expensive–was the “job finding” aspect, which included many hours of making presentations to, meeting with, and negotiating with potential employers. The authors also noted that funds are rarely available to subsidize the “job finding” component.

This same research group conducted a longer-term followup of their supported employment scheme, now titled “Prospects.”17 This prospective cohort study examined whether the gains in employment made during the first two years of the project73 persisted for up to 8 years and with a larger cohort (recruited from three regional sites in the United Kingdom). In addition to the 30 young adults with ASD reported on in the earlier study,73 an additional 117 young adults who began receiving services between 2002 and 2003 were added to the cohort. The mean age of individuals added to the cohort was 31.4 years (standard deviation [SD] = 9.3). All had a clinical diagnosis of autism or Asperger syndrome made by a psychiatrist or psychologist, and this diagnosis was confirmed by using the Autism Diagnostic Interview in 20 percent of cases.

Thirteen of the 19 young adults in the original sample who found employment remained employed 7 to 8 years later. For the young adults who were added since the original cohort, the rate of employment remained high, ranging from 70.5 percent to 54.3 percent (depending on regional site). The majority of employed young adults with ASD (84.7%) were generally happy with their job.

A final cross-sectional study examined the impact of vocational/employment interventions conducted in the United States.48 This study examined the effectiveness of vocational rehabilitative services for adults with ASD compared with adults with other developmental disabilities. The investigators identified 1,707 adults with ASD from national data obtained from the U.S. Department of Education’s Office of Special Education and Rehabilitative Services. Participants with ASD were identified using primary impairment causes for the disability in the vocational rehabilitation dataset. Approximately 73 percent of the sample of adults with ASD was 18 to 25 years of age; 15.5 percent was 25 to 34 years; and 11.1 percent was 35 years of age or older. Eighty-four percent of adults were white, 12.8 percent were black, and 4.2 percent were of Hispanic ethnicity. As this was an administrative database, data were not available about autism symptoms or cognitive abilities. The study reported that the presence of on-the-job supports (which could include counseling, on-the-job training, job search assistance, assessment and diagnosis, and assistive technology) was associated with a higher likelihood of employment in the community (competitive or supported), and that on-the-job supports were just as effective in promoting employment for adults with ASD as for adults with other developmental disabilities.

## Studies of Medical Interventions

### Key Points

- Eight studies of pharmacologic agents met our review criteria; four of these were RCTs of fair quality. One additional RCT and three case series were poor quality.
- The strength of evidence related to challenging or repetitive behaviors and harms for each of the agents assessed is insufficient based on no good studies and lack of replication.
- Little evidence supports the use of medical interventions in the adolescent and young adult population; most studies focused on the use of medications to address specific challenging behaviors.
- Studies of risperidone reported improvements in aggression, irritability/agitation, repetitive behavior, sensory motor behaviors, and overall behavioral symptoms in participants receiving risperidone.
- A placebo-controlled crossover study reported that haloperidol significantly improved hyperactivity/defiance ratings, but no significant difference was found for irritability/agitation or other symptoms.
- Studies of serotonin reuptake inhibitors (SRIs) had inconsistent results: an RCT of fluvoxamine reported decreases in repetitive behavior, aggression, autistic symptoms, and language usage and case series addressing sertraline, fluoxetine, and clomipramine reported some benefits, while a crossover study of clomipramine versus placebo reported no significant differences in autistic symptoms between groups.
- A crossover study of naltrexone reported no significant improvements in problem behavior and worsening of stereotyped behavior with naltrexone compared with placebo.
- Harms reported across all studies included sedation, weight gain, fatigue, self-injurious behavior, constipation, anxiety, and insomnia.

### Overview of the Literature

We identified a total of eight studies of medical interventions.50–53, 67–69, 71 All eight of these were studies of pharmacological agents. Overall, no studies were good quality, four were fair quality,50–53 and four were poor quality.67–69, 71 Appendix G provides the quality ratings for each study.

Three RCTs addressed the efficacy of antipsychotic medications (Table 11).50, 51, 67 Two were conducted in the United States, and one in Canada. All of these RCTs were conducted in academic clinic settings using institutional and grant funding, and one was fair quality51 and two poor.50, 67

Table 11 Key outcomes of studies assessing antipsychotics

Author, Year, Country Groups, N Enrollment/N Final Study Quality | Mean Age, Years ± SD | Mean IQ ± SD | Outcome Measure/Baseline Scores, Mean ± SD | Outcome Measure/Post-Treatment Scores, Mean ± SD Quality Considerations
Hellings et al.,67 2006 United States G1+G2: Placebo phase, then dose risperidone, followed by crossover to the other risperidone dose, then another placebo phase Placebo I phase: 3–5 weeks of placebo, n = 40 Acute Dose phase: G1 Low dose (n = 39) or G2 high dose risperidone (n = 36) Placebo II phase: 3–5 weeks of placebo, n = 33 Maintenance phase: Optimal dose risperidone, n = 32 Quality: Poor | G1+G2: 22 ± 13.1 | NR, 40/40 with intellectual disability | ABC-C Irritability: G1+G2, Placebo I phase: 19.16 ± 9.96 G1+G2, Placebo II phase: 18.23 ± 12.36 | ABC-C Irritability: G1, Low dose acute phase: 11.15 ± 9.28 G2, High dose acute phase: 13.31 ± 8.92 p = 0.13 G1 vs. G2 p = 0.0002 G1+G2 Acute phase vs. G1+G2 Placebo II Maintenance phase scores only reported graphically Quality considerations: inappropriate comparison group; treatment adherence not reported
Remington et al.,50 2001 Canada G1: Clomipramine G2: Haloperidol G3: Placebo Overall N: 37/36 Quality: Fair | Overall: 16.3 (SD NR) | NR | CARS Overall: 41.8 ± 7.1 | CARS: G1: 37.8 ± 8.7 G2: 36.7 ± 6.1 G3: 39.4 ± 7.0 p<0.05, G2 vs. baseline ABC reported only graphically Quality considerations: participants not clearly characterized (no cognitive or developmental measures); outcomes not coded by masked assessors
McDougle et al.,51 1998 United States G1: Risperidone, 15/12 G2: Placebo,16/12 G2a: Open label risperidone following placebo, n = 15 Quality: Fair | G1+G2: 28.1 ± 7.3 | G1+G2: 54.6 ± 23.9 | Y-BOCS, compulsion: G1: 16.5 ± 3.58 G2: 14.29 ± 3.50 G2a: 14.27 ± 2.92 SIB-Q: G1: 47.8 ± 19.5 G2: 37.7 ± 11.9 G2a: 32.43 ± 15.89 | Y-BOCS, compulsion: G1: 12.77 ± 3.63 G2: 14.35 ± 3.02 p<.001, G1 vs. G2 G2a: 11.47 ± 3.64 p<0.03, G2a vs. BL SIB-Q: G1: 24.2 ± 9.5 G2: 32.8 ± 15.0 p<0.001, G2 vs. G1 G2a: 23.07 ± 13.45 p<0.05, G2a vs. BL Quality considerations: treatment adherence not reported

ABC = Aberrant Behavior Checklist; ABC-I = Aberrant Behavior Checklist-Community Rating Scale-Irritability; ASD = autism spectrum disorders; CARS = Childhood Autism Rating Scale; G = group; IQ = intelligence quotient; n = number; NR = not reported; SD = standard deviation; SIB-Q = Self-Injurious Behavior Questionnaire; Y-BOCS=Yale-Brown Obsessive Compulsive Scale

One fair quality RCT was conducted in an academic clinic in the Netherlands and investigated an opiate antagonist (Table 12).53 Funding for the study came from institutional and grant sources. Five studies investigated SRIs (Table 13).50, 52, 68, 69, 71 Two studies were fair quality,50, 52 and the balance were poor.68, 69, 71 These studies included two RCTs;50, 52 one was conducted in the United States and one in Canada. Three poor quality case series were conducted in the United States.68, 69, 71 All five of these studies were conducted in academic clinic settings using institutional and grant funding.

Table 12 Key outcomes of studies assessing opioid receptor antagonists

Author, Year, Country Groups, N Enrollment/N Final Study Quality | Mean Age, Years ± SD | Mean IQ ± SD | Outcome Measure/Baseline Scores, Mean ± SD | Outcome Measure/Post-Treatment Scores, Mean ± SD Quality Considerations
Willemsen-Swinkles et al.,53 2005 Netherlands G1+G2: 4 week naltrexone phase for cohorts 1 (50mg daily) and 2 (150mg daily) (ASD patients only) G3+G4: 4 week placebo phase for cohorts 1 and 2 (ASD patients only) Overall N: 33/31 Quality: Fair | Overall: 29 ± 6.0 | NR | ABC Stereotypy G1+G2: 9.7 ± 4.7 G3+G4: 8.3 ± 5.2 | ABC Stereotypy G1+G2: 10.0 ± 4.7 G3+G4: 9.0 ± 4.8 p = 0.018, G1+G2 vs. G3+G4 Quality considerations: randomization method not clearly described; participants not clearly characterized (no cognitive or developmental measures); treatment adherence not reported; differences in concomitant interventions not reported

ABC = Aberrant Behavior Checklist; ASD = autism spectrum disorders; G = group; IQ = intelligence quotient; mg = milligrams; n = number; NR = not reported; SD = standard deviation

Table 13 Key outcomes of studies assessing SRIs

Author, Year, Country Groups, N Enrollment/N Final Study Quality | Mean Age, Years ± SD | Mean IQ ± SD | Outcome Measure/Baseline Scores, Mean ± SD | Outcome Measure/Post-Treatment Scores, Mean ± SD Quality Considerations
Remington et al.,50 2001 Canada G1: Clomipramine G2: Haloperidol G3: Placebo Overall N: 37/36 Quality: Fair | Overall: 16.3 (SD NR) | NR | CARS Overall: 41.8 ± 7.1 | CARS: G1: 37.8 ± 8.7 G2: 36.7 ± 6.1 G3: 39.4 ± 7.0 p<0.05, G2 vs. baseline ABC reported only graphically Quality considerations: participants not clearly characterized (no cognitive or developmental measures); treatment adherence not reported; outcomes not coded by masked assessors
McDougle et al.,68 1998 United States G1: Sertraline, n = 42/37 G1a: AD G1b: AS G1c: PDD NOS Quality: Poor | 26.1 ± 5.8 | 60.5 ± 22.7 (28 with intellectual disability) | Y-BOCS, total score: G1a: 16.5 ± 6.7 G1b: 25.7 ±4.1 G1c: 18.2 ± 4.8 Vineland maladaptive behavior: G1a: 27.0 ± 9.4 G1b: 19.8 ± 8.6 G1c: 28.3 ± 10.8 SIB-Q: G1a: 32.7 ± 16.5 G1b: 17.5 ± 7.7 G1c: 36.2 ± 16.4 | Y-BOCS, total score: G1a: 11.5 ± 5.8 G1b: 27.8 ± 5.3 G1c: 14.8 ± 5.7 p = 0.005, G1 vs. baseline Vineland maladaptive behavior: G1a: 13.8 ± 6.0 G1b: 20.2 ± 8.2 G1c: 19.5 ± 9.1 p = 0.0001, G1 vs. baseline SIB-Q: G1a: 15.5 ± 9.5 G1b: 18.8 ± 7.7 G1c: 20.2 ± 12.8 p = 0.0001, G1 vs. baseline Quality considerations: no comparison group; treatment adherence not reported; outcomes not coded by masked assessors; differences in concomitant interventions not reported
Brodkin et al.,69 1997 United States G1: Clomipramine, 35/33 G1a: Responders, n = 18 G1b: Nonresponders, n = 15 Quality: Poor | G1: 30.2 ± 7.0 | G1: 64.6 ± 27.2 | Y-BOCS, total score: G1a: 18.7 ± 6.8 G1b: 17.9 ± 6.2 Y-BOCS, compulsion subscale: G1a: 13.7 ± 3.3 G1b: 13.9 ± 2.5 Y-BOCS, obsession subscale: G1a: 10 ± 6.8 G1b: 6.7 ± 6.2 Brown Aggression Scale: G1a: 10.6 ± 7.4 G1b: 6.5 ± 4.1 | Y-BOCS, total score: G1a: 9.1 ± 3.0 G1b: 17.3 ± 7.8 p<0.001, G1 vs. baseline p<0.001, G1a vs. G1b Y-BOCS, compulsion subscale: G1a: 6.9 ± 2.1 G1b: 12.5 ± 3.3 p<0.001, G1 vs. baseline p< 0.001, G1a vs. G1b Y-BOCS, obsession subscale: G1a: 4.4 ± 2.8 G1b: 8 ± 6.6 p<0.001, G1 vs. baseline p<0.001, G1a vs. G1b Brown Aggression Scale: G1a: 3.7 ± 3.6 G1b: 6.4 ± 4.6 p<0.001, G1 vs. baseline p<0.001, G1a vs. G1b Quality considerations: no comparison group; treatment adherence not reported; outcomes not coded by masked assessors
McDougle et al.,52 1996 United States G1: Fluvoxamine, 15/15 G2: Placebo, 15/15 Quality: Fair | G1: 30.1 ± 7.1 G2: 30.1 ± 8.4 | G1: 82.5 ± 26.8 G2: 77.3 ± 33.1 | Y-BOCS, total score: G1: 21.4 ± 7.3 G2: 21.5 ± 6.8 | Y-BOCS, total score: G1: 13.7 ± 9.1 G2: 21.9 ± 6.7 p<.003, G1 vs. G2 Data for Vineland Maladaptive Behavior and Brown Aggression Scale were not reported, although statistically significant improvements were noted. Quality considerations: randomization method not clearly described; treatment adherence not reported
Cook et al.,71 1992 United States G1: Fluoxetine, 23/23 Quality: Poor | 15.9 ± 6.2 | NR, 19 with intellectual disability | CGI-S, total: 5.7 ± 0.8 CGI-S, compulsion: 5.5 ± 1.5 | CGI-S, total: 4.9 ± 1.1 p<0.002, G1 vs. baseline CGI-S, compulsion: 4.7 ±1.6 p<0.005, G1 vs. baseline Quality considerations: no comparison group; inclusion and exclusion criteria not clearly stated; treatment adherence not reported; outcomes not coded by masked assessors

ABC = Aberrant Behavior Checklist; ABC-I = Aberrant Behavior Checklist-Community Rating Scale-Irritability; CARS = Childhood Autism Rating Scale; CGI-S = Clinical Global Impression-Severity; G = group; n = number; NR = not reported; PDD-NOS = pervasive developmental disorder-not otherwise specified; SD = standard deviation; SIB-Q = Self-Injurious Behavior Questionnaire; SRIs = serotonin reuptake inhibitors; Y-BOCS = Yale-Brown Obsessive Compulsive Scale

### Detailed Analysis

#### Medical Studies Addressing Comorbidities and Associated Symptoms

We summarize results of studies of medical interventions meeting our criteria below. The Introduction section of the report contains a description of the mechanism of action of these drugs.

##### Antipsychotics

Three studies addressed the efficacy of antipsychotics (Table 11).50, 51, 67 One fair quality RCT51 assessed the efficacy and safety of risperidone in adults with autistic disorder or pervasive developmental disorder-not otherwise specified (PDD-NOS). Inclusion criteria were being an adult, having an Autistic Disorder or PDD-NOS diagnosis based on DSM-IV criteria, and at least “moderate” symptom severity on the Clinical Global Impression of Severity (CGI-S) Scale. Participants had either a Yale-Brown Obsessive Compulsive Scale (Y-BOCS) compulsive subscale score greater than 10, a Self-injurious Behavior Questionnaire (SIB-Q) score of 25 or greater, or a Ritvo-Freeman Real-life Rating Scale overall score of 0.20 or more. Exclusion criteria included a diagnosis of schizophrenia or psychosis, or any significant acute medical condition. The experimental design was a 12-week randomized, double-blind, placebo-controlled phase followed by a 12-week open-label risperidone treatment phase for patients from the placebo group. Subjects were off all psychiatric medications for more than 4 weeks before the trial started.

Risperidone dosing began with 1 milligram (mg) at night and advanced to twice daily dosing, increasing every 3 to 4 days by 1 mg/day, up to a maximal clinical effect or a maximum dose of 10 mg/day. Outcome measures included a modified version of the Y-BOCS, the SIB-Q, the Ritvo-Freeman Real-life Rating Scale, visual analog scales of different mood states, the Clinical Global Impression of Improvement (CGI-I), vital signs, and monitoring for extrapyramidal effects or other adverse effects. Subjects with a CGI-I score of “much improved” or “very much improved” were considered responders. The primary outcomes were global improvement (CGI), repetitive behavior (Y-BOCS), aggression (SIB-Q), and social relatedness (Ritvo-Freeman).

The mean age of the 31 subjects who began the trial was 28.1 years (SD 7.3) and mean full-scale IQ was 54.6 (SD 23.9). Only 24 subjects completed the trial. Fifty seven percent (8 of 14 subjects) were considered responders in the risperidone group, while none (0 of 16 subjects) in the placebo group were responders (p<0.002). Repetitive behavior as measured by Y-BOCS improved over time (p<0.001) for the risperidone group compared with the placebo group at each time point. This result was consistent with improvements over time in the open-label phase (p<0.03). Aggressive behavior as measured by SIB-Q improved over time (p<0.001) for the risperidone group compared with the placebo group. This result was consistent with improvements over time in the open-label phase (p<0.05). Symptomatic improvements as measured by the Ritvo-Freeman for the risperidone group compared with placebo were significant over time for sensory motor (p<0.004), affectual reactions (p<0.001), and overall score (p<0.05); however differences for social relationships, sensory responses, or language were not significant.

These results were consistent with the improvements over time in the open label phase except that sensory responses reached significance in the open label phase. Clinician-rated visual analog scales were significantly decreased in the risperidone group compared with placebo for “anxious or nervous” (p<0.02), “depressed” (p<0.03), and “irritable” (p<0.01); however there were no significant differences for “calm,” “eye contact,” “happy,” “restless,” “social interaction,” “talkative,” or “tired.” Seven subjects did not complete the trial (3 in the risperidone arm and 4 in the placebo arm), with six subjects dropping out due to lack of improvement or agitation, and one subject in the risperidone arm with abnormal gait.

A poor quality crossover study addressed the safety and efficacy of risperidone in children, adolescents, and adults with intellectual disability.67 Inclusion criteria were age 6 to 65 years; a 6-month or longer history of aggression, property destruction, or self-injury; and Aberrant Behavior Checklist-Community (ABC-C) scales above normal range. Exclusion criteria included a history of hypersensitivity to risperidone, neuroleptic malignant syndrome, seizures within the last year, degenerative brain disease, and problematic living/social situation. Subjects were free of all psychiatric medications for at least 2 weeks prior to entering the trial. The placebo-crossover design began with a placebo run-in phase (3 to 5 weeks). The study randomized participants to low dose risperidone (1 mg/day for children and adolescents, 2 mg/day for adults) or high dose risperidone (0.05 mg/kg/day), divided into a twice-daily schedule. The first treatment period started with 2 weeks of titration followed by 4 weeks at a constant dose. For the second treatment period, subjects crossed over to the other dose with 2 weeks of titration followed by 4 weeks at a constant dose. The crossover study design changed to an open-label design after a second placebo period (3 to 5 weeks) followed by 24 weeks of unblinded maintenance at the better risperidone dose.

Outcome measures included the ABC-C, the Dyskinesia Identification System Condensed User Scale, the Neuroleptic Side Effects Checklist, routine laboratory tests, and weight. Prolactin, hemoglobin A1c, and lipid profile were measured in a subset of the study subjects (n = 20). The primary outcome was the ABC-C Irritability subscale score.

Of the forty subjects, all had intellectual disability, 28 (70%) met DSM-IV criteria for autistic disorder, and 8 (20%) met DSM-IV criteria for PDD-NOS. The mean age was 22.0 years (SD 13.1). Twenty-three (57.5%) of subjects responded fully, and 35 (87.5%) had at least a partial response. The study defined a 50 percent reduction in the ABC-C Irritability/Agitation subscale score as a full response and a 25 percent reduction as a partial response. The mean ABC-C Irritability/Agitation subscale score was significantly different for both treatment periods compared with the second placebo period (p = 0.0002). There was no significant dose effect for the ABC-C Irritability/Agitation subscale between low- and high-dose risperidone (p = 0.13).

A fair quality crossover study50 investigated the efficacy of haloperidol for the treatment of autism. Inclusion criteria were a DSM-IV diagnosis of autism; a recommendation for pharmacotherapy based on initial assessments; and never previously having completed an adequate trial of haloperidol or the SRI clomipramine. Exclusion criteria were not reported. The study design was a double-blind, placebo-controlled, crossover with random assignment to 7-week treatment phases of haloperidol, clomipramine, and placebo. Haloperidol dosing started at 0.25 mg at bedtime and increased in 0.25 mg increments every 2 days until the dose was 0.50 mg twice daily, then further 0.25 mg adjustments were made every 3 to 4 days based on clinical assessment. The dose was reduced to the last dose tolerated if adverse effects were experienced. There was a dosage taper during week 7 of each treatment phase. There were one-week placebo washout periods between each treatment phase. No other psychotropic drugs were allowed except benztropine. Outcome measures included the CARS, the Aberrant Behavior Checklist (ABC), the Dosage Treatment Emergent Symptom Scale, and the Extrapyramidal Symptom Rating Scale.

We summarize results for haloperidol and placebo here and address clomipramine results below (see Serotonin Reuptake Inhibitor section). Of the 37 subjects recruited, 36 (mean age = 16.3 years) were included in final analyses. The mean daily dose of haloperidol was 1.3 mg. The mean duration of haloperidol treatment was 5.8 weeks with 23 of 33 (69.7%) subjects completing the 7-week treatment phase. Seven of 10 subjects who discontinued had adverse effects (see Harms section below). The mean duration of placebo treatment was 5.4 weeks with 21 of 32 (65.6%) subjects completing the 7-week phase; 1 of 9 subjects who discontinued had adverse effects which only included nose bleeds (n = 1). The other 8 subjects discontinued due to lack of improvement in symptoms. Haloperidol versus placebo was significant for reductions in ABC Hyperactivity/Defiance scores (p<0.05), but not for the other ABC subscales. The study did not report statistical comparisons of haloperidol versus placebo for the CARS, Extrapyramidal Symptom Rating Scale, or Dosage Treatment Emergent Symptom Scale. The investigators note that carry-over of effects between treatment phases may have affected results in this crossover design, especially with the short one-week washout. Other comparisons between haloperidol and placebo were not discussed.

##### Opioid Receptor Antagonists

One study of an opioid receptor antagonist met our review criteria (Table 12).53 This fair quality randomized, double blind crossover study tested the efficacy and safety of naltrexone on self-injurious behavior and other autistic symptoms in intellectually disabled adults. Inclusion criteria included a diagnosis using the Diagnostic and Statistical Manual of Mental Disorders, Third Edition, Revised (DSM-III-R) criteria that was agreed upon by two clinicians. The study also required that participants’ level of social impairment had to go beyond what was expected by the severity of their intellectual disability, although the details of this determination were not reported. The study also included a subgroup with moderate to high levels of self-injurious behaviors, even though they did not meet criteria for autistic disorder. No exclusion criteria were reported.

Concurrent medications, including antipsychotics, were held stable. The study randomized participants to naltrexone or placebo with a 2-week single-blinded placebo period followed by a single dose of naltrexone (100 mg) with placebo for the remainder of that week. This phase was followed by a 4-week treatment period, a 4-week washout period, and finally a crossover to the second 4-week treatment period. The first cohort received naltrexone 50 mg/day, but the dose for the second cohort was changed to naltrexone 150 mg/day. Outcome measures included the ABC; a clinician-rated checklist individualized to self-injurious behavior, stereotyped, and compulsive behaviors of each subject; the CGI-I scale; direct observation for a subgroup of 11 subjects; and laboratory analyses (liver function tests, plasma beta-endorphin, and plasma cortisol levels). The primary outcome was self-injurious behavior.

Of the 33 subjects that participated, 24 had autistic disorder and 9 did not. Participants mean age was 29 years (SD = 6), and IQ was not reported. Eleven subjects were taking antipsychotics with the dose held steady during the study. The single dose had no effect on the clinician-rated questionnaire, direct observation, self-injurious behavior, or plasma beta-endorphins. Plasma cortisol was significantly increased (p = 0.006) for naltrexone compared with placebo.

Longer term treatment (4 weeks) with naltrexone resulted in a significant increase in stereotypy as measured by the ABC stereotypy subscale. No changes in any of the other outcome measures were significant. The study did not report comparative statistics, but the CGI scale indicated that placebo was superior to 50 mg/day naltrexone in 12 of 18 subjects. The CGI scale showed that 50 mg/day of naltrexone was better than placebo in only 4 of 18 subjects, while placebo was superior in 12 of 18 subjects. The CGI scale also showed that 150 mg/day of naltrexone was better than placebo in 5 of 14 subjects, while placebo was superior in an equal number of subjects (5 of 14). There were no significant correlations between behavioral changes after the single dose of 100 mg naltrexone and the 4-week treatments with naltrexone (50 mg or 150 mg). Further analyses with groups divided into subjects with concurrent antipsychotic and subjects without did not yield any significant effect for naltrexone versus placebo.

##### Serotonin Reuptake Inhibitors

Five studies focused on SRIs met our criteria (Table 13).50, 52, 68, 69, 71 One fair quality RCT52 investigated the efficacy of fluvoxamine in adults with autistic disorder. Inclusion criteria were adults with a diagnosis of autistic disorder based on the DSM-III-R. Exclusion criteria were a DSM-III-R diagnosis of schizophrenia, psychotic symptoms, illicit substance abuse within the prior 6 months, “notable” medical conditions, seizure disorder, or pregnancy. Participants were not on any psychotropic medications for at least 6 weeks prior to starting the trial. The study randomized participants to placebo or fluvoxamine. Fluvoxamine was initiated at 50 mg daily and increased 50 mg every 3 to 4 days to maximum clinical response or a maximum dose of 300 mg/day. Outcome measures included the Y-BOCS, the maladaptive subscales of the Vineland Adaptive Behavior Scales, the Brown Aggression Scale, the CGI-I, and the Ritvo-Freeman Real-Life Rating Scale.

All 30 participants (15 fluvoxamine, 15 placebo) completed the 12-week trial. The mean age was 30.1 years (SD 7.1) for the fluvoxamine group and 30.1 years (SD 8.4) for the placebo group. The mean daily dose was 276.7 mg/day (SD 41.7) for the fluvoxamine group and 283.3 mg/day (SD 36.2) for the placebo group (difference not significant). Global improvement as measured by CGI-I was higher for fluvoxamine compared with placebo (p<0.001). Subjects were classified as responders if the CGI-I scores were “very much improved” or “much improved.” There were significantly more responders (p<0.001) in the fluvoxamine group (8 of 15 subjects) compared with the placebo group (0 of 15). Scores for the fluvoxamine group improved more than those for the placebo group for the Y-BOCS (p<0.001), Vineland maladaptive subscales (p<0.001), Brown Aggression Scale (p<0.03), overall Ritvo-Freeman Scale (p<0.04), and Ritvo-Freeman Scale language usage subscale (p<0.008).

Another fair quality study50 used a double-blind, placebo-controlled crossover design to investigate the efficacy of clomipramine and haloperidol for the treatment of autism. Inclusion criteria were a DSM-IV diagnosis of autism; a recommendation for pharmacotherapy based on initial assessments; never previously having completed an adequate trial of haloperidol or clomipramine. Exclusion criteria were not reported. Investigators randomized participants to 7-week treatment phases of haloperidol, clomipramine, and placebo. Clomipramine dosing started at 25 mg at bedtime and increased in 25 mg increments every 2 days until the dose was 50 mg twice daily, then further 25 mg adjustments were made every 3 to 4 days based on clinical assessment. The dose was reduced to the last dose tolerated if adverse effects were experienced. There was a dosage taper during week 7 of each treatment phase and 1-week placebo washout periods between each treatment phase. No other psychotropic drugs were allowed except benztropine. Outcome measures included the CARS, the ABC, the Dosage Treatment Emergent Symptom Scale, and the Extrapyramidal Symptom Rating Scale. Adverse effect outcomes were changes in stereotypy as measured by the Extrapyramidal Symptom Rating Scale and toleration of adverse effects which was measured by continuation of each treatment phase.

We summarize results for clomipramine and placebo here and haloperidol results above (see Antipsychotic section). Of the 37 subjects recruited, 36 (mean age = 16.3 years) were included in final analyses. The mean daily dose of clomipramine was 128.4 mg. The mean duration of clomipramine treatment was 4.5 weeks with 12 of 32 (37.5%) subjects completing the 7-week treatment phase; 12 of 20 subjects who discontinued did so at least partially because of adverse effects (see Harms section below).

The mean duration of placebo treatment was 5.4 weeks with 21 of 32 (65.6%) subjects completing the 7-week treatment phase. One of 9 subjects who discontinued had adverse effects which only included nose bleeds (n = 1). The study did not report statistical comparisons for clomipramine versus placebo for the CARS, Extrapyramidal Symptom Rating Scale, or Dosage Treatment Emergent Symptom Scale. The study did not report on the effects of clomipramine compared with placebo for ABC subscales. The investigators note that carry-over of effects between treatment phases may have affected results in this crossover design, especially with the short 1 week washout.

One poor quality study69 assessed the efficacy and tolerability of clomipramine using a prospective open-label case series design over 12 weeks. The inclusion criterion was a DSM-IV diagnosis of a pervasive developmental disorder (autistic disorder, Asperger disorder, and PDD-NOS). Subjects were excluded if they had any additional DSM-IV diagnosis other than intellectual disability, had abused illicit drugs within 6 months, were pregnant, or had an acute medical illness. Clomipramine was initially dosed at 50 mg daily, and then increased by 50 mg every 3 to 4 days up to the maximum clinical response or a maximum dose of 250 mg daily. No psychotropic medications were allowed except antiepileptic medication which were held stable and chloral hydrate as needed for agitation. Outcome measures included the Y-BOCS, Brown Aggression Scale, Ritvo-Freeman Real-Life Rating Scale (sensory motor behaviors, social relationship, affectual reactions, sensory responses, and language subscales), and CGI-I. Of the 35 subjects, 33 completed the study and were taking a mean dose of 139 mg (SD 50). There was a significant improvement (p<0.001) in CGI-I global symptoms over time with clomipramine treatment. Of the 33 subjects completing the trial, 18 (55%) were responders as determined by CGI score of “very much improved” or “much improved.” Clomipramine treatment significantly reduced (p<0.001) repetitive thoughts and behaviors as measured by Y-BOCS. Aggression as measured by the Brown Aggression Scale significantly decreased (p<0.001) over time with clomipramine treatment. Clomipramine treatment significantly improved (p<0.001) autistic symptoms as measured by the Ritvo-Freeman Scale overall score, as well as all each subscale. The two subjects not completing the trial withdrew due to agitation in one individual and abdominal cramping in the second participant. There was no placebo control group to compare with the clomipramine treatment group in this open-label trial.

Another poor quality, 12 week open-label prospective case series68 investigated the efficacy and tolerability of sertraline. Inclusion criteria were a DSM-IV diagnosis of autistic disorder, Asperger disorder, or PDD-NOS; a minimum Y-BOCS score (> 15 for verbal subjects, >7 for nonverbal subjects); minimum of score of 0.20 on the Ritvo-Freeman scale, minimum score of 25 on the SIB-Q; and a minimum of 5 on the Vineland Maladaptive Behavior Scale, part 2. Sertraline was initially dosed at 50 mg daily, and then increased by 50 mg every week to a maximum clinical response, maximal dose tolerated, or maximum dose of 200 mg daily. The study allowed no psychotropic medications except chloral hydrate as needed for agitation. Outcome measures included the Y-BOCS, SIB-Q, Ritvo-Freeman Real-Life Rating Scale, and CGI-I. Of the 42 subjects, 37 completed the trial. The mean sertraline dose was 122.0 mg (SD 60.5). Of the 42 subjects starting the trial, 24 (57%) were considered responders based on CGI-I score of “very much improved” or “much improved.” Five subjects withdrew from the study: three due to anxiety/agitation, one due to syncope, one due to noncompliance. There was no placebo control group for comparison of possible therapeutic effects or adverse events.

Finally, a poor quality retrospective case series71 studied the therapeutic effects and tolerability of fluoxetine and included 23 individuals with ASD (mean age 15.9 ± 6.2). Most participants (21/23) had concomitant intellectual disability. Participants received up to 80 mg/day of fluoxetine for a mean of 189 ± 153 days. CGI ratings of overall clinical severity improved in 15 participants as did ratings of perseverative or compulsive behavior.

#### Medical Studies Reporting Harms

In one study of risperidone51 the authors describe sedation as the most prominent adverse effect. Seven subjects did not complete the trial (three in the risperidone arm and four in the placebo arm), with six subjects dropping out due to lack of improvement or agitation, and one subject in the risperidone arm with abnormal gait. In another study of risperidone67 the most common adverse effects during the risperidone periods of the crossover phase were sedation and gastrointestinal complaints. In 13 subjects these adverse effects triggered automatic 50 percent dose reductions per the study protocol. The Dyskinesia Identification System Condensed User Scale scores from the treatment phases were not statistically different when compared either with the first placebo period (p = 0.052) or the second placebo period (p = 0.482). Symptoms on the Neuroleptic Side Effects Checklist that were the most significant (p<0.001) with treatment included drowsiness, weight gain, and increased appetite. Other symptoms were also significant (p<0.05) including “too quiet,” “not themselves,” tremor, “lack of spontaneity,” and nasal congestion. Mean weight gain during the entire study was 8.3 kg for adolescents and 6.0 kg for adults. There were no abnormal laboratory tests.

In a study of haloperidol50 the mean duration of haloperidol treatment was 5.8 weeks with 23 of 33 (69.7%) subjects completing the 7-week treatment phase; seven of 10 subjects who discontinued had adverse effects, including fatigue (n = 5), dystonia (n = 1), and depression (n = 1). The mean duration of placebo treatment was 5.4 weeks with 21 of 32 subjects (65.6%) completing the 7-week phase; one of nine subjects who discontinued had adverse effects which only included nose bleeds. The other eight subjects discontinued due to lack of improvement in symptoms. There were no significant changes in 12-lead electrocardiogram variables, either in the haloperidol or placebo phases.

In one study of opioid receptor antagonist identified,53 11 subjects were taking antipsychotics with the dose held steady during the study. Possible adverse events included one subject with an acute increase in self-injurious behavior, one subject with nausea and tiredness, and three subjects with sedation. Liver function tests remained within normal ranges. The single dose had no effect on the clinician-rated questionnaire, direct observation, self-injurious behavior, or plasma beta-endorphins. Plasma cortisol was significantly increased (p = 0.006) for naltrexone compared with placebo. Long-term treatment (4 weeks) with naltrexone resulted in a significant increase in stereotypy as measured by the ABC stereotypy subscale.

One study of clomipramine50 used a crossover design with a mean duration of clomipramine treatment of 4.5 weeks with 12 of 32 (37.5%) subjects completing the 7-week treatment phase; 12 of 12 subjects that discontinued had adverse effects which included fatigue or lethargy (n = 4), tremor (n = 2), tachycardia (n = 1), insomnia (n = 1), diaphoresis (n = 1), nausea or vomiting (n = 1), decreased appetite (n = 1), and preexisting right bundle branch block (n = 1). The mean duration of placebo treatment was 5.4 weeks with 21 of 32 (65.6%) subjects completing the 7-week treatment phase; 1 of 9 subjects that discontinued had adverse effects which only included nose bleeds (n = 1). There were no significant changes in 12-lead electrocardiogram variables, either in the clomipramine or placebo arms. Statistical comparisons were not reported for the clomipramine versus placebo for the CARS, Extrapyramidal Symptom Rating Scale, or Dosage Treatment Emergent Symptom Scale.

Another study assessing the efficacy and tolerability of clomipramine reported adverse effects in 13 individuals, 3 of whom had seizures during clomipramine treatment.69 Two of the three participants with seizures had previously diagnosed seizure disorders and were concurrently medicated with antiepileptic medication. The two participants not completing the trial withdrew due to agitation in one individual and abdominal cramping in the second. Other participants who completed the trial experienced constipation (n = 3), weight gain (n = 3), anorgasmia (n = 1), and sedation (n = 2). There were no cardiovascular or extrapyramidal adverse effects. There was no placebo control group to compare with the clomipramine treatment group in this open-label trial.

One RCT52 investigated the efficacy of fluvoxamine in adults with autistic disorder. Adverse effects in the fluvoxamine group included mild sedation (n = 2) and nausea (n = 3). There were no significant changes in anticholinergic effects, vital signs, routine lab analyses, or electrocardiogram.

In a case series68 assessing the efficacy and tolerability of sertraline, five subjects withdrew from the study: three due to anxiety/agitation, one due to syncope, one due to noncompliance. There were no cardiovascular, extrapyramidal, or seizure adverse effects. There was no placebo control group for comparison of possible therapeutic effects or adverse events. Finally, another case series71 examined fluoxetine and reported that six of 23 participants experienced side effects that “significantly” interfered with function or outweighed therapeutic benefits. Harms reported overall included agitation (n = 5), insomnia (n = 4), elated affect (n = 4), decreased appetite (n = 4), and increased screaming (n = 2). Additional harms were reported in at least one individual (inappropriate behavior, crying, yawning, rash).

## Studies of Allied Health Interventions

### Key Points

- Five studies, one fair and four poor quality, investigated disparate allied health approaches. Three studies included individuals with ASD and intellectual disability.
- A leisure/recreation program reported positive effects on stress and quality of life in a fair quality RCT.
- Facilitated communication did not increase participants’ communication or literacy abilities over their independent abilities.
- Some positive effects on social skills were reported in studies of music therapy, but outcome measures were unvalidated and largely subjective.
- No two studies assessed the same intervention; therefore, although individual studies report promising results, without replication, and with no studies of good quality, the strength of evidence for the body of literature is insufficient that any allied health approach is associated with positive outcomes.

### Overview of the Literature

We identified five studies of allied health interventions49, 58–60, 70 including one fair quality RCT investigating a leisure/recreation program.49 Appendix G provides the quality ratings for each study. The RCT, conducted in Spain, included 71 individuals ranging from 17 to 49 years of age with mean Leiter mental age scores of 64.36 ± 21.33 months in the intervention group and 61.44 ± 9.37 months in the control group. Assessments included measures of quality of life and stress. Two poor quality prospective case series addressed facilitated communication,59, 70 and two poor quality retrospective case series addressed music therapy.58, 60 Studies were conducted in the United States58–60 and Canada70 and included participants ranging in age from 2 to 40 across the studies. The duration of treatment ranged from 20 hours to 7 months in three studies;59, 60, 70 one study of music therapy reviewed data from participants who had participated in varying hours of therapy.58 Studies of facilitated communication59, 70 employed outcome measures gauging the number of correct responses to a given task with and without the aid of a facilitator. Facilitators helped to steady or physically support the hand of an individual with ASD either typing responses on a keyboard or pointing to images. Study evaluating a music therapy program58, 60 reported on the number of goals met and social outcomes or social outcomes using largely subjective measures. Tables 14 and 15 summarize key study outcomes.

Table 14 Key outcomes of studies of allied health interventions addressing core symptoms of ASD

Author, Year, Country Groups, N Enrollment/N Final Study Quality | Age, Yrs, Mean ± SD IQ, Mean ± SD | Key Outcomes
Music Therapy
Kaplan et al.,58 2005 United States G1: Music therapy, 40/40 Quality: Poor | G1: 13.9 (range 2–49) NR | - Retrospective review of client database records; music therapists set goals and determined percentage increase/decrease in skills/behavior relevant to goal.; - 40/40 participants with ASD met initial goals within 12 months of therapy; over 70% of participants met intermediate goals.; - All caregivers returning generalization surveys (n = 30) reported use of skills practiced in therapy sessions in non-therapy sessions occasionally or frequently.; - Quality considerations: no comparison group; systematic diagnostic approach not reported within study; participants not clearly characterized (no cognitive or developmental measures); attrition not reported; intervention not fully described; measure of treatment fidelity not reported; outcome measures not valid/reliable; outcomes not coded by masked assessors.
Facilitated Communication
Bebko et al.,70 1996 Canada G1: Facilitated communication Quality: Poor | G1: 13 (range 6–21) G1: 1.3 years – 4 years (mental age range) | - 6 weeks of FC training and practice with up to 7months followup data for 7 participants.; - Scores on visual stimulus experiment increased from baseline when FC used and facilitator aware of word being prompted (56.86% correct responses vs. 75%); scores decreased from baseline when FC used and facilitator not informed of word prompted (30% correct responses vs.25.57%).; - Visual stimulus scores increased from baseline when no FC used and facilitator was informed of word being prompted (36.71% correct responses vs. 53.57%) and decreased when no FC used and facilitator not informed of word (35.71% correct vs. 32.57%).; - FC did not enhance communication beyond participants’ independent abilities.; - Quality considerations: no comparison group; inclusion and exclusion criteria not clearly stated; measure of treatment fidelity not reported; differences in concomitant interventions not reported; outcomes not coded by masked assessors.
Eberlin et al.,59 1993 United States G1: Facilitated communication, 21/21 Quality: Poor | G1: 15.5 (range 11.3–20.2) G1: Mild to moderate intellectual disability, n = 2 Moderate to severe intellectual disability, n = 11 Severe to profound intellectual disability, n = 8 | - 20 total hours FC training.; - Median correct answers declined from baseline (no FC) after testing using FC with facilitator not. informed of words prompted (8 correct answers vs. 0); median score at testing with FC and facilitator informed of word prompted = 1.; - Communication ability or literacy did not improve for any participants.; - Quality considerations: no comparison group; differences in concomitant interventions not reported; outcomes not coded by masked assessors.

ASD = autism spectrum disorders; FC = facilitated communication; G = group; IQ = intelligence quotient; N = number; SD = standard deviation

Table 15 Summary of outcomes of studies of allied health interventions addressing independent functioning

Author, Year, Country Groups, N Enrollment/N Final Study Quality | Age, Yrs, Mean ± SD IQ, Mean ± SD | Key Outcomes
Garcia-Villamisar et al.,49 2010 Spain G1: Leisure/recreation program, 37/37 G2: Wait list control, 34/34 Quality: Fair | G1: 31.49 ± 4.83 G2: 30.06 ± 3.44 IQ (Leiter) G1: 63.46 ± 21.33 G2: 61.44 ± 9.37 | - Participants randomized to 12-month recreation/leisure program or waiting list.; - Stress and total quality of life scores improved for treatment group compared with wait list group (p<0.001).; - Scores on empowerment/independence and social/integration subscale improved for treatment group vs. control but not significantly.; - Quality considerations: randomization method not clearly described; attrition not reported; measure of treatment fidelity not reported; differences in concomitant interventions not reported.
Greher et al.,60 2010 United States G1: Music therapy (SoundScape), 22/22 Quality: Poor | G1: 18 (range: 13–29) NR | - 8-week program emphasizing understanding elements of music and recording music.; - Participants and parents rated social benefits of program highly.; - 11 participants and 19 parents reported that they/their child had developed friendships through the program.; - Quality considerations: no comparison group; systematic diagnostic approach not reported within study; participants not clearly characterized (no cognitive or developmental measures); measure of treatment fidelity not reported; differences in concomitant interventions not reported; outcomes not coded by masked assessors.

G = group; IQ = intelligence quotient; N = number; NR = not reported; SD = standard deviation

### Detailed Analysis

#### Allied Health Studies Addressing Core Symptoms of ASD

##### Music Therapy

A poor quality case series addressing music therapy58 used 2 years of therapist database records to assess the number of goals met and types of music therapy employed with 40 clients. Participants ages ranged from 2 to 49 years (mean age = 13.9) and all had diagnoses on the autism spectrum. Diagnoses were not reported as confirmed within the study. Music therapy involved individual or small or large group sessions and occurred in settings including a community music school or group home. The number of sessions varied for each client.

Therapists assessed each client’s “level of difficulty” related to aggression, property destruction, on-task behavior, and other domains on a scale with a maximum value of 14 points (highest level of difficulty); participants’ level of difficulty ratings averaged 2.5. Therapists also set and tracked goals met in areas including behavioral/psychosocial skills, language/communication skills, perceptual/motor skills, and cognitive skills. Therapists defined meeting a goal as an increase or decrease of 25 percent from a client’s baseline level of performance. Parents also completed annual questionnaires to assess generalizations of skills to other settings. All participants achieved their initial goal within 1 year as well as achieved 77 percent of intermediate goals. Attainment of goals was not affected by client level of difficulty or session type. Thirty caregivers returned generalization surveys, which reported that all participants used skills practiced in music therapy in nontherapy settings occasionally or frequently.

##### Facilitated Communication

Two poor quality case series addressed facilitated communication,59, 70 and included 41 individuals with ASD ranging in age from 8 to 21. Both studies included individuals with limited literacy, and one assessed the effects of facilitated communication via a series of picture recognition tasks performed with and without a facilitator and with the facilitator informed and uninformed of the object presented.70 Facilitators, staff members of a school for individuals with autism, all received 2 days of facilitated communication training. In one task involving participants’ pointing to the picture of a word displayed previously, the number of correct responses was greatest when facilitators were aware of the word displayed. Facilitated communication did not enhance participant performance beyond participants’ independent communication abilities, and facilitator influence was evident for at least 12 of 20 participants. In a second task using headphones and requiring responses to auditory cues, facilitators heard the same message as participants, a different message, or white noise. Responses across all 3 trials were not significantly different, and facilitator influence was evident for 14/20 participants.

In a third task participants completed segments of the Peabody Picture Vocabulary Test with and without facilitated communication. Scores on the text did not differ significantly between conditions; all 12 participants completing the test showed receptive language difficulties, and there were no clear patterns of facilitator influence. The investigators also collected followup data for seven participants after 5 to 7 additional months of facilitated communication use. Additional time with facilitated communication did not increase participants’ accuracy of responding and was associated with increased facilitator influence in one task (p<0.03).

A second case series addressing facilitated communication included 21 participants (mean age = 15.5) with ASD and mild to profound intellectual disability and language development age equivalent ranging from 1.6 to 5.1 years.59 Study tasks involved both facilitated and non-facilitated communication. In the non-facilitated condition, facilitators were screened from stimuli or investigator cues visible or audible to participants. Facilitators were trained in the history and principles of facilitated communication for roughly 4 hours before participating in the study, and facilitators unfamiliar to participants spent at least 2 weeks prior to the study helping participants acclimate. Participants completed baseline measures without facilitation and pretest measures with the assistance of screened facilitators. These tests were followed by 20 hours of facilitated communication exposure and training prior to completing post-test outcome measures.

Investigators scored participant responses liberally, counting as correct partial words, misspellings, and recognizable character strings embedded in other text (e.g., the characters “OSY” were scored correctly for “yes”). Performance on initial test measures declined from baseline (14/21 participants able to answer some questions correctly) to pretest (2/21 participants able to answer some questions correctly). At post-test, conducted after facilitated communication training and with screened facilitation, 2 of 21 participants were able to answer some questions correctly. Scores for a test session during which facilitators were not screened were higher, with 6 out of 21 participants able to answer some questions correctly. No participants demonstrated improved communication abilities or literacy.

#### Allied Health Studies Addressing Independent Functioning

One fair quality RCT investigating a leisure/recreation program randomized individuals with ASD to either a waiting list control group (n = 34) or a 12-month leisure program emphasizing engagement in exercise, playing games and completing crafts, interacting with media, and attending social events (n = 37) (Table 15).49 ASD diagnoses were confirmed within the study. Participants ranged in age from 17 to 49 years and had mean Leiter mental age scores of 64.36 ± 21.33 months in the intervention group and 61.44 ± 9.37 months in the control group. Assessments included measures of quality of life and stress completed at baseline and after 12 months by participants with adequate verbal skills or by individuals familiar with the participant.

Scores on the stress assessment improved for individuals in the intervention group compared with those in the control group (p<0.001). Overall quality of life scores similarly improved for intervention participants compared with the waiting list group; however, scores on empowerment/independence and social/integration subscales did not improve significantly between groups.

One poor quality case series investigated music therapy interventions using largely subjective measures. One study addressed a university-based program aimed at assessing the feasibility of a music program in promoting social skills in adolescents and young adults with ASD.60 The 22 participants ranged from age 13 to 29 (mean = 18), and diagnoses were not reported as confirmed within the study. The program’s curriculum included sessions in learning about music, music appreciation, video production, and storytelling with music over 8 weeks. Investigators assessed participants’ and parents’ impressions of social benefits gained via a 1 (low) to 10 (high) scale and open-ended questions. Both parents and participants rated the program highly with mean scores of nearly 7. Nineteen participants indicated that they had made friends during the program, and 11 parents noted that their children had made friends.