# References

1 Prevalence of the Autism Spectrum Disorders (ASDs) in Multiple Areas of the United States, 2004 and 2006. Centers for Disease Control and Prevention. Atlanta. 2009. www.cdc.gov/ncbddd/autism/states/ADDMCommunityReport2009.pdf.
2 Fombonne E. Epidemiological surveys of autism and other pervasive developmental disorders: an update. J Autism Dev Disord. Aug. 2003;33(4):365-82. [pmid: 12959416].
3 Shattuck PT, Seltzer MM, Greenberg JS, et al. Change in autism symptoms and maladaptive behaviors in adolescents and adults with an autism spectrum disorder. J Autism Dev Disord. Oct. 2007;37(9):1735-47. [pmid: 17146700].
4 McGovern CW, Sigman M. Continuity and change from early childhood to adolescence in autism. J Child Psychol Psychiatry. Apr. 2005;46(4):401-8. [pmid: 15819649].
5 Fecteau S, Mottron L, Berthiaume C, et al. Developmental changes of autistic symptoms. Autism. Sep. 2003;7(3):255-68. [pmid: 14516059].
6 Seltzer MM, Shattuck P, Abbeduto L, et al. Trajectory of development in adolescents and adults with autism. Ment Retard Dev Disabil Res Rev. 2004;10(4):234-47. [pmid: 15666341].
7 Seltzer MM GJ, Taylor JL, Smith L, Orsmond GI, Esbensen A, Hong J. Adolescents and adults with autism spectrum disorders. Amaral DDG, Geschwind D, editors. Autism Spectrum Disorders. New York. Oxford. 2011:241-52.
8 Ballaban-Gil K, Rapin I, Tuchman R, et al. Longitudinal examination of the behavioral, language, and social changes in a population of adolescents and young adults with autistic disorder. Pediatr Neurol. Oct. 1996;15(3):217-23. [pmid: 8916159].
9 Billstedt E, Gillberg IC, Gillberg C. Autism after adolescence: population-based 13- to 22-year follow-up study of 120 individuals with autism diagnosed in childhood. J Autism Dev Disord. Jun. 2005;35(3):351-60. [pmid: 16119476].
10 Eaves LC, Ho HH. Young adult outcome of autism spectrum disorders. J Autism and Dev Disord. Apr. 2008;38(4):739-47. [pmid: 17764027].
11 Howlin P, Goode S, Hutton J, et al. Adult outcome for children with autism. J Child Psychol Psychiatry. Feb. 2004;45(2):212-29. [pmid: 14982237].
12 Taylor JL, Seltzer MM. Employment and post-secondary educational activities for young adults with autism spectrum disorders during the transition to adulthood. J Autism Dev Disord. May. 2011;41(5):566-74. [pmid: 20640591].
13 Ganz ML. The lifetime distribution of the incremental societal costs of autism. Arch Pediatr Adolesc Med. Apr. 2007;161(4):343-9. [pmid: 17404130].
14 Croen LA, Najjar DV, Ray GT, et al. A comparison of health care utilization and costs of children with and without autism spectrum disorders in a large group-model health plan. Pediatrics. Oct. 2006;118(4):e1203-11. [pmid: 17015508].
15 Cimera RE, Cowan RJ. The costs of services and employment outcomes achieved by adults with autism in the US. Autism. May. 2009;13(3):285-302. [pmid: 19369389].
16 Taylor JL, Seltzer MM. Changes in the autism behavioral phenotype during the transition to adulthood. J Autism Dev Disord. 2010. Apr. 2. [pmid: 20361245].
17 Howlin P, Alcock J, Burkin C. An 8 year follow-up of a specialist supported employment service for high-ability adults with autism or Asperger syndrome. Autism. Dec. 2005;9(5):533-49. [pmid: 16287704].
18 Howlin P. Outcomes in autism spectrum disorders. Volkmar FR, editor. Handbook of autism and pervasive developmental disorders. 3rd ed. Hoboken, NJ. John Wiley and Sons. 2005:201-20.
19 Harmon A. Autistic and Seeking a Place in an Adult World. New York Times. New York Times Company. New York. September. 17. 2011.
20 Taylor JL. The transition out of high school and into adulthood for individuals with autism and their families. Hodapp R, editor. International Review of Research in Mental Retardation. Waltham, MA. Academic Press. 2009;38:2-28.
21 National Autism Center. National Standards Report. National Autism Center. Randolph, MA. 2009.
22 Nazeer A. Psychopharmacology of autistic spectrum disorders in children and adolescents. Pediatr Clin North Am. Feb. 2011;58(1):85-97. x. [pmid: 21281850].
23 Huffman LC, Sutcliffe TL, Tanner IS, et al. Management of symptoms in children with autism spectrum disorders: a comprehensive review of pharmacologic and complementary-alternative medicine treatments. J Dev Behav Pediatr. Jan. 2011;32(1):56-68. [pmid: 21160435].
24 Robb AS. Managing Irritability and Aggression in Autism Spectrum Disorders in Children and Adolescents. Dev Disabil Res Rev. 2010;16(3):258-64. [pmid: 20981764].
25 Williams K, Wheeler DM, Silove N, et al. Selective serotonin reuptake inhibitors (SSRIs) for autism spectrum disorders (ASD). Cochrane Database Syst Rev. 2010;(8):CD004677. [pmid: 20687077].
26 Sinha Y, Silove N, Wheeler D, et al. Auditory integration training and other sound therapies for autism spectrum disorders: a systematic review. Arch Dis Child. Dec. 2006;91(12):1018-22. [pmid: 16887860].
27 IMPAQ International. Autism Spectrum Disorders (ASDs) Services Final Report on Environmental Scan. IMPAQ International. Columbia, MD. March. 9. 2010. www.impaqint.com/files/4-content/1-6-publications/1-6-2-project-reports/finalasdreport.pdf.
28 Carpenter WT, Koenig JI. The evolution of drug development in schizophrenia: past issues and future opportunities. Neuropsychopharmacology. Aug. 2008;33(9):2061-79. [pmid: 18046305].
29 Akam E, Strange PG. Inverse agonist properties of atypical antipsychotic drugs. Biochem Pharmacol. Jun. 1. 2004;67(11):2039-45. [pmid: 15135301].
30 Meltzer HY, Huang M. In vivo actions of atypical antipsychotic drug on serotonergic and dopaminergic systems. Prog Brain Res. 2008;172:177-97. [pmid: 18772033].
31 Kuroki T, Nagao N, Nakahara T. Neuropharmacology of second-generation antipsychotic drugs: a validity of the serotonin-dopamine hypothesis. Prog Brain Res. 2008;172:199-212. [pmid: 18772034].
32 McPheeters ML, Warren Z, Sathe N, et al. A systematic review of medical treatments for children with autism spectrum disorders. Pediatrics. May. 2011;127(5):e1312-21. [pmid: 21464191].
33 Cath DC, Ran N, Smit JH, et al. Symptom overlap between autism spectrum disorder, generalized social anxiety disorder and obsessive-compulsive disorder in adults: a preliminary case-controlled study. Psychopathology. 2008;41(2):101-10. [pmid: 18033980].
34 Jacob S, Landeros-Weisenberger A, Leckman JF. Autism spectrum and obsessive-compulsive disorders: OC behaviors, phenotypes and genetics. Autism Res. Dec. 2009;2(6):293-311. [pmid: 20029829].
35 Mulder EJ, Anderson GM, Kema IP, et al. Platelet serotonin levels in pervasive developmental disorders and mental retardation: diagnostic group differences, within-group distribution, and behavioral correlates. J Am Acad Child Adolesc Psychiatry. Apr. 2004;43(4):491-9. [pmid: 15187810].
36 Gordon CT, Rapoport JL, Hamburger SD, et al. Differential response of seven subjects with autistic disorder to clomipramine and desipramine. Am J Psychiatry. Mar. 1992;149(3):363-6. [pmid: 1536276].
37 Kolevzon A, Mathewson KA, Hollander E. Selective serotonin reuptake inhibitors in autism: a review of efficacy and tolerability. J Clin Psychiatry. Mar. 2006;67(3):407-14. [pmid: 16649827].
38 Deutsch SI. Rationale for the administration of opiate antagonists in treating infantile autism. Am J Ment Defic. May. 1986;90(6):631-5. [pmid: 2872816].
39 Chabane N, Leboyer M, Mouren-Simeoni MC. Opiate antagonists in children and adolescents. Eur Child Adolesc Psychiatry. Suppl 1. 2000;9:I44-50. [pmid: 11140779].
40 Feldman HM, Kolmen BK, Gonzaga AM. Naltrexone and communication skills in young children with autism. J Am Acad Child Adolesc Psychiatry. May. 1999;38(5):587-93. [pmid: 10230191].
41 Gillberg C. Endogenous opioids and opiate antagonists in autism: brief review of empirical findings and implications for clinicians. Dev Med Child Neurol. Mar. 1995;37(3):239-45. [pmid: 7890130].
42 Schall C, McDonough J. Autism spectrum disorders in adolescence and early adulthood: characteristics and issues. J Vocat Rehabil. 2010;32:81-8.
43 Warren Z, Veenstra-VanderWeele J, Stone W, Bruzek JL, Nahmias AS, Foss-Feig JH, Jerome RN, Krishnaswami S, Sathe NA, Glasser AM, Surawicz T, McPheeters ML. Therapies for Children With Autism Spectrum Disorders, Comparative Effectiveness Review No. 26. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I) AHRQ Publication No. 11-EHC029-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm. [pmid: 21834171].
44 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):502-12. [pmid: 18823754].
45 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. Rockville, MD. 2008. www.ncbi.nlm.nih.gov/entrez/query.fcgi?cmd=Retrieve&db=PubMed&dopt=Citation&list_uids=21433403.
46 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
47 Golan O, Baron-Cohen S. Systemizing empathy: teaching adults with Asperger syndrome or high-functioning autism to recognize complex emotions using interactive multimedia. Dev Psychopathol. Spring. 2006;18(2):591-617. [pmid: 16600069].
48 Lawer L, Brusilovskiy E, Salzer MS, et al. Use of vocational rehabilitative services among adults with autism. J Autism Dev Disord. Mar. 2009;39(3):487-94. [pmid: 18810627].
49 Garcia-Villamisar DA, Dattilo J. Effects of a leisure programme on quality of life and stress of individuals with ASD. J Intellect Disabil Res. Jul. 2010;54(7):611-9. [pmid: 20500784].
50 Remington G, Sloman L, Konstantareas M, et al. Clomipramine versus haloperidol in the treatment of autistic disorder: a double-blind, placebo-controlled, crossover study. J Clin Psychopharmacol. Aug. 2001;21(4):440-4. [pmid: 11476129].
51 McDougle CJ, Holmes JP, Carlson DC, et al. A double-blind, placebo-controlled study of risperidone in adults with autistic disorder and other pervasive developmental disorders. Arch Gen Psychiatry. Jul. 1998;55(7):633-41. [pmid: 9672054].
52 McDougle CJ, Naylor ST, Cohen DJ, et al. A double-blind, placebo-controlled study of fluvoxamine in adults with autistic disorder. Arch Gen Psychiatry. Nov. 1996;53(11):1001-8. [pmid: 8911223].
53 Willemsen-Swinkels SH, Buitelaar JK, Nijhof GJ, et al. Failure of naltrexone hydrochloride to reduce self-injurious and autistic behavior in mentally retarded adults. Double-blind placebo-controlled studies. Arch Gen Psychiatry. Sep. 1995;52(9):766-73. [pmid: 7654128].
54 Van Bourgondien ME, Reichle NC, Schopler E. Effects of a model treatment approach on adults with autism. J Autism Dev Disord. Apr. 2003;33(2):131-40. [pmid: 12757352].
55 Nelson DL, Gergenti E, Hollander AC. Extra prompts versus no extra prompts in self-care training of autistic children and adolescents. J Autism Dev Disord. Sep. 1980;10(3):311-21. [pmid: 6927657].
56 Jewell JD, Grippi A, Hupp SDA, et al. The effects of a rotating classroom schedule on classroom crisis events in a school for autism. N Am J Psychol. 2007;9(1):37-52.
57 Gentry T, Wallace J, Kvarfordt C, et al. Personal digital assistants as cognitive aids for high school students with autism: results of a community-based trial. J Vocat Rehabil. 2010;32(2):101-7.
58 Kaplan RS, Steele AL. An analysis of music therapy program goals and outcomes for clients with diagnoses on the autism spectrum. J Music Ther. Spring. 2005;42(1):2-19. [pmid: 15839730].
59 Eberlin M, McConnachie G, Ibel S, et al. Facilitated communication: a failure to replicate the phenomenon. J Autism Dev Disord. Sep. 1993;23(3):507-30. [pmid: 8226584].
60 Greher GR, Hillier A, Dougherty M, et al. SoundScape: An interdisciplinary music intervention for adolescents and young adults on the autism spectrum. Int J Educ Arts. 2010;11(9).
61 Laugeson EA, Frankel F, Mogil C, et al. Parent-assisted social skills training to improve friendships in teens with autism spectrum disorders. J Autism Dev Disord. Apr. 2009;39(4):596-606. [pmid: 19015968].
62 Tse J, Strulovitch J, Tagalakis V, et al. Social skills training for adolescents with Asperger syndrome and high-functioning autism. J Autism Dev Disord. Nov. 2007;37(10):1960-8. [pmid: 17216559].
63 Silver M, Oakes P. Evaluation of a new computer intervention to teach people with autism or Asperger syndrome to recognize and predict emotions in others. Autism. Sep. 2001;5(3):299-316. [pmid: 11708589].
64 Valenti M, Cerbo R, Masedu F, et al. Intensive intervention for children and adolescents with autism in a community setting in Italy: A single-group longitudinal study. Child Adolesc Psychiatry Ment Health. 2010;4(1).
65 O’Connor IM, Klein PD. Exploration of strategies for facilitating the reading comprehension of high-functioning students with autism spectrum disorders. J Autism Dev Disord. Apr. 2004;34(2):115-27. [pmid: 15162931].
66 Elliott RO Jr, Hall K, Soper HV. Analog language teaching versus natural language teaching: generalization and retention of language learning for adults with autism and mental retardation. J Autism Dev Disord. Dec. 1991;21(4):433-47. [pmid: 1778959].
67 Hellings JA, Zarcone JR, Reese RM, et al. A crossover study of risperidone in children, adolescents and adults with mental retardation. J Autism Dev Disord. Apr. 2006;36(3):401-11. [pmid: 16596465].
68 McDougle CJ, Brodkin ES, Naylor ST, et al. Sertraline in adults with pervasive developmental disorders: a prospective open-label investigation. J Clin Psychopharmacol. Feb. 1998;18(1):62-6. [pmid: 9472844].
69 Brodkin ES, McDougle CJ, Naylor ST, et al. Clomipramine in adults with pervasive developmental disorders: a prospective open-label investigation. J Child Adolesc Psychopharmacol. Summer. 1997;7(2):109-21. [pmid: 9334896].
70 Bebko JM, Perry A, Bryson S. Multiple method validation study of facilitated communication: II. Individual differences and subgroup results. J Autism Dev Disord. Feb. 1996;26(1):19-42. [pmid: 8819769].
71 Cook EH, Rowlett R, Jaselskis C, et al. Fluoxetine treatment of children and adults with autistic disorder and mental retardation. J Am Acad Child Adolesc Psychiatry. Jul. 1992;31(4):739-45. [pmid: 1644739].
72 Garcia-Villamisar D, Hughes C. Supported employment improves cognitive performance in adults with Autism. J Intellect Disabil Res. Feb. 2007;51(Pt 2):142-50. [pmid: 17217478].
73 Mawhood L, Howlin P. The outcome of a supported employment scheme for high-functioning adults with autism or Asperger syndrome. Autism. Sep. 1999;3(3):229-54.
74 García-Villamisar D, Wehman P, Navarro MD. Changes in the quality of autistic people’s life that work in supported and sheltered employment. A 5-year follow-up study. J Vocat Rehabil. 2002;17(4):309-12.
75 García-Villamisar D, Ross D, Wehman P. Clinical differential analysis of persons with autism in a work setting: A follow-up study. J Vocat Rehabil. 2000;14(3):183-5.
76 Laugeson EA, Frankel F, Gantman A, et al. Evidence-based social skills training for adolescents with autism spectrum disorders: The UCLA PEERS Program. J Autism Dev Disord. 2011. Aug. 20. [pmid: 21858588].
77 Verhoeven EW, Marijnissen N, Berger HJ, et al. Brief report: Relationship between self-awareness of real-world behavior and treatment outcome in autism spectrum disorders. J Autism Dev Disord. 2011. Jun. 23. [pmid: 21698498].
78 Mandell DS, Morales KH, Marcus SC, et al. Psychotropic medication use among Medicaid-enrolled children with autism spectrum disorders. Pediatrics. Mar. 2008;121(3):e441-8. [pmid: 18310165].
79 Hollander E, Soorya L, Chaplin W, et al. A double-blind placebo-controlled trial of fluoxetine for repetitive behaviors and global severity in adult autism spectrum disorders. Am J Psychiatry. 2011;A iA:1-8.
80 Rendell JM, Gijsman HJ, Bauer MS, et al. Risperidone alone or in combination for acute mania. Cochrane Database Syst Rev. 2006;(1):CD004043. [pmid: 16437472].
81 Komossa K, Rummel-Kluge C, Schwarz S, et al. Risperidone versus other atypical antipsychotics for schizophrenia. Cochrane Database Syst Rev. 2011;(1):CD006626. [pmid: 21249678].