# Methods

## Topic Development and Refinement

The topic for this report was nominated by Autism Speaks in a public process. We drafted the initial Key Questions and analytic framework and refined them with input from key informants and a focus group of family members of adolescents and young adults with autism spectrum disorders (ASD). After review from the Agency for Healthcare Research and Quality (AHRQ), the questions and framework were posted to a public Web site. The public was invited to comment on these questions.

After reviewing the public commentary, we drafted final Key Questions and submitted them to AHRQ for review. We identified technical experts on the topic of ASD in adolescents and young adults to provide assistance during the project. Technical Expert Panel (TEP) members represented the clinical and research communities from a range of perspectives. They were invited to participate based on our commitment to engaging a range of experts who could help solidify the decisional dilemmas facing individuals and families with ASD. They included both researchers and clinicians with expertise in behavioral, medical, social, psychological and educational issues. The TEP contributed to AHRQ’s broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included six members serving as technical or clinical experts. To ensure robust, scientifically relevant work, we called on the TEP to provide reactions to work in progress. TEP members participated in conference calls and discussions through e-mail to:

- Refine the analytic framework and Key Questions at the beginning of the project;
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria;
- Provide input on assessing the quality of the literature.

### Role of the AHRQ Task Order Officer

The Task Order Officer (TOO) was responsible for overseeing all aspects of this project. The TOO helped to develop a common understanding among all parties involved in the project, resolved questions and ambiguities, and addressed our queries regarding the scope and processes of the project. The TOO reviewed the report for consistency, clarity, and to ensure that it conforms to AHRQ standards.

## Analytic Framework

The analytic framework (Figure 1) summarizes the process by which individuals with ASD and their families/caregivers make and modify treatment choices. Treatment choices include surgical or nonsurgical approaches and may lead to intermediate outcomes including changes in communication skills, academic skill development, or social skills. Interventions may also lead to long-term outcomes such as adaptive independence and changes in psychosocial well-being. Interventions may also lead to changes in family outcomes such as parent distress and may be associated with harms/adverse effects. Numbers in circles within the diagram indicate the placement of Key Questions in relation to the treatment process.

Figure 1 Analytic framework for interventions for adolescents and young adults with ASD

KQ = Key Question

The analytic framework summarizes the process by which individuals with autism spectrum disorders (ASD) and their families/caregivers make and modify treatment choices. Treatment choices may target intermediate outcomes including changes in communication skills, academic skill development, or social skills. Interventions lead to long-term outcomes such as adaptive independence and changes in psychosocial well-being. Family outcomes such as parent distress may also be targeted by interventions and may lead in turn to long-term outcomes. Finally, interventions may be associated with harms/adverse effects. Numbers in circles within the diagram indicate the placement of Key Questions in relation to the treatment process.

## Literature Search Strategy

### Databases

A librarian employed search strategies provided in Appendix A to retrieve research on therapies for adolescents and young adults with ASD. Our primary literature search employed 4 databases: MEDLINE^®^ via the PubMed interface, PsycINFO^®^ (psychology and psychiatry literature), the Educational Resources Information Clearinghouse, and the Cumulative Index of Nursing and Allied Health Literature database. Our search strategies used a combination of subject heading terms appropriate for each database and key words relevant to ASD (e.g., autism, Asperger). We limited searches to the English language and literature published since 1980 and the publication of standardized diagnostic criteria for ASD (i.e., Diagnostic and Statistical Manual of Mental Disorders III).

We also manually searched the reference lists of included studies and of recent narrative and systematic reviews and meta-analyses addressing ASD. We also invited TEP members to provide additional citations.

### Regulatory Information

The AHRQ Scientific Resource Center also searched for information on the following specific medications and interventions used to treat ASD. We requested regulatory information on these drugs and devices as they are either approved by the U.S. Food and Drug Administration to treat irritability in ASD or are beginning to be used in the ASD population and have not yet been well-reported in the published literature (i.e., hyperbaric oxygen):

- Risperidone
- Aripiprazole
- Hyperbaric oxygen chambers.

The Scientific Resource Center sought information in resources including the websites of the Food and Drug Administration and Health Canada and clinical trials registries such as ClinicalTrials.gov. We also gave manufacturers of these medications and devices an opportunity to provide additional information, though none did so.

### Search Terms

Controlled vocabulary terms served as the foundation of our search in each database (e.g., MEDLINE vocabulary terms including autistic disorder, child development disorders, pervasive), complemented by additional keyword phrases (e.g., Asperger, autism). We also limited searches to items published in English and from 1980 to the present. Our searches were executed between September 2010 and December 2011. Appendix A provides our search terms and the yield from each database. We imported all citations into an electronic database.

## Process for Study Selection

### Inclusion and Exclusion Criteria

We developed criteria for inclusion and exclusion based on the patient populations, interventions, outcome measures, and types of evidence specified in the Key Questions and in consultation with the TEP. Table 1 summarizes criteria.

Table 1 Inclusion and exclusion criteria

Category | Criteria
Study population | Adolescents or young adults (ages 13–30) with ASD (autistic disorder, Asperger syndrome, PDD-NOS) or families/caregivers of individuals with ASD between the ages of 13–30
Interventions | Interventions aimed at ameliorating core symptoms of ASD, affecting independent functioning, adaptive behavior, or the transition process, or targeting family outcomes
Comparators | Placebo Other intervention
Outcomes | Social skills/interaction, language and communication, repetitive and other maladaptive behaviors, motor outcomes, psychological distress, adaptive skills development, academic skills development, and family outcomes including family distress and family satisfaction
Time period | Studies published from 1980–present with no limits on timing of outcomes
Setting | Any setting including educational, residential, and clinic
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible designs]; - Controlled trials, observational studies including prospective and retrospective cohort studies, prospective and retrospective case series; [underlined: Study size]; - N ≥ 20 total individuals between 13–30 years of age with ASD or family members of such individuals; [underlined: Other criteria]; - Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results; - Patient populations must include adolescents or young adults (13–30 years of age) with ASD or families/caregivers of individuals with ASD between the ages of 13–30; - Studies must address one or more of the following:; ○ Treatment modality aimed at modifying ASD core symptoms, common comorbidities, family-related outcomes, or assisting with transitional issues; ○ Outcomes (including harms) related to interventions for ASD; - Studies must include extractable data on relevant outcomes, including data presented in text or tables (vs. solely in figures); - Studies must present aggregate data (vs. only data for each individual participant)

ASD = autism spectrum disorders; N = number; PDD-NOS = pervasive developmental disorder-not otherwise specified

#### Study Population

Studies needed to provide adequate information to ensure that participants fell within the target age range of age 13 to 30. We selected the lower bound of 13 as a previous AHRQ comparative effectiveness review of therapies for children with ASD included studies with individuals ≤ age 12.^43^ As this review is focused in part on individuals in the period of transitioning to more independent functioning, we used the upper bound of 30 as individuals with ASD can remain in the secondary school system until age 21. Thus some individuals may not experience the transition to more independent functioning in their twenties as would be expected for typically developing individuals. The upper age of 30 accounted for potential developmental delays in individuals with ASD.

For studies with populations including individuals with ASD either under the age of 13 or over age 30, we retained the study if we could infer that at least 50 percent of the study participants were in the 13 to 30 age range or if the mean age of participants was in the 13 to 30 age range. Similarly, for studies including individuals with ASD and those with other developmental disabilities we retained the study if we could isolate data on those participants with ASD.

We note that if a research study used a comparison group that did not contribute to an estimate of the contrast of interest in our review, we included the one arm of the study that was relevant. For example, an intervention study in which the intervention group is individuals with ASD and the comparison group is a group of individuals with Down Syndrome would not provide an estimate of the effect of the intervention for children with ASD. Rather than exclude this study, we include the group of individuals with ASD as a case series.

#### Sample Size

We excluded studies that included fewer than 20 total participants in the target age range with ASD or family members of such individuals. Our goal was to identify and review the best evidence for assessing the efficacy and effectiveness of therapies for adolescents and young adults with ASD, with an eye toward utility in the treatment setting. Interventions to address ASDs are frequently behavioral in nature and highly intensive. They are also frequently adapted to be targeted to specific study participants given the significant heterogeneity of individuals with ASD. In part because this makes behavioral research quite complex and intensive, study sizes tend to be very small. A cutoff sample size of 20 provides a balance, allowing us to review and comment on adequate literature for the review but with studies large enough to suggest effects of the interventions.

With the assistance of our technical experts, we selected a minimum sample size of 20 in order to maximize our ability to describe the state of the current literature, while balancing the need to identify studies that could be used to assess treatment effectiveness.

#### Study Design

We accepted any study designs except individual case reports. Our approach to categorizing study designs is presented in Appendix B.

#### Outcomes

We assessed outcomes in the broad areas of social skills/interaction, language and communication, repetitive and other maladaptive behaviors, motor outcomes, psychological distress, adaptive skills development, academic skills development, and family outcomes including family distress and family satisfaction related to interventions. We considered intermediate outcomes as those that occur directly as a result of the intervention and that may also have longer term implications for the ultimate, functional outcomes that are the long-term goal of therapies. We also considered changes in long-term functional outcome areas, including adaptive independence/self care, academic/occupational/vocational engagement and attainment, psychological well-being, psychosocial adaptation, residential outcomes, legal outcomes, social/relationship-focused outcomes (interpersonal relationships, community involvement/societal participation, self-actualization and acceptance, etc.), access to health services (conservatorship, access to day care, access to health care, access to social, financial, and other support systems), and use of public programs.

We also assessed the harms of interventions, defined by the AHRQ Effective Health Care program as the totality of adverse consequences of an intervention.44 Harms may include—

- Adverse behavioral or psychosocial reactions to behavioral or other therapies (e.g., increased aggression or anxiety)
- Regression of language, skills, or behaviors
- Increases in or worsening of comorbid symptoms
- Adverse reactions to drug therapies (e.g., somnolence, weight gain)
- Reduction in and negative influences on quality of life.

#### Language

We focused the review on studies published in English. In the opinion of our content experts, most research on ASD is published in English regardless of the native language of the investigators or country of publication.

## Screening of Studies

Once we identified articles through the electronic database searches, review articles, and bibliographies, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated each abstract for inclusion or exclusion, using an Abstract Review Form (Appendix C). If one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it for full text assessment.

Two reviewers independently assessed the full text of each included study using a standardized form (Appendix C) that included questions stemming from our inclusion/exclusion criteria. Disagreements between reviewers were resolved by a third-party adjudicator. The group of abstract and full text reviewers included expert clinicians and researchers and health services researchers.

## Categorization of Interventions

Interventions to treat ASD overlap substantially21 and cleanly identifying the category into which an intervention should be placed is difficult. We adapted the categorization approach we used in our previous review of therapies for children with ASD,43 and studies fell into the following categories:

- Behavioral interventions. We defined behavioral interventions to include intensive behavioral and developmental interventions and social skills interventions employing either peer group- or computer-based approaches.
- Educational interventions. Educational interventions are those focusing on improving educational and cognitive skills and intended primarily to be administered in educational settings, or studies for which the educational arm was most clearly categorized.
- Adaptive/life skills-focused interventions. We considered those interventions focused on developing skills to assist with independent functioning and independent execution of activities of daily living as falling within this category. Interventions described in this review include interventions targeting transitioning to a new school routine, self-care, and cognitive aids.
- Vocational interventions. We classified interventions targeting job skills, employment supports, or placing individuals into work as vocational interventions. Such interventions included in the literature meeting our criteria for this review comprise sheltered workshops, supported employment, and vocational rehabilitation.
- Medical and related interventions. We broadly defined medical and related interventions as those that included the administration of external substances to the body in order to treat symptoms of ASD; medical interventions represented in the literature included in this review comprised prescription medications.
- Allied health interventions. Allied health interventions included therapies that may be provided by occupational and physical therapists, including recreational therapies and promoting engagement in physical activity. We also considered therapies such as facilitated communication and music therapy as allied health interventions.

## Data Extraction and Data Management

The staff members and clinical experts who conducted this review jointly developed the evidence tables, which were used to extract data from the studies. We designed the tables to provide sufficient information to enable readers to understand the studies, including issues of study design, descriptions of the study populations (for applicability), description of the intervention, and baseline and outcome data on constructs of interest.

The team abstracted several articles into the evidence table and then reconvened as a group to discuss the utility of the table design. We repeated this process through several iterations until we decided that the table included the appropriate categories for gathering the information contained in the articles. All team members shared the task of initially entering information into the evidence table. Another member of the team also independently reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. The full research team met regularly during the article extraction period and discussed issues related to data extraction (e.g., optimal level of detail in the description of the intervention, what constituted assessment of treatment fidelity). In addition to outcomes related to treatment effectiveness and family outcomes, we extracted all data available on harms. Harms encompass the full range of specific negative effects, including the narrower definition of adverse events.

The final evidence tables are presented in their entirety in Appendix D. Studies are presented in the evidence tables alphabetically by the last name of the first author within each year. When possible to identify, analyses resulting from the same study were grouped into a single evidence table.

## Individual Study Quality Assessment

We used a components approach to assessing the quality of individual studies, following methods outlined in the AHRQ Effective Health Care program’s Methods Guide for Effectiveness and Comparative Effectiveness Reviews.45 Decision rules regarding application of the tools were developed a priori by the research team. In some instances, it was appropriate to apply specific questions only to one body of literature (e.g., treatment fidelity to behavioral studies and medication adherence to medical studies) and we note those cases where appropriate. We assessed each domain individually and combined them for an overall quality level as described below. Three levels were possible: good, fair, and poor (Table 2). Appendix E includes the questions we used to assess each domain.

Table 2 Description of study quality levels

Quality Level | Description
Good | Good studies are considered to have the least bias and results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to treatments; has a low dropout rate; and uses appropriate means to prevent bias; measure outcomes; analyze and report results.
Fair | Fair studies are susceptible to some bias, but probably not sufficient to invalidate the results. A study may be missing information, making it difficult to assess limitations and potential problems. As the “fair quality” category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
Poor | Poor studies are subject to significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

### Determining Quality Levels

We assessed each domain described above individually and considered the individual ratings to determine an overall quality assessment of good, fair, or poor. We required that studies receive positive scores on all questions to receive a rating of good quality. We required that studies receive positive ratings on the following questions for a fair rating:

- Did the study employ a group design?
- Was there an appropriate comparison group?
- Was a systematic diagnostic approach used within the study?
- Were inclusion and exclusion criteria clearly stated?
- Was the intervention fully described?
- Did outcome measures demonstrate adequate reliability and validity?
- Were outcome data collected from sources appropriate to the target outcome?
- Was an appropriate statistical analysis used?

We rated studies without positive scores on these questions as poor quality and retained poor quality studies as part of the evidence base.

## Data Synthesis

There was significant heterogeneity among studies reporting therapeutic results of interventions for adolescents and young adults with ASD, including heterogeneity of population characteristics, heterogeneity of interventions, and heterogeneity of outcome measures. Therefore, it was not appropriate to perform any meta-analysis.

## Grading the Body of Evidence for Each Key Question

The assessment of the literature is done by considering both the observed effectiveness of interventions and the confidence that we have in the stability of those effects in the face of future research. The degree of confidence that the observed effect of an intervention is unlikely to change is presented as strength of evidence, and it can be regarded as insufficient, low, moderate, or high. Strength of evidence describes the adequacy of the current research, both in terms of quantity and quality, as well as the degree to which the entire body of current research provides a consistent and precise estimate of effect. Interventions that have demonstrated benefit in a small number of studies but have not yet been replicated using the most rigorous study designs will therefore have insufficient or low strength of evidence to describe the body of research. Future research may find that the intervention is either effective or ineffective.

Methods for applying strength of evidence assessments are established in the AHRQ Effective Health Care Program’s Methods Guide for Effectiveness and Comparative Effectiveness Reviews46 and are based on consideration of four domains: risk of bias, consistency in direction of the effect, directness in measuring intended outcomes, and precision of effect (Table 3). Strength of evidence is assessed separately for major intervention-outcome pairs.

Table 3 Domains used to assess strength of evidence^a^

Domain | Explanation
Risk of bias | Degree to which the included studies for a given outcome or comparison have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through two main elements:; - Study design (e.g., RCTs or observational studies); - Aggregate quality of the studies under consideration.; Information for this determination comes from the rating of quality (good/fair/poor) done for individual studies
Consistency | Degree to which reported effect sizes from included studies appear to have the same direction of effect. This can be assessed through two main elements:; - Effect sizes have the same sign (that is, are on the same side of “no effect”); - The range of effect sizes is narrow
Directness | Relates to whether the evidence links the interventions directly to health outcomes. For a comparison of two treatments, directness implies that head-to-head trials measure the most important health or ultimate outcomes. Evidence is indirect if:; - It uses intermediate or surrogate outcomes instead of ultimate health outcomes. In this case, one body of evidence links the intervention to intermediate outcomes and another body of evidence links the intermediate to most important (health or ultimate) outcomes; - It uses two or more bodies of evidence to compare interventions A and B, e.g., studies of A vs. placebo and B vs. placebo, or studies of A vs. C and B vs. C but not A vs. B.; Indirectness always implies that more than one body of evidence is required to link interventions to the most important health outcomes. Directness may be contingent on the outcomes of interest.
Precision | Precision is the degree of certainty surrounding an effect estimate with respect to a given outcome (i.e., for each outcome separately). If a meta-analysis was performed, this will be the confidence interval around the summary effect size.

a Excerpted from Owens et al., 2010^46^

Based on the approach used in the prior AHRQ review of therapies for children with ASD,43 we required at least three fair quality studies to be available to assign a low strength of evidence rather than considering it to be insufficient. For determining the strength of evidence for effectiveness outcomes, we only assessed the body of literature deriving from studies that included comparison groups. We required at least one good study for moderate strength of evidence and two good studies for high strength of evidence. In addition, to be considered “moderate” or higher, intervention-outcome pairs needed a positive response on two out of the three domains other than risk of bias. For determining the strength of evidence related to harms, we also considered data from case series.

Once we had established the maximum strength of evidence possible based upon these criteria, we assessed the number of studies and range of study designs for a given intervention-outcome pair, and downgraded the rating when the cumulative evidence was not sufficient to justify the higher rating. The possible grades were—

- High: High confidence that the evidence reflects the true effect. Further research is unlikely to change estimates.
- Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low: Low confidence that the evidence reflects the true effect. Further research is likely to change confidence in the estimate of effect and is also likely to change the estimate.
- Insufficient: Evidence is either unavailable or does not permit a conclusion.

## Applicability

Finally, it is important to consider the ability of the outcomes observed to apply both to other populations and to other settings (especially for those therapies that take place within a clinical/treatment setting but are hoped to change behavior overall). Our assessment of applicability included determining the population, intervention, comparator, and setting in each study and developing an overview of these elements for each intervention category.

## Peer Review and Public Commentary

Researchers and clinicians with expertise in behavioral, medical, social, psychological and educational issues and individuals representing stakeholder and user communities were invited to provide external peer review of this report; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented changes and revisions to the report in a disposition of comments report that will be made available 3 months after AHRQ posts the final CER on the AHRQ Web site.