# Introduction

## Need for Evidence Regarding Treatment of Autism Spectrum Disorders in Adolescents and Young Adults

Autism Spectrum Disorders (ASD) are among the most common neurodevelopmental disorders, with an estimated prevalence of one in 110 children in the United States having an ASD.1 They are typically diagnosed in early childhood, often at or before preschool age. The diagnosis is fundamentally behaviorally based (i.e., there is no specific genetic test or clinical/laboratory procedure for diagnosis) and rests on documented core impairments related to social interaction, communication, as well as restricted and repetitive behavior. Diagnoses made by clinical providers, often pediatricians or behavioral providers, are based on documented symptom patterns in these domains.

Numerous screening and diagnostic tools are available to help document and measure symptoms of autism, with research investigations increasingly utilizing such measures in combination with clinical diagnoses in order to more accurately describe, measure, and analyze the heterogeneity in presentation associated with ASD. In addition to impairments in core symptom areas, many individuals with ASD also have impaired cognitive skills, atypical sensory behaviors, or other complex medical and psychiatric symptoms and conditions, such as seizure disorders, motor impairments, hyperactivity, anxiety, and self-injury/aggression.

More than 55,000 individuals between the ages of 15 and 17 in the United States likely have an ASD.2 For some individuals, core symptoms of ASD (impairments in communication and social interaction and restricted/repetitive behaviors and interests) may improve with intervention and over time;3–5 however, deficits typically remain throughout the lifespan although developmental expression may vary.6 As children transition to adolescence and young adulthood, developmentally appropriate interventions to ameliorate core deficits may continue, but the focus of treatment often shifts toward promoting adaptive behaviors that can facilitate and enhance independent functioning.6 Treatments for some must take into account that new symptoms may emerge with adolescence as well as engagement with new developmental challenges (e.g., independent living, vocational engagement, postsecondary education). In particular, families and caregivers have to make choices regarding care that cross a broad spectrum of clinical, behavioral and educational areas.

Current data suggest that attainment of independent living or employment in adulthood for individuals with an ASD is variable, with factors that predict the ability to live and work independently not well elucidated.6 Furthermore, the limited extant research on outcomes for adolescents and young adults with ASD documents difficulties in achieving markers of functional independence, including employment, for the vast majority of these individuals.7 Specifically, most adults with ASD live dependent lives that require considerable supports; fewer than a third have regular employment; most live with their parents or in supported living; and those who are employed are often in jobs that pay below a living wage.8–12 In part because of these high levels of dependence, most individuals with ASD will require some sort of supports or intervention, often at intensive levels, throughout adolescence and adulthood.

The estimated costs of medical and non-medical care (e.g., special education, daycare) are prodigiously high. One study estimates that the total yearly societal per capita cost of caring for and treating a person with autism in the United States at $3.2 million and at about $35 billion for an entire birth cohort of individuals with autism.13 A study of health care utilization in a large group health plan revealed increased medication costs in older children with an ASD when compared with younger children, as well as similarly aged adolescents without an ASD; other care costs were also higher in this population, including a significantly increased rate of hospitalizations.14

Costs of transitional and employment programs are also high for young adults with ASD. A recent analysis of U.S. federal- and state-funded vocational rehabilitation programs showed that enrolled individuals with ASD were among the most costly of nine disability groups examined, with costs even higher among those with ASD and another comorbid disability. These data also showed, however, that those with ASD had a higher rate of employment (40.8%) at the time of case closure when compared with those with other disabilities, though with fewer work hours and lower wages than some other disability groups.15

Although few studies have examined this stage of the lifespan specifically, one study suggests that improvements in symptoms and problem behaviors observed while youth with ASD were in high school slowed down or stopped after they left high school.16 Many individuals lose access to school- and age-linked services, and many of the services available to adults require waiting lists.16, 17 The lack of services available to help young adults with ASD transition to greater independence has been noted by researchers for a number of years,18 and is increasingly a topic in the lay media.19 To date, the specific programs and interventions that underlie more positive functional, adaptive, social, and employment outcomes for individuals with ASD during the transition to adulthood and beyond are poorly understood. Further, it is unclear how such outcomes are best assessed in the face of the inherent heterogeneity and wide scope of impairments associated with ASD.6, 20 This lack of information potently limits the ability of individuals, families, practitioners and service systems to provide the appropriate care to optimize quality of life and minimize the costs associated with ASD over the lifespan.

This review examines the effects of available interventions in adolescents and young adults with ASD, focusing on the following outcomes: core symptoms of ASD; medical and mental health comorbidities; functional behaviors and independence; the transition to adulthood, and family outcomes.

## Interventions Used To Treat ASD

The expression and severity of symptoms of ASD differs widely across individuals and over time. Treatments may include a range of behavioral, psychosocial, educational, medical, and complementary approaches as well as those focused on transitional process and improving outcomes for parents/families of individuals with ASD.

The following sections briefly describe interventions discussed in the literature meeting our criteria for this review. Additional interventions for adolescents and young adults with ASD that did not meet criteria for our review are described in recent systematic and narrative reviews.21–27

### Behavioral Interventions

Studies of behavioral interventions available for this review are presented in the broad subcategories of social skills interventions and intensive behavioral interventions.

#### Social Skills Interventions

Difficulty with reciprocal social interaction is considered one of the core impairments of ASD. The social impairment seen in ASD takes many forms and can vary greatly from one individual to the next. For adolescents and young adults, social skills interventions often focus on enhancing individuals’ interactions with peers and other adults by teaching skills necessary for fluid interaction including instruction perspective-taking, social problem-solving, and understanding social and emotional rules. Skill-based approaches have tried to address social vulnerability through direct group instruction as well as interactive computer based instruction.

#### Intensive Behavioral Interventions

Comprehensive intensive behavioral interventions that focus simultaneously on multiple target areas are quite common for preschool children with ASD (e.g., University of California, Los Angeles/Lovaas model and early intensive behavioral intervention variants, Early Start Denver model, parent training paradigms). Studies that use behavioral approaches in an intensive and comprehensive fashion are uncommon during adolescence and young adulthood, although some programs for older individuals with ASD (not included in this review) may use elements of comprehensive approaches.

### Educational Interventions

Most children and adolescents with ASD receive a substantial amount of their treatment in an educational or center-based setting, often beginning early in life (e.g., preschool age). Educational interventions often aim at enhancing specific areas of academic functioning (e.g., reading skills), but also quite frequently attempt to address social, cognitive, and behavioral challenges within an educational setting. In addition to these targets, psychoeducational interventions are also often provided in an attempt to prevent or ameliorate specific areas of behavioral concern (i.e., sleep issues, puberty/sexuality related concerns) and provide family support.

### Vocational Interventions

Given the core and associated impairments related to ASD, many young adults exhibit challenges finding and sustaining involvement in appropriate and meaningful vocational activities. A number of interventions related to vocational attainment have focused on developing supportive mechanisms to secure employment. Such approaches often involve an interventionist, such as a job coach, and explicit instruction in the skills necessary to accomplish specific occupational functions. In addition, some approaches have attempted to incorporate instruction in the social and other skills necessary to identify and realize potential employment opportunities (e.g., interviewing).

### Adaptive/Life Skills Interventions

While comprehensive behavioral interventions for adolescents and young adults are uncommon, many interventions use applied behavior analysis-based intervention to target and improve important areas of daily functional impairment. These skills, often called adaptive or life skills, vary by specific targets (e.g., feeding, dressing) or more complex tasks (e.g., teaching a sequence of behavior). These interventions may also target reducing challenging behaviors (e.g., self-injury, self-stimulatory behavior, aggression) that interfere with day to day skills and functioning.

### Medical and Related Interventions

Medical interventions for symptoms of ASD include pharmacological agents, therapeutic diets, hormonal supplements, hyperbaric oxygen, chelating agents, and many other therapies. Risperidone (age 5 to 16 years) and aripiprazole (age 6 to 17 years), both atypical antipsychotic medications, are the only medical interventions that have U.S. Food and Drug Administration approval for patients with autistic disorder. Other core and related symptoms are treated with medications that are used in an “off-label” fashion. Antipsychotic medications act on the dopamine system and other neurotransmitter systems, such as serotonin.28–31 Antipsychotic medications are generally divided into typical antipsychotics, which are older and primarily have affinity for dopamine D_2_ receptors, and atypical antipsychotics which are newer and show a more diverse receptor profile. Typical antipsychotics studied in ASD include medications like haloperidol. Atypical antipsychotic medications include risperidone and aripiprazole, which are approved to treat irritability in children with autism, and have moderate and high evidence of efficacy based upon an earlier systematic review in children with ASD.32

Serotonin reuptake inhibitors (SRIs) are effective in treating anxiety, depression, and obsessive-compulsive disorder. There is overlap between the repetitive behaviors of ASD and obsessive compulsive disorder.33, 34 Additionally, high blood levels of serotonin are a biomarker seen in 25 to 30 percent of children with autism, pointing to the serotonin system as a potential target for treatment.35, 36 Randomized controlled trials and open-label trials with serotonin reuptake inhibitors in children with ASD have shown some promise but considerable variability in treating repetitive behaviors, anxiety, and aggression.32, 37 SRIs include tricyclic antidepressants and more selective inhibitors. The newer class of SRIs, selective serotonin reuptake inhibitors, includes fluvoxamine, sertraline, and fluoxetine.

Opioid antagonists have been used in patients with ASD based upon the hypothesis that the opioid system may be involved in maintaining or reinforcing self-injurious behaviors.38 Naltrexone is one opiate antagonist that has been investigated for treatment of self-injury, hyperactivity, or stereotyped movements in children with autism; although without evidence from randomized controlled trials favoring its use.39–41

### Allied Health Interventions

Several allied health interventions address core symptoms of ASD as well as associated difficulties and deficits. Social communication vulnerabilities are considered core features of ASD. As such, language difficulties and nonverbal communication challenges are often important targets of treatment. Historically, one communication intervention, facilitated communication, focused on helping individuals with communication and language challenges communicate via an interventionist or facilitator. More recently, interventions have utilized technology and augmentative communication therapies/devices in improving communication skills in individuals with ASD.

Other approaches have focused on teaching specific aspects of speech and language development (i.e., production, pragmatic language interventions). A number of additional interventions include occupational therapy techniques, movement and music therapies, as well as approaches aimed at sensory integration or addressing challenging sensory behaviors.

## Importance of this Review

Current data suggest that attainment of independent living or employment in adulthood for individuals with an ASD is variable, with factors that predict the ability to live and work independently not well elucidated.6 Available data suggest that individuals with ASD will require some sort of intervention throughout adolescence and adulthood, and the estimated costs of medical and non-medical (e.g., special education, daycare) care are prodigiously high.27 One study estimates that the total yearly societal per capita cost of caring for and treating a person with autism in the United States at $3.2 million and at about $35 billion for an entire birth cohort of individuals with autism.13 A study of healthcare utilization in a large group health plan revealed increased medication costs in older children with ASD as compared with younger children as well as similarly-aged adolescents without ASD; other care costs were also higher in this population, and the rate of hospitalizations was significantly increased.14

Costs of transitional and employment programs are also high for young adults with ASD. A recent analysis of U.S. federal and state-funded vocational rehabilitation programs showed that the prevalence of ASD among those in training programs increased from 0.2 percent to 0.6 percent from 2002 to 2006; those with ASD were among the most costly of nine disability groups examined, with costs even higher among those with ASD and another comorbid disability. These data also showed, however, that those with ASD had a higher rate of employment (40.8%) at the time of case closure as compared with those with other disabilities, though with fewer work hours and lower wages than some other disability groups.15

There is no cure for ASD and no global consensus regarding which intervention strategies are most effective. Chronic management, often using multiple treatment approaches, may be required to maximize ultimate functional independence and quality of life by minimizing the core ASD features, facilitating development and learning, promoting socialization, reducing maladaptive behaviors, and educating and supporting families. Investigators in the area have noted that less research on therapies for adolescents or young adults exists than for younger children,42 and such research is increasingly critical as the prevalence of ASD continues to grow and as children with ASD diagnoses reach adolescence.

## Scope and Key Questions

### Scope of This Report

We focused this review on interventions for adolescents and young adults between the ages of 13 and 30 with ASD (Autistic Disorder, Asperger syndrome, pervasive developmental disorder-not otherwise specified) and addressed questions related to the effectiveness of therapies targeting core symptoms of ASD (impairments in communication, social interaction, and behavior); aimed at common medical or mental health comorbidities, which include associated symptoms such as irritability; addressing the process of transitioning to adulthood; and addressing family outcomes.

### Key Questions

We have synthesized evidence in the published literature to address these Key Questions:

- Key Question 1: Among adolescents and young adults with ASD, what are the effects of available interventions on the core symptoms of ASD?
- Key Question 2: Among adolescents and young adults with ASD, what are the effects of available interventions on common medical and mental health comorbidities (e.g., epilepsy, sleep disorders, motor impairments, obesity, depression, anxiety, acute and episodic aggression, attention deficit hyperactivity disorder, etc.)?
- Key Question 3: Among adolescents and young adults with ASD, what are the effects of available interventions on functional behavior, attainment of goals toward independence, educational attainment, occupational/vocational attainment, life satisfaction, access to health and other services, legal outcomes, and social outcomes?
- Key Question 4: Among adolescents and young adults with ASD, what is the effectiveness of interventions designed to support the transitioning process, specifically to affect attainment of goals toward independence, educational attainment, occupational/vocational attainment, life satisfaction, access to health and other services, legal outcomes, and social outcomes?
- Key Question 5: Among adolescents and young adults with ASD, what harms are associated with available interventions? Harms are defined by the Effective Health Care Program as all possible adverse consequences of an intervention, including adverse events.
- Key Question 6: What are the effects of interventions on family outcomes?

## Organization of This Evidence Report

The Methods section describes our processes including our search strategy, inclusion and exclusion criteria, approach to review of abstracts and full publications, and our method for extraction of data into evidence tables and compiling evidence. We also describe our approach to grading of the quality of the literature and to evaluating the strength of the body of evidence.

The Results section presents the findings of the evidence report, synthesizing them by category of intervention, Key Question, and outcomes reported. We report the number and type of studies identified, and we differentiate between total numbers of publications and unique studies. The final section of the report discusses key findings and expands on methodologic considerations relevant to each Key Question. We also outline the current state of the literature and challenges for future research in ASD in the target age range.

The report includes a number of appendixes to provide further detail on our methods and the studies assessed. The appendixes are as follows—

- Appendix A. Exact Search Strings and Results
- Appendix B. Categorization of Study Designs
- Appendix C. Sample Data Extraction Forms
- Appendix D. Evidence Tables
- Appendix E. Quality Assessment Form
- Appendix F. Excluded Studies
- Appendix G. Quality of the Literature

We also include a list of abbreviations and acronyms at the end of the report.

## Uses of This Report

This evidence report addresses the Key Questions outlined previously using methods described in the report to conduct a systematic review of published literature. We anticipate that the report will be of value to clinicians who treat individuals with ASD, including pediatricians, psychologists, psychiatrists, allied health professionals, and other clinicians who provide care for ASD. The report itself is not a guideline. It is a review of evidence that other groups and individuals can use in developing guidelines or treatment decisions, but we assume that those decisions would be made with other considerations as well, including an individual’s diagnosis, severity of ASD symptoms, concomitant conditions, and ability to transition to more independent functioning.

In addition, this review will be of use to the National Institutes of Health, Centers for Medicare & Medicaid Services, and the Health Resources and Services Administration–all of which have offices or bureaus devoted to developmental issues. This report can bring practitioners up to date about the current state of evidence, and it provides an assessment of the quality of studies that aim to determine the outcomes of therapeutic options for the management of ASD. It will be of interest to individuals affected by ASD and their families because of the high prevalence of ASD, significant personal costs associated with it, and the recurring need for individuals with ASD, their families, and their health care providers to make the best possible decisions among numerous options.

Researchers can obtain a concise analysis of the current state of knowledge in this field. They will be poised to pursue further investigations that are needed to understand best approaches to therapies for adolescents and young adults with ASD.