# Peer Reviewers

Somer L. Bishop, Ph.D.

Cincinnati Children’s Hospital

Cincinnati, OH

Edwin H. Cook, Jr., M.D.

University of Illinois, Chicago

Chicago, IL

Patricia Howlin, Ph.D.

Institute of Psychiatry

London, United Kingdom

Doris Lotz, M.D.

New Hampshire Department of Health and Human Services

Concord, NH

Gary Mesibov, Ph.D.

University of North Carolina

Chapel Hill, NC

Jim Perrin, M.D.

Massachusetts General Hospital

Boston, MA

Lawrence Scahill, Ph.D.

Yale University

New Haven, CT

Tristram Smith, Ph.D.

University of Rochester

Rochester, NY

Peter Szatmari, M.D., M.Sc.

McMaster University

Hamilton, Ontario, Canada