# Technical Expert Panel

Somer L. Bishop, Ph.D.

Cincinnati Children’s Hospital

Cincinnati, OH

Daniel Coury, M.D.

Ohio State University

Columbus, OH

Edwin H. Cook, Jr., M.D.

University of Illinois, Chicago

Chicago, IL

Patricia Howlin, Ph.D.

Institute of Psychiatry

London, United Kingdom

Jim Perrin, M.D.

Massachusetts General Hospital

Boston, MA

Peter Szatmari, M.D., M.Sc.

McMaster University

Hamilton, Ontario, Canada