# Key Informants

Somer L. Bishop, Ph.D.

Cincinnati Children’s Hospital

Cincinnati, OH

Edwin H. Cook, Jr., M.D.

University of Illinois, Chicago

Chicago, IL

Jim Perrin, M.D.

Massachusetts General Hospital

Boston, MA

Marcia Mailick Seltzer, Ph.D.

Waisman Center

Madison, WI

Fred R. Volkmar, M.D.

Yale Child Study Center

New Haven, CT