# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project:

Dr. Adeola Davis assisted with reviewing abstracts and full-text articles and data extraction. We appreciate her willingness to take on whatever was asked of her.

Dr. Shanthi Krishnaswami lent her keen eye for detail to data extraction and reviews of abstracts and full text articles. We also appreciate her thoughtful input into methodological discussions.

Ms. Kathy Lee provided helpful assistance in locating articles and preparing materials for meetings.

Ms. Sanura Latham and Ms. Leah Vance assisted with formatting tables and appendices and lent their support to logistical elements of the review.