# Quality of the Literature

Table G-1 Quality of the literature

Author Year | Group Design | Random Assignment | Appropriate Comparison Group | Correct Randomization | Systematic Diagnostic Approach | Clear Sample Characterization | Clear Inclusion/Exclusion Criteria | Attrition Reported | Intervention Fully Described | Treatment Fidelity Monitored | Adherence Measured/Reported | Concomitant Interventions Held Steady/Reported | Outcome Measures Reliable and Valid | Outcome Data Collected From Appropriate Sources | Outcomes Coded Blindly | Appropriate Statistical Analysis | Rating
Laugeson 2011^1^ | + | − | + | − | − | + | + | − | + | + | − | − | + | + | − | + | P
Verhoven 2011^2^ | − | NA | NA | NA | + | + | + | NA | − | − | NA | − | + | + | − | + | P
Garcia-Villamisar 2010^3^ | + | + | + | − | + | + | + | − | + | − | NA | − | + | + | + | + | F
Gentry 2010^4^ | − | NA | NA | NA | − | − | + | + | + | + | + | − | + | + | − | + | P
Greher 2010^5^ | − | NA | NA | NA | − | − | + | NA | + | − | − | − | − | + | − | − | P
Valenti 2010^6^ | − | NA | NA | NA | + | + | + | NA | + | − | NA | − | + | + | − | + | P
Laugeson 2009^7^ | + | + | + | − | − | + | + | + | + | + | NA | + | + | + | − | + | P
Lawer 2009^8^ | − | NA | NA | NA | − | − | + | NA | − | − | NA | − | + | + | − | + | P
Garcia-Villamisar 2007^9^ | + | − | + | NA | + | + | + | − | − | − | NA | − | + | + | − | + | P
Jewell 2007^10^ | − | NA | NA | NA | − | − | + | − | + | NA | NA | − | + | + | − | + | P
Tse 2007^11^ | − | NA | NA | NA | − | − | + | + | + | − | NA | − | + | + | − | + | P
Golan 2006-1^12^ | + | − | + | NA | − | + | + | + | + | − | + | + | + | + | + | + | P
Golan 2006-2^12^ | + | − | + | NA | − | + | − | + | + | − | + | − | + | + | + | + | P
Hellings 2006^13^ | + | + | − | + | + | + | + | + | + | NA | − | + | + | + | + | + | P
Kaplan 2005^14^ | − | NA | NA | NA | − | − | + | − | − | − | NA | − | − | + | − | + | P
Howlin 2005^15^ | − | NA | NA | NA | + | + | + | − | + | + | NA | − | + | + | − | + | P
O’Connor 2004^16^ | + | + | + | − | + | + | + | NA | + | NA | NA | − | + | + | − | + | P
Van Bourgondien 2003^17^ | + | − | + | NA | − | + | − | − | − | − | NA | − | − | + | − | − | P
Garcia-Villamisar 2002^18, 19^ | + | − | + | NA | + | + | − | − | − | − | NA | − | + | + | − | − | P
Remington 2001^20^ | + | + | + | + | + | − | + | + | + | NA | − | + | + | + | − | + | F
Silver 2001^21^ | + | + | + | − | − | + | + | + | + | + | + | − | + | − | + | − | P
Mawhood 1999^22^ | + | − | + | NA | − | + | + | + | + | + | + | − | + | + | − | − | P
McDougle 1998^23^ | − | NA | NA | NA | + | + | + | + | + | NA | − | + | + | + | − | + | P
McDougle 1998^24^ | + | + | + | + | + | + | + | + | + | NA | − | + | + | + | + | + | F
Brodkin 1997^25^ | − | NA | NA | NA | + | + | + | + | + | NA | − | + | + | + | − | + | P
Bebko 1996^26^ | − | NA | NA | NA | + | + | − | + | + | − | NA | − | + | + | − | + | P
McDougle 1996^27^ | + | + | + | − | + | + | + | + | + | NA | − | + | + | + | + | + | F
Willemsen-Swinkels 1995^28^ | + | + | + | − | + | − | + | + | + | NA | − | − | + | + | + | + | F
Eberlin 1993^29^ | − | NA | NA | NA | + | + | + | + | + | + | NA | − | + | + | − | − | P
Cook 1992^30^ | − | NA | NA | NA | + | + | − | + | + | NA | − | − | + | + | − | + | P
Elliott 1991^31^ | + | − | + | NA | + | + | − | − | + | + | NA | − | + | + | − | + | P
Nelson 1980^32^ | + | + | + | − | − | + | + | − | + | − | NA | − | + | + | − | + | P

F=fair; NA=not applicable; P=poor

## References

1 Laugeson EA, Frankel F, Gantman A, et al. Evidence-Based Social Skills Training for Adolescents with Autism Spectrum Disorders: The UCLA PEERS Program. J Autism Dev Disord. 2011. Aug. 20. [pmid: 21858588].
2 Verhoeven EW, Marijnissen N, Berger HJ, et al. Brief Report: Relationship Between Self-Awareness of Real-World Behavior and Treatment Outcome in Autism Spectrum Disorders. J Autism Dev Disord. 2011. Jun. 23. [pmid: 21698498].
3 Garcia-Villamisar DA, Dattilo J. Effects of a leisure programme on quality of life and stress of individuals with ASD. J Intellect Disabil Res. Jul. 2010;54(7):611-9. [pmid: 20500784].
4 Gentry T, Wallace J, Kvarfordt C, et al. Personal digital assistants as cognitive aids for high school students with autism: results of a community-based trial. Journal of Vocational Rehabilitation. 2010;32(2):101-7.
5 Greher GR, Hillier A, Dougherty M, et al. SoundScape: An Interdisciplinary Music Intervention for Adolescents and Young Adults on the Autism Spectrum. International Journal of Education & the Arts. 2010;11(9).
6 Valenti M, Cerbo R, Masedu F, et al. Intensive intervention for children and adolescents with autism in a community setting in Italy: A single-group longitudinal study. Child and Adolescent Psychiatry and Mental Health. 2010;4(1).
7 Laugeson EA, Frankel F, Mogil C, et al. Parent-assisted social skills training to improve friendships in teens with autism spectrum disorders. J Autism Dev Disord. Apr. 2009;39(4):596-606. [pmid: 19015968].
8 Lawer L, Brusilovskiy E, Salzer MS, et al. Use of vocational rehabilitative services among adults with autism. J Autism Dev Disord. Mar. 2009;39(3):487-94. [pmid: 18810627].
9 Garcia-Villamisar D, Hughes C. Supported employment improves cognitive performance in adults with Autism. J Intellect Disabil Res. Feb. 2007;51(Pt 2):142-50. [pmid: 17217478].
10 Jewell JD, Grippi A, Hupp SDA, et al. The effects of a rotating classroom schedule on classroom crisis events in a school for autism. North American Journal of Psychology. 2007;9(1):37-52.
11 Tse J, Strulovitch J, Tagalakis V, et al. Social skills training for adolescents with Asperger syndrome and high-functioning autism. J Autism Dev Disord. Nov. 2007;37(10):1960-8. [pmid: 17216559].
12 Golan O, Baron-Cohen S. Systemizing empathy: teaching adults with Asperger syndrome or high-functioning autism to recognize complex emotions using interactive multimedia. Dev Psychopathol. Spring. 2006;18(2):591-617. [pmid: 16600069].
13 Hellings JA, Zarcone JR, Reese RM, et al. A crossover study of risperidone in children, adolescents and adults with mental retardation. J Autism Dev Disord. Apr. 2006;36(3):401-11. [pmid: 16596465].
14 Kaplan RS, Steele AL. An analysis of music therapy program goals and outcomes for clients with diagnoses on the autism spectrum. J Music Ther. Spring. 2005;42(1):2-19. [pmid: 15839730].
15 Howlin P, Alcock J, Burkin C. An 8 year follow-up of a specialist supported employment service for high-ability adults with autism or Asperger syndrome. Autism. Dec. 2005;9(5):533-49. [pmid: 16287704].
16 O'Connor IM, Klein PD. Exploration of strategies for facilitating the reading comprehension of high-functioning students with autism spectrum disorders. J Autism Dev Disord. Apr. 2004;34(2):115-27. [pmid: 15162931].
17 Van Bourgondien ME, Reichle NC, Schopler E. Effects of a model treatment approach on adults with autism. J Autism Dev Disord. Apr. 2003;33(2):131-40. [pmid: 12757352].
18 García-Villamisar D, Wehman P, Navarro MD. Changes in the quality of autistic people's life that work in supported and sheltered employment. A 5-year follow-up study. Journal of Vocational Rehabilitation. 2002;17(4):309-12.
19 García-Villamisar D, Ross D, Wehman P. Clinical differential analysis of persons with autism in a work setting: A follow-up study. Journal of Vocational Rehabilitation. 2000;14(3):183-5.
20 Remington G, Sloman L, Konstantareas M, et al. Clomipramine versus haloperidol in the treatment of autistic disorder: a double-blind, placebo-controlled, crossover study. J Clin Psychopharmacol. Aug. 2001;21(4):440-4. [pmid: 11476129].
21 Silver M, Oakes P. Evaluation of a new computer intervention to teach people with autism or Asperger syndrome to recognize and predict emotions in others. Autism. Sep. 2001;5(3):299-316. [pmid: 11708589].
22 Mawhood L, Howlin P. The outcome of a supported employment scheme for high-functioning adults with autism or Asperger syndrome. Autism. Sep. 1999;3(3):229-54.
23 McDougle CJ, Brodkin ES, Naylor ST, et al. Sertraline in adults with pervasive developmental disorders: a prospective open-label investigation. J Clin Psychopharmacol. Feb. 1998;18(1):62-6. [pmid: 9472844].
24 McDougle CJ, Holmes JP, Carlson DC, et al. A double-blind, placebo-controlled study of risperidone in adults with autistic disorder and other pervasive developmental disorders. Arch Gen Psychiatry. Jul. 1998;55(7):633-41. [pmid: 9672054].
25 Brodkin ES, McDougle CJ, Naylor ST, et al. Clomipramine in adults with pervasive developmental disorders: a prospective open-label investigation. J Child Adolesc Psychopharmacol. Summer. 1997;7(2):109-21. [pmid: 9334896].
26 Bebko JM, Perry A, Bryson S. Multiple method validation study of facilitated communication: II. Individual differences and subgroup results. J Autism Dev Disord. Feb. 1996;26(1):19-42. [pmid: 8819769].
27 McDougle CJ, Naylor ST, Cohen DJ, et al. A double-blind, placebo-controlled study of fluvoxamine in adults with autistic disorder. Arch Gen Psychiatry. Nov. 1996;53(11):1001-8. [pmid: 8911223].
28 Willemsen-Swinkels SH, Buitelaar JK, Nijhof GJ, et al. Failure of naltrexone hydrochloride to reduce self-injurious and autistic behavior in mentally retarded adults. Double-blind placebo-controlled studies. Arch Gen Psychiatry. Sep. 1995;52(9):766-73. [pmid: 7654128].
29 Eberlin M, McConnachie G, Ibel S, et al. Facilitated communication: a failure to replicate the phenomenon. J Autism Dev Disord. Sep. 1993;23(3):507-30. [pmid: 8226584].
30 Cook EH, Rowlett R, Jaselskis C, et al. Fluoxetine treatment of children and adults with autistic disorder and mental retardation. Journal of the American Academy of Child & Adolescent Psychiatry. Jul. 1992;31(4):739-45. [pmid: 1644739].
31 Elliott RO Jr, Hall K, Soper HV. Analog language teaching versus natural language teaching: generalization and retention of language learning for adults with autism and mental retardation. J Autism Dev Disord. Dec. 1991;21(4):433-47. [pmid: 1778959].
32 Nelson DL, Gergenti E, Hollander AC. Extra prompts versus no extra prompts in self-care training of autistic children and adolescents. J Autism Dev Disord. Sep. 1980;10(3):311-21. [pmid: 6927657].