# Excluded Studies

Reasons for exclusion

X-1 Ineligible population

X-2 Not original research

X-3 Ineligible study size

X-4 Does not address key questions/Not an intervention study

X-5 Not published in English

X-6 Does not contain extractable data

X-7 Unable to obtain full text

1 What is a reasonable cost of appropriate education?. J Autism Dev Disord. Dec. 1980;10(4):459-72. X-1, X-2, X-3, X-4. [pmid: 6821494].
2 Sex education and sexual awareness building for autistic children and youth: some viewpoints and considerations. J Autism Dev Disord. Jun. 1985;15(2):213-27. X-, X-2, X-3, X-4. [pmid: 3997748].
3 Treatment of destructive behaviors in persons with developmental disabilities. J Autism Dev Disord. Sep. 1990;20(3):403-29. X-2, X-3. [pmid: 2101592].
4 Community care: suffering acts of omission. Nurs Stand. Jun. 17–23. 1992;6(39):50-1. X-4. [pmid: 1642990].
5 Position of the American Dietetic Association: nutrition in comprehensive program planning for persons with developmental disabilities. J Am Diet Assoc. May. 1992;92(5):613-5. X-1, X-2, X-3, X-4. [pmid: 1374088].
6 Three perspectives of facilitated communication: unexpected literacy, clever Hans, or enigma?. Top Lang Disord. Aug. 1992;12(4):60-8. X-1, X-2, X-3, X-4.
7 Auditory integration training. ASHA. Nov. 1994;36(11):55-8. X-1, X-2, X-3, X-4. [pmid: 7529024].
8 Auditory integration training and facilitated communication for autism American Academy of Pediatrics Committee on Children with Disabilities. Pediatrics. Aug. 1998;102(2 Pt 1):431-3. X-2, X-4. [pmid: 9685446].
9 MMR vaccine coverage shows signs of recovery. Commun Dis Rep CDR Wkly. Sep. 24. 1999;9(39):345. X-2, X-4. [pmid: 10510563].
10 Significant achievement award. A comprehensive program for treating profoundly autistic children--Center for Autistic Children, Philadelphia. Psychiatr Serv. Nov. 2000;51(11):1439-40. X-2. [pmid: 11058194].
11 American Academy of Pediatrics: counseling families who choose complementary and alternative medicine for their child with chronic illness or disability. Committee on Children With Disabilities. Pediatrics. Mar. 2001;107(3):598-601. X-2, X-4. [pmid: 11230608].
12 Autism and Lovaas treatment: a systematic review of effectiveness evidence. Int J Technol Assess Health Care. Spring. 2001;17(2):252. X-2, X-4. [pmid: 11446138].
13 JAMA patient page. Autistic disorder. JAMA. Apr. 4. 2001;285(13):1798. X-2. [pmid: 11302153].
14 Technical report: the pediatrician’s role in the diagnosis and management of autistic spectrum disorder in children. Pediatrics. May. 2001;107(5):E85. X-2, X-4. [pmid: 11331735].
15 Science finds no link between MMR vaccine and autism. Mich Med. Sep–Oct. 2002;101(5):37. X-2, X-4. [pmid: 12645252].
16 Autism: neural basis and treatment possibilities. Symposium proceedings. London, United Kingdom. 18–20 June 2002. Novartis Found Symp. 2003;251:1-310. [pmid: 14986681]. X-2, X-4.
17 MMR vaccine--how effective and how safe?. Drug Ther Bull. Apr. 2003;41(4):25-9. X-2, X-4. [pmid: 12724845].
18 Ziprasidone may help treat behavior problems associated with autism Brown University. Child Adolesc Psychopharmacology Update. 2003;5(1):1. X-1, X-3, X-4.
19 This is slow advocacy—not like the advocacy where our partners are able to tell us what they want Ment Health Today. 2004 Dec–2005 Jan:22 15657999 X-1, X-3, X-4
20 Global Advisory Committee on Vaccine Safety. 2–3 December 2004. Wkly Epidemiol Rec. Jan. 7. 2005;80(1):3-7. [pmid: 15673064]. X-2, X-4.
21 Randomized, controlled, crossover trial of methylphenidate in pervasive developmental disorders with hyperactivity. Arch Gen Psychiatry. Nov. 2005;62(11):1266-74. X-1, X-3. [pmid: 16275814].
22 Risperidone treatment of autistic disorder: longer-term benefits and blinded discontinuation after 6 months. Am J Psychiatry. Jul. 2005;162(7):1361-9. X-1, X-3. [pmid: 15994720].
23 Background and methodological approach. Monographs of the Society for Research in Child Development. 2006;71(2):29-47. X-1, X-2, X-3, X-4.
24 Parent interviews. Monogr Soc Res Child Dev. 2006;71(2):48-74. X-1, X-2, X-3, X-4.
25 Describing pride and guilt. Monogr Soc Res Child Dev. 2006;71(2):75-93. X-1, X-3, X-4.
26 Risperidone: new indication Behavioural disorders in children with autism or mental disabilities: no progress. Prescrire Int. Apr. 2006;15(82):43-5. X-2, X-4. [pmid: 16602211].
27 Manifesting pride, guilt, and embarrassment/coyness. Monogr Soc Res Child Dev. 2006;71(2):94-112. X-1, X-3, X-4.
28 Self-consciousness revisited. Monogr Soc Res Child Dev. 2006;71(2):113-27. X-1, X-2, X-3, X-4.
29 PeDIATRICS electronic pages. Pediatrics. 2007;119(1):129-49. X-1, X-2, X-3, X-4.
30 Bibliography. Current world literature. Developmental disorders. Curr Opin Neurol. Apr. 2008;21(2):202-13. X-2, X-4. [pmid: 18317281].
31 The right stuff: sometimes you find the perfect job and sometimes it finds you. Technology & Learning. Oct. 2008;29(3):50. X-1, X-2, X-3, X-4.
32 Inter-agency working. Unlock the full spectrum of care. Health Serv J. Feb. 5. 2009;119(6142):24-5. X-2. [pmid: 19326517].
33 Special report: aCGH for the genetic evaluation of patients with developmental delay/mental retardation or autism spectrum disorder. Technol Eval Cent Asses Program Exec Summ. Apr. 2009;23(10):1-5. X-1, X-2, X-3, X-4. [pmid: 19824216].
34 Special report: early intensive behavioral intervention based on applied behavior analysis among children with autism spectrum disorders. Technol Eval Cent Asses Program Exec Summ. Feb. 2009;23(9):1-5. X-2, X-4. [pmid: 19297806].
35 What is Asperger syndrome?. J Pract Nurs. Summer. 2009;59(2):25. X-2, X-4. [pmid: 19719004].
36 What is autism?. J Pract Nurs. Summer. 2009;59(2):22-4. X-2, X-4. [pmid: 19719002].
37 Current world literature. Curr Opin Neurol. Apr. 2010;23(2):194-201. X-1, X-2, X-3, X-4. [pmid: 20216346].
38 Effectiveness of group cognitive-behavioural treatment for men with intellectual disabilities at risk of sexual offending. J Appl Res Intellect Disabil. Nov. 2010;23(6):537-51. X-1, X-3, X-4.
39 Massachusetts & New Hampshire. Insurance; autism spectrum disorders. Ment Phys Disabil Law Rep. Sep–Oct. 2010;34(5):812. X-1, X-2, X-3, X-4. [pmid: 21197720].
40 Fear and its consequences. Sci Am. Feb. 2011;304(2):14. X-2, X-3. [pmid: 21319529].
41 Abbey D. Helping families find the best evidence: CAM therapies for autism spectrum disorders and Asperger’s Disorder. J Spec Pediatr Nurs. Jul. 2009;14(3):200-2. X-2, X-4. [pmid: 19614829].
42 Abelson AG. The development of gender identity in the autistic child. Child Care Health Dev. Nov–Dec. 1981;7(6):347-56. X-1, X-3, X-4. [pmid: 7326841].
43 Able-Boone H, Crais ER, Downing K. Preparation of early intervention practitioners for working with young children with low incidence disabilities. Teach Educ Spec Educ. Win. 2003;26(1):79-82. X-1, X-4.
44 Ackland MJ, Wade RW. Health status of Victorian special school children. J Paediatr Child Health. Oct. 1995;31(5):423-7. X-4. [pmid: 8554863].
45 Acuda SW. Practical therapeutics the management of child psychiatric disorders. East Afr Med J. Jan. 1982;59(1):6-10. X-1, X-2, X-3, X-4. [pmid: 7117180].
46 Adamek L, Nichols S, Tetenbaum SP, et al. Individual temperament and problem behavior in children with autism spectrum disorders. Focus Autism Other Dev Disabil. Sep. 2011;26(3):173-83. X-1, X-3, X-4.
47 Adamo SMG. An adolescent and his imaginary companions: From quasi-delusional constructs to creative imagination. J Child Psychother. Nov. 2004;30(3):275-95. X-3.
48 Adamo SMG. On not being able to enter Noah’s Ark. J Child Psychother. Apr. 2010;36(1):48-60. X-3.
49 Adams C, Lloyd J, Aldred C, et al. Exploring the effects of communication intervention for developmental pragmatic language impairments: a signal-generation study. Int J Lang Commun Disord. Jan–Feb. 2006;41(1):41-65. X-1, X-3, X-4. [pmid: 16272002].
50 Adams JB, Baral M, Geis E, et al. Safety and efficacy of oral DMSA therapy for children with autism spectrum disorders: Part A--medical results. BMC Clin Pharmacol. 2009;9:16. X-1, X-2, X-3, X-4. [pmid: 19852789].
51 Adams JB, Baral M, Geis E, et al. Safety and efficacy of oral DMSA therapy for children with autism spectrum disorders: part B - behavioral results. BMC Clin Pharmacol. 2009;9:17. X-1, X-2, X-3, X-4. [pmid: 19852790].
52 Adams JB, George F, Audhya T. Abnormally high plasma levels of vitamin B6 in children with autism not taking supplements compared to controls not taking supplements. J Altern Complement Med. Jan–Feb. 2006;12(1):59-63. X-1, X-3, X-4. [pmid: 16494569].
53 Adams JB, Holloway C. Pilot study of a moderate dose multivitamin/mineral supplement for children with autistic spectrum disorder. J Altern Complement Med. 2004;10(6):1033-9. X-1, X-3, X-4. [pmid: 15673999].
54 Adams JB, Johansen LJ, Powell LD, et al. Gastrointestinal flora and gastrointestinal status in children with autism—comparisons to typical children and correlation with autism severity. BMC Gastroenterol. 2011;11:22. X-1, X-3, X-4. [pmid: 21410934].
55 Adams JB, Romdalvik J, Ramanujam VM, et al. Mercury, lead, and zinc in baby teeth of children with autism versus controls. J Toxicol Environ Health A. Jun. 2007;70(12):1046-51. X-4. [pmid: 17497416].
56 Adams L, Conn S. Nutrition and its relationship to autism. Focus Autism Other Dev Disabil. Spr. 1997;12(1):53-8. X-2, X-4.
57 Adams L, Gouvousis A, VanLue M, et al. Social story intervention: improving communication skills in a child with an autism spectrum disorder. Focus Autism Other Dev Disabil. Jun. 2004;19(2):87-94. X-1, X-2, X-3, X-4.
58 Adams SJ, Burton N, Cutress A, et al. Development of double blind gluten and casein free test foods for use in an autism dietary trial... Selected abstracts from the British Dietetic Association Conference 2008. J Hum Nutr Diet. 2008;21(4):374. X-1, X-2, X-3, X-4.
59 Adamson A, O’Hare A, Graham C. Impairments in sensory modulation in children with autistic spectrum disorder. Br J Occup Ther. Aug. 2006;69(8):357-64. X-4.
60 Adamson LB, Bakeman R, Deckner DF, et al. Joint engagement and the emergence of language in children with autism and Down syndrome. J Autism Dev Disord. Jan. 2009;39(1):84-96. X-1, X-3, X-4. [pmid: 18581223].
61 Adcock J, Cuvo AJ. Enhancing learning for children with autism spectrum disorders in regular education by instructional modifications. Res Autism Spectr Disord. Apr–Jun. 2009;3(2):319-28. X-1, X-3, X-4.
62 Addison L, Lerman DC. Descriptive analysis of teachers’ responses to problem behavior following training. J Appl Behav Anal. Sum. 2009;42(2):485-90. X-4. [pmid: 19949540].
63 Adelinis JD, Hagopian LP. The use of symmetrical “do” and “don’t” requests to interrupt ongoing activities. J Appl Behav Anal. Win. 1999;32(4):519-23. X-3. [pmid: 10641305].
64 Adelinis JD, Piazza CC, Goh HL. Treatment of multiply controlled destructive behavior with food reinforcement. J Appl Behav Anal. Spr. 2001;34(1):97-100. X-3. [pmid: 11317997].
65 Adreon D, Stella J. Transition to middle and high school: increasing the success of students with Asperger syndrome. Interv School Clinic. May. 2001;36(5):266-71. X-1, X-2, X-3, X-4.
66 Adrien JL, Faure M, Perrot A, et al. Autism and family home movies: preliminary findings. J Autism Dev Disord. Mar. 1991;21(1):43-9. X-4. [pmid: 2037548].
67 Adrien JL, Martineau J, Barthelemy C, et al. Disorders of regulation of cognitive activity in autistic children. J Autism Dev Disord. Jun. 1995;25(3):249-63. X-4. [pmid: 7559291].
68 Adrien JL, Rossignol-Deletang N, Martineau J, et al. Regulation of cognitive activity and early communication development in young autistic, mentally retarded, and young normal children. Dev Psychobiol. Sep. 2001;39(2):124-36. X-4. [pmid: 11568882].
69 Afzal MA, Ozoemena LC, O’Hare A, et al. Absence of detectable measles virus genome sequence in blood of autistic children who have had their MMR vaccination during the routine childhood immunization schedule of UK. J Med Virol. May. 2006;78(5):623-30. X-4. [pmid: 16555271].
70 Agam Y, Joseph RM, Barton JJ, et al. Reduced cognitive control of response inhibition by the anterior cingulate cortex in autism spectrum disorders. Neuroimage. Aug. 1. 2010;52(1):336-47. X-4. [pmid: 20394829].
71 Agosta E, Graetz JE, Mastropieri MA, et al. Teacher-researcher partnerships to improve social behavior through social stories. Interv School Clinic. May. 2004;39(5):276-87. X-1, X-3, X-4.
72 Aguilera Jimenez A, Moreno Perez FJ, Rodriguez Ortiz IR. Prevalence estimates of autism spectrum disorder in the school population of Seville, Spain. Br J Dev Disabil. 2007;53(part 2(105)):97-109. X-4.
73 Agyapong V, Migone M, Crosson C, et al. Recognition and management of Asperger’s syndrome: perceptions of primary school teachers. Ir J Psychol Med. Mar. 2010;27(1):6-10. X-1, X-3, X-4.
74 Ahearn WH. Using simultaneous presentation to increase vegetables consumption in a mildly selective child with autism. J Appl Behav Anal. Fal. 2003;36(3):361-5. X-3. [pmid: 14596577].
75 Ahearn WH, Clark KM, DeBar R, et al. On the role of preference in response competition. J Appl Behav Anal. Sum. 2005;38(2):247-50. X-1, X-3. [pmid: 16033172].
76 Ahearn WH, Clark KM, Gardenier NC, et al. Persistence of stereotypic behavior: examining the effects of external reinforcers. J Appl Behav Anal. Winter. 2003;36(4):439-48. X-3. [pmid: 14768664].
77 Ahearn WH, Clark KM, MacDonald RP, et al. Assessing and treating vocal stereotypy in children with autism. J Appl Behav Anal. Summer. 2007;40(2):263-75. X-3. [pmid: 17624067].
78 Ahrens EN, Lerman DC, Kodak T, et al. Further evaluation of response interruption and redirection as treatment for stereotypy. J Appl Behav Anal. 2011;44(1):95-108. X-3. [pmid: 21541130].
79 Ahumada JL. What is a clinical fact? Clinical psychoanalysis as inductive method. Int J Psychoanal. Dec. 1994;75(5–6):949-62. X-2, X-4. [pmid: 7713672].
80 Aiken JM, Salzberg CL. The effects of a sensory extinction procedure on stereotypic sounds of two autistic children. J Autism Dev Disord. Sep. 1984;14(3):291-9. X-1, X-3, X-4. [pmid: 6480547].
81 Akande A. Autism—A case in early childhood: a South African investigation. Early Child Dev Care. Aug. 1999;155:71-8. X-3.
82 Akhondzadeh S, Erfani S, Mohammadi MR, et al. Cyproheptadine in the treatment of autistic disorder: a double-blind placebo-controlled trial. J Clin Pharm Ther. Apr. 2004;29(2):145-50. X-1, X-3, X-4. [pmid: 15068403].
83 Akhondzadeh S, Fallah J, Mohammadi MR, et al. Double-blind placebo-controlled trial of pentoxifylline added to risperidone: effects on aberrant behavior in children with autism. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 1. 2010;34(1):32-6. X-1, X-3, X-4. [pmid: 19772883].
84 Akhondzadeh S, Tajdar H, Mohammadi MR, et al. A double-blind placebo controlled trial of piracetam added to risperidone in patients with autistic disorder. Child Psychiatry Hum Dev. Sep. 2008;39(3):237-45. X-1, X-3, X-4. [pmid: 17929164].
85 Akmanoglu N, Tekin-Iftar E. Teaching children with autism how to respond to the lures of strangers. Autism. Mar. 2011;15(2):205-22. X-1, X-3, X-4. [pmid: 21339247].
86 Akmanoglu-Uludag N, Batu S. Teaching naming relatives to individuals with autism using simultaneous prompting. Educ Train Dev Disabil. Dec. 2005;40(4):401-10. X-1, X-3, X-4.
87 Akshoomoff N, Stahmer AC, Corsello C, et al. What happens next? Follow-up from the children’s toddler school program. J Posit Behav Interv. Oct. 2010;12(4):245-53. X-1, X-3, X-4. [pmid: 21113315].
88 Al Anbar NN, Dardennes RM, Prado-Netto A, et al. Treatment choices in autism spectrum disorder: the role of parental illness perceptions. Res Dev Disabil. May–Jun. 2010;31(3):817-28. X-4. [pmid: 20299185].
89 Alamy SS, Jarskog LF, Sheitman BB, et al. Secretin in a patient with treatment-resistant schizophrenia and prominent autistic features. Schizophr Res. Feb. 2004;66(2–3):183-6. X-3. [pmid: 15061252].
90 Alanay Y, Unal F, Turanli G, et al. A multidisciplinary approach to the management of individuals with fragile X syndrome. J Intellect Disabil Res. Feb. 2007;51(Pt 2):151-61. X-4. [pmid: 17217479].
91 Alberti A, Pirrone P, Elia M, et al. Sulphation deficit in “low-functioning” autistic children: a pilot study. Biol Psychiatry. Aug. 1. 1999;46(3):420-4. X-4. [pmid: 10435209].
92 Alcantara J, Alcantara JD. A systematic review of the literature on the chiropractic care of patients with autism spectrum disorder. Explore (NY). Nov. 2011;7(6):384-90. X-1, X-2, X-3, X-4. [pmid: 22051563].
93 Alcantara PR. Effects of videotape instructional package on purchasing skills of children with autism. Except Child. Sep. 1994;61(1):40-55. X-1, X-3, X-4.
94 Alden NE, Rabbitts A, Rolls JA, et al. Burn injury in patients with early-onset neurological impairments: 2002 ABA paper. J Burn Care Rehabil. Jan–Feb. 2004;25(1):107-11. X-2. [pmid: 14726747].
95 Alderman C. Community care: integration is beautiful. Nurs Stand. Feb. 12–18. 1992;6(21):20-1. X-1, X-2, X-3, X-4. [pmid: 1547111].
96 Alderman C. Inclusion zone. Nurs Stand. Nov. 24–30. 1999;14(10):16-7. X-1, X-2, X-3, X-4. [pmid: 11209321].
97 Aldred C, Green J, Adams C. A new social communication intervention for children with autism: pilot randomised controlled treatment study suggesting effectiveness. J Child Psychol Psychiatry. Nov. 2004;45(8):1420-30. X-1, X-3, X-4. [pmid: 15482502].
98 Aldred C, Pollard C, Adams C. Child’sTalk: for children with autism and pervasive developmental disorder. Int J Lang Commun Disord. 2001;36:469-74. X-2. [pmid: 11340834].
99 Aldred C, Pollard C, Phillips R, et al. Multidisciplinary social communication intervention for children with autism and pervasive developmental disorder: the Child’s Talk project. Educ Child Psychol. 2001;18(2):76-87. X-1, X-2, X-3, X-4.
100 Aldred CR, Green J. Early social communication interventions for autism. Br J Hosp Med (Lond). Mar. 2009;70(3):143-5. X-2. [pmid: 19274002].
101 Alexander RT, Green FN, O’Mahony B, et al. Personality disorders in offenders with intellectual disability: a comparison of clinical, forensic and outcome variables and implications for service provision. J Intellect Disabil Res. Jul. 2010;54(7):650-8. X-1, X-3, X-4. [pmid: 20136682].
102 Alexander RT, Michael DM, Gangadharan SK. The use of risperidone in adults with Asperger syndrome. Br J Dev Disabil. 2004;50(99,Pt2):109-15. X-3.
103 Alfredsson G, Harnryd C, Wiesel FA. Effects of sulpiride and chlorpromazine on autistic and positive psychotic symptoms in schizophrenic patients—relationship to drug concentrations. Psychopharmacology (Berl). 1985;85(1):8-13. X-1, X-3, X-4. [pmid: 3920702].
104 Ali S, Frederickson N. Investigating the evidence base of social stories. Educ Psychol Pract. Dec. 2006;22(4):355-77. X-1, X-2, X-3, X-4.
105 Aljunied M, Frederickson N. Cognitive indicators of different levels of special educational support needs in autism. Res Autism Spectr Disord. Jan–Mar. 2011;5(1):368-76. X-4.
106 Allam H, ElDine NG, Helmy G. Scalp acupuncture effect on language development in children with autism: a pilot study. J Altern Complement Med. Mar. 2008;14(2):109-14. X-1, X-3, X-4. [pmid: 18315511].
107 Allen D, Evans C, Hider A, et al. Offending behaviour in adults with Asperger syndrome. J Autism Dev Disord. Apr. 2008;38(4):748-58. X-1, X-3, X-4. [pmid: 17805955].
108 Allen DA, Affleck G, McQueeney M, et al. Validation of the parent behavior progression in an early intervention program. Ment Retard. Aug. 1982;20(4):159-63. X-1, X-3, X-4. [pmid: 7144556].
109 Allen DA, Mendelson L. Parent, child, and professional: meeting the needs of young autistic children and their families in a multidisciplinary therapeutic nursery model. Psychoanal Inq. Special Issue: Autistic spectrum disorders and psychoanalytic ideas: Reassessing the fit. 2000;20(5):704-31. X-1, X-3, X-4.
110 Allen DG, Lowe K, Moore K, et al. Predictors, costs and characteristics of out of area placement for people with intellectual disability and challenging behaviour. J Intellect Disabil Res. Jun. 2007;51(Pt. 6):409-16. X-1, X-3, X-4. [pmid: 17493024].
111 Allen K. Managing Prader-Willi syndrome in families: an embodied exploration. Soc Sci Med. Feb. 2011;72(4):460-8. X-1, X-2, X-3, X-4. [pmid: 21216515].
112 Allen KD, Wallace DP, Greene DJ, et al. Community-based vocational instruction using videotaped modeling for young adults with Autism Spectrum Disorders performing in air-inflated mascots. Focus Autism Other Dev Disabil. Sep. 2010;25(3):186-92. X-3, X-4.
113 Allen KD, Wallace DP, Renes D, et al. Use of video modeling to teach vocational skills to adolescents and young adults with autism spectrum disorders. Educ Treat Children. Special Issue: Using video-based interventions with individuals with autism spectrum disorders. Aug. 2010;33(3):339-49. X-3.
114 Allgood N. Parents’ perceptions of family-based group music therapy for children with autism spectrum disorders. Music Ther Perspect. 2005;23(2):92-9. X-2.
115 Allik H, Larsson JO, Smedje H. Insomnia in school-age children with Asperger syndrome or high-functioning autism. BMC Psychiatry. 2006;6:18. X-1, X-3, X-4. [pmid: 16646974].
116 Allison DB, Basile VC, MacDonald RB. Brief report: comparative effects of antecedent exercise and lorazepam on the aggressive behavior of an autistic man. J Autism Dev Disord. Mar. 1991;21(1):89-94. X-3. [pmid: 2037553].
117 Alonim H. The Mifne Method—ISRAEL: Early intervention in the treatment of autism/PDD: A therapeutic programme for the nuclear family and their child. J Child Adolesc Ment Health. 2004;16(1):39-43. X-2.
118 Al-Shammari Z. Special education teachers’ attitudes toward autistic students in the autism school in the state of Kuwait: a case study. J Instr Psychol. Sep. 2006;33(3):170-8. X-4.
119 Al-Shammari Z, Daniel C, Faulkner P, et al. Improving inappropriate social behavior of autistic students, using the LISTEN Intervention Strategy. J Instr Psychol. Dec. 2010;37(4):286-94. X-2, X-3.
120 Althaus M, Renk M, Minderaa RB, et al. Initiatory and reactive behaviour in young children with a pervasive developmental disorder: two independent components in communicative behaviour for distinguishing subgroups. Eur Child Adolesc Psychiatry. 1994;3(4):242-54. X-1, X-4.
121 Altschuler EL. Play with online virtual pets as a method to improve mirror neuron and real world functioning in autistic children. Med Hypotheses. 2008;70(4):748-9. X-2, X-4. [pmid: 17826922].
122 Aluri U, Karanth P. Rehabilitation facilities available for children with autism/PDD in Bangalore City -- a survey. Asia Pacific Disabil Rehabil J. 2002;13(2):115-24. X-4.
123 Alvarez A. The problem of neutrality: some reflections on the psychoanalytic attitude in the treatment of borderline and psychotic children. J of Child Psychother. 1985;11(1):87-103. X-1, X-3, X-4.
124 Alvarez A. Making the thought thinkable: on introjection and projection. Psychoanal Inq. 1993;13(1):103-22. X-2, X-4.
125 Alvarez A. Levels of analytic work and levels of pathology: the work of calibration. Int J Psychoanal. Aug. 2010;91(4):859-78. X-2, X-4. [pmid: 20840643].
126 Alvin J. A research project–Martin. Nordic J of Music Ther. 2000;9(1):50-9. X-1, X-3, X-4.
127 Alwell M, Cobb B. Social and communicative interventions and transition outcomes for youth with disabilities: a systematic review. Career Dev Exceptional Indiv. 2009;32(2):94-107. X-1, X-2.
128 Aly H. Preemptive strike in the war on pain: is it a safe strategy for our vulnerable infants?. Pediatrics. Nov. 2004;114(5):1335-7. X-2. [pmid: 15520116].
129 Aman MG, Armstrong SA. Regarding secretin for treating autistic disorder. J Autism Dev Disord. Feb. 2000;30(1):71-2. X-1, X-3, X-4. [pmid: 10819123].
130 Aman MG, Arnold LE, McDougle CJ, et al. Acute and long-term safety and tolerability of risperidone in children with autism. J Child Adolesc Psychopharmacol. Dec. 2005;15(6):869-84. X-1, X-3. [pmid: 16379507].
131 Aman MG, et al. Fenfluramine and methylphenidate in children with mental retardation and attention deficit hyperactivity disorder: Laboratory effects. J Autism Dev Disord. Sep. 1993;23(3):491-506. X-1, X-3, X-4. [pmid: 8226583].
132 Aman MG, Hollway JA, McDougle CJ, et al. Cognitive effects of risperidone in children with autism and irritable behavior. J Child Adolesc Psychopharmacol. Jun. 2008;18(3):227-36. X-1, X-3, X-4. [pmid: 18582177].
133 Aman MG, Kasper W, Manos G, et al. Line-item analysis of the Aberrant Behavior Checklist: results from two studies of aripiprazole in the treatment of irritability associated with autistic disorder. J Child Adolesc Psychopharmacol. Oct. 2010;20(5):415-22. X-1, X-3, X-4. [pmid: 20973712].
134 Aman MG, Lam KS, Collier-Crespin A. Prevalence and patterns of use of psychoactive medicines among individuals with autism in the Autism Society of Ohio. J Autism Dev Disord. Oct. 2003;33(5):527-34. X-4. [pmid: 14594332].
135 Aman MG, Lam KS, Van Bourgondien ME. Medication patterns in patients with autism: temporal, regional, and demographic influences. J Child Adolesc Psychopharmacol. Feb. 2005;15(1):116-26. X-1, X-3, X-4. [pmid: 15741793].
136 Aman MG, Langworthy KS. Pharmacotherapy for hyperactivity in children with autism and other pervasive developmental disorders. J Autism Dev Disord. Oct. 2000;30(5):451-59. X-2. [pmid: 11098883].
137 Aman MG, McDougle CJ, Scahill L, et al. Medication and parent training in children with pervasive developmental disorders and serious behavior problems: results from a randomized clinical trial. J Amer Acad Child Adolesc Psychiatry. Dec. 2009;48(12):1143-54. X-1, X-3, X-4. [pmid: 19858761].
138 Aman MG, Turbott SH. Prediction of clinical response in children taking methylphenidate. J Autism Dev Disord. Jun. 1991;21(2):211-28. X-1, X-3, X-4. [pmid: 1864828].
139 Aman MG, Van Bourgondien ME, Wolford PL, et al. Psychotropic and anticonvulsant drugs in subjects with autism: prevalence and patterns of use. J Am Acad Child Adolesc Psychiatry. Dec. 1995;34(12):1672-81. X-4. [pmid: 8543539].
140 Amano K, Nomura Y, Segawa M, et al. Mutational analysis of the MECP2 gene in Japanese patients with Rett syndrome. J Hum Genet. 2000;45(4):231-6. X-4. [pmid: 10944854].
141 Amato J Jr, Barrow M, Domingo R. Symbolic play behavior in very young verbal and nonverbal children with autism. Infant-Toddler Interv. Jun. 1999;9(2):185-94. X-1, X-3, X-4.
142 Amato Jr, Slavin DA. preliminary investigation of oromotor function in young verbal and nonverbal children with autism. Infant-Toddler Interv. 1998;8(2):175-84. X-1, X-3, X-4.
143 Ambrosini PJ, Elia J, Rynn MA. 49th Annual meeting of the American Academy of Child & Adolescent Psychiatry. 22–27 October 2002. San Francisco, CA, USA. Expert Opin Pharmacother. Apr. 2003;4(4):591-4. [pmid: 12667122]. X-2, X-4.
144 Ames CS, Jarrold C. Identifying symbolic relationships in autism spectrum disorders: a deficit in the identification of temporal co-occurrence?. J Autism Dev Disord. 2009;39(12):1723-34. X-4. [pmid: 19593646].
145 Amir N, Gross-Tsur V. Paradoxical normalization in childhood epilepsy. Epilepsia. Sep–Oct. 1994;35(5):1060-4. X-4. [pmid: 7925152].
146 Amminger GP, Berger GE, Schafer MR, et al. Omega-3 fatty acids supplementation in children with autism: a double-blind randomized, placebo-controlled pilot study. Biol Psychiatry. Feb. 15. 2007;61(4):551-3. X-3. [pmid: 16920077].
147 Anagnostou E, Hansen R. Medical treatment overview: traditional and novel psycho-pharmacological and complementary and alternative medications. Curr Opin Pediatr. Dec. 2011;23(6):621-7. X-1, X-2, X-3, X-4. [pmid: 22001766].
148 Anan RM, Warner LJ, McGillivary JE, et al. Group Intensive Family Training (GIFT) for preschoolers with autism spectrum disorders. Behav Interv. Jul. 2008;23(3):165-80. X-1, X-3, X-4.
149 Anastasiou D, Kauffman JM. A social constructionist approach to disability: implications for special education. Except Child. Spr. 2011;77(3):367-84. X-1, X-2, X-3, X-4.
150 Anckarsater H, Nilsson T, Saury JM, et al. Autism spectrum disorders in institutionalized subjects. Nord J Psychiatry. 2008;62(2):160-7. X-4. [pmid: 18569781].
151 Andari E, Duhamel JR, Zalla T, et al. Promoting social behavior with oxytocin in high-functioning autism spectrum disorders. Proc Natl Acad Sci U S A. Mar. 2. 2010;107(9):4389-94. X-3. [pmid: 20160081].
152 Andersen IM, Kaczmarska J, McGrew SG, et al. Melatonin for insomnia in children with autism spectrum disorders. J Child Neurol. May. 2008;23(5):482-5. X-1, X-4. [pmid: 18182647].
153 Anderson A, Moore DW, Bourne T. Functional communication and other concomitant behavior change following PECS training: a case study. Behav Change. Aug. 2007;24(3):173-81. X-1, X-3, X-4.
154 Anderson A, Moore DW, Godfrey R, et al. Social skills assessment of children with autism in free-play situations. Autism. Dec. 2004;8(4):369-85. X-1, X-3, X-4. [pmid: 15556957].
155 Anderson DK, Oti RS, Lord C, et al. Patterns of growth in adaptive social abilities among children with autism spectrum disorders. J Abnormal Child Psychol. Oct. 2009;37(7):1019-34. X-4.
156 Anderson GM, Freedman DX, Cohen DJ, et al. Whole blood serotonin in autistic and normal subjects. J Child Psychol Psychiatry. Nov. 1987;28(6):885-900. X-4. [pmid: 3436995].
157 Anderson GM, Scahill L, McCracken JT, et al. Effects of short- and long-term risperidone treatment on prolactin levels in children with autism. Biol Psychiatry. Feb. 15. 2007;61(4):545-50. X-1, X-3, X-4. [pmid: 16730335].
158 Anderson J, Le DD. Abatement of intractable vocal stereotypy using an overcorrection procedure. Behav Interv. Apr. 2011;26(2):134-46. X-1, X-3, X-4.
159 Anderson LT, Campbell M, Adams P, et al. The effects of haloperidol on discrimination learning and behavioral symptoms in autistic children. J Autism Dev Disord. Jun. 1989;19(2):227-39. X-1, X-3, X-4. [pmid: 2663834].
160 Anderson LT, Campbell M, Grega DM, et al. Haloperidol in the treatment of infantile autism: effects on learning and behavioral symptoms. Am J Psychiatry. Oct. 1984;141(10):1195-202. X-1, X-3, X-4. [pmid: 6385731].
161 Anderson LT, Ernst M. Self-injury in Lesch-Nyhan disease. J Autism Dev Disord. Feb. 1994;24(1):67-81. X-1, X-3, X-4. [pmid: 8188575].
162 Anderson S, Hanson R, Malecha M, et al. The effectiveness of naltrexone in treating task attending, aggression, self-injury and stereotypic mannerisms of six young males with autism or pervasive developmental disorders. J Dev Phys Disabil. Sep. 1997;9(3):211-42. X-3.
163 Anderson SR, Avery DL, DiPietro EK, et al. Intensive home-based early intervention with autistic children. Educ Treat Children. Special Issue: New developments in the treatment of persons exhibiting autism and severe behavior disorders. Nov. 1987;10(4):352-66. X-1, X-3, X-4.
164 Anderson-Hanley C, Tureck K, Schneiderman RL. Autism and exergaming: effects on repetitive behaviors and cognition. Psychol Res Behav Manag. 2011;4:129-37. X-3. [pmid: 22114543].
165 Ando H, Yoshimura I, Wakabayashi S. Effects of age on adaptive behavior levels and academic skill levels in autistic and mentally retarded children. J Autism Dev Disord. Jun. 1980;10(2):173-84. X-1, X-3, X-4. [pmid: 6927685].
166 Andreae MC, Freed GL, Katz SL. Safety concerns regarding combination vaccines. Perspective of select European countries. Hum Vaccin. Jan–Feb. 2005;1(1):1-5. X-2, X-4. [pmid: 17038825].
167 Andrews E, Decker J, Boswell B. From the field. Stimulus prompting of children with autism. Clin Kinesiology. 1998;52(1):12-7. X-1, X-3, X-4.
168 Andrews N, Miller E, Taylor B, et al. Recall bias, MMR, and autism. Arch Dis Child. Dec. 2002;87(6):493-4. X-4. [pmid: 12456546].
169 Anglesea MM, Hoch H, Taylor BA. Reducing rapid eating in teenagers with autism: use of a pager prompt. J Appl Behav Anal. Spring. 2008;41(1):107-11. X-3. [pmid: 18468283].
170 Anson HM, Todd JT, Cassaretto KJ. Replacing overt verbal and gestural prompts with unobtrusive covert tactile prompting for students with autism. Behav Res Methods. Nov. 2008;40(4):1106-10. X-1, X-3, X-4. [pmid: 19001402].
171 Antshel KM, Polacek C, McMahon M, et al. Comorbid ADHD and anxiety affect social skills group intervention treatment efficacy in children with autism spectrum disorders. J Dev Behav Pediatr. Jul–Aug. 2011;32(6):439-46. X-1, X-3, X-4. [pmid: 21654508].
172 Aoi T, Takashima H, Takada T, et al. Fragile X chromosome in institutionalized male adults with mental retardation. Keio J Med. Mar. 1989;38(1):36-9. X-1, X-3, X-4. [pmid: 2785613].
173 Apple AL, Billingsley F, Schwartz IS. Effects of video modeling alone and with self-management on compliment-giving behaviors of children with high-functioning ASD. J Posit Behav Interv. Win. 2005;7(1):33-46. X-1, X-3, X-4.
174 Arbelle S, Benjamin J, Golin M, et al. Relation of shyness in grade school children to the genotype for the long form of the serotonin transporter promoter region polymorphism. Am J Psychiatry. Apr. 2003;160(4):671-6. X-4. [pmid: 12668354].
175 Arco L. Improving program outcome with process-based feedback. J Organ Behav Manage. 1997;17(1):37-64. X-1, X-3, X-4.
176 Arco L, Millett R. Maintaining instructional behavior after on-the-job training with process-based performance feedback. Behav Modif. Jul. 1996;20(3):300-20. X-1, X-3, X-4. [pmid: 8779639].
177 Arick JR, Young HE, Falco RA, et al. Designing an outcome study to monitor the progressof students with autism spectrum disorders. Focus Autism Other Dev Disabil. Sum. 2003;18(2):75-87. X-1, X-3, X-4.
178 Arieff Z, Kaur M, Gameeldien H, et al. 5-HTTLPR polymorphism: analysis in South African autistic individuals. Hum Biol. Jun. 2010;82(3):291-300. X-4. [pmid: 20649385].
179 Arnal L, Fazzio D, Martin GL, et al. Instructing university students to conduct discrete-trials teaching with confederates simulating children with autism. Dev Disabil Bull. 2007;35(1–2):131-7. X-4.
180 Arndorfer RE, Miltenberger RG, Woster SH, et al. Home-based descriptive and experimental analysis of problem behaviors in children. Topics Early Child Spec Educ. Spr. 1994;14(1):64-87. X-3.
181 Arnold GL, Hyman SL, Mooney RA, et al. Plasma amino acids profiles in children with autism: potential risk of nutritional deficiencies. J Autism Dev Disord. Aug. 2003;33(4):449-54. X-1, X-3, X-4. [pmid: 12959424].
182 Arnold LE, Aman MG, Cook AM, et al. Atomoxetine for hyperactivity in autism spectrum disorders: placebo-controlled crossover pilot trial. J Am Acad Child Adolesc Psychiatry. Oct. 2006;45(10):1196-205. X-3. [pmid: 17003665].
183 Arnold LE, Farmer C, Kraemer HC, et al. Moderators, mediators, and other predictors of risperidone response in children with autistic disorder and irritability. J Child Adolesc Psychopharmacol. Apr. 2010;20(2):83-93. X-1, X-3, X-4. [pmid: 20415603].
184 Arnold LE, Vitiello B, McDougle C, et al. Parent-defined target symptoms respond to risperidone in RUPP autism study: customer approach to clinical trials. J Am Acad Child Adolesc Psychiatry. Dec. 2003;42(12):1443-50. X-1, X-4. [pmid: 14627879].
185 Arntzen E, Gilde K, Pedersen E. Generalized schedule following in a youth with autism. Scand J Behav Ther. 1998;27(3):135-41. X-3, X-4.
186 Arntzen E, Halstadtro L-B, Halstadtro M. The “silent dog” method: analyzing the impact of self-generated rules when teaching different computer chains to boys with autism. Anal Verbal Behav. 2009;25:51-66. X-3. [pmid: 22477428].
187 Arntzen E, Tønnessen IR, Brouwer G. Reducing aberrant verbal behavior by building a repertoire of rational verbal behavior. Behav Interv. Jul. 2006;21(3):177-93. X-1, X-3, X-4.
188 Arrieta MI, Martinez B, Criado B, et al. Dermatoglyphic analysis of autistic basque children. Am J Med Genet. Jan. 1990;35(1):1-9. X-4. [pmid: 2301457].
189 Arron K, Oliver C, Moss J, et al. The prevalence and phenomenology of self-injurious and aggressive behaviour in genetic syndromes. J Intellect Disabil Res. Feb. 2011;55(2):109-20. X-1, X-3, X-4. [pmid: 20977515].
190 Arthi K, Tamilarasi A. Prediction of autistic disorder using neuro fuzzy system by applying ANN technique. Int J Dev Neurosci. Nov. 2008;26(7):699-704. X-2, X-4. [pmid: 18706991].
191 Arvans RK, LeBlanc LA. Functional assessment and treatment of migraine reports and school absences in an adolescent with Asperger’s disorder. Educ Treat Children. Feb. 2009;32(1):151-66. X-3.
192 Asaro K, Saddler B. Effects of planning instruction on a young writer with Asperger Syndrome. Interv School Clinic. 2009;44(5):268-75. X-3.
193 Asberg J, Sandberg AD. Discourse comprehension intervention for high-functioning students with autism spectrum disorders: preliminary findings from a school-based study. J Res Spec Educ Needs. Jun. 2010;10(2):91-8. INCLUDE, X-3.
194 Ashburner J, Ziviani J, Rodger S. Sensory processing and classroom emotional, behavioral, and educational outcomes in children with autism spectrum disorder. Am J Occup Ther. Sep–Oct. 2008;62(5):564-73. X-1, X-4. [pmid: 18826017].
195 Askalan R, Mackay M, Brian J, et al. Prospective preliminary analysis of the development of autism and epilepsy in children with infantile spasms. J Child Neurol. Mar. 2003;18(3):165-70. X-4. [pmid: 12731640].
196 Asmus JM, Franzese JC, Conroy MA, et al. Clarifying functional analysis outcomes for disruptive behaviors by controlling consequence delivery for stereotypy. School Psych Rev. 2003;32(4):624-30. X-1, X-3, X-4.
197 Association AP. Diagnostic and statistical manual of mental disorders. IV ed. Washington DC. American Psychiatric Association. 2000.
198 Aston-Jones G, Rajkowski J, Cohen J. Locus coeruleus and regulation of behavioral flexibility and attention. Prog Brain Res. 2000;126:165-82. X-2. [pmid: 11105646].
199 Athens ES, Vollmer TR. An investigation of differential reinforcement of alternative behavior without extinction. J Appl Behav Anal. Winter. 2010;43(4):569-89. X-1, X-3, X-4. [pmid: 21541145].
200 Athens ES, Vollmer TR, Sloman KN, et al. An analysis of vocal stereotypy and therapist fading. J Appl Behav Anal. Sum. 2008;41(2):291-7. X-1, X-3, X-4. [pmid: 18595296].
201 Atkinson RP, Jenson WR, Rovner L, et al. Brief report: validation of the autism reinforcer checklist for children. J Autism Dev Disord. Dec. 1984;14(4):429-33. X-3, X-4. [pmid: 6520095].
202 Atladottir HO, Thorsen P, Ostergaard L, et al. Maternal infection requiring hospitalization during pregnancy and autism spectrum disorders. J Autism Dev Disord. Dec. 2010;40(12):1423-30. X-4. [pmid: 20414802].
203 Atladottir HO, Thorsen P, Schendel DE, et al. Association of hospitalization for infection in childhood with diagnosis of autism spectrum disorders: a Danish cohort study. Arch Pediatr Adolesc Med. May. 2010;164(5):470-7. X-4. [pmid: 20439799].
204 Atlas JA. Play in assessment and intervention in the childhood psychoses. Child Psychiatry Hum Dev. Win. 1990;21(2):119-33. X-1, X-3, X-4. [pmid: 2249494].
205 Atlas JA, Gerbino-Rosen G. Differential diagnostic and treatment of an inpatient adolescent showing pervasive developmental disorder and mania. Psychol Rep. Aug. 1995;77(1):207-10. X-3. [pmid: 7501761].
206 Atlas JA, Lapidus LB. Patterns of symbolic expression in subgroups of the childhood psychoses. J Clin Psychol. Mar. 1987;43(2):177-88. X-1. [pmid: 2437158].
207 Attwood T. Unusual behaviours associated with autism. Health Visit. Nov. 1993;66(11):402-3. X-1, X-3, X-4. [pmid: 8276606].
208 August GJ, Raz N, Baird TD. Effects of fenfluramine on behavioral, cognitive, and affective disturbances in autistic children. J Autism Dev Disord. Mar. 1985;15(1):97-107. X-1, X-3, X-4. [pmid: 3884585].
209 August GJ, Raz N, Baird TD. Fenfluramine response in high and low functioning autistic children. J Am Acad Child Adolesc Psychiatry. May. 1987;26(3):342-6. X-1, X-3. [pmid: 3298200].
210 August GJ, Raz N, Papanicolaou AC, et al. Fenfluramine treatment in infantile autism. Neurochemical, electrophysiological, and behavioral effects. J Nerv Ment Dis. Oct. 1984;172(10):604-12. X-3. [pmid: 6384430].
211 Austin DW, Abbott JM, Carbis C. The use of virtual reality hypnosis with two cases of autism spectrum disorder: a feasibility study. Contemporary Hypnosis. 2008;25(2):102-9. X-3.
212 Auxter D, Halloran W, Berry HG, et al. The precarious safety net: supplemental security income and age 18 redeterminations. Focus Autism Dev Disabil. Win. 1999;14(4):194-203. 11. X-1, X-2, X-3, X-4.
213 Auyeung B, Baron-Cohen S, Ashwin E, et al. Fetal testosterone and autistic traits. Br J Psychol. 2009;100(Part 1):1-22. X-1, X-3, X-4. [pmid: 18547459].
214 Avdi E. Negotiating a pathological identity in the clinical dialogue: discourse analysis of a family therapy. Psychol Psychother. Dec. 2005;78(Pt 4):493-511. X-1, X-2, X-3, X-4. [pmid: 16354441].
215 Avino TA, Hutsler JJ. Abnormal cell patterning at the cortical gray-white matter boundary in autism spectrum disorders. Brain Res. Nov. 11. 2010;1360:138-46. X-3, X-4. [pmid: 20816758].
216 Axe JB, Sainato DM. Matrix training of preliteracy skills with preschoolers with autism. J Appl Behav Anal. Winter. 2010;43(4):635-52. X-1, X-3, X-4. [pmid: 21541149].
217 Ayres AJ, Mailloux ZK. Possible pubertal effect on therapeutic gains in an autistic girl. Am J Occup Ther. Aug. 1983;37(8):535-40. X-1, X-3, X-4. [pmid: 6624850].
218 Ayres AJ, Tickle LS. Hyper-responsivity to touch and vestibular stimuli as a predictor of positive response to sensory integration procedures by autistic children. Am J Occup Ther. Jun. 1980;34(6):375-81. X-3. [pmid: 6971048].
219 Ayres KM, Maguire A, McClimon D. Acquisition and generalization of chained tasks taught with computer based video instruction to children with autism. Educ Train Dev Disabil. Dec. 2009;44(4):493-508. X-1, X-3, X-4.
220 Azadi B, Seddigh A, Tehrani-Doost M, et al. Executive dysfunction in treated phenylketonuric patients. Eur Child Adolesc Psychiatry. Jun. 2009;18(6):360-8. X-4. [pmid: 19221856].
221 Azano A, Tuckwiller ED. GPS for the English classroom: understanding executive dysfunction in secondary students with Autism. Teach Except Child. Jul–Aug. 2011;43(6):38-43. X-1, X-2, X-3, X-4.
222 Azrin NH, Besalel VA, Jamner JP, et al. Comparative study of behavioral methods of treating severe self-injury. Behav Resid Treat. Apr. 1988;3(2):119-52. X-3.
223 Azrin NH, Vinas V, Ehle CT. Physical activity as reinforcement for classroom calmness of ADHD children: a preliminary study. Child Fam Behav Ther. Jun. 2007;29(2):1-8. X-1, X-3, X-4.
224 Baas K. Specialty: autism approaches need to be tailored to each person. Pa Nurse. Mar. 2006;61(1):14-5. X-2. [pmid: 16625766].
225 Babel DA, Martin GL, Fazzio D, et al. Assessment of the reliability and validity of the Discrete-Trials Teaching Evaluation Form. Dev Disabil Bull. 2008;36(1–2):67-80. X-1, X-2, X-3, X-4.
226 Baer DM. Quasi-random assignment can be as convincing as random assignment. Am J Ment Retard. Jan. 1993;97(4):373-75. X-1, X-2, X-3, X-4.
227 Baerg KL. Effective communication with autistic children. Rehabil Nurs. Mar–Apr. 1991;16(2):8-90. discussion -3. X-2, X-4. [pmid: 2000468].
228 Bagatell N, Mirigliani G, Patterson C, et al. Effectiveness of therapy ball chairs on classroom participation in children with autism spectrum disorders. Am J Occup Ther. Nov–Dec. 2010;64(6):895-903. X-2, X-4. [pmid: 21218680].
229 Baghdadli A, Pascal C, Grisi S, et al. Risk factors for self-injurious behaviours among 222 young children with autistic disorders. J Intellect Disabil Res. Nov. 2003;47(Pt 8):622-7. X-4. [pmid: 14641810].
230 Baharav E, Darling R. Case report: using an auditory trainer with caregiver video modeling to enhance communication and socialization behaviors in Autism. J Autism Dev Disord. Apr. 2008;38(4):771-5. X-1, X-3, X-4. [pmid: 17710521].
231 Baharav E, Reiser C. Using telepractice in parent training in early autism. Telemed J E Health. Jul–Aug. 2010;16(6):727-31. X-1, X-3, X-4. [pmid: 20583950].
232 Bain SK, Brown KS, Jordan KR. Teacher candidates’ accuracy of beliefs regarding childhood interventions. Teacher Educ. Apr. 2009;44(2):71-89. X-4.
233 Bainbridge N, Myles BS. The use of priming to introduce toilet training to a child with autism. Focus Autism Dev Disabil. Sum. 1999;14(2):106-9. X-1, X-3, X-4.
234 Baird G, Pickles A, Simonoff E, et al. Measles vaccination and antibody response in autism spectrum disorders. Arch Dis Child. Oct. 2008;93(10):832-7. X-4. [pmid: 18252754].
235 Bakare MO, Agomoh AO, Ebigbo PO, et al. Etiological explanation, treatability and preventability of childhood autism: A survey of Nigerian healthcare workers’ opinion. Ann Gen Psychiatry. 2009;8(6). X-4.
236 Bakare MO, Ebigbo PO, Agomoh AO, et al. Knowledge about childhood autism and opinion among healthcare workers on availability of facilities and law caring for the needs and rights of children with childhood autism and other developmental disorders in Nigeria. BMC Pediatr. 2009;9:12. X-4. [pmid: 19216754].
237 Baker DL. Public policy and the shaping of disability: incidence growth in educational Autism. Educ Policy Anal Arch. 2004;12(11). X-2, X-4.
238 Baker DL. Neurodiversity, neurological disability and the public sector: notes on the autism spectrum. Disabil Soc. 2006;21(1):15-29. X-1, X-2, X-3, X-4.
239 Baker DL, Stokes S. Brain politics: aspects of administration in the comparative issue definition of autism-related policy. Public Adm Rev. Jul. 2007;67(4):757-67. X-2, X-4.
240 Baker F, Wigram T, Stott D, et al. Therapeutic songwriting in music therapy, part II: comparing the literature with practice across diverse clinical populations. Nord J Music Ther. 2009;18(1):32-56. X-1, X-3, X-4.
241 Baker LJ, Milner Y. Sensory reinforcement with autistic children. Behav Psychother. Oct. 1985;13(4):328-41. X-3.
242 Baker MJ. Incorporating the thematic ritualistic behaviors of children with autism into games: increasing social play interactions with siblings. J Posit Behav Interv. Spr. 2000;2(2):66-84. X-1, X-3, X-4.
243 Baker MJ, Koegel RL, Koegel LK. Increasing the social behavior of young children with autism using their obsessive behaviors. J Assoc Pers Sev Handicaps. Win. 1998;23(4):300-8. X-1, X-3, X-4.
244 Baker N. Exploring the mental health nurse practitioner scope of practice in youth early psychosis: an anecdotal account. Contemp Nurse. Feb–Mar. 2010;34(2):211-20. X-1, X-2, X-3, X-4. [pmid: 20509805].
245 Baker SD, Lang R, O’Reilly M. Review of video modeling with students with emotional and Behav Disord. Educ Treat Children. Aug. 2009;32(3):403-20. X-2, X-4.
246 Baker SM. Sidney MacDonald Baker, MD: taking a biomedical approach to autism treatment. Interview by Frank Lampe and Suzanne Snyder. Altern Ther Health Med. Nov–Dec. 2008;14(6):60-9. X-2, X-4. [pmid: 19043940].
247 Baker-Ericzen MJ, Brookman-Frazee L, Stahmer A. Stress levels and adaptability in parents of toddlers with and without autism spectrum disorders. Res Pract Persons Severe Disabl. Win. 2005;30(4):194-204. X-1, X-3, X-4.
248 Baker-Ericzén MJ, Stahmer AC, Burns A. Child demographics associated with outcomes in a community-based pivotal response training program. J Posit Behav Interv. Win. 2007;9(1):52-60. X-1, X-3, X-4.
249 Bakken TL, Eilertsen DE, Smeby NA, et al. Effective communication related to psychotic disorganised behaviour in adults with intellectual disability and autism. Vard Nord Utveckl Forsk/Vård i Norden. 2008;28(2):9-13. X-7.
250 Bakken TL, Friis S, Lovoll S, et al. Behavioral disorganization as an indicator of psychosis in adults with intellectual disability and autism. Mental Health Asp Dev Disab. 2007;10(2):37-46. X-4.
251 Bal E, Harden E, Lamb D, et al. Emotion recognition in children with autism spectrum disorders: relations to eye gaze and autonomic state. J Autism Dev Disord. Mar. 2010;40(3):358-70. X-1, X-3, X-4. [pmid: 19885725].
252 Bala J. “Mama stop doing MMMMMMM”: TA in the treatment of autistic children. Transact Anal J. Oct. 1986;16(4):234-9. X-3.
253 Ballaban-Gil K, Rapin I, Tuchman R, et al. Longitudinal examination of the behavioral, language, and social changes in a population of adolescents and young adults with autistic disorder. Pediatr Neurol. Oct. 1996;15(3):217-23. X-4. [pmid: 8916159].
254 Banach M, Iudice J, Conway L, et al. Family support and empowerment: post autism diagnosis support group for parents. Soc Work Groups. Jan–Mar. 33. 2010;2010(1):69-83. X-3, X-4.
255 Banda DR, Copple KS, Koul RK, et al. Video modelling interventions to teach spontaneous requesting using AAC devices to individuals with autism: a preliminary investigation. Disabil Rehabil. 2010;32(16):1364-72. X-3. [pmid: 20465397].
256 Banda DR, Grimmett E, Hart SL. Activity schedules: helping students with autism spectrum disorders in general education classrooms manage transition issues. Teach Except Child. Mar–Apr. 2009;41(4):16-21. X-2.
257 Banda DR, Hart SL, Liu-Gitz L. Impact of training peers and children with autism on social skills during center time activities in inclusive classrooms. Res Autism Spectr Disord. Oct–Dec. 2010;4(4):619-25. X-1, X-3, X-4.
258 Banda DR, Kubina RM Jr. The effects of a high-probability request sequencing technique in enhancing transition behaviors. Educ Treat Children. Aug. 2006;29(3):507-16. X-3.
259 Banda DR, Kubina RM Jr. Increasing academic compliance with mathematics tasks using the high-preference strategy with a student with autism. Prev School Failure. 2010;54(2):81-5. X-3.
260 Banda DR, McAfee JK, Hart SL. Decreasing self-injurious behavior in a student with autism and Tourette Syndrome through positive attention and extinction. Child Family Behav Ther. 2009;31(2):144-56. X-3.
261 Bara BG, Bucciarelli M, Colle L. Communicative abilities in autism: evidence for attentional deficits. Brain Lang. May. 2001;77(2):216-40. X-1, X-4. [pmid: 11300705].
262 Barakova E, Gillessen J, Feijs L. Social training of autistic children with interactive intelligent agents. J Integr Neurosci. Mar. 2009;8(1):23-34. X-1, X-3, X-4. [pmid: 19412978].
263 Baranek GT. Efficacy of sensory and motor interventions for children with autism. J Autism Dev Disord. Oct. 2002;32(5):397-422. X-2. [pmid: 12463517].
264 Baranek GT, Boyd BA, Poe MD, et al. Hyperresponsive sensory patterns in young children with autism, developmental delay, and typical development. Am J Ment Retard. Jul. 2007;112(4):233-45. X-1, X-3, X-4. [pmid: 17559291].
265 Baranek GT, Foster LG, Berkson G. Tactile defensiveness and stereotyped behaviors. Am J Occup Ther. Feb. 1997;51(2):91-5. X-1, X-3, X-4. [pmid: 9124275].
266 Barba L. A one-stop shop for autism services. Behav Healthc. Jun. 30. 2010;30(6):28-1. X-1, X-2, X-3, X-4. [pmid: 20666201].
267 Barber M. Using intensive interaction to add to the palette of interactive possibilities in teacher-pupil communication. Eur J Spec Needs Educ. Nov. 2008;23(4):393-402. X-3.
268 Bardenheier B, Yusuf H, Schwartz B, et al. Are parental vaccine safety concerns associated with receipt of measles-mumps-rubella, diphtheria and tetanus toxoids with acellular pertussis, or hepatitis B vaccines by children?. Arch Pediatr Adolesc Med. Jun. 2004;158(6):569-75. X-4. [pmid: 15184221].
269 Barker ET, Hartley SL, Seltzer MM, et al. Trajectories of emotional well-being in mothers of adolescents and adults with autism. Dev Psychol. Mar. 2011;47(2):551-61. X-4. [pmid: 21171753].
270 Barnhill GP. Outcomes in adults with Asperger Syndrome. Focus Autism Dev Disabil. 2007;22(2):116-26. X-1, X-2, X-3, X-4.
271 Barnhill GP, Polloway EA, Sumutka BM. A survey of personnel preparation practices in autism spectrum disorders. Focus Autism Dev Disabil. Jun. 2011;26(2):75-86. X-1, X-3, X-4.
272 Barnoy EL, Najdowski AC, Tarbox J, et al. Evaluation of a multicomponent intervention for diurnal bruxism in a young child with autism. J Appl Behav Anal. Winter. 2009;42(4):845-8. X-1, X-3, X-4. [pmid: 20514192].
273 Baron-Cohen S, Golan O, Ashwin E. Can emotion recognition be taught to children with autism spectrum conditions?. Philos Trans R Soc Lond B Biol Sci. Dec. 12. 2009;364(1535):3567-74. X-1, X-3, X-4. [pmid: 19884151].
274 Baron-Cohen S, Scott FJ, Allison C, et al. Prevalence of autism-spectrum conditions: UK school-based population studies. Br J Psychiatry. Jun. 2009;194(6):500-9. X-4. [pmid: 19478287].
275 Baron-Cohen S, Wheelwright S. The Friendship Questionnaire: an investigation of adults with Asperger syndrome or high-functioning autism, and normal sex differences. J Autism Dev Disord. Oct. 2003;33(5):509-17. X-4. [pmid: 14594330].
276 Barrera RD, Sulzer-Azaroff B. An alternating treatment comparison of oral and total communications training programs with echolalic autistic children. J Appl Behav Anal. Winter. 1983;16(4):379-94. X-3. [pmid: 6654770].
277 Barrett RP, Feinstein C, Hole WT. Effects of naloxone and naltrexone on self-injury: A double-blind, placebo-controlled analysis. Am J Ment Retard. Special Issue: Drug treatment. May. 1989;93(6):644-51. X-1, X-3, X-4. [pmid: 2655671].
278 Barrows P. The use of stories as autistic objects. J Child Psychother. Apr. 2001;27(1):69-82. X-2, X-4.
279 Barrows P. Becoming verbal: Autism, trauma and playfulness. J Child Psychother. Apr. 2002;28(1):53-72. X-1, X-3, X-4.
280 Barry LM, Burlew SB. Using social stories to teach choice and play skills to children with autism. Focus Autism Dev Disabil. Mar. 2004;19(1):45-51. X-1, X-3, X-4.
281 Barry LM, Singer GHS. A family in crisis: replacing the aggressive behavior of a child with autism toward an infant sibling. J Posit Behav Interv. Win. 2001;3(1):28-38. X-1, X-3, X-4.
282 Barry TD, Klinger LG, Lee JM, et al. Examining the effectiveness of an outpatient clinic-based social skills group for high-functioning children with autism. J Autism Dev Disord. Dec. 2003;33(6):685-701. X-1, X-3, X-4. [pmid: 14714936].
283 Barthelemy C, Bruneau N, Jouve J, et al. Urinary dopamine metabolites as indicators of the responsiveness to fenfluramine treatment in children with autistic behavior. J Autism Dev Disord. Jun. 1989;19(2):241-54. X-3. [pmid: 2745390].
284 Barthelemy C, et al. Validation of the revised behavior summarized evaluation scale. J Autism Dev Disord. Apr. 1997;27(2):139-53. X-1, X-3, X-4. [pmid: 9105965].
285 Bartlett SM, Rapp JT, Krueger TK, et al. The use of response cost to treat spitting by a child with autism. Behav Interv. Feb. 2011;26(1):76-83. X-1, X-3, X-4.
286 Bartley JJ. An update on autism: science, gender, and the law. Gend Med. Jun. 2006;3(2):73-8. X-2, X-4. [pmid: 16860267].
287 Bartman S, Freeman N. Teaching language to a two-year-old with autism. J Dev Disab. Fal. 2003;10(1):47-53. X-1, X-3, X-4.
288 Baruth JM, Casanova MF, El-Baz A, et al. Low-frequency repetitive transcranial magnetic stimulation modulates evoked-gamma frequency oscillations in autism spectrum disorder. J Neurother. Jul. 2010;14(3):179-94. X-1, X-3, X-4. [pmid: 21116441].
289 Basil C, Reyes S. Acquisition of literacy skills by children with severe disability. Child Lang Teach Ther. 2003;19(1):27-48. X-3, X-4.
290 Bass JD, Mulick JA. Social Play Skill Enhancement of Children with Autism Using Peers and Siblings as Therapists. Psychol Sch. Sep. 2007;44(7):727-35. X-2.
291 Bass MM, Duchowny CA, Llabre MM. The effect of therapeutic horseback riding on social functioning in children with autism. J Autism Dev Disord. Sep. 2009;39(9):1261-7. X-1, X-3, X-4. [pmid: 19350376].
292 Bassoukou IH, Nicolau J, dos Santos MT. Saliva flow rate, buffer capacity, and pH of autistic individuals. Clin Oral Investig. Mar. 2009;13(1):23-7. X-4. [pmid: 18594879].
293 Batchelder A, McLaughlin TF, Weber KP, et al. The effects of hand-over-hand and a dot-to-dot tracing procedure on teaching an autistic student to write his name. J Dev Phys Disabil. Apr. 2009;21(2):131-8. X-3.
294 Bateman DF. Due process hearing case study. Teach Except Child. Mar–Apr. 2009;41(4):73-5. X-2, X-4.
295 Bauer AM, Sapona RH. Facilitating communication as a basis for intervention for students with severe Behav Disord. Behav Disord. Aug. 1988;13(4):280-87. X-1, X-3, X-4.
296 Bauer SC, Smith PJ, Chien AT, et al. Educating pediatric residents about development and social-emotional health. Inf Young Child. 2009;22(4):309-20. X-1, X-3, X-4.
297 Bauer W, Bauer JL. Adolescent schizophrenia. Adolescence. Fall. 1982;17(67):685-93. X-1, X-3, X-4. [pmid: 7180632].
298 Bauminger N. The facilitation of social-emotional understanding and social interaction in high-functioning children with autism: intervention outcomes. J Autism Dev Disord. Aug. 2002;32(4):283-98. X-1, X-3, X-4. [pmid: 12199133].
299 Bauminger N. Brief report: group social-multimodal intervention for HFASD. J Autism Dev Disord. Sep. 2007;37(8):1605-15. X-1, X-3, X-4. [pmid: 17072752].
300 Bauminger N. Brief report: individual social-multi-modal intervention for HFASD. J Autism Dev Disord. Sep. 2007;37(8):1593-604. X-1, X-3, X-4. [pmid: 17072753].
301 Beadle-Brown J, Murphy G, Wing L. The Camberwell cohort 25 years on: characteristics and changes in skills over time. J Appl Res Intellect Disabil. Dec. 2006;19(4):317-29. X-4.
302 Beadle-Brown J, Murphy G, Wing L, et al. Changes in skills for people with intellectual disability: a follow-up of the Camberwell Cohort. J Intellect Disabil Res. Feb. 2000;44(Pt 1):12-24. X-4. [pmid: 10711646].
303 Beadle-Brown JD, Whiten A. Elicited imitation in children and adults with autism: is there a deficit?. J Intellect Dev Disabil. 2004;29(2):147-63. X-4.
304 Beall PM, Moody EJ, McIntosh DN, et al. Rapid facial reactions to emotional facial expressions in typically developing children and children with autism spectrum disorder. J Exp Child Psychol. Nov. 2008;101(3):206-23. X-4. [pmid: 18561942].
305 Beard-Pfeuffer M. Understanding the world of children with autism. RN. Feb. 2008;71(2):40-5. quiz 6. X-2. [pmid: 18386443].
306 Beatson JE. Walk a mile in their shoes: Implementing family-centered care in serving children and families affected by autism spectrum disorder. Top Lang Disord. Oct–Dec. 2008;28(4):309-22. X-1, X-2, X-3, X-4.
307 Beatson JE, Prelock PA. The Vermont rural autism project: sharing experiences, shifting attitudes. Focus Autism Dev Disabil. Spr. 2002;17(1):48-54. X-3, X-4.
308 Beaumont R, Sofronoff K. A multi-component social skills intervention for children with Asperger syndrome: the Junior Detective Training Program. J Child Psychol Psychiatry. Jul. 2008;49(7):743-53. X-1, X-3, X-4. [pmid: 18503531].
309 Bebbington A, Beecham J. Social services support and expenditure for children with autism. Autism. Jan. 2007;11(1):43-61. X-4. [pmid: 17175573].
310 Bebko JM, Konstantareas MM, Springer J. Parent and professional evaluations of family stress associated with characteristics of autism. J Autism Dev Disord. Dec. 1987;17(4):565-76. X-1, X-4. [pmid: 3680156].
311 Bebko JM, Lennox C. Teaching the control of diurnal bruxism to two children with autism using a simple cueing procedure. Behav Ther. Spr. 1988;19(2):249-55. X-1, X-3, X-4.
312 Beck A, Hastings RP, Daley D. Pro-social behaviour and behaviour problems independently predict maternal stress. J Intellect Dev Disabil. 2004;29(4):339-49. X-4.
313 Beck AR, Pirovano CM. Facilitated communicators’ performance on a task of receptive language. J Autism Dev Disord. Oct. 1996;26(5):497-512. X-1, X-3, X-4. [pmid: 8906452].
314 Beck MH, Cataldo M, Slifer KJ, et al. Teaching children with Attention Deficit Hyperactivity Disorder (ADHD) and Autistic Disorder (AD) how to swallow Pills. Clin Pediatr (Phila). Jul–Aug. 2005;44(6):515-26. X-1, X-3, X-4. [pmid: 16015399].
315 Becker KG. Autism, asthma, inflammation, and the hygiene hypothesis. Med Hypotheses. 2007;69(4):731-40. X-2. [pmid: 17412520].
316 Becker-Cottrill B, McFarland J, Anderson V. A model of positive behavioral support for individuals with autism and their families: the family focus process. Focus Autism Dev Disabil. Sum. 2003;18(2):113-23. X-1, X-3, X-4.
317 Beckett C, Castle J, Groothues C, et al. Health problems in children adopted from Romania: association with duration of deprivation and behavioural problems. Adopt Fostering. 2003;27(4):19-29. X-4.
318 Bedrosian J, Lasker J, Speidel K, et al. Enhancing the written narrative skills of an AAC student with autism: evidence-based research issues. Top Lang Disord. 2003;23(4):305. X-3.
319 Beeghly JH, Kuperman S, Perry PJ, et al. Fenfluramine treatment of autism: relationship of treatment response to blood levels of fenfluramine and norfenfluramine. J Autism Dev Disord. Dec. 1987;17(4):541-8. X-3. [pmid: 3316172].
320 Begeer S, Gevers C, Clifford P, et al. Theory of mind training in children with autism: a randomized controlled trial. J Autism Dev Disord. Aug. 2011;41(8):997-1006. X-1, X-3, X-4. [pmid: 20976617].
321 Beglinger L, Smith T. Concurrent validity of social subtype and IQ after early intensive behavioral intervention in children with autism: a preliminary investigation. J Autism Dev Disord. Jun. 2005;35(3):295-303. X-1, X-3, X-4. [pmid: 16119470].
322 Beherec L, Lambrey S, Quilici G, et al. Retrospective review of clozapine in the treatment of patients with autism spectrum disorder and severe disruptive behaviors. J Clin Psychopharmacol. Jun. 2011;31(3):341-4. X-1, X-3. [pmid: 21508854].
323 Beisler JM, Tsai LY. A pragmatic approach to increase expressive language skills in young autistic children. J Autism Dev Disord. Sep. 1983;13(3):287-303. X-1, X-3, X-4. [pmid: 6643374].
324 Beisler JM, Tsai LY, Stiefel B. The effects of fenfluramine on communication skills in autistic children. J Autism Dev Disord. Jun. 1986;16(2):227-33. X-3. [pmid: 3722120].
325 Beitchman JH. Childhood schizophrenia. A review and comparison with adult-onset schizophrenia. Psychiatr Clin North Am. Dec. 1985;8(4):793-814. X-1, X-2, X-3, X-4. [pmid: 3878510].
326 Belcher TL. Behavioral treatment vs behavioral control: a case study. J Dev Phys Disabil. Sep. 1995;7(3):235-41. X-3.
327 Belderbos R, Chowdhury U, Skuse D. Prevalence of autistic personality traits in children with psychiatric problems... British Paediatric Neurology Association Annual Meeting 2007, 17th–19th January. Dev Med Child Neurol. 2007;49:24. X-4.
328 Belfiore PJ, Fritts KM, Herman BC. The role of procedural integrity: using self-monitoring to enhance Discrete Trial Instruction (DTI). Focus Autism Dev Disabil. Jun. 2008;23(2):95-102. X-2.
329 Bell JG, MacKinlay EE, Dick JR, et al. Essential fatty acids and phospholipase A2 in autistic spectrum disorders. Prostaglandins Leukot Essent Fatty Acids. Oct. 2004;71(4):201-4. X-4. [pmid: 15301788].
330 Bell KS, Kirby JR. Teaching emotion and belief as mindreading instruction for children with autism. Dev Disabil Bull. 2002;30(1):16-50. X-1, X-3, X-4.
331 Bell MD, Conway Greig T, Bryson G, et al. Patterns of object relations and reality testing deficits in schizophrenia: clusters and their symptom and personality correlates. J Clin Psychol. Dec. 2001;57(12):1353-67. X-4. [pmid: 11745581].
332 Bellini S. Social skill deficits and anxiety in high-functioning adolescents with autism spectrum disorders. Focus Autism Dev Disabil. 2004;19(2):78-86. X-4.
333 Bellini S, Akullian J, Hopf A. Increasing social engagement in young children with autism spectrum disorders using video self-modeling. School Psych Rev. 2007;36(1):80-90. X-1, X-3, X-4.
334 Bellini S, Hopf A. The development of the “Autism Social Skills Profile”: a preliminary analysis of psychometric properties. Focus Autism Dev Disabil. Sum. 2007;22(2):80-7. X-4.
335 Bellini S, McConnell LL. Strength-based educational programming for students with autism spectrum disorders: a case for video self-modeling. Prev School Failure. 2010;54(4):220-7. X-1, X-2, X-3, X-4.
336 Bellini S, Peters JK, Benner L, et al. A meta-analysis of school-based social skills interventions for children with autism spectrum disorders. Remedial Spec Educ. May–Jun. 2007;28(3):153-62. X-2.
337 Bellon ML, Ogletree BT, Harn WE. Repeated storybook reading as a language intervention for children with autism: a case study on the application of scaffolding. Focus Autism Dev Disabil. Spr. 2000;15(1):52-8. X-1, X-3, X-4.
338 Bellon-Harn ML, Harn WE. Scaffolding strategies during repeated storybook reading: an extension using a voice output communication aid. Focus Autism Dev Disabil. 2008;23(2):112-24. X-3, X-4.
339 Bellon-Harn ML, Harn WE, Watson GD. Targeting prosody in an eight-year-old child with high-functioning autism during an interactive approach to therapy. Child Lang Teach Ther. 2007;23(2):157-79. X-1, X-3, X-4.
340 Belotto KC, Raposo NR, Ferreira AS, et al. Relative bioavailability of two oral formulations of risperidone 2 mg: a single-dose, randomized-sequence, open-label, two-period crossover comparison in healthy Brazilian volunteers. Clin Ther. Nov. 2010;32(12):2106-15. X-1, X-3, X-4. [pmid: 21118746].
341 Belsito KM, Law PA, Kirk KS, et al. Lamotrigine therapy for autistic disorder: a randomized, double-blind, placebo-controlled trial. J Autism Dev Disord. Apr. 2001;31(2):175-81. X-1, X-3, X-4. [pmid: 11450816].
342 Ben Chaabane DB, Alber-Morgan SR, DeBar RM. The effects of parent-implemented PECS training on improvisation of mands by children with autism. J Appl Behav Anal. Fall. 2009;42(3):671-7. X-3. [pmid: 20190927].
343 Ben Itzchak E, Lahat E, Burgin R, et al. Cognitive, behavior and intervention outcome in young children with autism. Res Dev Disabil. Sep–Oct. 2008;29(5):447-58. X-1, X-3, X-4. [pmid: 17923388].
344 Ben Said M, Robel L, Vion E, et al. TEDIS: an information system dedicated to patients with pervasive developmental disorders. Stud Health Technol Inform. 2010;160(Pt 1):198-202. X-1, X-2, X-3, X-4. [pmid: 20841677].
345 Benderix Y, Nordstrom B, Sivberg B. Parents’ experience of having a child with autism and learning disabilities living in a group home: a case study. Autism. 2006;10(6):629-41. X-1, X-3, X-4. [pmid: 17088278].
346 Benderix Y, Nordstrum B, Nyberg P, et al. Staff members’ views of the work climate in sheltered homes for adults with autism spectrum disorders. Vard Nord Utveckl Forsk/Vård i Norden. 2009;29(2):38-41. X-1, X-3, X-4.
347 Benderix Y, Sivberg B. Siblings’ experiences of having a brother or sister with autism and mental retardation: a case study of 14 siblings from five families. J Pediatr Nurs. Oct. 2007;22(5):410-8. X-3. [pmid: 17889735].
348 Benedetti G. Interview with Gaetano Benedetti, M. D. J Am Acad Psychoanal Dyn Psychiatry. Spring. 2003;31(1):75-87. X-2, X-4. [pmid: 12722889].
349 Ben-Itzchak E, Zachor DA. The effects of intellectual functioning and autism severity on outcome of early behavioral intervention for children with autism. Res Dev Disabil. May–Jun. 2007;28(3):287-303. X-1, X-3, X-4. [pmid: 16730944].
350 Bennett K, Brady MP, Scott J, et al. The effects of covert audio coaching on the job performance of supported employees. Focus Autism Dev Disabil. Sep. 2010;25(3):173-85. X-1, X-3, X-4.
351 Bennett K, Reichow B, Wolery M. Effects of structured teaching on the behavior of young children with disabilities. Focus Autism Dev Disabil. Sep. 2011;26(3):143-52. X-1, X-3, X-4.
352 Bennett S, McKenna K, Tooth L, et al. Searches and content of the OTseeker database: informing research priorities. Am J Occup Ther. Sep–Oct. 2006;60(5):524-30. X-4. [pmid: 17022340].
353 Bennett T, Rowe V, DeLuca D. Getting to know Abby. Focus Autism Dev Disabil. Fal. 1996;11(3):183-8. X-1, X-3, X-4.
354 Ben-Sasson A, Cermak SA, Orsmond GI, et al. Extreme sensory modulation behaviors in toddlers with autism spectrum disorders. Am J Occup Ther. Sep–Oct. 2007;61(5):584-92. X-1, X-3, X-4. [pmid: 17944296].
355 Ben-Sasson A, Stimmell KE, Cermak SA. Sequence of gestural representations in children with high functioning autism. Israel Journal of Occupational Therapy. 2009;18(4):E57-73. X-4.
356 Benson P, Karlof KL, Siperstein GN. Maternal involvement in the education of young children with autism spectrum disorders. Autism. Jan. 2008;12(1):47-63. X-4. [pmid: 18178596].
357 Bent S, Bertoglio K, Ashwood P, et al. A pilot randomized controlled trial of omega-3 fatty acids for autism spectrum disorder. J Autism Dev Disord. May. 2011;41(5):545-54. X-1, X-3, X-4. [pmid: 20683766].
358 Bent S, Bertoglio K, Ashwood P, et al. Brief report: Hyperbaric Oxygen Therapy (HBOT) in children with autism spectrum disorder: a clinical trial. J Autism Dev Disord. 2011. Aug. 5. X-1, X-3, X-4. [pmid: 21818676].
359 Bent S, Bertoglio K, Hendren RL. Omega-3 fatty acids for autistic spectrum disorder: a systematic review. J Autism Dev Disord. Aug. 2009;39(8):1145-54. X-2. [pmid: 19333748].
360 Bentivegna S, Schwartz L, Deschner D. The use of art with an autistic child in residential care. Am J Art Ther. Jan. 1983;22(2):51-6. X-1, X-3, X-4. [pmid: 10318567].
361 Benton TD. Aripiprazole to treat irritability associated with autism: a placebo-controlled, fixed-dose trial. Curr Psychiatry Rep. Apr. 2011;13(2):77-9. X-1, X-2, X-3, X-4. [pmid: 21286868].
362 Benveniste D. The archetypal image of the mouth and its relation to autism. Arts Psychother. Sum. 1983;10(2):99-112. X-3.
363 Anderson-Hanley C, Tureck K, Schneiderman RL. Autism and exergaming: effects on repetitive behaviors and cognition. Psychol Res Behav Manag. 2011;4:129-37. X-3. [pmid: 22114543].
364 Beresford B, Tozer R, Rabiee P, et al. Developing an approach to involving children with autistic spectrum disorders in a social care research project. Brit J Learn Disab. 2004;32(4):180-5. X-1, X-2, X-3, X-4.
365 Berger HJ, Aerts FH, van Spaendonck KP, et al. Central coherence and cognitive shifting in relation to social improvement in high-functioning young adults with autism. J Clin Exp Neuropsychol. Jun. 2003;25(4):502-11. X-4. [pmid: 12911104].
366 Berger HJ, van Spaendonck KP, Horstink MW, et al. Cognitive shifting as a predictor of progress in social understanding in high-functioning adolescents with autism: a prospective study. J Autism Dev Disord. Jun. 1993;23(2):341-59. X-3. [pmid: 8331051].
367 Bergstrom R, Tarbox J, Gutshall KA. Behavioral intervention for domestic pet mistreatment in a young child with autism. Res Autism Spectr Disord. Jan–Mar. 2011;5(1):218-21. X-1, X-3, X-4.
368 Berkeley SL, Zittel LL, Pitney LV, et al. Locomotor and object control skills of children diagnosed with autism. Adapt Phys Activ Q. 2001;18(4):405-16. X-1, X-3, X-4.
369 Berkowitz S. A comparison of two methods of prompting in training discrimination of communication book pictures by autistic students. J Autism Dev Disord. Jun. 1990;20(2):255-62. X-3. [pmid: 2347823].
370 Bernad-Ripoll S. Using a self-as-model video combined with social stories to help a child with Asperger Syndrome understand emotions. Focus Autism Dev Disabil. Sum. 2007;22(2):100-6. X-1, X-3, X-4.
371 Bernard-Opitz V, Ing S, Kong TY. Comparison of behavioural and natural play interventions for young children with autism. Autism. Sep. 2004;8(3):319-33. X-1, X-3, X-4. [pmid: 15358873].
372 Bernard-Opitz V, Kok A. Training parents of autistic children in Singapore. Int J Rehabil Res. 1992;15(1):82-4. X-6. [pmid: 1601571].
373 Bernard-Opitz V, Kwook KW, Sapuan S. Epidemiology of autism in Singapore: findings of the first autism survey. Int J Rehabil Res. Mar. 2001;24(1):1-6. X-4. [pmid: 11302459].
374 Bernard-Opitz V, Ross K, Tuttas ML. Computer assisted instruction for autistic children. Ann Acad Med Singapore. Sep. 1990;19(5):611-6. X-1. [pmid: 2260815].
375 Bernard-Opitz V, Sriram N, Nakhoda-Sapuan S. Enhancing social problem solving in children with autism and normal children through computer-assisted instruction. J Autism Dev Disord. Aug. 2001;31(4):377-84. X-1, X-3, X-4. [pmid: 11569584].
376 Bernard-Opitz V, Sriram N, Sapuan S. Enhancing vocal imitations in children with autism using the IBM SpechViewer. Autism. Jun. 1999;3(2):131-47. X-1, X-3, X-4.
377 Berry P. Psychodynamic therapy and intellectual disabilities: dealing with challenging behaviour. Dev Med Child Neurol. Mar. 2003;50(1):39-51. X-3.
378 Berry-Kravis E, Krause SE, Block SS, et al. Effect of CX516, an AMPA-modulating compound, on cognition and behavior in fragile X syndrome: a controlled trial. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):525-40. X-4. [pmid: 17069542].
379 Berry-Kravis E, Raspa M, Loggin-Hester L, et al. Seizures in fragile X syndrome: characteristics and comorbid diagnoses. Am J Intellect Dev Disabil. Nov. 2010;115(6):461-72. X-1, X-3, X-4. [pmid: 20945999].
380 Berry-Kravis E, Sumis A, Kim O-K, et al. Characterization of potential outcome measures for future clinical trials in Fragile X Syndrome. J Autism Dev Disord. Oct. 2008;38(9):1751-7. X-4. [pmid: 18369716].
381 Bertoglio K, James SJ, Deprey L, et al. Pilot study of the effect of methyl B12 treatment on behavioral and biomarker measures in children with autism. J Altern Complement Med. May. 2010;16(5):555-60. X-1, X-3, X-4. [pmid: 20804367].
382 Bettison S. The long-term effects of auditory training on children with autism. J Autism Dev Disord. Jun. 1996;26(3):361-74. X-6. [pmid: 8792266].
383 Betz A, Higbee TS, Reagon KA. Using joint activity schedules to promote peer engagement in preschoolers with autism. J Appl Behav Anal. Summer. 2008;41(2):237-41. X-1, X-3, X-4. [pmid: 18595287].
384 Bevan-Brown J, Carroll-Lind J, Kearney A, et al. Making assumptions vs. building relationships: lessons from a participatory action research project to identify effective practices for learners with autism spectrum disorder. Kairaranga. 2008;9(spec iss):22-31. X-3.
385 Beversdorf DQ, Carpenter AL, Miller RF, et al. Effect of propranolol on verbal problem solving in autism spectrum disorder. Neurocase. 2008;14(4):378-83. X-3. [pmid: 18766980].
386 Beversdorf DQ, Saklayen S, Higgins KF, et al. Effect of propranolol on word fluency in autism. Cogn Behav Neurol. Mar. 2011;24(1):11-7. X-1, X-3. [pmid: 21487259].
387 Beversdorf DQ, Smith BW, Crucian GP, et al. Increased discrimination of “false memories” in autism spectrum disorder. Proc Natl Acad Sci U S A. Jul. 18. 2000;97(15):8734-7. X-1, X-3, X-4. [pmid: 10900024].
388 Bhandari A, Sandlow JI, Brannigan RE. Risks to offspring associated with advanced paternal age. J Androl. Mar–Apr. 2011;32(2):121-2. X-1, X-2, X-3, X-4. [pmid: 20467047].
389 Bhatara A, Quintin EM, Levy B, et al. Perception of emotion in musical performance in adolescents with autism spectrum disorders. Autism Res. Oct. 2010;3(5):214-25. X-4. [pmid: 20717952].
390 Bhaumik S, Branford D, McGrother C, et al. Autistic traits in adults with learning disabilities. Br J Psychiatry. Jun. 1997;170:502-6. X-4. [pmid: 9330013].
391 Bhaumik S, Tyrer FC, McGrother C, et al. Psychiatric service use and psychiatric disorders in adults with intellectual disability. J Intellect Disabil Res. Nov. 2008;52(11):986-95. X-4. [pmid: 19017168].
392 Bianco M, Carothers DE, Smiley LR. Gifted students with Asperger Syndrome: strategies for strength-based programming. Interv School Clinic. 2009;44(4):206-15. X-1, X-2, X-3, X-4.
393 Bibby P, Eikeseth S, Martin NT, et al. Progress and outcomes for children with autism receiving parent-managed intensive interventions. Res Dev Disabil. Nov–Dec. 2001;22(6):425-47. X-1, X-3, X-4. [pmid: 11768669].
394 Bibby P, Eikeseth S, Martin NT, et al. Erratum to “Progress and Outcomes for Children with Autism Receiving Parent-Managed Intensive Interventions”. [Research in Developmental Disabilities 22 (2001) 425–447]. Res Dev Disabil. Jan–Feb. 2002;23(1):79-104. X-1, X-2, X-3, X-4.
395 Bibby P, Eikeseth S, Martin NT, et al. Progress and outcomes for children with autism receiving parent-managed intensive interventions. Res Dev Disabil. Jan–Feb. 2002;23(1):81-104. X-1, X-2, X-3, X-4. [pmid: 12071397].
396 Biederman GB, Stepaniuk S, Davey VA, et al. Observational learning in children with Down syndrome and developmental delays: The effect of presentation speed in videotaped modelling. Downs Syndr Res Pract. Aug. 1999;6(1):12-8. X-1, X-3, X-4. [pmid: 10890243].
397 Bierly C, Billingsley FF. An investigation of the educative effects of overcorrection on the behavior of an autistic child. Behav Disord. Nov. 1983;9(1):11-21. X-1, X-3, X-4.
398 Bigelow KM, Huynen KB, Lutzker JR. Using a changing criterion design to teach fire escape to a child with developmental disabilities. J Dev Phys Disabil. Jun. 1993;5(2):121-8. X-1, X-3, X-4.
399 Bigham S. Comprehension of pretence in children with autism. Br J Dev Psychol. 2008;26(Part 2):265-80. X-1, X-3, X-4.
400 Bijou SW. Commentary. J Autism Dev Disord. Sep. 1990;20(3):431-32. X-1, X-2, X-3, X-4.
401 Biklen D, Burke J. Presuming competence. Equity & excellence in education. May. 2006;39(2):166-75. X-1, X-2, X-3, X-4.
402 Biklen D, et al. Facilitated communication: implications for individuals with autism. Top Lang Disord. Aug. 1992;12(4):1-28. X-1, X-2, X-3, X-4.
403 Biklen D, Schubert A. New words: the communication of students with autism. Remedial Spec Educ. Nov–Dec. 1991;12(6):46-57. X-1, X-3, X-4.
404 Billard A, Robins B, Nadel J, et al. Building robota, a mini-humanoid robot for the rehabilitation of children with autism. Assist Technol. Spr. 2007;19(1):37-49. X-2, X-4. [pmid: 17461289].
405 Billington T, McNally B, McNally C. Autism: working with parents, and discourse in experience, expertise and learning. Educ Psychol Prac. Apr. 2000;16(1):59-68. X-1, X-3, X-4.
406 Billstedt E, Gillberg IC, Gillberg C. Autism after adolescence: population-based 13- to 22-year follow-up study of 120 individuals with autism diagnosed in childhood. J Autism Dev Disord. Jun. 2005;35(3):351-60. X-4. [pmid: 16119476].
407 Billstedt E, Gillberg IC, Gillberg C. Aspects of quality of life in adults diagnosed with autism in childhood: a population-based study. Autism. Jan. 2011;15(1):7-20. X-4. [pmid: 20923888].
408 Binnendyk L, Lucyshyn JM. A family-centered positive behavior support approach to the amelioration of food refusal behavior: an empirical case study. J Posit Behav Interv. 2009;11(1):47-62. X-1, X-3, X-4.
409 Binnie LM, Williams JM. Intuitive psychological, physical and biological knowledge in typically developing preschoolers, children with autism and children with Down’s syndrome. Br J Dev Psychol. 2002;20(Part 3):343-59. X-1, X-3, X-4.
410 Bird F, Dores PA, Moniz D, et al. Reducing severe aggressive and self-injurious behaviors with functional communication training. Am J Ment Retard. Jul. 1989;94(1):37-48. X-3. [pmid: 2751890].
411 Birenbaum A, Cohen HJ. On the importance of helping families: policy implications from a national study. Ment Retard. Apr. 1993;31(2):67-74. X-2, X-4. [pmid: 8479331].
412 Birkan B, Krantz PJ, McClannahan LE. Teaching children with autism spectrum disorders to cooperate with injections. Res Autism Spectr Disord. Apr–Jun. 2011;5(2):941-8. X-3, X-4.
413 Birkin C, Anderson A, Moore DW, et al. Evaluating the efficacy of parent-focused interventions for autism: how do we know what will work?. Aust J Early Child. Sep. 2004;29(3):42-7. X-1, X-2, X-3, X-4.
414 Birkin C, Anderson A, Seymour F, et al. A parent-focused early intervention program for autism: who gets access?. J Intellect Dev Disabil. Jun. 2008;33(2):108-16. X-2. [pmid: 18569398].
415 Birmaher B, Quintana H, Greenhill LL. Methylphenidate treatment of hyperactive autistic children. J Am Acad Child Adolesc Psychiatry. Mar. 1988;27(2):248-51. X-1, X-3, X-4. [pmid: 3360732].
416 Birnbrauer JS, Leach DJ. The Murdoch Early Intervention Program after 2 years. Behav Change. 1993;10(2):63-74. X-1, X-3, X-4.
417 Bisagni F. The Sound-Hand. J Child Psychother. Dec. 2009;35(3):229-49. X-2, X-4.
418 Bishop DV. Curing dyslexia and attention-deficit hyperactivity disorder by training motor co-ordination: miracle or myth?. J Paediatr Child Health. Oct. 2007;43(10):653-5. X-2, X-4. [pmid: 17854448].
419 Bishop DV. Which neurodevelopmental disorders get researched and why?. PLoS One. 2010;5(11):e15112. X-1, X-3, X-4. [pmid: 21152085].
420 Bishop SL, Richler J, Lord C. Association between restricted and repetitive behaviors and nonverbal IQ in children with autism spectrum disorders. Child Neuropsychol. Aug. 2006;12(4–5):247-67. X-4. [pmid: 16911971].
421 Bitsika V, Sharpley C. An explanatory examination of the effects of support groups on the well-being of parents of children with autism: I: General counselling. J Appl Health Behav. 1999;1(2):16-22. X-3.
422 Bitsika V, Sharpley C. Development and testing of the effects of support groups on the well-being of parents of children with autism-II: Specific stress management techniques. J Appl Health Behav. 2000;2(1):8-15. X-3, X-4.
423 Bitsika V, Sharpley CF, Orapeleng S. An exploratory analysis of the use of cognitive, adaptive and behavioural indices for cluster analysis of ASD subgroups. J Intellect Disabil Res. Nov. 2008;52(11):973-85. X-1, X-3, X-4. [pmid: 19017167].
424 Bitsko RH, Visser SN, Schieve LA, et al. Unmet health care needs among CSHCN with neurologic conditions. Pediatrics. Dec. Suppl 4. 2009;124:S343-51. X-4. [pmid: 19948598].
425 Bitterman A, Daley TC, Misra S, et al. A national sample of preschoolers with autism spectrum disorders: special education services and parent satisfaction. J Autism Dev Disord. Sep. 2008;38(8):1509-17. X-4. [pmid: 18228122].
426 Blacher J, Kraemer BR, Howell EJ. Family expectations and transition experiences for young adults with severe disabilities: does syndrome matter?. Adv Ment Health Learn Disabil. Mar. 2010;4(1):3-16. X-4.
427 Blacher J, McIntyre LL. Syndrome specificity and behavioural disorders in young adults with intellectual disability: cultural differences in family impact. J Intellect Disabil Res. Mar. 2006;50(Pt 3):184-98. X-4. [pmid: 16430730].
428 Blackledge JT, Hayes SC. Using acceptance and commitment training in the support of parents of children diagnosed with autism. Child Fam Behav Ther. 2006;28(1):1-18. X-6.
429 Blacklock K, Perry A. Testing the application of benchmarks for children in Ontario’s IBI program: six case studies. J Dev Disab. 2010;16(2):33-43. X-1, X-2, X-3, X-4.
430 Blackwood DH, Muir WJ, Roxborough HM, et al. “Schizoid” personality in childhood: auditory P300 and eye tracking responses at follow-up in adult life. J Autism Dev Disord. Aug. 1994;24(4):487-500. X-4. [pmid: 7961332].
431 Blair J, Scahill L, State M, et al. Electrocardiographic changes in children and adolescents treated with ziprasidone: a prospective study. J Am Acad Child Adolesc Psychiatry. Jan. 2005;44(1):73-9. X-3. [pmid: 15608546].
432 Blair K-SC, Lee I-S, Cho S-J, et al. Positive behavior support through family–school collaboration for young children with autism. Topics Early Child Spec Educ. May. 2011;31(1):22-36. X-1, X-3, X-4.
433 Blair K-SC, Umbreit J, Dunlap G, et al. Promoting inclusion and peer participation through assessment-based intervention. Topics Early Child Spec Educ. Fall. 2007;27(3):134-47. X-1, X-3, X-4.
434 Blake KE. Spectrum disorders: a new generation of complex patients. Pa Nurse. Dec. 2010;65(4):9-11. 5. X-2. [pmid: 21329281].
435 Blakeley-Smith A, Carr EG, Cale SI, et al. Environmental fit: A model for assessing and treating problem behavior associated with curricular difficulties in children with autism spectrum disorders. Focus Autism Dev Disabil. Sep. 2009;24(3):131-45. X-3.
436 Blankenship K, Erickson CA, Stigler KA, et al. Aripiprazole for irritability associated with autistic disorder in children and adolescents aged 6–17 years. Ped Health. Sep. 29. 2010;4(4):375-81. X-1, X-2, X-3. [pmid: 21359119].
437 Blardi P, de Lalla A, Ceccatelli L, et al. Variations of plasma leptin and adiponectin levels in autistic patients. Neurosci Lett. Jul. 19. 2010;479(1):54-7. X-1, X-3, X-4. [pmid: 20478355].
438 Blindert HD, Hartridge CL, Gwadry FG. Controlling self-injurious escape behaviors. Behav Interv. Jul. 1995;10(3):173-9. X-1, X-3, X-4.
439 Bloch J, Gersten E, Kornblum S. Evaluation of a language program for young autistic children. J Speech Hear Disord. Feb. 1980;45(1):76-89. X-1, X-3, X-4. [pmid: 7354632].
440 Bloch JR, Gardner M. Accessing a diagnosis for a child with an autism spectrum disorder: the burden is on the caregiver. Am J Nurse Pract. 2007;11(8):10-7. X-4.
441 Bock MA. Acquisition, maintenance, and generalization of a categorization strategy by children with autism. J Autism Dev Disord. Feb. 1994;24(1):39-51. X-3. [pmid: 8188573].
442 Bock MA. Sorting laundry: Categorization strategy application to an authentic learning activity by children with autism. Focus Autism Dev Disabil. Win. 1999;14(4):220-30. X-1, X-3, X-4.
443 Bock MA. The impact of social-behavioral learning strategy training on the social interaction skills of four students with Asperger Syndrome. Focus Autism Dev Disabil. Sum. 2007;22(2):88-95. X-1, X-3, X-4.
444 Boddaert N, Belin P, Chabane N, et al. Perception of complex sounds: abnormal pattern of cortical activation in autism. Am J Psychiatry. Nov. 2003;160(11):2057-60. X-4. [pmid: 14594758].
445 Boddaert N, Chabane N, Belin P, et al. Perception of complex sounds in autism: abnormal auditory cortical processing in children. Am J Psychiatry. Nov. 2004;161(11):2117-20. X-4. [pmid: 15514415].
446 Boettcher M, Koegel RL, McNerney EK, et al. A family-centered prevention approach to PBS in a time of crisis. J Posit Behav Interv. Win. 2003;5(1):55-9. X-1, X-3, X-4.
447 Bogte H, Flamma B, van der Meere J. Do high functioning autistic individuals treated in a residential setting differ in divided attention abilities from those treated in an out-patient setting?. Int J Circumpolar Health. Suppl 2. 2002;61:15-21. X-3. [pmid: 12585817].
448 Bogte H, Flamma B, Van Der Meere J, et al. Divided attention capacity in adults with autism spectrum disorders and without intellectual disability. Autism. 2009;13(3):229-43. X-3. [pmid: 19369386].
449 Boiron M, Barthelemy C, Adrien JL, et al. The assessment of psychophysiological dysfunction in children using the BSE scale before and during therapy. Acta Paedopsychiatr. 1992;55(4):203-6. X-1, X-3, X-4. [pmid: 1492548].
450 Bokszanska A, Martin G, Vanstraelen M, et al. Risperidone and olanzapine in adults with intellectual disability: a clinical naturalistic study. Int Clin Psychopharmacol. Sep. 2003;18(5):285-91. X-1, X-3, X-4. [pmid: 12920389].
451 Bolman WM. Brief report: 25-year follow-up of a high-functioning autistic child. J Autism Dev Disord. Jan. 2008;38(1):181-3. X-3, X-4. [pmid: 17364231].
452 Bolman WM, Richmond JA. A double-blind, placebo-controlled, crossover pilot trial of low dose dimethylglycine in patients with autistic disorder. J Autism Dev Disord. Jun. 1999;29(3):191-4. X-3. [pmid: 10425581].
453 Bölte S, Bosch G. The long-term outcome in two females with autism spectrum disorder. Psychopathology. May–Jun. 2005;38(3):151-4. X-3. [pmid: 15905639].
454 Bolte S, Feineis-Matthews S, Leber S, et al. The development and evaluation of a computer-based program to test and to teach the recognition of facial affect. Int J Circumpolar Health. Suppl 2. 2002;61:61-8. X-3. [pmid: 12585821].
455 Bölte S, Hubl D, Feineis-Matthews S, et al. Facial affect recognition training in autism: can we animate the fusiform gyrus?. Behav Neurosci. Feb. 2006;120(1):211-6. X-3. [pmid: 16492133].
456 Bolton J, Mayer MD. Promoting the generalization of paraprofessional discrete trial teaching skills. Focus Autism Dev Disabil. 2008;23(2):103-11. X-4.
457 Bomba C, O’Donnell L, Markowitz C, et al. Evaluating the impact of facilitated communication on the communicative competence of fourteen students with autism. J Autism Dev Disord. Feb. 1996;26(1):43-58. X-3. [pmid: 8819770].
458 Bonde E. Comorbidity and subgroups in childhood autism. Eur Child Adolesc Psychiatry. Mar. 2000;9(1):7-10. X-1, X-3, X-4. [pmid: 10795850].
459 Bonell S, McCarthy J. A case study of a young man with intellectual disability, mitochondrial disorder, epilepsy, autism and psychosis: How did we decide which psychotropic drug to use?. Adv Ment Health Intell Disabil. Sep. 2010;4(3):45-8. X-3, X-4.
460 Bonnel A, McAdams S, Smith B, et al. Enhanced pure-tone pitch discrimination among persons with autism but not Asperger syndrome. Neuropsychologia. Jul. 2010;48(9):2465-75. X-4. [pmid: 20433857].
461 Bono MA, Daley T, Sigman M. Relations among joint attention, amount of intervention and language gain in autism. J Autism Dev Disord. Oct. 2004;34(5):495-505. X-1, X-3, X-4. [pmid: 15628604].
462 Bonvillian JD, Nelson KE, Rhyne JM. Sign language and autism. J Autism Dev Disord. Mar. 1981;11(1):125-37. X-1, X-2, X-3, X-4. [pmid: 6927693].
463 Bopp KD, Mirenda P, Zumbo BD. Behavior predictors of language development over 2 years in children with autism spectrum disorders. J Speech Lang Hear Res. Oct. 2009;52(5):1106-20. X-1, X-3, X-4. [pmid: 19797136].
464 Boris M, Goldblatt A. Pollen exposure as a cause for the deterioration of neurobehavioral function in children with autism and attention deficit hyperactive disorder. J Nutr Environ Med. 2004;14(1):39-45. X-4.
465 Boris M, Goldblatt A, Edelson SM. Improvements in children with autism treated with intravenous gamma globulin. J Nutr Environ Med. 2005;15(4):169-76. X-1, X-3, X-4.
466 Boris M, Goldblatt A, Galanko J, et al. Association of MTHFR gene variants with autism. J Am Physicians Surg. 2004;9(4):106-8. X-4.
467 Boris M, Kaiser CC, Goldblatt A, et al. Effect of pioglitazone treatment on behavioral symptoms in autistic children. J Neuroinflammation. 2007;4:3. X-1, X-3. [pmid: 17207275].
468 Borremans E, Rintala P, McCubbin JA. Physical fitness and physical activity in adolescents with Asperger syndrome: a comparative study. Adapt Phys Activ Q. 2010;27(4):308-20. X-4. [pmid: 20956837].
469 Borrero CS, Borrero JC. Descriptive and experimental analyses of potential precursors to problem behavior. J Appl Behav Anal. Spring. 2008;41(1):83-96. X-4. [pmid: 18468281].
470 Boso M, Comelli M, Emanuele E, et al. Seasonal fluctuations in problem behaviors among young adults with autism and intellectual disability. Med Sci Monit. Apr. 28. 2010;16(5):CR213-6. X-4. [pmid: 20424547].
471 Boso M, Emanuele E, Minazzi V, et al. Effect of long-term interactive music therapy on behavior profile and musical skills in young adults with severe autism. J Altern Complement Med. Sep. 2007;13(7):709-12. X-1. [pmid: 17931062].
472 Bosseler A, Massaro DW. Development and evaluation of a computer-animated tutor for vocabulary and language learning in children with autism. J Autism Dev Disord. Dec. 2003;33(6):653-72. X-3. [pmid: 14714934].
473 Botting N. Narrative as a tool for the assessment of linguistic and pragmatic impairments. Child Lang Teach Ther. 2002;18(1):1-21. X-3, X-4.
474 Botts BH, Hershfeldt PA, Christensen-Sandfort RJ. Snoezelen[R]: Empirical review of product representation. Focus Autism Dev Disabil. 2008;23(3):138-47. X-4.
475 Boucher J, Bigham S, Mayes A, et al. Recognition and language in low functioning autism. J Autism Dev Disord. Aug. 2008;38(7):1259-69. X-4. [pmid: 18064549].
476 Bouder JN, Spielman S, Mandell DS. Brief report: Quantifying the impact of autism coverage on private insurance premiums. J Autism Dev Disord. Jun. 2009;39(6):953-7. X-2, X-4. [pmid: 19214727].
477 Boudreau CA, Christian WP, Thibadeau SF. Reducing absenteeism in a human service setting: a low cost alternative. J Organ Behav Manage. 1993;13(2):37-50. X-1, X-3, X-4.
478 Boulton TJ, Smith R, Single T. Psychosocial growth failure: a positive response to growth hormone and placebo. Acta Paediatr. Apr. 1992;81(4):322-5. X-4. [pmid: 1606393].
479 Boulware G-L, Schwartz IS, Sandall SR, et al. Project DATA for toddlers: an inclusive approach to very young children with autism spectrum disorder. Topics Early Child Spec Educ. Sum. 2006;26(2):94-105. X-1, X-2, X-3, X-4.
480 Bouma R, Schweitzer R. The impact of chronic childhood illness on family stress: a comparison between autism and cystic fibrosis. J Clin Psychol. Nov. 1990;46(6):722-30. X-1, X-2, X-3, X-4. [pmid: 2286663].
481 Boutot EA, Bryant DP. Social integration of students with autism in inclusive settings. Educ Train Dev Disabil. Mar. 2005;40(1):14-23. X-1, X-3, X-4.
482 Bouvard MP, Leboyer M, Launay JM, et al. Low-dose naltrexone effects on plasma chemistries and clinical symptoms in autism: a double-blind, placebo-controlled study. Psychiatry Res. Oct. 16. 1995;58(3):191-201. X-1, X-3, X-4. [pmid: 8570775].
483 Bowers L. An audit of referrals of children with autistic spectrum disorder to the dietetic service. J Hum Nutr Diet. Apr. 2002;15(2):141-4. X-4. [pmid: 11972743].
484 Bowker A, D’Angelo NM, Hicks R, et al. Treatments for autism: parental choices and perceptions of change. J Autism Dev Disord. Oct. 2011;41(10):1373-82. X-4. [pmid: 21161676].
485 Bowman LG, Piazza CC, Fisher WW, et al. Assessment of preference for varied versus constant reinforcers. J Appl Behav Anal. Fall. 1997;30(3):451-8. X-4. [pmid: 9316258].
486 Boyd BA, Baranek GT, Sideris J, et al. Sensory features and repetitive behaviors in children with autism and developmental delays. Autism Res. Apr. 2010;3(2):78-87. X-1, X-3, X-4. [pmid: 20437603].
487 Boyd BA, McDonough SG, Rupp B, et al. Effects of a family-implemented treatment on the repetitive behaviors of children with autism. J Autism Dev Disord. Oct. 2011;41(10):1330-41. X-1, X-3, X-4. [pmid: 21161576].
488 Boyd BA, Odom SL, Humphreys BP, et al. Infants and toddlers with autism spectrum disorder: early identification and early intervention. J Early Interv. 2010;32(2):75-98. X-2, X-4.
489 Boyd BA, Shaw E. Autism in the classroom: a group of students changing in population and presentation. Prev School Failure. 2010;54(4):211-9. X-1, X-2, X-3, X-4.
490 Boyd RD. Sex as a possible source of group inequivalence in Lovaas 1987. J Autism Dev Disord. Jun. 1998;28(3):211-5. X-2, X-4. [pmid: 9656132].
491 Boyd RD, Corley MJ. Outcome survey of early intensive behavioral intervention for young children with autism in a community setting. Autism. Dec. 2001;5(4):430-41. X-1, X-3, X-4. [pmid: 11777258].
492 Boyer L, Lee C. Converting challenge to success: supporting a new teacher of students with autism. J Spec Educ. Sum. 2001;35(2):75-83. X-1, X-2, X-3, X-4.
493 Boyle C, Alexander M. Public health research at the CDC implications for communication sciences and disorders. J Commun Disord. Jul–Aug. 2005;38(4):263-70. X-2. [pmid: 15862809].
494 Brachlow AE, Ness KK, McPheeters ML, et al. Comparison of indicators for a primary care medical home between children with autism or asthma and other special health care needs: National Survey of Children’s Health. Arch Pediatr Adolesc Med. Apr. 2007;161(4):399-405. X-4. [pmid: 17404138].
495 Brackenbury T, Burroughs E, Hewitt LE. A qualitative examination of current guidelines for evidence-based practice in child language intervention. Lang Speech Hear Serv Sch. Jan. 2008;39(1):78-88. X-4. [pmid: 18162650].
496 Bradley LA, Krakowski B, Thiessen A. With little research out there it’s a matter of learning what works in teaching students with deafness and autism. Odyssey. Spr-Sum. 2008;9(1):16-8. X-1, X-2, X-3, X-4.
497 Bradstreet JJ, Smith S, Granpeesheh D, et al. Spironolactone might be a desirable immunologic and hormonal intervention in autism spectrum disorders. Med Hypotheses. 2007;68(5):979-87. X-1, X-2, X-3, X-4. [pmid: 17150311].
498 Brady NC, Steeples T, Fleming K. Effects of prelinguistic communication levels on initiation and repair of communication in children with disabilities. J Speech Lang Hear Res. Oct. 2005;48(5):1098-113. X-4. [pmid: 16411798].
499 Bragesjo F, Hallberg M. Dilemmas of a vitalizing vaccine market: lessons from the MMR vaccine/autism debate. Sci Context. Mar. 2011;24(1):107-25. X-1, X-2, X-3, X-4. [pmid: 21560548].
500 Brambring M, Asbrock D. Validity of false belief tasks in blind children. J Autism Dev Disord. Dec. 2010;40(12):1471-84. X-1, X-3, X-4. [pmid: 20379770].
501 Branford D, Bhaumik S, Naik B. Selective serotonin re-uptake inhibitors for the treatment of perseverative and maladaptive behaviours of people with intellectual disability. J Intellect Disabil Res. Aug. 1998;42(Pt 4):301-6. X-1. [pmid: 9786445].
502 Brasić JR, Barnett JY. Hyperkinesias in a prepubertal boy with autistic disorder treated with haloperidol and valproic acid. Psychol Rep. Feb. 1997;80(1):163-70. X-1, X-3, X-4. [pmid: 9122323].
503 Brasic JR, Barnett JY, Kaplan D, et al. Clomipramine ameliorates adventitious movements and compulsions in prepubertal boys with autistic disorder and severe mental retardation. Neurology. Jul. 1994;44(7):1309-12. X-1, X-3, X-4. [pmid: 8035936].
504 Brasic JR, Barnett JY, Sheitman BB, et al. Clinical assessment of adventitious movements. Psychol Rep. Dec. 1998;83(3 Pt 1):739-50. X-4. [pmid: 9923147].
505 Breen C, Haring T, Pitts-Conway V, et al. The training and generalization of social interaction during breaktime at two job sites in the natural environment. J Assoc Pers Sev Handicaps. Spr. 1985;10(1):41-50. X-3.
506 Brendel DH. Complications to consent. J Clin Ethics. Spring-Summer. 2003;14(1–2):90-4. X-2. [pmid: 12953356].
507 Breslin CM, Rudisill ME. The effect of visual supports on performance of the TGMD-2 for children with autism spectrum disorder. Adapt Phys Activ Q. 2011;28(4):342-53. X-1, X-3, X-4. [pmid: 21914906].
508 Brewin BJ, Renwick R, Schormans AF. Parental perspectives of the quality of life in school environments for children with Asperger syndrome. Focus Autism Dev Disabil. Dec. 2008;23(4):242-52. X-3.
509 Brightman RP, Baker BL, Clark DB, et al. Effectiveness of alternative parent training formats. J Behav Ther Exp Psychiatry. Jun. 1982;13(2):113-7. X-1, X-3, X-4. [pmid: 6215431].
510 Bristol MM, et al. State of the science in autism: report to the National Institutes of Health. J Autism Dev Disord. Apr. 1996;26(2):121-54. X-1, X-2, X-3, X-4. [pmid: 8744475].
511 Britton LN, Carr JE, Kellum KK, et al. A variation of noncontingent reinforcement in the treatment of aberrant behavior. Res Dev Disabil. Nov–Dec. 2000;21(6):425-35. X-3, X-4. [pmid: 11153827].
512 Britton LN, Carr JE, Landaburu HJ, et al. The efficacy of non-contingent reinforcement as treatment for automatically reinforced stereotypy. Behav Interv. Apr–Jun. 2002;17(2):93-103. X-1, X-3.
513 Broadstock M, Doughty C, Eggleston M. Systematic review of the effectiveness of pharmacological treatments for adolescents and adults with autism spectrum disorder. Autism. 2007;11(4):335-48. X-2. [pmid: 17656398].
514 Brock M, Hatton D. Distinguishing features of autism in boys with Fragile X Syndrome. J Intellect Disabil Res. Oct. 2010;54(10):894-905. X-4. [pmid: 20704635].
515 Brock SE. An examination of the changing rates of autism in special education. Calif School Psychol. 2006;11:31-40. X-1, X-2, X-4.
516 Broderick AA. Autism, “recovery (to normalcy),” and the politics of hope. Intellect Dev Disabil. Aug. 2009;47(4):263-81. X-2, X-4. [pmid: 19650681].
517 Broderick AA, Ne’eman A. Autism as metaphor: narrative and counter-narrative. Int J Inclusive Educ. Sep. 2008;12(5–6):459-76. X-2, X-4.
518 Broderick C, Caswell R, Gregory S, et al. ‘Can I join the club?’: a social integration scheme for adolescents with Asperger syndrome. Autism. Dec. 2002;6(4):427-31. X-2. [pmid: 12540132].
519 Bromfield R. It’s the tortoise’s race: long-term psychodynamic psychotherapy with a high-functioning autistic adolescent. Psychoanal Inq. Special Issue: Autistic spectrum disorders and psychoanalytic ideas: Reassessing the fit. 2000;20(5):732-45. X-3.
520 Bromley BE. Broadcasting disability: an exploration of the educational potential of a video sharing web site. J Spec Educ Technology. 2008;23(4):2008-9. X-4.
521 Bromley RL, Mawer G, Clayton-Smith J, et al. Autism spectrum disorders following in utero exposure to antiepileptic drugs. Neurology. Dec. 2. 2008;71(23):1923-4. X-1, X-3, X-4. [pmid: 19047565].
522 Brookman-Frazee L. Using parent/clinician partnerships in parent education programs for children with autism. J Posit Behav Interv. Fal. 2004;6(4):195-213. X-1, X-3, X-4.
523 Brookman-Frazee L, Baker-Ericzen M, Stahmer A, et al. Involvement of youths with autism spectrum disorders or intellectual disabilities in multiple public service systems. J Ment Health Res Intellect Disabil. 2009;2(3):201-19. X-4. [pmid: 19809531].
524 Brookman-Frazee L, LaRosa A, Nyp SS, et al. Journal article reviews. J Dev Behav Pediatr. Apr. 2011;32(3):268. X-1, X-2, X-3.
525 Brookman-Frazee L, Stahmer A, Baker-Ericzen MJ, et al. Parenting interventions for children with autism spectrum and disruptive behavior disorders: opportunities for cross-fertilization. Clin Child Fam Psychol Rev. Dec. 2006;9(3–4):181-200. X-2. [pmid: 17053963].
526 Brookman-Frazee LI, Taylor R, Garland AF. Characterizing community-based mental health services for children with autism spectrum disorders and disruptive behavior problems. J Autism Dev Disord. Oct. 2010;40(10):1188-201. X-1, X-3, X-4. [pmid: 20204690].
527 Brosnan J, Healy O. A review of behavioral interventions for the treatment of aggression in individuals with developmental disabilities. Res Dev Disabil. Mar–Apr. 2011;32(2):437-46. X-1, X-2, X-3. [pmid: 21239140].
528 Broun L. Take the pencil out of the process. Teach Except Child. Sep–Oct. 2009;42(1):14-21. X-2, X-4.
529 Browder DM, Trela K, Jimenez B. Training teachers to follow a task analysis to engage middle school students with moderate and severe developmental disabilities in grade-appropriate literature. Focus Autism Dev Disabil. 2007;22(4):206-19. X-1, X-3, X-4.
530 Browder JA. Pediatric diagnosis and management of children with developmental disabilities. J Dev Behav Pediatr. Jun. 1983;4(2):99-102. X-1, X-3, X-4. [pmid: 6192153].
531 Brower-Breitwieser CM, Miltenberger RG, Gross A, et al. The use of concurrent operants preference assessment to evaluate choice of interventions for children diagnosed with autism. Int J Behav Consult Ther. Special Issue: Applied behavior analysis in developmental disabilities. 2008;4(3):270-8. X-1, X-3, X-4.
532 Brown DW. Autism, Asperger’s syndrome and the Crick-Mitchison theory of the biological function of REM sleep. Med Hypotheses. Nov. 1996;47(5):399-403. X-2. [pmid: 8951804].
533 Brown GE, Jones SD, MacKewn AS, et al. An exploration of possible pre- and postnatal correlates of autism: a pilot survey. Psychol Rep. Feb. 2008;102(1):273-82. X-4. [pmid: 18481687].
534 Brown J, Murray D. Strategies for enhancing play skills for children with autism spectrum disorder. Educ Train Ment Retard Dev Disabil. Sep. 2001;36(3):312-7. X-2.
535 Brown KA, Wacker DP, Derby KM, et al. Evaluating the effects of functional communication training in the presence and absence of establishing operations. J Appl Behav Anal. Spring. 2000;33(1):53-71. X-3. [pmid: 10738952].
536 Brown KE, Mirenda P. Contingency mapping: use of a novel visual support strategy as an adjunct to functional equivalence training. J Posit Behav Interv. Sum. 2006;8(3):155-64. X-3.
537 Brown N, Panksepp J. Low-dose naltrexone for disease prevention and quality of life. Med Hypotheses. Mar. 2009;72(3):333-7. X-2. [pmid: 19041189].
538 Brown T. Right treatment, right patient?. Am J Nurs. Jun. 2011;111(6):72. X-1, X-2, X-3, X-4. [pmid: 21613926].
539 Brown WT, Cohen IL, Fisch GS, et al. High dose folic acid treatment of fragile (X) males. Am J Med Genet. Jan–Feb. 1986;23(1–2):263-71. X-1, X-3, X-4. [pmid: 3513568].
540 Browne ME. Communicating with the child who has autistic spectrum disorder: a practical introduction. Paediatr Nurs. Feb. 2006;18(1):14-7. X-2, X-4. [pmid: 16518946].
541 Brownell MD. Musically adapted social stories to modify behaviors in students with autism: four case studies. J Music Ther. Sum. 2002;39(2):117-44. X-1, X-3, X-4. [pmid: 12213082].
542 Browning ER. A memory pacer for improving stimulus generalization. J Autism Dev Disord. Dec. 1983;13(4):427-32. X-1, X-2, X-3, X-4. [pmid: 6662845].
543 Brownlow C. Presenting the self: negotiating a label of autism. J Intellect Dev Disabil. Mar. 2010;35(1):14-21. X-2, X-4. [pmid: 20121662].
544 Brownlow C, O’Dell L. Challenging understandings of “theory of mind”: a brief report. Intellect Dev Disabil. Dec. 2009;47(6):473-8. X-2. [pmid: 20020803].
545 Bruce SM, Vargas C. Intentional communication acts expressed by children with severe disabilities in high-rate contexts. Augment Altern Commun. 2007;23(4):300-11. X-3, X-4. [pmid: 17852056].
546 Bruck M, London K, Landa R, et al. Autobiographical memory and suggestibility in children with autism spectrum disorder. Dev Psychopathol. Winter. 2007;19(1):73-95. X-4. [pmid: 17241485].
547 Bruder MB. A well walked path to program efficacy: the details tell the story. Topics Early Child Spec Educ. Nov. 2011;31(3):158-61. X-1, X-2, X-3, X-4.
548 Brudnak MA. Application of genomeceuticals to the molecular and immunological aspects of autism. Med Hypotheses. Aug. 2001;57(2):186-91. X-2, X-4. [pmid: 11461171].
549 Brudnak MA. Probiotics as an adjuvant to detoxification protocols. Med Hypotheses. May. 2002;58(5):382-5. X-2, X-4. [pmid: 12056873].
550 Brudnak MA, Rimland B, Kerry RE, et al. Enzyme-based therapy for autism spectrum disorders -- is it worth another look?. Med Hypotheses. May. 2002;58(5):422-8. X-2. [pmid: 12056881].
551 Brulotte J, Bukutu C, Vohra S. Complementary, holistic, and integrative medicine: fish oils and neurodevelopmental disorders. Pediatr Rev. Apr. 2009;30(4):e29-33. X-2. [pmid: 19339384].
552 Bruneau N, Barthelemy C, Roux S, et al. Auditory evoked potential modifications according to clinical and biochemical responsiveness to fenfluramine treatment in children with autistic behavior. Neuropsychobiology. 1989;21(1):48-52. X-3. [pmid: 2682347].
553 Bruneau N, Garreau B, Roux S, et al. Modulation of auditory evoked potentials with increasing stimulus intensity in autistic children. Electroencephalogr Clin Neurophysiol Suppl. 1987;40:584-9. X-1, X-3, X-4. [pmid: 3480179].
554 Bruneau N, Roux S, Adrien JL, et al. Auditory associative cortex dysfunction in children with autism: evidence from late auditory evoked potentials (N1 wave-T complex). Clin Neurophysiol. Nov. 1999;110(11):1927-34. X-4. [pmid: 10576489].
555 Brunner DL, Seung H. Evaluation of the efficacy of communication-based treatments for autism spectrum disorders: a literature review. Commun Disord Q. 2009;31(1):15-41. X-2, X-4.
556 Bruns DA, Gallagher EA. Having their piece of the PIIE: promoting the communicative behaviors of young children with autism/PDD. Young Except Child. Win. 2003;6(2):20-7. X-1, X-3, X-4.
557 Brusa E, Richman D. Developing stimulus control for occurrences of stereotypy exhibited by a child with autism. Int J Behav Consult Ther. Special Issue: Applied behavior analysis in developmental disabilities. 2008;4(3):264-9. X-1, X-3, X-4.
558 Bryan LC, Gast DL. Teaching on-task and on-schedule behaviors to high-functioning children with autism via picture activity schedules. J Autism Dev Disord. Dec. 2000;30(6):553-67. X-1, X-3, X-4. [pmid: 11261467].
559 Bryson SA, Corrigan SK, McDonald TP, et al. Characteristics of children with autism spectrum disorders who received services through community mental health centers. Autism. Jan. 2008;12(1):65-82. X-2, X-4. [pmid: 18178597].
560 Bryson SE. Brief report: epidemiology of autism. J Autism Dev Disord. Apr. 1996;26(2):165-67. X-1, X-2, X-3, X-4. [pmid: 8744478].
561 Bryson SE, Koegel LK, Koegel RL, et al. Large scale dissemination and community implementation of pivotal response treatment: program description and preliminary data. Res Pract Persons Severe Disabl. Sum. 2007;32(2):142-53. X-1, X-4.
562 Bucholz JL, Brady MP. Teaching positive work behavior with literacy-based behavioral interventions: an intervention for students and employees with developmental disabilities. Teach Except Child. Nov–Dec. 2008;41(2):50-5. X-2.
563 Buchsbaum MS, Hollander E, Haznedar MM, et al. Effect of fluoxetine on regional cerebral metabolism in autistic spectrum disorders: a pilot study. Int J Neuropsychopharmacol. Jun. 2001;4(2):119-25. X-3. [pmid: 11466160].
564 Buchwald JS, Erwin R, Van Lancker D, et al. Midlatency auditory evoked responses: P1 abnormalities in adult autistic subjects. Electroencephalogr Clin Neurophysiol. Mar–Apr. 1992;84(2):164-71. X-4. [pmid: 1372231].
565 Buck LA, Goldstein F, Kardeman E. Art as a means of interpersonal communication in autistic young adults. J Psychol Christ. Fal. 1984;3(3):73-84. X-3.
566 Buck LA, Kardeman E, Goldstein F. Artistic talent in “autistic” adolescents and young adults. Empir Stud Arts. 1985;3(1):81-104. X-3.
567 Buckley SD, Newchok DK. Differential impact of response effort within a response chain on use of mands in a student with autism. Res Dev Disabil. Jan–Feb. 2005;26(1):77-85. X-3. [pmid: 15590240].
568 Buckley SD, Newchok DK. An evaluation of simultaneous presentation and differential reinforcement with response cost to reduce packing. J Appl Behav Anal. Fall. 2005;38(3):405. X-1, X-3, X-4. [pmid: 16270850].
569 Buckley SD, Newchok DK. Analysis and treatment of problem behavior evoked by music. J Appl Behav Anal. Spr. 2006;39(1):141-4. X-1, X-3. [pmid: 16602395].
570 Buckley SD, Strunck PG, Newchok DK. A comparison of two multicomponent procedures to increase food consumption. Behav Interv. Apr. 2005;20(2):139-46. X-1, X-3, X-4.
571 Budd KS, Hella B, Bae H, et al. Delivering parent-child interaction therapy in an urban community clinic. Cogn Behav Pract. Nov. 2011;18(4):502-14. X-3.
572 Buffington DM, Krantz PJ, McClannahan LE, et al. Procedures for teaching appropriate gestural communication skills to children with autism. J Autism Dev Disord. Dec. 1998;28(6):535-45. X-3. [pmid: 9932240].
573 Buggey T. Video self-modeling applications with students with autism spectrum disorder in a small private school setting. Focus Autism Dev Disabil. Spr. 2005;20(1):52-63. X-3.
574 Buggey T. A picture is worth...: video self-modeling applications at school and home. J Posit Behav Interv. 2007;9(3):151-8. X-2, X-4.
575 Buggey T, Hoomes G. Using video self-modeling with preschoolers with autism spectrum disorder: seeing can be believing. Young Except Child. Sep. 2011;14(3):2-12. X-1, X-3, X-4.
576 Buggey T, Toombs K, Gardener P, et al. Training responding behaviors in students with autism: using videotaped self-modeling. J Posit Behav Interv. Fal. 1999;1(4):205-14. X-1, X-3, X-4.
577 Buhagiar N. Symposium on paediatrics. Preschool autistic children: therapists’ perspectives on practice. Int J Ther Rehabil. 2000;7(10):414-7. X-1, X-3, X-4.
578 Buitelaar JK. Why have drug treatments been so disappointing?. Novartis Found Symp. 2003;251:235-44. discussion 45–9, 81–97. X-2, X-4. [pmid: 14521196].
579 Buitelaar JK, Dekker ME, van Ree JM, et al. A controlled trial with ORG 2766, an ACTH-4–9 analog, in 50 relatively able children with autism. Eur Neuropsychopharmacol. Mar. 1996;6(1):13-9. X-1, X-3, X-4. [pmid: 8866933].
580 Buitelaar JK, van der Gaag RJ, van der Hoeven J. Buspirone in the management of anxiety and irritability in children with pervasive developmental disorders: results of an open-label study. J Clin Psychiatry. Feb. 1998;59(2):56-9. X-3. [pmid: 9501886].
581 Buitelaar JK, van Engeland H, de Kogel CH, et al. Deficits in social behavior in autism and their modification by a synthetic adrenocorticotrophic hormone 4–9 analog. Experientia. Apr. 15. 1992;48(4):391-4. X-2. [pmid: 1316288].
582 Buitelaar JK, van Engeland H, de Kogel K, et al. The adrenocorticotrophic hormone 4–9 analog ORG 2766 benefits autistic children: report on a second controlled clinical trial. J Am Acad Child Adolesc Psychiatry. Nov. 1992;31(6):1149-56. X-1, X-3, X-4. [pmid: 1331023].
583 Buitelaar JK, van Engeland H, de Kogel KH, et al. The use of adrenocorticotrophic hormone 4–9 analog ORG 2766 in autistic children: effects on the organization of behavior. Biol Psychiatry. Jun. 1. 1992;31(11):1119-29. X-3. [pmid: 1326339].
584 Buitelaar JK, van Engeland H, van Ree JM, et al. Behavioral effects of Org 2766, a synthetic analog of the adrenocorticotrophic hormone 4–9 in 14 outpatient autistic children. J Autism Dev Disord. Dec. 1990;20(4):467-78. X-3. [pmid: 2177746].
585 Buitelaar JK, Willemsen-Swinkels SH. Medication treatment in subjects with autistic spectrum disorders. Eur Child Adolesc Psychiatry. Suppl 1. 2000;9:I85-97. X-2, X-3, X-4. [pmid: 11140783].
586 Burd L, Fisher W, Kerbeshian J. Pervasive developmental disorders in multiply disabled children. Rehabil Lit. Sep–Oct. 1985;46(9–10):246-9. X-1, X-2, X-3, X-4. [pmid: 4070778].
587 Burd L, Gascon G, Kerbeshian J. Rett Syndrome: Case reports and management strategies. Neurosci Biobehav Rev. Special Issue: Tourette’s syndrome and movement disorders. Fal–Win. 1988;12(3–4):283-7. X-1, X-3, X-4. [pmid: 3226656].
588 Burd L, Kerbeshian J, Westerland A, et al. Prospective long-term follow-up of patients with pervasive developmental disorders. J Child Neurol. Sep. 2002;17(9):681-8. X-3, X-4. [pmid: 12503645].
589 Burd L, Stenehjem A, Franceschini LA, et al. A 15-year follow-up of a boy with pyridoxine (vitamin B_6_)-dependent seizures with autism, breath holding, and severe mental retardation. J Child Neurol. Nov. 2000;15(11):763-5. X-3. [pmid: 11108513].
590 Burgess DC, Burgess MA, Leask J. The MMR vaccination and autism controversy in United Kingdom 1998–2005 inevitable community outrage or a failure of risk communication?. Vaccine. May. 1. 2006;24(18):3921-8. X-2, X-4. [pmid: 16564116].
591 Burke JC. Some developmental implications of a disturbance in responding to complex environmental stimuli. Am J Ment Retard. Jul. 1991;96(1):37-52. X-1, X-2, X-3, X-4. [pmid: 1878187].
592 Burke JC, Cerniglia L. Stimulus complexity and autistic children’s responsivity: assessing and training a pivotal behavior. J Autism Dev Disord. Jun. 1990;20(2):233-53. X-1, X-3, X-4. [pmid: 2347822].
593 Burke LM, Kalpakjian CZ, Smith YR, et al. Gynecologic issues of adolescents with Down syndrome, autism, and cerebral palsy. J Pediatr Adolesc Gynecol. Feb. 2010;23(1):11-5. X-3, X-4. [pmid: 19643648].
594 Burke P. Listening to young people with special needs: the influence of group activities. J Intellect Disabil. Dec. 2005;9(4):359-76. X-2. [pmid: 16330489].
595 Burke RV, Andersen MN, Bowen SL, et al. Evaluation of two instruction methods to increase employment options for young adults with autism spectrum disorders. Res Dev Disabil. Nov–Dec. 2010;31(6):1223-33. X-3. [pmid: 20800988].
596 Burkhart N. Understanding and managing the autistic child in the dental office. Dent Hyg (Chic). Feb. 1984;58(2):60-3. X-1, X-2, X-3, X-4. [pmid: 6239794].
597 Burrows KE, Adams CL. Challenges of service-dog ownership for families with autistic children: lessons for veterinary practitioners. J Vet Med Educ. Winter. 2008;35(4):559-66. X-2. [pmid: 19228909].
598 Burrows KE, Adams CL, Spiers J. Sentinels of safety: service dogs ensure safety and enhance freedom and well-being for families with autistic children. Qual Health Res. Dec. 2008;18(12):1642-9. X-1, X-3, X-4. [pmid: 18955467].
599 Burstein ND. The effects of classroom organization on mainstreamed preschool children. Except Child. Feb. 1986;52(5):425-34. X-1, X-3, X-4. [pmid: 2936606].
600 Burt DB, Fuller SP, Lewis KR. Brief report: competitive employment of adults with autism. J Autism Dev Disord. Jun. 1991;21(2):237-42. X-3. [pmid: 1864830].
601 Busch de Ahumada LC, Ahumada JL. From mimesis to agency: clinical steps in the work of psychic two-ness. Int J Psychoanal. Jun. 2005;86(3):721-36. X-1, X-3, X-4. [pmid: 16096072].
602 Buschbacher P, Fox L, Clarke S. Recapturing desired family routines: a parent-professional behavioral collaboration. Res Pract Persons Severe Disabl. Spr. 2004;29(1):25-39. X-1, X-3, X-4.
603 Buschbacher PW, Fox L. Understanding and intervening with the challenging behavior of young children with autism spectrum disorder. Lang Speech Hear Serv Sch. Jul. 2003;34(3):217-27. X-1, X-2, X-3, X-4.
604 Buschmann A, Jooss B, Rupp A, et al. Children with developmental language delay at 24 months of age: results of a diagnostic work-up. Dev Med Child Neurol. Mar. 2008;50(3):223-9. X-4. [pmid: 18266869].
605 Butler LR, Luiselli JK. Escape-maintained problem behavior in a child with autism: antecedent functional analysis and intervention evaluation of noncontingent escape and instructional fading. J Posit Behav Interv. 2007;9(4):195-202. X-1, X-3, X-4.
606 Butter EM, Mulick JA, Metz B. Eight case reports of learning recovery in children with pervasive developmental disorders after early intervention. Behav Interv. Nov. 2006;21(4):227-43. X-3.
607 Butter EM, Wynn J, Mulick JA. Early intervention critical to autism treatment. Pediatr Ann. Oct. 2003;32(10):677-84. X-2, X-4. [pmid: 14606218].
608 Cabay M. Brief report: a controlled evaluation of facilitated communication using open-ended and fill-in questions. J Autism Dev Disord. Aug. 1994;24(4):517-27. X-1, X-3, X-4. [pmid: 7961334].
609 Caci B, D’Amico A, Cardaci M. New frontiers for psychology and education: robotics. Psychol Rep. Jun. 2004;94(3 Pt 2):1372-4. X-2, X-4. [pmid: 15362418].
610 Cafiero JM. The effect of an augmentative communication entervention on the communication, behavior, and academic program of an adolescent with autism. Focus Autism Dev Disabil. Fall. 2001;16(3):179-89. X-3.
611 Caglayan AO. Genetic causes of syndromic and non-syndromic autism. Dev Med Child Neurol. Feb. 2010;52(2):130-8. X-2, X-4. [pmid: 20059518].
612 Caicedo C, Williams SH. Risperidone improves behavior in children with autism. J Fam Pract. Nov. 2002;51(11):915. X-1, X-3, X-4. [pmid: 12485538].
613 Cain J. Teaming from three perspectives: interviews with participatory action research participants. Kairaranga. 2008;9(spec iss):43-5. X-1, X-3, X-4.
614 Calandrillo SP. Vanishing vaccinations: why are so many Americans opting out of vaccinating their children?. Univ Mich J Law Reform. Winter. 2004;37(2):353-440. X-2, X-4. [pmid: 15568260].
615 Calarge CA, Miller del D. Predictors of risperidone and 9-hydroxyrisperidone serum concentration in children and adolescents. J Child Adolesc Psychopharmacol. Apr. 2011;21(2):163-9. X-1, X-4. [pmid: 21486167].
616 Calculator SH, Singer KM. Letter to the editor: preliminary validation of facilitated communication. Top Lang Disord. Nov. 1992;13(1):ix-xvi. X-3.
617 Calder AJ, Lawrence AD, Keane J, et al. Reading the mind from eye gaze. Neuropsychologia. 2002;40(8):1129-38. X-4,. [pmid: 11931917].
618 Cale SI, Carr EG, Blakeley-Smith A, et al. Context-based assessment and intervention for problem behavior in children with autism spectrum disorder. Behav Modif. Nov. 2009;33(6):707-42. X-3. [pmid: 19933441].
619 Calhoun VD, Kiehl KA, Pearlson GD. Modulation of temporally coherent brain networks estimated using ICA at rest and during cognitive tasks. Hum Brain Mapp. Jul. 2008;29(7):828-38. X-2, X-4. [pmid: 18438867].
620 Callahan K, Henson RK, Cowan AK. Social validation of evidence-based practices in autism by parents, teachers, and administrators. J Autism Dev Disord. Apr. 2008;38(4):678-92. X-4. [pmid: 17924182].
621 Callahan K, Rademacher JA. Using self-management strategies to increase the on-task behavior of a student with autism. J Posit Behav Interv. Spr. 1999;1(2):117-22. X-1, X-3, X-4.
622 Callahan K, Shukla-Mehta S, Magee S, et al. ABA versus TEACCH: the case for defining and validating comprehensive treatment models in autism. J Autism Dev Disord. Jan. 2010;40(1):74-88. X-4. [pmid: 19649699].
623 Callicott KJ. Culturally sensitive collaboration within person-centered planning. Focus Autism Dev Disabil. Spr. 2003;18(1):60-8. X-1, X-2, X-3, X-4.
624 Campbell A, Tincani M. The power card strategy: strength-based intervention to increase direction following of children with autism spectrum disorder. J Posit Behav Interv. Oct. 2011;13(4):240-9. X-1, X-3, X-4.
625 Campbell DB, Buie TM, Winter H, et al. Distinct genetic risk based on association of MET in families with co-occurring autism and gastrointestinal conditions. Pediatrics. Mar. 2009;123(3):1018-24. X-4. [pmid: 19255034].
626 Campbell DG, Reichle NC, Van Bourgondien ME. The Autism Survey: an evaluation of reliability and validity. J Autism Dev Disord. Dec. 1996;26(6):621-34. X-1, X-3, X-4. [pmid: 8986848].
627 Campbell JM. Efficacy of behavioral interventions for reducing problem behavior in persons with autism: a quantitative synthesis of single-subject research. Res Dev Disabil. Mar–Apr. 2003;24(2):120-38. X-1, X-2, X-3, X-4. [pmid: 12623082].
628 Campbell JM. Statistical comparison of four effect sizes for single-subject designs. Behav Modif. Mar. 2004;28(2):234-46. X-2, X-4. [pmid: 14997950].
629 Campbell JM. Middle school students’ response to the self-introduction of a student with autism: effects of perceived similarity, prior awareness, and educational message. Remedial Spec Educ. May–Jun. 2007;28(3):163-73. X-3, X-4.
630 Campbell M, Adams P, Small AM, et al. Efficacy and safety of fenfluramine in autistic children. J Am Acad Child Adolesc Psychiatry. Jul. 1988;27(4):434-9. X-1, X-3, X-4. [pmid: 3053609].
631 Campbell M, Adams P, Small AM, et al. Naltrexone in infantile autism. Psychopharmacol Bull. 1988;24(1):135-9. X-1, X-3, X-4. [pmid: 3387517].
632 Campbell M, Anderson LT, Deutsch SI, et al. Psychopharmacological treatment of children with the syndrome of autism. Pediatr Ann. Apr. 1984;13(4):309-13. 16. X-1, X-2, X-3, X-4. [pmid: 6145142].
633 Campbell M, Anderson LT, Green WH. Behavior-disordered and aggressive children: new advances in pharmacotherapy. J Dev Behav Pediatr. Dec. 1983;4(4):265-71. X-1, X-2, X-3, X-4. [pmid: 6582068].
634 Campbell M, Anderson LT, Small AM. Pharmacotherapy in autism: a summary of research at Bellevue/New York University. Brain Dysfunct. Nov–Dec. 1990;3(5–6):299-307. X-1, X-3, X-4.
635 Campbell M, Anderson LT, Small AM, et al. Naltrexone in autistic children: behavioral symptoms and attentional learning. J Am Acad Child Adolesc Psychiatry. Nov. 1993;32(6):1283-91. X-1, X-3, X-4. [pmid: 8282676].
636 Campbell M, Anderson LT, Small AM, et al. Naltrexone in autistic children: a double-blind and placebo-controlled study. Psychopharmacol Bull. 1990;26(1):130-5. X-1, X-3, X-4. [pmid: 2196621].
637 Campbell M, Anderson LT, Small AM, et al. The effects of haloperidol on learning and behavior in autistic children. J Autism Dev Disord. Jun. 1982;12(2):167-75. X-1, X-3, X-4. [pmid: 7174605].
638 Campbell M, Armenteros JL, Malone RP, et al. Neuroleptic-related dyskinesias in autistic children: a prospective, longitudinal study. J Am Acad Child Adolesc Psychiatry. Jun. 1997;36(6):835-43. X-1, X-3, X-4. [pmid: 9183140].
639 Campbell M, Cohen IL, Anderson LT. Pharmacotherapy for autistic children: a summary of research. Can J Psychiatry. Jun. 1981;26(4):265-73. X-1, X-2, X-3, X-4. [pmid: 6117366].
640 Campbell M, Deutsch SI, Perry R, et al. Short-term efficacy and safety of fenfluramine in hospitalized preschool-age autistic children: an open study. Psychopharmacol Bull. 1986;22(1):141-7. X-1, X-3, X-4. [pmid: 3726060].
641 Campbell M, Harris JC. Resolved: autistic children should have a trial of naltrexone. J Am Acad Child Adolesc Psychiatry. Feb. 1996;35(2):246-9. discussion 9–51. X-1, X-2, X-3, X-4. [pmid: 8720635].
642 Campbell M, Locascio JJ, Choroco MC, et al. Stereotypies and tardive dyskinesia: abnormal movements in autistic children. Psychopharmacol Bull. 1990;26(2):260-6. X-1, X-3, X-4. [pmid: 2236468].
643 Campbell M, Overall JE, Small AM, et al. Naltrexone in autistic children: an acute open dose range tolerance trial. J Am Acad Child Adolesc Psychiatry. Mar. 1989;28(2):200-6. X-1, X-3, X-4. [pmid: 2925573].
644 Campbell M, Palij M. Behavioral and cognitive measures used in psychopharmacological studies of infantile autism. Psychopharmacol Bull. 1985;21(4):1047-53. X-1, X-3, X-4. [pmid: 4089099].
645 Campbell M, Perry R, Polonsky BB, et al. An open study of fenfluramine in hospitalized young autistic children. J Autism Dev Disord. Dec. 1986;16(4):495-506. X-1, X-3, X-4. [pmid: 3804962].
646 Campbell RV, Lutzker JR. Using functional equivalence training to reduce severe challenging behavior: a case study. J Dev Phys Disabil. Sep. 1993;5(3):203-16. X-1, X-3, X-4.
647 Canitano R. Clinical experience with Topiramate to counteract neuroleptic induced weight gain in 10 individuals with autistic spectrum disorders. Brain Dev. Apr. 2005;27(3):228-32. X-3. [pmid: 15737706].
648 Canitano R. Self injurious behavior in autism: clinical aspects and treatment with risperidone. J Neural Transm. Mar. 2006;113(3):425-31. X-3. [pmid: 16075185].
649 Cann P. Timely intervention. Nurs Stand. Apr 26-May 2. 2000;14(32):20. X-2. [pmid: 11975289].
650 Cantu ES, Stone JW, Wing AA, et al. Cytogenetic survey for autistic fragile X carriers in a mental retardation center. Am J Ment Retard. Jan. 1990;94(4):442-7. X-4. [pmid: 2297426].
651 Caplan R, Guthrie D, Komo S. Blink rate in children with attention-deficit–hyperactivity disorder. Biol Psychiatry. Jun. 1996;39(12):1032-8. X-1, X-3, X-4. [pmid: 8780838].
652 Capone GT, Goyal P, Grados M, et al. Risperidone use in children with Down syndrome, severe intellectual disability, and comorbid autistic spectrum disorders: a naturalistic study. J Dev Behav Pediatr. Apr. 2008;29(2):106-16. X-1, X-3, X-4. [pmid: 18349709].
653 Capp PL, de Faria ME, Siqueira SR, et al. Special care dentistry: Midazolam conscious sedation for patients with neurological diseases. Eur J Paediatr Dent. Dec. 2010;11(4):162-4. X-2, X-3, X-4. [pmid: 21250764].
654 Capute AJ, Palmer FB. A pediatric overview of the spectrum of developmental disabilities. J Dev Behav Pediatr. Jun. 1980;1(2):66-9. X-1, X-2, X-3, X-4. [pmid: 6164696].
655 Caraballo RH, Sakr D, Mozzi M, et al. Symptomatic occipital lobe epilepsy following neonatal hypoglycemia. Pediatr Neurol. Jul. 2004;31(1):24-9. X-3, X-4. [pmid: 15246488].
656 Carbone PS, Behl DD, Azor V, et al. The medical home for children with autism spectrum disorders: parent and pediatrician perspectives. J Autism Dev Disord. Mar. 2010;40(3):317-24. X-4. [pmid: 19768528].
657 Carbone PS, Farley M, Davis T. Primary care for children with autism. Am Fam Physician. Feb. 15. 2010;81(4):453-60. X-2, X-4. [pmid: 20148499].
658 Carbone VJ, Sweeney-Kerwin EJ, Attanasio V, et al. Increasing the vocal responses of children with autism and developmental disabilities using manual sign mand training and prompt delay. J Appl Behav Anal. Winter. 2010;43(4):705-9. X-1, X-3, X-4. [pmid: 21541153].
659 Cardaciotto L, Herbert JD. Cognitive behavior therapy for social anxiety disorder in the context of Asperger’s syndrome: a single-subject report. Cogn Behav Pract. Win. 2004;11(1):75-81. X-3, X-4.
660 Cardon TA, Wilcox MJ. Promoting imitation in young children with autism: a comparison of reciprocal imitation training and video modeling. J Autism Dev Disord. May. 2011;41(5):654-66. X-1, X-3, X-4. [pmid: 20697791].
661 Cardon TA, Wilcox MJ, Campbell PH. Caregiver perspectives about assistive technology use with their young children with autism spectrum disorders. Infants Young Child. Apr–Jun. 2011;24(2):153-73. X-1, X-3, X-4.
662 Cardoso C, Montenegro ML. Speech and language pathology and autistic spectrum. Span J Psychol. Nov. 2009;12(2):686-95. X-3. [pmid: 19899669].
663 Carey T, Ratliff-Schaub K, Funk J, et al. Double-blind placebo-controlled trial of secretin: effects on aberrant behavior in children with autism. J Autism Dev Disord. Jun. 2002;32(3):161-7. X-1, X-3, X-4. [pmid: 12108617].
664 Carlson B, McLaughlin TF, Derby KM, et al. Teaching preschool children with autism and developmental delays to write. Electronic J Res Educ Psychol. Apr. 2009;7(1):225-38. X-1, X-3, X-4.
665 Carlson GA, Mick E. Drug-induced disinhibition in psychiatrically hospitalized children. J Child Adolesc Psychopharmacol. Summer. 2003;13(2):153-63. X-2. [pmid: 12880509].
666 Carlson JI, Luiselli JK, Slyman A, et al. Choice-making as intervention for public disrobing in children with developmental disabilities. J Posit Behav Interv. Apr. 2008;10(2):86-90. X-3.
667 Carlson JS, Brinkman T, Majewicz-Hefley A. Medication treatment outcomes for school-aged children diagnosed with autism. Calif School Psychol. 2006;11:21-30. X-1, X-2, X-3, X-4.
668 Carlson TS, McGeorge CR, Halvorson S. Marriage and family therapists’ ability to diagnose Aspergers’ syndrome: a vignette study. Contemp Fam Ther. Jun. 2007;29(1–2):25-37. X-4.
669 Carlsson LH, Gillberg C, Lannerö E, et al. Autism: screening toddlers with CHAT in a child health care programme did not improve early identification. Acta Paediatrica. Dec. 2010;99(12):1897-9. X-1, X-3, X-4. [pmid: 20670307].
670 Carminati GG, Gerber F, Baud MA, et al. Evaluating the effects of a structured program for adults with autism spectrum disorders and intellectual disabilities. Res Autism Spectr Disord. Jul–Sep. 2007;1(3):256-65. X-1, X-3, X-4.
671 Carmody DP, Kaplan M, Gaydos AM. Spatial orientation adjustments in children with autism in Hong Kong. Child Psychiatry Hum Dev. Spring. 2001;31(3):233-47. X-1, X-3, X-4. [pmid: 11196013].
672 Carmody DP, Moreno R, Mars AE, et al. Brief report: brain activation to social words in a sedated child with autism. J Autism Dev Disord. Aug. 2007;37(7):1381-5. X-4. [pmid: 17136453].
673 Carnahan C, Basham J, Musti-Rao S. A low-technology strategy for increasing engagement of students with autism and significant learning needs. Exceptionality. Apr. 2009;17(2):76-87. X-1, X-3, X-4.
674 Carnahan C, Musti-Rao S, Bailey J. Promoting active engagement in small group learning experiences for students with autism and significant learning needs. Educ Treat Children. Feb. 2009;32(1):37-61. X-3.
675 Carnahan CR, Hume K, Clarke L, et al. using structured work systems to promote independence and engagement for students with autism spectrum disorders. Teach Except Child. Mar–Apr. 2009;41(4):6-14. X-2.
676 Caronna EB, Augustyn M, Zuckerman B. Revisiting parental concerns in the age of autism spectrum disorders: the need to help parents in the face of uncertainty. Arch Pediatr Adolesc Med. Apr. 2007;161(4):406-8. X-2. [pmid: 17404139].
677 Carpenter LA, Soorya L, Halpern D. Asperger’s syndrome and high-functioning autism. Pediatr Ann. Jan. 2009;38(1):30-5. X-2. [pmid: 19213291].
678 Carr D. Effects of exemplar training in exclusion responding on auditory-visual discrimination tasks with children with autism. J Appl Behav Anal. Winter. 2003;36(4):507-24. X-1, X-3, X-4. [pmid: 14768669].
679 Carr D, Felce J. Brief report: increase in production of spoken words in some children with autism after PECS teaching to Phase III. J Autism Dev Disord. Apr. 2007;37(4):780-7. X-1, X-3, X-4. [pmid: 17048094].
680 Carr D, Felce J. The effects of PECS teaching to Phase III on the communicative interactions between children with autism and their teachers. J Autism Dev Disord. Apr. 2007;37(4):724-37. X-1, X-3, X-4. [pmid: 17006780].
681 Carr D, Felce J. Teaching picture-to-object relations in picture-based requesting by children with autism: a comparison between error prevention and error correction teaching procedures. J Intellect Disabil Res. Apr. 2008;52(Pt 4):309-17. X-1, X-3, X-4. [pmid: 18339093].
682 Carr EG. Comment: replacing factionalism with functionalism. J Autism Dev Disord. Sep. 1991;21(3):277-80. X-1, X-2, X-3, X-4.
683 Carr EG, Blakeley-Smith A. Classroom intervention for illness-related problem behavior in children with developmental disabilities. Behav Modif. Nov. 2006;30(6):901-24. X-1, X-3, X-4. [pmid: 17050770].
684 Carr EG, Carlson JI. Reduction of severe behavior problems in the community using a multicomponent treatment approach. J Appl Behav Anal. Summer. 1993;26(2):157-72. X-1, X-3, X-4. [pmid: 8331013].
685 Carr EG, Darcy M. Setting generality of peer modeling in children with autism. J Autism Dev Disord. Mar. 1990;20(1):45-59. X-1, X-3, X-4. [pmid: 2324055].
686 Carr EG, Kemp DC. Functional equivalence of autistic leading and communicative pointing: analysis and treatment. J Autism Dev Disord. Dec. 1989;19(4):561-78. X-3. [pmid: 2606885].
687 Carr EG, Kologinsky E. Acquisition of sign language by autistic children. II: spontaneity and generalization effects. J Appl Behav Anal. Fall. 1983;16(3):297-314. X-3. [pmid: 6643322].
688 Carr EG, Kologinsky E, Leff-Simon S. Acquisition of sign language by autistic children. III: generalized descriptive phrases. J Autism Dev Disord. Jun. 1987;17(2):217-29. X-3. [pmid: 3610996].
689 Carr EG, Ladd MV, Schulte CF. Validation of the contextual assessment inventory for problem behavior. J Posit Behav Interv. 2008;10(2):91-104. X-4.
690 Carr EG, Levin L, McConnachie G, et al. Comprehensive multisituational intervention for problem behavior in the community: long-term maintenance and social validation. J Posit Behav Interv. Win. 1999;1(1):5-25. X-3.
691 Carr EG, Owen-DeSchryver JS. Physical illness, pain, and problem behavior in minimally verbal people with developmental disabilities. J Autism Dev Disord. Mar. 2007;37(3):413-24. X-4. [pmid: 16897378].
692 Carr EG, Pridal C, Dores PA. Speech versus sign comprehension in autistic children: analysis and prediction. J Exp Child Psychol. Jun. 1984;37(3):587-97. X-1, X-3. [pmid: 6747550].
693 Carr EG, Yarbrough SC, Langdon NA. Effects of idiosyncratic stimulus variables on functional analysis outcomes. J Appl Behav Anal. Winter. 1997;30(4):673-86. X-4. [pmid: 9433791].
694 Carr JE, Dozier CL, Patel MR, et al. Treatment of automatically reinforced object mouthing with noncontingent reinforcement and response blocking: experimental analysis and social validation. Res Dev Disabil. Jan–Feb. 2002;23(1):37-44. X-3, X-4. [pmid: 12071394].
695 Carré AJM, Le Grice B, Blampied NM, et al. Picture exchange communication (PECS) training for young children: does training transfer at school and to home?. Behav Change. May. 2009;26(1):54-65. X-1, X-3, X-4.
696 Carrington S, Graham L. Perceptions of school by two teenage boys with Asperger syndrome and their mothers: a qualitative study. Autism. Mar. 2001;5(1):37-48. X-3, X-4. [pmid: 11708388].
697 Carroll RA, Rapp JT, Rieck TM, et al. The effects of noncontingent reinforcement with alternative oral stimulation in the treatment of rumination. J Dev Disab. 2011;17(1):72-6. X-3.
698 Carter AS, Messinger DS, Stone WL, et al. A randomized controlled trial of hanen’s “more than words” in toddlers with early autism symptoms. J Child Psychol Psychiatry. Jul. 2011;52(7):741-52. X-1, X-3, X-4. [pmid: 21418212].
699 Carter AS, Volkmar FR, Sparrow SS, et al. The Vineland Adaptive Behavior Scales: supplementary norms for individuals with autism. J Autism Dev Disord. Aug. 1998;28(4):287-302. X-4. [pmid: 9711485].
700 Carter C, Meckes L, Pritchard L, et al. The Friendship Club: an after-school program for children with Asperger syndrome. Fam Community Health. Apr–Jun. 2004;27(2):143-50. X-1, X-3, X-4. [pmid: 15596981].
701 Carter EW, Sisco LG, Chung Y-C, et al. Peer interactions of students with intellectual disabilities and/or autism: a map of the intervention literature. Res Pract Persons Severe Disabl. Fall-Win. 2010;35(3–4):63-79. X-1, X-2, X-3.
702 Carter I. Positive and negative experiences of parents involved in online self-help groups for autism. J Dev Disab. 2009;15(1):44-52. X-4.
703 Carter J. Looking into a distorted mirror. J Clin Ethics. Spring-Summer. 2003;14(1–2):95-100. X-2. [pmid: 12953357].
704 Carter S. Bullying of students with Asperger syndrome. Issues Compr Pediatr Nurs. 2009;32(3):145-54. X-4. [pmid: 21992104].
705 Carvill S, Marston G. People with intellectual disability, sensory impairments and behaviour disorder: a case series. J Intellect Disabil Res. 2002;46(part 3):264-72. X-1, X-2, X-3, X-4. [pmid: 11896812].
706 Cascade EF, Kalali AH, Feifel D. Treatment of autistic children. Psychiatry. Feb. 2008;5(2):35-7. X-2, X-4. [pmid: 19727292].
707 Casella SE, Wilder DA, Neidert P, et al. The effects of response effort on safe performance by therapists at an autism treatment facility. J Appl Behav Anal. Win. 2010;43(4):729-34. X-1, X-3, X-4. [pmid: 21541157].
708 Case-Smith J, Arbesman M. Evidence-based review of interventions for autism used in or of relevance to occupational therapy. Am J Occup Ther. Jul–Aug. 2008;62(4):416-29. X-2. [pmid: 18712004].
709 Case-Smith J, Bryan T. The effects of occupational therapy with sensory integration emphasis on preschool-age children with autism. Am J Occup Ther. Sep–Oct. 1999;53(5):489-97. X-1, X-3, X-4. [pmid: 10500857].
710 Case-Smith J, Miller H. Occupational therapy with children with pervasive developmental disorders. Am J Occup Ther. Sep–Oct. 1999;53(5):506-13. X-4. [pmid: 10500859].
711 Casey BJ, Gordon CT, Mannheim GB, et al. Dysfunctional attention in autistic savants. J Clin Exp Neuropsychol. Nov. 1993;15(6):933-46. X-4. [pmid: 8120129].
712 Casey SD, Merical CL. The use of functional communication training without additional treatment procedures in an inclusive school setting. Behav Disord. Nov. 2006;32(1):46-54. X-3.
713 Cashin A, Sci DA, Barker P. The triad of impairment in autism revisited. J Child Adolesc Psychiatr Nurs. Nov. 2009;22(4):189-93. X-1, X-2, X-3, X-4. [pmid: 19930299].
714 Casiday RE. Children’s health and the social theory of risk: insights from the British measles, mumps and rubella (MMR) controversy. Soc Sci Med. Sep. 2007;65(5):1059-70. X-4. [pmid: 17540488].
715 Cass H, Gringras P, March J, et al. Absence of urinary opioid peptides in children with autism. Arch Dis Child. Sep. 2008;93(9):745-50. X-4. [pmid: 18337276].
716 Cassella MD, Sidener TM, Sidener DW, et al. Response interruption and redirection for vocal stereotypy in children with autism: a systematic replication. J Appl Behav Anal. Spring. 2011;44(1):169-73. X-1, X-3, X-4. [pmid: 21541114].
717 Cassidy A, McConkey R, Truesdale-Kennedy M, et al. Preschoolers with autism spectrum disorders: The impact on families and the supports available to them. Early Child Dev Care. Feb. 2008;178(2):115-28. X-1, X-3, X-4.
718 Castelli F. The Valley task: understanding intention from goal-directed motion in typical development and autism. Br J Dev Psychol. 2006;24(Part 4):655-68. X-4.
719 Castillo H, Patterson B, Hickey F, et al. Difference in age at regression in children with autism with and without Down syndrome. J Dev Behav Pediatr. Apr. 2008;29(2):89-93. X-4. [pmid: 18367994].
720 Castorina LL, Negri LM. The inclusion of siblings in social skills training groups for boys with Asperger syndrome. J Autism Dev Disord. Jan. 2011;41(1):73-81. X-1, X-3, X-4. [pmid: 20461452].
721 Catania CN, Almeida D, Liu-Constant B, et al. video modeling to train staff to implement discrete-trial instruction. J Appl Behav Anal. Sum. 2009;42(2):387-92. X-4. [pmid: 19949529].
722 Catlett C. Resources within “reason”. Young Except Child. 2010;13(3):41-2. X-1, X-2, X-3, X-4.
723 Cattell-Gordon D, Cattell-Gordon D. The development of an effective applied behavioral analysis program for a young child with autism: a parent’s perspective. Infants Young Child. Jan. 1998;10(3):79-85. X-3.
724 Causton-Theoharis J, Ashby C, Cosier M. Islands of loneliness: exploring social interaction through the autobiographies of individuals with autism. Intellect Dev Disabil. Apr. 2009;47(2):84-96. X-4. [pmid: 19368487].
725 Cazzullo AG, Musetti MC, Musetti L, et al. Beta-endorphin levels in peripheral blood mononuclear cells and long-term naltrexone treatment in autistic children. Eur Neuropsychopharmacol. Jun. 1999;9(4):361-6. X-1, X-3, X-4. [pmid: 10422898].
726 Cecchi V. Analysis of a little girl with an autistic syndrome. Int J Psychoanal. 1990;71(3):403-10. X-1, X-3, X-4. [pmid: 2228440].
727 Celiberti DA, Harris SL. Behavioral intervention for siblings of children with autism: a focus on skills to enhance play. Behav Ther. Fal. 1993;24(4):573-99. X-1, X-3, X-4.
728 Ceulemans DL, Gelders YG, Hoppenbrouwers ML, et al. Effect of serotonin antagonism in schizophrenia: a pilot study with setoperone. Psychopharmacology (Berl). 1985;85(3):329-32. X-1, X-3, X-4. [pmid: 3923519].
729 Cezar GG. Profile of Gabriela G. Cezar. Interview by Kristie Nybo. BioTechniques. May. 2011;50(5):281. X-1, X-2, X-3, X-4. [pmid: 21548887].
730 Chadwick O, Cuddy M, Kusel Y, et al. Handicaps and the development of skills between childhood and early adolescence in young people with severe intellectual disabilities. J Intellect Disabil Res. Dec. 2005;49(Pt 12):877-88. X-1, X-3, X-4. [pmid: 16287477].
731 Chalfant AM, Rapee R, Carroll L. Treating anxiety disorders in children with high functioning autism spectrum disorders: a controlled trial. J Autism Dev Disord. Nov. 2007;37(10):1842-57. X-1, X-3. [pmid: 17171539].
732 Chan AS, Cheung MC, Sze SL, et al. Seven-star needle stimulation improves language and social interaction of children with autistic spectrum disorders. Am J Chin Med. 2009;37(3):495-504. X-1, X-3, X-4. [pmid: 19606510].
733 Chan JM, O’Reilly MF, Lang RB, et al. Evaluation of a social stories™ intervention implemented by pre-service teachers for students with autism in general education settings. Res Autism Spectr Disord. Apr–Jun. 2011;5(2):715-21. X-3.
734 Chan JM, O’Reilly MF. A Social Stories intervention package for students with autism in inclusive classroom settings. J Appl Behav Anal. Fall. 2008;41(3):405-9. X-3. [pmid: 18816978].
735 Chandler S, Christie P, Newson E, et al. Developing a diagnostic and intervention package for 2- to 3-year-olds with autism: outcomes of the frameworks for communication approach. Autism. Mar. 2002;6(1):47-69. X-1, X-3, X-4. [pmid: 11918109].
736 Chang CJ, May-Kuen Wong a A. Intraductal laser photocoagulation of the bilateral parotid ducts for reduction of drooling in patients with cerebral palsy. Plast Reconstr Surg. Apr. 1. 2001;107(4):907-13. X-4. [pmid: 11252081].
737 Chang S, Crothers C, Lai S, et al. Pediatric neurobehavioral diseases in Nevada counties with respect to perchlorate in drinking water: an ecological inquiry. Birth Defects Res A Clin Mol Teratol. Oct. 2003;67(10):886-92. X-4. [pmid: 14745943].
738 Chaplin E, Paschos D, O’Hara J, et al. Mental ill-health and care pathways in adults with intellectual disability across different residential types. Res Dev Disabil. Mar–Apr. 2010;31(2):458-63. X-1, X-3, X-4. [pmid: 19932596].
739 Chaplin E, Tsakanikos E, Wright S, et al. Clinical psychopathology, untoward incidents and the use of restrictive procedures in adults with intellectual disability. J Appl Res Intellect Disabil. Mar. 2009;22(2):169-78. X-4.
740 Chapman S, Fisher W, Piazza CC, et al. Functional assessment and treatment of life-threatening drug ingestion in a dually diagnosed youth. J Appl Behav Anal. Sum. 1993;26(2):255-6. X-3. [pmid: 8331021].
741 Charania SM, LeBlanc LA, Sabanathan N, et al. Teaching effective hand raising to children with autism during group instruction. J Appl Behav Anal. Fall. 2010;43(3):493-7. X-1, X-3, X-4. [pmid: 21358908].
742 Charlop MH. The effects of echolalia on acquisition and generalization of receptive labeling in autistic children. J Appl Behav Anal. Spring. 1983;16(1):111-26. X-1, X-3, X-4. [pmid: 6833164].
743 Charlop MH, Burgio LD, Iwata BA, et al. Stimulus variation as a means of enhancing punishment effects. J Appl Behav Anal. Spring. 1988;21(1):89-95. X-3. [pmid: 3372404].
744 Charlop MH, Kurtz PF, Casey FG. Using aberrant behaviors as reinforcers for autistic children. J Appl Behav Anal. Summer. 1990;23(2):163-81. X-1, X-3, X-4. [pmid: 2373653].
745 Charlop MH, Kurtz PF, Milstein JP. Too much reinforcement, too little behavior: assessing task interspersal procedures in conjunction with different reinforcement schedules with autistic children. J Appl Behav Anal. Winter. 1992;25(4):795-808. X-3. [pmid: 1478903].
746 Charlop MH, Milstein JP. Teaching autistic children conversational speech using video modeling. J Appl Behav Anal. Fall. 1989;22(3):275-85. X-3. [pmid: 2793634].
747 Charlop MH, Schreibman L, Thibodeau MG. Increasing spontaneous verbal responding in autistic children using a time delay procedure. J Appl Behav Anal. Summer. 1985;18(2):155-66. X-3. [pmid: 4019351].
748 Charlop MH, Schreibman L, Tryon AS. Learning through observation: the effects of peer modeling on acquisition and generalization in autistic children. J Abnorm Child Psychol. Sep. 1983;11(3):355-66. X-3. [pmid: 6643856].
749 Charlop MH, Trasowech JE. Increasing autistic children’s daily spontaneous speech. J Appl Behav Anal. Winter. 1991;24(4):747-61. X-3. [pmid: 1797777].
750 Charlop MH, Walsh ME. Increasing autistic children’s spontaneous verbalizations of affection: an assessment of time delay and peer modeling procedures. J Appl Behav Anal. Fall. 1986;19(3):307-14. X-3. [pmid: 3771424].
751 Charlop-Christy MH, Carpenter M, Le L, et al. Using the picture exchange communication system (PECS) with children with autism: assessment of PECS acquisition, speech, social-communicative behavior, and problem behavior. J Appl Behav Anal. Fall. 2002;35(3):213-31. X-3. [pmid: 12365736].
752 Charlop-Christy MH, Carpenter MH. Modified incidental teaching sessions: a procedure for parents to increase spontaneous speech in their children with autism. J Posit Behav Interv. Spr. 2000;2(2):98-112. X-1, X-3, X-4.
753 Charlop-Christy MH, Haymes LK. Using obsessions as reinforcers with and without mild reductive procedures to decrease inappropriate behaviors of children with autism. J Autism Dev Disord. Oct. 1996;26(5):527-46. X-1, X-3, X-4. [pmid: 8906454].
754 Charlop-Christy MH, Haymes LK. Using objects of obsession as token reinforcers for children with autism. J Autism Dev Disord. Jun. 1998;28(3):189-98. X-1, X-3, X-4. [pmid: 9656130].
755 Charlop-Christy MH, Kelso SE. Teaching children with autism conversational speech using a cue card/written script program. Educ Treat Children. May. 2003;26(2):108-27. X-1, X-3, X-4.
756 Charlop-Christy MH, Le L, Freeman KA. A comparison of video modeling with in vivo modeling for teaching children with autism. J Autism Dev Disord. Dec. 2000;30(6):537-52. X-3. [pmid: 11261466].
757 Charlot L, Abend S, Ravin P, et al. Non-psychiatric health problems among psychiatric inpatients with intellectual disabilities. J Intellect Disabil Res. Feb. 2011;55(2):199-209. X-1, X-4. [pmid: 20546095].
758 Charlot L, Deutsch CK, Albert A, et al. Mood and anxiety symptoms in psychiatric inpatients with autism spectrum disorder and depression. J Ment Health Res Intellect Disabil. 2008;1(4):238-53. X-4.
759 Charman T. Developmental approaches to understanding and treating autism. Folia Phoniatr Logop. 2010;62(4):166-77. X-1, X-2, X-3, X-4. [pmid: 20460929].
760 Charman T, Baird G, Simonoff E, et al. Efficacy of three screening instruments in the identification of autistic-spectrum disorders. Br J Psychiatry. Dec. 2007;191:554-9. X-4. [pmid: 18055961].
761 Charman T, Baron-Cohen S, Baird G, et al. Commentary: the modified checklist for autism in toddlers. J Autism Dev Disord. Apr. 2001;31(2):145-48. X-1, X-2, X-3, X-4. [pmid: 11450813].
762 Charman T, Howlin P, Aldred C, et al. Research into early intervention for children with autism and related disorders: methodological and design issues. Report on a workshop funded by the Wellcome Trust, Institute of Child Health. London, UK. November 2001. Autism. Jun. 2003;7(2):217-25. [pmid: 12846389]. X-2, X-4.
763 Charman T, Howlin P, Berry B, et al. Measuring developmental progress of children with autism spectrum disorder on school entry using parent report. Autism. Mar. 2004;8(1):89-100. X-4. [pmid: 15070549].
764 Charman T, Taylor E, Drew A, et al. Outcome at 7 years of children diagnosed with autism at age 2: predictive validity of assessments conducted at 2 and 3 years of age and pattern of symptom change over time. J Child Psychol Psychiatry. May. 2005;46(5):500-13. X-1, X-3, X-4. [pmid: 15845130].
765 Charnsil C. Efficacy of Atomoxetine in children with severe autistic disorders and symptoms of ADHD: an open-label study. J Atten Disord. 2010. Aug. 4. X-3. [pmid: 20686100].
766 Chase CA. An intergenerational e-mail pal project on attitudes of college students toward older adults. Educ Gerontol. 2011;37(1):27-37. X-1, X-3, X-4.
767 Chasson GS, Harris GE, Neely WJ. Cost comparison of early intensive behavioral intervention and special education for children with autism. J Child Fam Stud. Jun. 2007;16(3):401-13. X-4.
768 Chawarska K, Klin A, Paul R, et al. A prospective study of toddlers with ASD: short-term diagnostic and cognitive outcomes. J Child Psychol Psychiatry. Oct. 2009;50(10):1235-45. X-1, X-3, X-4. [pmid: 19594835].
769 Chawarska K, Shic F. Looking but not seeing: atypical visual scanning and recognition of faces in 2 and 4-year-old children with autism spectrum disorder. J Autism Dev Disord. 2009;39(12):1663-72. X-1, X-3, X-4. [pmid: 19590943].
770 Chazan SE. Using the Children’s Play Therapy Instrument (CPTI) to measure the development of play in simultaneous treatment: a case study. Infant Ment Health J. Jul. 2000;21(3):211-21. X-1, X-3, X-4.
771 Chell N. Experiences of parenting young people with a diagnosis of Asperger syndrome: a focus group study. Int J Psychiatr Nurs Res. May. 2006;11(3):1348-58. X-4. [pmid: 16776442].
772 Chen CY, Chen KH, Liu CY, et al. Increased risks of congenital, neurologic, and endocrine disorders associated with autism in preschool children: cognitive ability differences. J Pediatr. Mar. 2009;154(3):345-50. 50 e1. X-1, X-3, X-4. [pmid: 19028388].
773 Chen M-C, Wu T-F, Lin Y-L, et al. The effect of different representations on reading digital text for students with cognitive disabilities. Br J Educ Technol. Jul. 2009;40(4):764-70. X-3.
774 Chen SH, Bernard-Opitz V. Comparison of personal and computer-assisted instruction for children with autism. Ment Retard. Dec. 1993;31(6):368-76. X-3. [pmid: 8152382].
775 Chen WX, Wu-Li L, Wong VC. Electroacupuncture for children with autism spectrum disorder: pilot study of 2 cases. J Altern Complement Med. Oct. 2008;14(8):1057-65. X-3. [pmid: 18990052].
776 Cheseldine S, Manders D, McGowan C. The role of consultation clinics in services for children and young people with learning disabilities and/or autism. Child Adolesc Ment Health. 2005;10(3):140-2. X-1, X-3, X-4.
777 Chessick RD. Self-analysis: a fool for a patient?. Psychoanal Rev. Fall. 1990;77(3):311-40. X-2, X-4. [pmid: 2126871].
778 Chevallier C, Noveck I, Happe F, et al. What’s in a voice? Prosody as a test case for the Theory of Mind account of autism. Neuropsychologia. Feb. 2011;49(3):507-17. X-2, X-4. [pmid: 21134386].
779 Chez MG, Aimonovitch M, Buchanan T, et al. Treating autistic spectrum disorders in children: utility of the cholinesterase inhibitor rivastigmine tartrate. J Child Neurol. Mar. 2004;19(3):165-9. X-1, X-3, X-4. [pmid: 15119476].
780 Chez MG, Buchanan CP. Reply to B. Rimland’s “Comments on ‘secretin and autism: a two-part clinical investigation’“. J Autism Dev Disord. Apr. 2000;30(2):97-8. X-1, X-2, X-3, X-4.
781 Chez MG, Buchanan CP, Aimonovitch MC, et al. Double-blind, placebo-controlled study of L-carnosine supplementation in children with autistic spectrum disorders. J Child Neurol. Nov. 2002;17(11):833-7. X-1, X-3, X-4. [pmid: 12585724].
782 Chez MG, Buchanan CP, Bagan BT, et al. Secretin and autism: a two-part clinical investigation. J Autism Dev Disord. Apr. 2000;30(2):87-94. X-1, X-3, X-4. [pmid: 10832772].
783 Chez MG, Buchanan TM, Becker M, et al. Donepezil hydrochloride: a double-blind study in autistic children. Journal of Pediatric Neurology. Oct–Dec. 2003;1(2):83-8. X-1, X-3, X-4.
784 Chez MG, Burton Q, Dowling T, et al. Memantine as adjunctive therapy in children diagnosed with autistic spectrum disorders: an observation of initial clinical response and maintenance tolerability. J Child Neurol. May. 2007;22(5):574-9. X-1. [pmid: 17690064].
785 Chez MG, Chang M, Krasne V, et al. Frequency of epileptiform EEG abnormalities in a sequential screening of autistic patients with no known clinical epilepsy from 1996 to 2005. Epilepsy Behav. Feb. 2006;8(1):267-71. X-4. [pmid: 16403678].
786 Chi RP, Fregni F, Snyder AW. Visual memory improved by non-invasive brain stimulation. Brain Res. Sep. 24. 2010;1353:168-75. X-1, X-4. [pmid: 20682299].
787 Chiang HM. Naturalistic observations of elicited expressive communication of children with autism: an analysis of teacher instructions. Autism. Mar. 2009;13(2):165-78. X-4. [pmid: 19261686].
788 Chiang I, Lee Y, Frey G, et al. Testing the situationally modified social rank theory on friendship quality in male youth with high-functioning autism spectrum disorder. Ther Recreation J. 2004;38(3):261-74. X-3.
789 Childress DC. Play behaviors of parents and their young children with disabilities. Topics Early Child Spec Educ. Aug. 2011;31(2):112-20. X-1, X-2, X-3, X-4.
790 Chiu S, Widjaja F, Bates ME, et al. Anterior cingulate volume in pediatric bipolar disorder and autism. J Affect Disord. Jan. 2008;105(1–3):93-9. X-4. [pmid: 17568686].
791 Choi YB, Li HL, Kassabov SR, et al. Neurexin-neuroligin transsynaptic interaction mediates learning-related synaptic remodeling and long-term facilitation in aplysia. Neuron. May. 12. 2011;70(3):468-81. X-1, X-3, X-4. [pmid: 21555073].
792 Chong IM, Carr JE. Failure to demonstrate the differential outcomes effect in children with autism. Behav Interv. Nov. 2010;25(4):339-481. X-1, X-3, X-4.
793 Chouard CH, Fugain C, Meyer B. Technique and indications for the French multichannel cochlear implant “Chorimac-12” for total deafness rehabilitation. Am J Otol. Jul. 1985;6(4):291-4. X-1, X-2, X-3, X-4. [pmid: 3839632].
794 Chouard CH, Fugain C, Meyer B, et al. The Chorimac-12. A multichannel cochlear implant for total deafness. Description and clinical results. Acta Otorhinolaryngol Belg. 1985;39(4):735-48. X-1, X-2, X-3, X-4. [pmid: 3841455].
795 Christensen K, Mortensen PB. Facial clefting and psychiatric diseases: a follow-up of the Danish 1936–1987 Facial Cleft cohort. Cleft Palate Craniofac J. Jul. 2002;39(4):392-6. X-4. [pmid: 12071787].
796 Christensen TJ, Ringdahl JE, Bosch JJ, et al. Constipation associated with self-injurious and aggressive behavior exhibited by a child diagnosed with autism. Educ Treat Children. Feb. 2009;32(1):89-103. X-3.
797 Christian WP. A case study in the programming and maintenance of institutional change. J Organ Behav Manage. Fal-Win. 1983;5(3–4):99-153. X-4.
798 Christiansen AS. Persisting motor control problems in 11- to 12-year-old boys previously diagnosed with deficits in attention, motor control and perception (DAMP). Dev Med Child Neurol. Jan. 2000;42(1):4-7. X-4. [pmid: 10665968].
799 Christon LM, Mackintosh VH, Myers BJ. Use of complementary and alternative medicine (CAM) treatments by parents of children with autism spectrum disorders. Res Autism Spectr Disord. Apr–Jun. 2010;4(2):249-59. X-1, X-3, X-4.
800 Chugani HT, Da Silva E, Chugani DC. Infantile spasms: III. Prognostic implications of bitemporal hypometabolism on positron emission tomography. Ann Neurol. May. 1996;39(5):643-9. X-4. [pmid: 8619550].
801 Chung BI. Brief Report: Treatment of echolalia in a girl with Rubinstein-Taybi Syndrome: functional assessment of minimizing chances to provoke echolalia. J Autism Dev Disord. Dec. 1998;28(6):573-78. X-1, X-3, X-4. [pmid: 9932244].
802 Chung KM, Reavis S, Mosconi M, et al. Peer-mediated social skills training program for young children with high-functioning autism. Res Dev Disabil. Jul–Sep. 2007;28(4):423-36. X-1, X-3, X-4. [pmid: 16901676].
803 Chung SY, Luk SL, Lee PW. A follow-up study of infantile autism in Hong Kong. J Autism Dev Disord. Jun. 1990;20(2):221-32. X-1, X-3, X-4. [pmid: 2347821].
804 Chungpaibulpatana J, Sumpatanarax T, Thadakul N, et al. Hyperbaric oxygen therapy in Thai autistic children. J Med Assoc Thai. Aug. 2008;91(8):1232-8. X-3. [pmid: 18788696].
805 Church CC, Coplan J. The high-functioning autistic experience: birth to preteen years. J Pediatr Health Care. Jan–Feb. 1995;9(1):22-9. X-1, X-3, X-4. [pmid: 7745522].
806 Chuthapisith J, diMambro B, Doody G. Effectiveness of a computer assisted learning (CAL) package to raise awareness of autism. BMC Med Educ. 2009;9:12. X-4. [pmid: 19245703].
807 Cicero FR, Pfadt A. Investigation of a reinforcement-based toilet training procedure for children with autism. Res Dev Disabil. Sep–Oct. 2002;23(5):319-31. X-3. [pmid: 12401483].
808 Ciesielski KT, Harris RJ, Hart BL, et al. Cerebellar hypoplasia and frontal lobe cognitive deficits in disorders of early childhood. Neuropsychologia. May. 1997;35(5):643-55. X-4. [pmid: 9153027].
809 Ciesielski KT, Knight JE, Prince RJ, et al. Event-related potentials in cross-modal divided attention in autism. Neuropsychologia. Feb. 1995;33(2):225-46. X-4. [pmid: 7746366].
810 Cihak D, Fahrenkrog C, Ayres KM, et al. The use of video modeling via a video ipod and a system of least prompts to improve transitional behaviors for students with autism spectrum disorders in the general education classroom. J Posit Behav Interv. 2010;12(2):103-15. X-3.
811 Cihak DF. Comparing pictorial and video modeling activity schedules during transitions for students with autism spectrum disorders. Res Autism Spectr Disord. Jan–Mar. 2011;5(1):433-41. X-3.
812 Cimera RE, Burgess S. Do adults with autism benefit monetarily from working in their communities?. J Vocat Rehabil. 2011;34(3):173-80. X-4.
813 Cimera RE, Cowan RJ. The costs of services and employment outcomes achieved by adults with autism in the US. Autism. May. 2009;13(3):285-302. X-4. [pmid: 19369389].
814 Cimera RE, Wehman P, West M, et al. Do sheltered workshops enhance employment outcomes for adults with autism spectrum disorder?. Autism. 2011. May. 24. X-1, X-2, X-3. [pmid: 21610189].
815 Cipani E, Brendlinger J, McDowell L, et al. Continuous vs. intermittent punishment: a case study. J Dev Phys Disabil. Jun. 1991;3(2):147-56. X-1, X-3, X-4.
816 Clancy F. Sensory mystery. Minn Med. Nov. 2002;85(11):22-8. X-2. [pmid: 12498062].
817 Clancy F. Desperately seeking solutions. Minn Med. Mar. 2006;89(3):30-5. 51. X-2. [pmid: 16669430].
818 Clark E, Olympia DE, Jensen J, et al. Striving for autonomy in a contingency-governed world: another challenge for individuals with developmental disabilities. Psychol Sch. Jan. 2004;41(1):143-53. X-2.
819 Clark KM, Green G. Comparison of two procedures for teaching dictated-word/symbol relations to learners with autism. J Appl Behav Anal. Winter. 2004;37(4):503-7. X-1, X-3, X-4. [pmid: 15669408].
820 Clark M, Harris R, Jolleff N, et al. Worster-Drought syndrome: poorly recognized despite severe and persistent difficulties with feeding and speech. Dev Med Child Neurol. Jan. 2010;52(1):27-32. X-4. [pmid: 19824895].
821 Clarke J, van Amerom G. ‘Surplus suffering’: differences between organizational understandings of Asperger’s syndrome and those people who claim the ‘disorder’. Disabil Soc. 2007;22(7):761-76. X-1, X-3, X-4.
822 Clarke JC, Thomason S. The use of an aversive smell to eliminate autistic self-stimulatory behavior. Child Fam Behav Ther. Fal. 1983;5(3):51-67. X-1, X-3, X-4.
823 Clarke S, Dunlap G, Vaughn B. Family-centered, assessment-based intervention to improve behavior during an early morning routine. J Posit Behav Interv. Fal. 1999;1(4):235-41. X-1, X-3, X-4.
824 Clarkson G. Creative music therapy and facilitated communication: new ways of reaching students with autism. Prev School Failure. Win. 1994;38(2):31-3. X-3.
825 Clarkson G. The spiritual insights of a Guided Imagery and Music client with autism. J Assoc Music Imagery. 1998;6:87-103. X-4.
826 Clifford P, Friesen S, Jardine DW. Whatever happens to him happens to us: reading coyote reading the world. J Educ Thought. Apr. 2001;35(1):9-26. X-1, X-2, X-3, X-4.
827 Clifford S, Dissanayake C, Bui QM, et al. Autism spectrum phenotype in males and females with fragile X full mutation and premutation. J Autism Dev Disord. Apr. 2007;37(4):738-47. X-4. [pmid: 17031449].
828 Coakley T. State guidance documents for young children with autism spectrum disorders: content and comparison. Infants Young Child. Apr–Jun. 2010;23(2):145-64. X-1, X-2, X-3, X-4.
829 Coben R, Myers TE. The relative efficacy of connectivity guided and symptom based EEG biofeedback for autistic disorders. Appl Psychophysiol Biofeedback. Mar. 2010;35(1):13-23. X-1, X-2, X-3, X-4. [pmid: 19649702].
830 Coben R, Padolsky I. Assessment-guided neurofeedback for autistic spectrum disorder. J Neurother. 2007;11(1):5-23. X-1, X-3, X-4.
831 Coben R, Padolsky I. Infrared imaging and neurofeedback: initial reliability and validity. J Neurother. 2007;11(3):3-13. X-2.
832 Cocchi R. Drug therapies for sleep troubles, hyperactivity and aggression in young adult autistics. Ital J Intellective Impair. Dec. 1995;8(2):169-73. X-3.
833 Cocchi R. A work in progress on drug therapy of an autistic child aged three: 1. The first six months’ therapy. Ital J Intellective Impair. Dec. 1995;8(2):175-83. X-1, X-3, X-4.
834 Cocchi R. A work in progress on drug therapy of an autistic child aged three (at first consultation): 2. The second six-months’ therapy. Ital J Intellective Impair. Jun. 1996;9(1):31-40. 93. 102. X-1, X-3, X-4.
835 Cocchi R. A work in progress on drug therapy of an autistic child aged three (at first consultation): 3. The third six-months’ therapy. Ital J Intellective Impair. Dec. 1996;9(2):189-96. 259. 67. X-1, X-3, X-4.
836 Coe D, Matson J, Fee V, et al. Training nonverbal and verbal play skills to mentally retarded and autistic children. J Autism Dev Disord. Jun. 1990;20(2):177-87. X-3. [pmid: 2347818].
837 Coffin CM, Lowichik A, Putnam A. Lipoblastoma (LPB): a clinicopathologic and immunohistochemical analysis of 59 cases. Am J Surg Pathol. Nov. 2009;33(11):1705-12. X-4. [pmid: 19738456].
838 Coggins TE, Morisset C, Krasney L, et al. Brief report: does fenfluramine treatment enhance the cognitive and communicative functioning of autistic children?. J Autism Dev Disord. Sep. 1988;18(3):425-34. X-1, X-3, X-4. [pmid: 3170458].
839 Cohen D, Jay SM. Autistic barriers in the psychoanalysis of borderline adults. Int J Psychoanal. Oct. 1996;77(5):913-33. X-4. [pmid: 8933218].
840 Cohen D, Nicoulaud L, Maturana A, et al. Investigating the use of packing therapy in adolescents with catatonia: A retrospective study. Clin Neuropsychiatry. Feb. 2009;6(1):29-34. X-4.
841 Cohen H, Amerine-Dickens M, Smith T. Early intensive behavioral treatment: replication of the UCLA model in a community setting. J Dev Behav Pediatr. Apr. 2006;27(2 Suppl):S145-55. X-1, X-3, X-4. [pmid: 16685181].
842 Cohen IL. Criterion-related validity of the PDD Behavior Inventory. J Autism Dev Disord. Feb. 2003;33(1):47-53. X-4. [pmid: 12708579].
843 Cohen IL, Campbell M, Posner D. A study of haloperidol in young autistic children: a within-subjects design using objective rating scales. Psychopharmacol Bull. Jul. 1980;16(3):63-5. X-1, X-3, X-4. [pmid: 7403407].
844 Cohen IL, Campbell M, Posner D, et al. Behavioral effects of haloperidol in young autistic children. An objective analysis using a within-subjects reversal design. J Am Acad Child Psychiatry. Autumn. 1980;19(4):665-77. X-1, X-3, X-4. [pmid: 7204797].
845 Cohen IL, Liu X, Schutz C, et al. Association of autism severity with a monoamine oxidase A functional polymorphism. Clin Genet. Sep. 2003;64(3):190-7. X-4. [pmid: 12919132].
846 Cohen IL, Schmidt-Lackner S, Romanczyk R, et al. The PDD Behavior Inventory: a rating scale for assessing response to intervention in children with pervasive developmental disorder. J Autism Dev Disord. Feb. 2003;33(1):31-45. X-4. [pmid: 12708578].
847 Cohen MJ. The effect of increasing the rate of clerical skill performance on challenging behavior. J Precision Teach Celeration. 2005;21(1):2-12. X-7.
848 Cohen SA, Fitzgerald BJ, Khan SR, et al. The effect of a switch to ziprasidone in an adult population with autistic disorder: chart review of naturalistic, open-label treatment. J Clin Psychiatry. Jan. 2004;65(1):110-3. X-1, X-3, X-4. [pmid: 14744179].
849 Cohen SA, Ihrig K, Lott RS, et al. Risperidone for aggression and self-injurious behavior in adults with mental retardation. J Autism Dev Disord. Jun. 1998;28(3):229-33. X-3. [pmid: 9656134].
850 Cole LL. Autism in school-age chidren. A complex collage of development, behavior and communication. Adv Nurse Pract. Mar. 2008;16(3):38-47. quiz -8. X-2. [pmid: 19999503].
851 Cole PM, Michel MK, Teti LO. The development of emotion regulation and dysregulation: a clinical perspective. Monogr Soc Res Child Dev. 1994;59(2–3):73-100. X-1, X-2, X-3, X-4. [pmid: 7984169].
852 Coleman CL, Holmes PA. The use of noncontingent escape to reduce disruptive behaviors in children with speech delays. J Appl Behav Anal. Win. 1998;31(4):687-90. X-1, X-3, X-4. [pmid: 9891406].
853 Colle L, Baron-Cohen S, Wheelwright S, et al. Narrative discourse in adults with high-functioning autism or Asperger syndrome. J Autism Dev Disord. Jan. 2008;38(1):28-40. X-3, X-4. [pmid: 17345168].
854 Collier R. Fiction dereliction. CMAJ. Mar. 11. 2008;178(6):792. X-2. [pmid: 18332395].
855 Collins BC, Evans A, Creech-Galloway C, et al. Comparison of the acquisition and maintenance of teaching functional and core content sight words in special and general education settings. Focus Autism Dev Disabil. 2007;22(4):220-33. X-3, X-4.
856 Collins MSR, Kyle R, Smith S, et al. Coping with the usual family diet: eating behaviour and food choices of children with Doown’s syndrome, autistic spectrum disorders or cri du chat syndrome and comparison groups of siblings. J Learn Disabil. Jun. 2003;7(2):137-55. X-4.
857 Collins MSR, Laverty A, Roberts S, et al. Eating behaviour and food choices in children with Down’s syndrome, autistic spectrum disorder or cri du chat syndrome and comparison groups of siblings: diet and preventive dentistry. J Learn Disabil. Dec. 2004;8(4):331-50. X-4.
858 Comelli LT. The psychotherapeutic treatment of a psychotic child with marked autistic features. Psychoanal Psychother. 1987;3(1):11-25. X-1, X-3, X-4.
859 Conderman G, Katsiyannis A. State practices in serving individuals with autism. Focus Autism Dev Disabil. Spr. 1996;11(1):29-36. X-1, X-3, X-4.
860 Coniglio SJ, Lewis JD, Lang C, et al. A randomized, double-blind, placebo-controlled trial of single-dose intravenous secretin as treatment for children with autism. J Pediatr. May. 2001;138(5):649-55. X-1, X-4. [pmid: 11343038].
861 Connor DF, McLaughlin TJ. A naturalistic study of medication reduction in a residential treatment setting. J Child Adolesc Psychopharmacol. Apr. 2005;15(2):302-10. X-1, X-3, X-4. [pmid: 15910214].
862 Connor M. Monitoring and reviewing early behavioural intervention in autism (Lovaas). Educ Psychol Prac. Mar. 2003;19(1):21-33. X-1, X-2, X-3, X-4.
863 Connors SL, Crowell DE, Eberhart CG, et al. beta2-adrenergic receptor activation and genetic polymorphisms in autism: data from dizygotic twins. J Child Neurol. Nov. 2005;20(11):876-84. X-4. [pmid: 16417856].
864 Conroy MA. Seeing the forest among the trees: when data do not speak loud enough. J Early Interv. 2010;32(2):99-104. X-1, X-2, X-3, X-4.
865 Conroy MA, Asmus JM, Boyd BA, et al. Antecedent classroom factors and disruptive behaviors of children with autism spectrum disorders. J Early Interv. 2007;30(1):19-35. X-1, X-3, X-4.
866 Conroy MA, Asmus JM, Sellers JA, et al. The use of an antecedent-based intervention to decrease stereotypic behavior in a general education classroom: a case study. Focus Autism Dev Disabil. Win. 2005;20(4):223-30. X-1, X-2, X-3, X-4.
867 Conroy T. What is “appropriate” for school-aged children with autism?. J S C Med Assoc. Oct. 2006;102(8):285-8. X-2, X-4. [pmid: 17319246].
868 Constantino JN, Lajonchere C, Lutz M, et al. Autistic social impairment in the siblings of children with pervasive developmental disorders. Am J Psychiatry. Feb. 2006;163(2):294-6. X-4. [pmid: 16449484].
869 Constantino JN, Yang D, Gray TL, et al. Clarifying the associations between language and social development in autism: a study of non-native phoneme recognition. J Autism Dev Disord. Aug. 2007;37(7):1256-63. X-4. [pmid: 17080273].
870 Conti-Ramsden G, Botting N, Simkin Z, et al. Follow-up of children attending infant language units: outcomes at 11 years of age. Int J Lang Commun Disord. Apr–Jun. 2001;36(2):207-19. X-1, X-3, X-4. [pmid: 11344595].
871 Coo H, Ouellette-Kuntz H, Lloyd JEV, et al. Trends in autism prevalence: diagnostic substitution revisited. J Autism Dev Disord. Jul. 2008;38(6):1036-46. X-4. [pmid: 17975721].
872 Cook DG. A sensory approach to the treatment and management of children with autism. Focus Autism Other Dev Disabil. Feb. 1990;5(6):1-19. X-1, X-3, X-4.
873 Cook EH Jr, Anderson GM, Heninger GR, et al. Tryptophan loading in hyperserotonemic and normoserotonemic adults. Biol Psychiatry. Mar. 1. 1992;31(5):525-8. X-2, X-4. [pmid: 1581428].
874 Cook EH, Kieffer JE, Charak DA, et al. Case study: autistic disorder and post-traumatic stress disorder. J Am Acad Child Adolesc Psychiatry. Nov. 1993;32(6):1292-4. X-1, X-3, X-4. [pmid: 8282677].
875 Cooley N, Cooley J. Great expectations: Using an early childhood whole language curriculum to teach 6- through 11-year-old students in a TMI classroom. Focus Autism Other Dev Disabil. Apr. 1994;9(1):1-18. X-1, X-3, X-4.
876 Coolican J, Smith IM, Bryson SE. Brief parent training in pivotal response treatment for preschoolers with Autism. J Child Psychol Psychiatry. Dec. 2010;51(12):1321-30. X-1, X-3, X-4. [pmid: 21073457].
877 Coonrod EE, Stone WL. Early concerns of parents of children with autistic and nonautistic disorders. Inf Young Child. 2004;17(3):258-68. X-1, X-3, X-4.
878 Cooper SA, Smiley E, Allan LM, et al. Adults with intellectual disabilities: prevalence, incidence and remission of self-injurious behaviour, and related factors. J Intellect Disabil Res. Mar. 2009;53(3):200-16. X-4. [pmid: 18444987].
879 Cooper WO, Hickson GB, Fuchs C, et al. New users of antipsychotic medications among children enrolled in TennCare. Arch Pediatr Adolesc Med. Aug. 2004;158(8):753-9. X-4. [pmid: 15289247].
880 Coplan J, Souders MC, Mulberg AE, et al. Children with autistic spectrum disorders. II: parents are unable to distinguish secretin from placebo under double-blind conditions. Arch Dis Child. Aug. 2003;88(8):737-9. X-1, X-3, X-4. [pmid: 12876178].
881 Coppola G, Plouin P, Chiron C, et al. Migrating partial seizures in infancy: a malignant disorder with developmental arrest. Epilepsia. Oct. 1995;36(10):1017-24. X-4. [pmid: 7555952].
882 Corbett B, Khan K, Czapansky-Beilman D, et al. A double-blind, placebo-controlled crossover study investigating the effect of porcine secretin in children with autism. Clin Pediatr (Phila). Jun. 2001;40(6):327-31. X-3. [pmid: 11824175].
883 Corbett BA, Gunther JR, Comins D, et al. Brief report: Theatre as therapy for children with autism spectrum disorder. J Autism Dev Disord. Apr. 2011;41(4):505-11. X-3. [pmid: 20640592].
884 Corbett BA, Kantor AB, Schulman H, et al. A proteomic study of serum from children with autism showing differential expression of apolipoproteins and complement proteins. Mol Psychiatry. Mar. 2007;12(3):292-306. X-1, X-3, X-4. [pmid: 17189958].
885 Corbett BA, Mendoza S, Abdullah M, et al. Cortisol circadian rhythms and response to stress in children with autism. Psychoneuroendocrinology. Jan. 2006;31(1):59-68. X-4. [pmid: 16005570].
886 Corbett BA, Shickman K, Ferrer E. Brief report: the effects of Tomatis sound therapy on language in children with autism. J Autism Dev Disord. Mar. 2008;38(3):562-6. X-1, X-3, X-4. [pmid: 17610057].
887 Cordisco LK, Strain PS, Depew N. Assessment for generalization of parenting skills in home settings. J Assoc Pers Sev Handicaps. Fal. 1988;13(3):202-10. X-1, X-3, X-4.
888 Cornish E. A balanced approach towards healthy eating in autism. J Hum Nutr Diet. 1998;11(6):501-9. X-1, X-3, X-4.
889 Cornish E. Gluten and casein free diets in autism: a study of the effects on food choice and nutrition. J Hum Nutr Diet. Aug. 2002;15(4):261-9. X-1, X-3, X-4. [pmid: 12153499].
890 Correia CT, Almeida JP, Santos PE, et al. Pharmacogenetics of risperidone therapy in autism: association analysis of eight candidate genes with drug efficacy and adverse drug reactions. Pharmacogenomics J. Oct. 2010;10(5):418-30. X-1, X-3, X-4. [pmid: 19997080].
891 Corson AH, Barkenbus JE, Posey DJ, et al. A retrospective analysis of quetiapine in the treatment of pervasive developmental disorders. J Clin Psychiatry. Nov. 2004;65(11):1531-6. X-1, X-3, X-4. [pmid: 15554768].
892 Cosden M, Koegel LK, Koegel RL, et al. Strength-based assessment for children with autism spectrum disorders. Res Pract Persons Severe Disabl. Sum. 2006;31(2):134-43. X-2, X-4.
893 Coskun M, Karakoc S, Kircelli F, et al. Effectiveness of mirtazapine in the treatment of inappropriate sexual behaviors in individuals with autistic disorder. J Child Adolesc Psychopharmacol. Apr. 2009;19(2):203-6. X-3. [pmid: 19364298].
894 Cosper SM, Lee GP, Peters SB, et al. Interactive Metronome training in children with attention deficit and developmental coordination disorders. Int J Rehabil Res. Dec. 2009;32(4):331-6. X-4. [pmid: 19202457].
895 Costa RM, de Carvalho LA, Drummond R, et al. The UFRJ-UERJ group: interdisciplinary virtual reality experiments in neuropsychiatry. Cyberpsychol Behav. Oct. 2002;5(5):423-31. X-2, X-4. [pmid: 12448779].
896 Costa S, Resende J, Soares FO, et al. Applications of simple robots to encourage social receptiveness of adolescents with autism. Conf Proc IEEE Eng Med Biol Soc. 2009;2009:5072-5. X-3. [pmid: 19964856].
897 Costello EJ, Loeber R, Stouthamer-Loeber M. Pervasive and situational hyperactivity--confounding effect of informant: a research note. J Child Psychol Psychiatry. Jan. 1991;32(2):367-76. X-4. [pmid: 2033114].
898 Cotugno AJ. Social competence and social skills training and intervention for children with autism spectrum disorders. J Autism Dev Disord. Sep. 2009;39(9):1268-77. X-1, X-3, X-4. [pmid: 19365716].
899 Couper J. Who should pay for intensive behavioural intervention in autism? A parent’s view. J Paediatr Child Health. Sep–Oct. 2004;40(9–10):559-61. X-2, X-4. [pmid: 15367153].
900 Courchesne E, Townsend J, Akshoomoff NA, et al. Impairment in shifting attention in autistic and cerebellar patients. Behav Neurosci. Oct. 1994;108(5):848-65. X-2, X-4. [pmid: 7826509].
901 Couture SM, Roberts DL, Penn DL, et al. Do baseline client characteristics predict the therapeutic alliance in the treatment of schizophrenia?. J Nerv Ment Dis. Jan. 2006;194(1):10-4. X-4. [pmid: 16462549].
902 Couturier JL, Nicolson R. A retrospective assessment of citalopram in children and adolescents with pervasive developmental disorders. J Child Adolesc Psychopharmacol. Fall. 2002;12(3):243-8. X-3. [pmid: 12427298].
903 Cowan RJ, Allen KD. Using naturalistic procedures to enhance learning in individuals with autism: a focus on generalized teaching within the school setting. Psychol Sch. Sep. 2007;44(7):701-15. X-2.
904 Cox AL, Gast DL, Luscre D, et al. The effects of weighted vests on appropriate in-seat behaviors of elementary-age students with autism and severe to profound intellectual disabilities. Focus Autism Dev Disabil. 2009;24(1):17-26. X-3.
905 Coyle C, Cole P. A videotaped self-modelling and self-monitoring treatment program to decrease off-task behaviour in children with autism. J Intellect Dev Disabil. Mar. 2004;29(1):3-15. X-1, X-3, X-4.
906 Craddock N, Owen MJ. The Kraepelinian dichotomy - going, going... but still not gone. Br J Psychiatry. Feb. 2010;196(2):92-5. X-1, X-2, X-3, X-4. [pmid: 20118450].
907 Craig HK, Telfer AS. Hyperlexia and autism spectrum disorder: a case study of scaffolding language growth over time. Top Lang Disord. Oct–Dec. 2005;25(4):364-74. X-1, X-3, X-4.
908 Crescentini F. The autistic syndrome and endogenous ion cyclotron resonance: state of the art. Electromagn Biol Med. 2007;26(4):305-9. X-3. [pmid: 18097818].
909 Crighton P. Vaccines need a shot in the arm. Aust Nurs J. May. 2011;18(10):40-1. X-1, X-2, X-3, X-4. [pmid: 21667703].
910 Crockett JL, Fleming RK, Doepke KJ, et al. Parent training: acquisition and generalization of discrete trials teaching skills with parents of children with autism. Res Dev Disabil. Jan–Feb. 2007;28(1):23-36. X-1, X-3, X-4. [pmid: 16338118].
911 Croen LA, Najjar DV, Ray GT, et al. A comparison of health care utilization and costs of children with and without autism spectrum disorders in a large group-model health plan. Pediatrics. Oct. 2006;118(4):e1203-11. X-4. [pmid: 17015508].
912 Croen LA, Najjar DV, Ray GT, et al. A comparison of health care utilization and costs of children with and without autism spectrum disorders in a large group-model health plan. J Am Acad Child Adolesc Psychiatry. Apr. 2007;46(4):523. X-4.
913 Crooke PJ, Hendrix RE, Rachman JY. Brief Report: measuring the effectiveness of teaching social thinking to children with Asperger syndrome (AS) and High Functioning Autism (HFA). J Autism Dev Disord. Mar. 2008;38(3):581-91. X-3. [pmid: 18026829].
914 Croonenberghs J, Verkerk R, Scharpe S, et al. Serotonergic disturbances in autistic disorder: L-5-hydroxytryptophan administration to autistic youngsters increases the blood concentrations of serotonin in patients but not in controls. Life Sciences. Mar. 2005;76(19):2171-83. X-4. [pmid: 15733932].
915 Crosland KA, Zarcone JR, Lindauer SE, et al. Use of functional analysis methodology in the evaluation of medication effects. J Autism Dev Disord. Jun. 2003;33(3):271-9. X-3. [pmid: 12908830].
916 Crossley R. Getting the words out: case studies in facilitated communication training. Top Lang Disord. Aug. 1992;12(4):46-59. X-3.
917 Crossley R, Remington-Gurney J. Getting the words out: facilitated communication training. Top Lang Disord. Aug. 1992;12(4):29-45. X-1, X-2, X-3, X-4.
918 Crozier S, Tincani M. Effects of social stories on prosocial behavior of preschool children with autism spectrum disorders. J Autism Dev Disord. Oct. 2007;37(9):1803-14. X-1, X-3, X-4. [pmid: 17165149].
919 Crozier S, Tincani MJ. Using a modified social story to decrease disruptive behavior of a child with autism. Focus Autism Dev Disabil. Fall. 2005;20(3):150-7. X-1, X-3, X-4.
920 Cuhadar S, Diken IH. Effectiveness of instruction performed through activity schedules on leisure skills of children with autism. Educ Train Autism Dev Disabil. Sep. 2011;46(3):386-9. X-1, X-3, X-4.
921 Cullen L, Barlow J. ‘Kiss, cuddle, squeeze’: the experiences and meaning of touch among parents of children with autism attending a Touch Therapy Programme. J Child Health Care. Sep. 2002;6(3):171-81. X-2. [pmid: 12224834].
922 Cullen LA, Barlow JH, Cushway D. Positive touch, the implications for parents and their children with autism: an exploratory study. Complement Ther Clin Pract. Aug. 2005;11(3):182-9. X-3. [pmid: 16005835].
923 Cullen-Powell LA, Barlow JH, Cushway D. Exploring a massage intervention for parents and their children with autism: the implications for bonding and attachment. J Child Health Care. Dec. 2005;9(4):245-55. X-3. [pmid: 16275663].
924 Cummings AR, Carr JE. Evaluating progress in behavioral programs for children with autism spectrum disorders via continuous and discontinuous measurement. J Appl Behav Anal. Spring. 2009;42(1):57-71. X-3. [pmid: 19721730].
925 Curran AL, Sharples PM, White C, et al. Time costs of caring for children with severe disabilities compared with caring for children without disabilities. Dev Med Child Neurol. Aug. 2001;43(8):529-33. X-4. [pmid: 11508918].
926 Curtin C, Bandini LG, Perrin EC, et al. Prevalence of overweight in children and adolescents with attention deficit hyperactivity disorder and autism spectrum disorders: a chart review. BMC Pediatr. 2005;5:48. X-4. [pmid: 16371155].
927 Curtis J. Patient education. Autism Aust Fam Physician. Jul. 1993;22(7):1239. X-2, X-4. [pmid: 8373315].
928 Curtis K. An unusual case of recurrent emesis in a patient with autistic disorder. Mental Health Asp Dev Disab. Jan–Mar. 2005;8(1):1-4. X-3.
929 Cuvo AJ, Godard A, Huckfeldt R, et al. Training children with autism spectrum disorders to be compliant with an oral assessment. Res Autism Spectr Disord. Oct–Dec. 2010;4(4):681-96. X-1, X-3, X-4.
930 Cuvo AJ, Reagan AL, Ackerlund J, et al. Training children with autism spectrum disorders to be compliant with a physical exam. Res Autism Spectr Disord. Apr–Jun. 2010;4(2):168-85. X-1, X-3, X-4.
931 Cuvo AJ, Vallelunga LR. A transactional systems model of autism services. Behavior Analyst. Fall. 2007;30(2):161-80. X-2, X-4. [pmid: 22478495].
932 Czapanskiy KS. Chalimony: seeking equity between parents of children with disabilities and chronic illnesses. Rev Law Soc Change. 2010;34(2):253-98. X-1, X-2, X-3, X-4. [pmid: 20722202].
933 Dabrowska A, Pisula E. Parenting stress and coping styles in mothers and fathers of pre-school children with autism and Down syndrome. J Intellect Disabil Res. 2010;54(Part 3):266-80. X-1, X-3, X-4. [pmid: 20146741].
934 Dadds M, Schwartz S, Adams T, et al. The effects of social context and verbal skill on the stereotypic and task-involved behaviour of autistic children. J Child Psychol Psychiatry. Sep. 1988;29(5):669-76. X-3, X-4. [pmid: 3192667].
935 Dahle KB. The clinical and educational systems: differences and similarities. Focus Autism Dev Disabil. Win. 2003;18(4):238-46. 56. X-1, X-2, X-3, X-4.
936 Dahle KB. Services to include young children with autism in the general classroom. Early Child Educ J. Fall. 2003;31(1):65-70. X-1, X-2, X-3, X-4.
937 Dahle KB, Gargiulo RM. Understanding asperger disorder: a primer for early childhood educators. Early Child Educ J. Dec. 2004;32(3):199-203. X-1, X-2, X-3, X-4.
938 Dahlquist LM, et al. Enhancing an autistic girl’s cooperation with gynecological examinations. Clin Pediatr (Phila). Apr. 1984;23(4):203. X-3. [pmid: 6697629].
939 Dales L, Hammer SJ, Smith NJ. Time trends in autism and in MMR immunization coverage in California. JAMA. Mar. 7. 2001;285(9):1183-5. X-4. [pmid: 11231748].
940 Dalldorf JS, Schopler E. Diagnosis and management of autism. Compr Ther. Apr. 1981;7(4):67-74. X-1, X-2, X-3, X-4. [pmid: 7237988].
941 Dalrymple NJ, Angrist MH. Toilet training a sixteen year old with autism in a natural setting. J Ment Subnorm. Jul. [67]. 1988;34(2):117-30. X-3.
942 Dalrymple NJ, Ruble LA. Toilet training and behaviors of people with autism: parent views. J Autism Dev Disord. Jun. 1992;22(2):265-75. X-3, X-4. [pmid: 1624408].
943 Dalton MA. Education rights and the special needs child. Child Adolesc Psychiatr Clin N Am. Oct. 2002;11(4):859-68. X-1, X-2, X-3, X-4. [pmid: 12397902].
944 Dalton R, Bolding D, Forman MA. Psychiatric hospitalization of preschool children: a follow-up study. Child Psychiatry Hum Dev. Fall. 1990;21(1):57-64. X-1, X-3, X-4. [pmid: 2397655].
945 Dalton ST, Howell CC. Autism: psychobiological perspectives. J Child Adolesc Psychiatr Ment Health Nurs. Jul–Sep. 1989;2(3):92-6. X-1, X-2, X-3, X-4. [pmid: 2769591].
946 Dammann O. Paediatric neurology: the many faces of development. Lancet Neurol. Jan. 2007;6(1):12-4. X-2. [pmid: 17166793].
947 Daneshi A, Hassanzadeh S. Cochlear implantation in prelingually deaf persons with additional disability. J Laryngol Otol. Jul. 2007;121(7):635-8. X-4. [pmid: 17147840].
948 Danfors T, von Knorring AL, Hartvig P, et al. Tetrahydrobiopterin in the treatment of children with autistic disorder: a double-blind placebo-controlled crossover study. J Clin Psychopharmacol. Oct. 2005;25(5):485-9. X-1, X-3, X-4. [pmid: 16160627].
949 Daniels JL, Forssen U, Hultman CM, et al. Parental psychiatric disorders associated with autism spectrum disorders in the offspring. Pediatrics. May. 2008;121(5):e1357-62. X-4. [pmid: 18450879].
950 Danielsson S, Viggedal G, Gillberg C, et al. Lack of effects of vagus nerve stimulation on drug-resistant epilepsy in eight pediatric patients with autism spectrum disorders: a prospective 2-year follow-up study. Epilepsy Behav. Feb. 2008;12(2):298-304. X-3. [pmid: 18053767].
951 Danielsson S, Viggedal G, Steffenburg S, et al. Psychopathology, psychosocial functioning, and IQ before and after epilepsy surgery in children with drug-resistant epilepsy. Epilepsy Behav. Feb. 2009;14(2):330-7. X-1, X-3. [pmid: 19026763].
952 Danzer E, Gerdes M, D’Agostino JA, et al. Prospective, interdisciplinary follow-up of children with prenatally diagnosed giant omphalocele: short-term neurodevelopmental outcome. J Pediatr Surg. Apr. 2010;45(4):718-23. X-1, X-3, X-4. [pmid: 20385277].
953 Daoust A-M, Lusignan F-A, Braun CMJ, et al. Dream content analysis in persons with an autism spectrum disorder. J Autism Dev Disord. Apr. 2008;38(4):634-43. X-4. [pmid: 17682931].
954 Dardennes RM, Al Anbar NN, Prado-Netto A, et al. Treating the cause of illness rather than the symptoms: parental causal beliefs and treatment choices in autism spectrum disorder. Res Dev Disabil. May–Jun. 2011;32(3):1137-46. X-4. [pmid: 21316189].
955 Dardennes RM, Al Anbar NN, Prado-Netto A, et al. Treating the cause of illness rather than the symptoms: Parental causal beliefs and treatment choices in autism spectrum disorder. Res Dev Disabil. May–Jun. 2011;32(3):1137-46. X-4. [pmid: 21316189].
956 Darrou C, Pry R, Pernon E, et al. Outcome of young children with autism: does the amount of intervention influence developmental trajectories?. Autism. Nov. 2010;14(6):663-77. X-1, X-3, X-4. [pmid: 21149421].
957 Darrow A-A, Armstrong T. Research on music and autism: implications for music educators. Update Appl Res Music Educ. Fall-Win. 1999;18(1):15-20. X-1, X-2, X-3, X-4.
958 Dartnall NA, Holmes JP, Morgan SN, et al. Two-year control of behavioral symptoms with risperidone in two profoundly retarded adults with autism. J Autism Dev Disord. Feb. 1999;29(1):87-91. X-3. [pmid: 10097998].
959 Dauphin M, Kinney EM, Stromer R, et al. Using video-enhanced activity schedules and matrix training to teach sociodramatic play to a child with autism. J Posit Behav Interv. 2004;6(4):238-50. X-1, X-3, X-4.
960 Dauz-Williams PA, Harrison-Elder JA, Hill SM. Media approach to family training in behavior management: two families. Issues Compr Pediatr Nurs. 1986;9(2):59-77. X-3. [pmid: 2420769].
961 Davanzo PA, Belin TR, Widawski MH, et al. Paroxetine treatment of aggression and self-injury in persons with mental retardation. Am J Ment Retard. Mar. 1998;102(5):427-37. X-3. [pmid: 9544340].
962 Davidovitch M, Holtzman G, Tirosh E. Autism in the Haifa area--an epidemiological perspective. Isr Med Assoc J. Mar. 2001;3(3):188-9. X-4. [pmid: 11303376].
963 Davidson J. ‘It cuts both ways’: a relational approach to access and accommodation for autism. Soc Sci Med. Jan. 2010;70(2):305-12. X-2, X-4. [pmid: 19883964].
964 Davidson S. Fleeting smile. Teach Artist J. Jan. 2006;4(4):265-6. X-1, X-2, X-3, X-4.
965 Davies J. The role of the specialist for families with autistic children. Nurs Stand. Oct. 9. 1996;11(3):36-40. X-1, X-3, X-4. [pmid: 8945305].
966 Davies PL, Soon PL, Young M, et al. Validity and reliability of the school function assessment in elementary school students with disabilities. Phys Occup Ther Pediatr. 2004;24(3):23-43. X-4. [pmid: 15257967].
967 Davis CA, Brady MP, Hamilton R, et al. Effects of high-probability requests on the social interactions of young children with severe disabilities. J Appl Behav Anal. Special Issue: Integrating basic and applied research. Win. 1994;27(4):619-37. X-1, X-3, X-4. [pmid: 7844055].
968 Davis CA, Brady MP, Williams RE, et al. Effects of high-probability requests on the acquisition and generalization of responses to requests in young children with behavior disorders. J Appl Behav Anal. Winter. 1992;25(4):905-16. X-1, X-3, X-4. [pmid: 1478913].
969 Davis NO, Carter AS. Parenting stress in mothers and fathers of toddlers with autism spectrum disorders: associations with child characteristics. J Autism Dev Disord. Aug. 2008;38(7):1278-91. X-1, X-3, X-4. [pmid: 18240012].
970 Davit CJ, Hundley RJ, Bacic JD, et al. A pilot study to improve venipuncture compliance in children and adolescents with autism spectrum disorders. J Dev Behav Pediatr. Sep. 2011;32(7):521-5. X-1, X-3, X-4. [pmid: 21694630].
971 Dawson G, Adams A. Imitation and social responsiveness in autistic children. J Abnorm Child Psychol. Jun. 1984;12(2):209-25. X-1, X-3, X-4. [pmid: 6725782].
972 Dawson G, Burner K. Behavioral interventions in children and adolescents with autism spectrum disorder: a review of recent findings. Curr Opin Pediatr. Dec. 2011;23(6):616-20. X-1, X-2, X-3, X-4. [pmid: 22037220].
973 Dawson G, Fernald M. Perspective-taking ability and its relationship to the social behavior of autistic children. J Autism Dev Disord. Dec. 1987;17(4):487-98. X-3, X-4. [pmid: 3680151].
974 Dawson G, Rogers S, Munson J, et al. Randomized, controlled trial of an intervention for toddlers with autism: the Early Start Denver Model. Pediatrics. Jan. 2010;125(1):e17-23. X-1, X-3, X-4. [pmid: 19948568].
975 Dawson G, Watling R. Interventions to facilitate auditory, visual, and motor integration in autism: a review of the evidence. J Autism Dev Disord. Oct. 2000;30(5):415-21. X-2. [pmid: 11098877].
976 Dawson G, Zanolli K. Early intervention and brain plasticity in autism. Novartis Found Symp. 2003;251:266-74. discussion 74–80, 81–97. X-2. [pmid: 14521198].
977 de Bildt A, Sytema S, Kraijer D, et al. Adaptive functioning and behaviour problems in relation to level of education in children and adolescents with intellectual disability. J Intellect Disabil Res. Sep. 2005;49(Pt 9):672-81. X-1, X-3, X-4. [pmid: 16108984].
978 De Leo G, Leroy G. An online community for teachers of children with autism to support, observe, and evaluate communication enabled with smartphones. AMIA Annu Symp Proc. 2008;924. X-2, X-4. [pmid: 18998843].
979 de Los Reyes EC. Autism and immunizations: separating fact from fiction. Arch Neurol. Apr. 2010;67(4):490-2. X-1, X-2, X-3, X-4. [pmid: 20385917].
980 De Schipper JC, Schuengel C. Attachment behaviour towards support staff in young people with intellectual disabilities: associations with challenging behaviour. J Intellect Disabil Res. Jul. 2010;54(7):584-96. X-1, X-4. [pmid: 20492348].
981 Dean AJ, McDermott BM, Marshall RT. PRN sedation-patterns of prescribing and administration in a child and adolescent mental health inpatient service. Eur Child Adolesc Psychiatry. Aug. 2006;15(5):277-81. X-2. [pmid: 16583125].
982 Deb S, Bramble D, Drybala G, et al. Polydipsia amongst adults with a learning disability in an institution. J Intellect Disabil Res. Aug. 1994;38(Pt 4):359-67. X-4. [pmid: 7949788].
983 DeBar LL, Lynch F, Powell J, et al. Use of psychotropic agents in preschool children: associated symptoms, diagnoses, and health care services in a health maintenance organization. Arch Pediatr Adolesc Med. Feb. 2003;157(2):150-7. X-4. [pmid: 12580684].
984 De Bortoli T, Arthur-Kelly M, Foreman P, et al. Complex contextual influences on the communicative interactions of students with multiple and severe disabilities. Int J Speech Lang Pathol. 2011;13(5):422-35. X-1, X-3, X-4. [pmid: 21888559].
985 Decety J, Meyer M. From emotion resonance to empathic understanding: a social developmental neuroscience account. Dev Psychopathol. Fall. 2008;20(4):1053-80. X-2, X-4. [pmid: 18838031].
986 DeGrace BW. The everyday occupation of families with children with autism. Am J Occup Ther. Sep–Oct. 2004;58(5):543-50. X-3. [pmid: 15481781].
987 Deitchman C, Reeve SA, Reeve KF, et al. Incorporating video feedback into self-management training to promote generalization of social initiations by children with autism. Educ Treat Children. Special Issue: Using video-based interventions with individuals with autism spectrum disorders. Aug. 2010;33(3):475-88. X-3.
988 Dejong M. Some reflections on the use of psychiatric diagnosis in the looked after or “in care” child population. Clin Child Psychol Psychiatry. Oct. 2010;15(4):589-99. X-1, X-2, X-3, X-4. [pmid: 20923905].
989 del Real A, Brabban A, Tiffin PA. Pervasive developmental disorder and early intervention in psychosis services: A survey of care coordinators’ experiences. Early Interv Psychiatry. Feb. 2010;4(1):93-6. X-4. [pmid: 20199485].
990 Delano M, Snell ME. The effects of social stories on the social engagement of children with autism. J Posit Behav Interv. 2006;8(1):29-42. X-1, X-3, X-4.
991 Delano ME. Improving written language performance of adolescents with Asperger syndrome. J Appl Behav Anal. Summer. 2007;40(2):345-51. X-3. [pmid: 17624076].
992 Delano ME. Use of strategy instruction to improve the story writing skills of a student with asperger syndrome. Focus Autism Dev Disabil. 2007;22(4):252-8. X-1, X-3, X-4.
993 Delano ME. Video modeling interventions for individuals with autism. Remedial Spec Educ. Jan–Feb. 2007;28(1):33-42. X-2.
994 DeLeon IG, Anders BM, Rodriguez-Catter V, et al. The effects of noncontingent access to single- versus multiple-stimulus sets on self-injurious behavior. J Appl Behav Anal. Special Issue: Establishing operations in applied behavior analysis. Win. 2000;33(4):623-6. X-1, X-3, X-4. [pmid: 11214037].
995 DeLeon IG, Hagopian LP, Rodriguez-Catter V, et al. Increasing wearing of prescription glasses in individuals with mental retardation. J Appl Behav Anal. Spring. 2008;41(1):137-42. X-3. [pmid: 18468288].
996 DeLeon IG, Neidert PL, Anders BM, et al. Choices between positive and negative reinforcement during treatment for escape-maintained behavior. J Appl Behav Anal. Winter. 2001;34(4):521-5. X-3. [pmid: 11800194].
997 Delfs CH, Campbell JM. A quantitative synthesis of developmental disability research: the impact of functional assessment methodology on treatment effectiveness. Behav Anal Today. 2010;11(1):4-19. X-1, X-2, X-3, X-4.
998 Delgado JAP, Greer RD. The effects of peer monitoring training on the emergence of the capability to learn from observing instruction received by peers. Psychological Record. Sum. 2009;59(3):407-34. X-3.
999 DelGiudice-Asch G, Simon L, Schmeidler J, et al. A pilot open clinical trial of intravenous immunoglobulin in childhood autism. J Autism Dev Disord. Apr. 1999;29(2):157-60. X-1, X-3, X-4. [pmid: 10382136].
1000 Delinicolas EK, Young RL. Joint attention, language, social relating, and stereotypical behaviours in children with autistic disorder. Autism. Sep. 2007;11(5):425-36. X-4. [pmid: 17942456].
1001 Delong G. A positive association found between autism prevalence and childhood vaccination uptake across the U.S. population. J Toxicol Environ Health A. Jan. 2011;74(14):903-16. X-1, X-3, X-4. [pmid: 21623535].
1002 DeLong GR, Ritch CR, Burch S. Fluoxetine response in children with autistic spectrum disorders: correlation with familial major affective disorder and intellectual achievement. Dev Med Child Neurol. Oct. 2002;44(10):652-9. X-1, X-3, X-4. [pmid: 12418789].
1003 DeLong GR, Teague LA, Kamran MM. Effects of fluoxetine treatment in young children with idiopathic autism. Dev Med Child Neurol. Aug. 1998;40(8):551-62. X-1, X-3, X-4. [pmid: 9746008].
1004 Delprato DJ. Comparisons of discrete-trial and normalized behavioral language intervention for young children with autism. J Autism Dev Disord. Jun. 2001;31(3):315-25. X-2, X-4. [pmid: 11518484].
1005 DeMattei R, Cuvo A, Maurizio S. Oral assessment of children with an autism spectrum disorder. J Dent Hyg. Summer. 2007;81(3):65. X-4. [pmid: 17908421].
1006 DeMore M, Cataldo M, Tierney E, et al. Behavioral approaches to training developmentally disabled children for an overnight EEG procedure. J Dev Phys Disabil. Aug. 2009;21(4):245-51. X-4. [pmid: 20617101].
1007 Dempsey AG, Llorens A, Brewton C, et al. Emotional and behavioral adjustment in typically developing siblings of children with autism spectrum disorders. J Autism Dev Disord. 2011. Oct. 8. X-4. [pmid: 21984214].
1008 DeMyer MK, Hingtgen JN, Jackson RK. Infantile autism reviewed: a decade of research. Schizophr Bull. 1981;7(3):388-451. X-1, X-2, X-3, X-4. [pmid: 6116276].
1009 DeMyer W, DeMyer M. Infantile autism. Neurol Clin. Feb. 1984;2(1):139-52. X-1, X-2, X-3, X-4. [pmid: 6503931].
1010 Denkyirah AM, Agbeke WK. Strategies for transitioning preschoolers with autism spectrum disorders to kindergarten. Early Child Educ J. Dec. 2010;38(4):265-70. X-1, X-3, X-4.
1011 Dennis M, Lockyer L, Lazenby AL, et al. Intelligence patterns among children with high-functioning autism, phenylketonuria, and childhood head injury. J Autism Dev Disord. Feb. 1999;29(1):5-17. X-2, X-4. [pmid: 10097991].
1012 Deonna T, Ziegler A, Maeder M, et al. Reversible behavioural autistic-like regression: a manifestation of a special (new?) epileptic syndrome in a 28-month-old child A 2-year longitudinal study. Neurocase (Psychology Press). 1995;1(2):91-9. X-1, X-3, X-4.
1013 Depositario-Cabacar DFT, Zelleke TG. Treatment of epilepsy in children with developmental disabilities. Dev Disabil Res Rev. 2010;16(3):239-47. X-1, X-2, X-3. [pmid: 20981762].
1014 DeQuinzio JA, Townsend DB, Sturmey P, et al. Generalized imitation of facial models by children with autism. J Appl Behav Anal. Winter. 2007;40(4):755-9. X-3. [pmid: 18189112].
1015 Dereu M, Warreyn P, Raymaekers R, et al. Screening for autism spectrum disorders in Flemish day-care centres with the checklist for early signs of developmental disorders. J Autism Dev Disord. Oct. 2010;40(10):1247-58. X-1, X-3, X-4. [pmid: 20198413].
1016 DeRosier ME, Swick DC, Davis NO, et al. The efficacy of a social skills group intervention for improving social behaviors in children with high functioning autism spectrum disorders. J Autism Dev Disord. Aug. 2011;41(8):1033-43. X-1, X-3, X-4. [pmid: 21042870].
1017 Desha L, Ziviani J, Rodger S. Play preferences and behavior of preschool children with autistic spectrum disorder in the clinical environment. Phys Occup Ther Pediatr. 2003;23(1):21-42. X-1, X-3, X-4. [pmid: 12703383].
1018 Desousa A. An open-label trial of risperidone and fluoxetine in children with autistic disorder. Indian J Psychol Med. Jan. 2010;32(1):17-21. X-1. [pmid: 21799554].
1019 DeStefano F, Bhasin TK, Thompson WW, et al. Age at first measles-mumps-rubella vaccination in children with autism and school-matched control subjects: a population-based study in metropolitan atlanta. Pediatrics. Feb. 2004;113(2):259-66. X-4. [pmid: 14754936].
1020 DeStefano F, Chen RT. Autism and measles, mumps, and rubella vaccine: no epidemiological evidence for a causal association. J Pediatr. Jan. 2000;136(1):125-6. X-2, X-4. [pmid: 10681219].
1021 DeThorne LS, Johnson CJ, Walder L, et al. When “Simon says” doesn’t work: alternatives to imitation for facilitating early speech development. Am J Speech Lang Pathol. May. 2009;18(2):133-45. X-2. [pmid: 18930909].
1022 Dettmer S, Simpson RL, Myles BS, et al. The use of visual supports to facilitate transitions of students with autism. Focus Autism Dev Disabil. Fal. 2000;15(3):163-9. X-1, X-3, X-4.
1023 Deurell M, Weischer M, Pagsberg AK, et al. The use of antipsychotic medication in child and adolescent psychiatric treatment in Denmark. A cross-sectional survey. Nord J Psychiatry. 2008;62(6):472-80. X-1, X-3, X-4. [pmid: 18841508].
1024 Deutsch SI. Rationale for the administration of opiate antagonists in treating infantile autism. Am J Ment Defic. May. 1986;90(6):631-5. X-1, X-2, X-3, X-4. [pmid: 2872816].
1025 Deutsch SI, Campbell M. Relative affinities for different classes of neurotransmitter receptors predict neuroleptic efficacy in infantile autism: a hypothesis. Neuropsychobiology. 1986;15(3–4):160-4. X-1, X-2, X-3, X-4. [pmid: 2431345].
1026 Deutsch SI, Campbell M, Perry R, et al. Plasma growth hormone response to insulin-induced hypoglycemia in infantile autism: a pilot study. J Autism Dev Disord. Mar. 1986;16(1):59-68. X-1, X-3, X-4. [pmid: 2870051].
1027 Deutsch SI, Milstoc M, Platovsky G, et al. Cholinesterase activities in blood in infantile autism. Biol Psychiatry. Feb. 1987;22(2):234-6. X-1, X-3, X-4. [pmid: 3814674].
1028 Devlin S, Healy O, Leader G, et al. Comparison of behavioral intervention and sensory-integration therapy in the treatment of challenging behavior. J Autism Dev Disord. Oct. 2011;41(10):1303-20. X-3. [pmid: 21161577].
1029 Dhossche D. Brief report: catatonia in autistic disorders. J Autism Dev Disord. Aug. 1998;28(4):329-31. X-3. [pmid: 9711489].
1030 Dhossche DM, Stanfill S. Could ECT be effective in autism?. Med Hypotheses. 2004;63(3):371-6. X-2, X-4. [pmid: 15288351].
1031 Di Martino A, Melis G, Cianchetti C, et al. Methylphenidate for pervasive developmental disorders: safety and efficacy of acute single dose test and ongoing therapy: an open-pilot study. J Child Adolesc Psychopharmacol. Summer. 2004;14(2):207-18. X-3. [pmid: 15319018].
1032 Diamond L, Dobson L, Boucher J. Is time a problem for children with autism as well as for children with specific language impairments?. Child Lang Teach Ther. 1998;14(2):181-98. X-1, X-3, X-4.
1033 Dias GG, Prado EF, Vadasz E, et al. Evaluation of the efficacy of a dental plaque control program in autistic patients. J Autism Dev Disord. Jun. 2010;40(6):704-8. X-1, X-3. [pmid: 20052608].
1034 Dib N, Sturmey P. Reducing student stereotypy by improving teachers’ implementation of discrete-trial teaching. J Appl Behav Anal. Summer. 2007;40(2):339-43. X-3. [pmid: 17624075].
1035 Dichter GS, Benning SD, Holtzclaw TN, et al. Affective modulation of the startle eyeblink and postauricular reflexes in autism spectrum disorder. J Autism Dev Disord. Jul. 2010;40(7):858-69. X-4. [pmid: 20049632].
1036 Dickinson J, Miller M. complex learning difficulties and EBD. Emot Behav Difficulties. Nov. 2002;7(4):197-206. X-1, X-2, X-3, X-4.
1037 Dickson CA, Deutsch CK, Wang SS, et al. Matching-to-sample assessment of stimulus overselectivity in students with intellectual disabilities. Am J Ment Retard. Nov. 2006;111(6):447-53. X-4. [pmid: 17029502].
1038 Dickson CA, Wang SS, Lombard KM, et al. Overselective stimulus control in residential school students with intellectual disabilities. Res Dev Disabil. Nov–Dec. 2006;27(6):618-31. X-4. [pmid: 16290082].
1039 Dickstein D. The costs of mental illness. J Am Acad Child Adolesc Psychiatry. May. 2009;48(5):459-60. X-2. [pmid: 19395898].
1040 Dickstein DP. In this issue/abstract thinking: the new normal. J Am Acad Child Adolesc Psychiatry. Nov. 2010;49(11):1087-8. X-1, X-2, X-3, X-4. [pmid: 20970695].
1041 Diehl SF. Epilogue: autism spectrum disorder: the context of speech-language pathologist intervention. Lang Speech Hear Serv Sch. Jul. 2003;34(3):253-54. X-1, X-2, X-3, X-4.
1042 Diehl SF. The SLP’s role in collaborative assessment and intervention for children with ASD. Top Lang Disord. Apr–Jun. 2003;23(2):95-115. X-1, X-3, X-4.
1043 Diehl SF, Ford CS, Federico J. The communication journey of a fully included child with an autism spectrum disorder. Top Lang Disord. Oct–Dec. 2005;25(4):375-87. X-1, X-3, X-4.
1044 DiGennaro Reed FD, Reed DD, Baez CN, et al. A parametric analysis of errors of commission during discrete-trial training. J Appl Behav Anal. Fall. 2011;44(3):611-5. X-1, X-3, X-4. [pmid: 21941391].
1045 DiLalla DL, Rogers SJ. Domains of the childhood autism rating scale: relevance for diagnosis and treatment. J Autism Dev Disord. Apr. 1994;24(2):115-28. X-4. [pmid: 8040157].
1046 Diler RS, Firat S, Avci A. An open-label trial of risperidone in children with autism. Curr Ther Res Clin Exp. Jan. 2002;63(1):91-102. X-1, X-3, X-4.
1047 Dillard JW, Elliott R, Milo T, et al. Demographics and development of fifty-eight disturbed children: a retrospective analysis. Psychology. 1985;22(1):20-6. X-1, X-3, X-4.
1048 Dillenburger K, Keenan M. None of the As in ABA stand for autism: dispelling the myths. J Intellect Dev Disabil. Jun. 2009;34(2):193-5. X-2, X-4. [pmid: 19404840].
1049 Dillenburger K, Keenan M, Gallagher S, et al. Parent education and home-based behaviour analytic intervention: An examination of parents’ perceptions of outcome. J Intellect Dev Disabil. Jun. 2004;29(2):119-30. X-1, X-3, X-4.
1050 Dillon KM, Fenlason JE, Vogel DJ. Belief in and use of a questionable technique, facilitated communication, for children with autism. Psychol Rep. Aug. 1994;75(1 Pt 2):459-64. X-4. [pmid: 7809318].
1051 Dimitropoulos A, Schultz RT. Food-related neural circuitry in Prader-Willi Syndrome: response to high- versus low-calorie foods. J Autism Dev Disord. Oct. 2008;38(9):1642-53. X-4. [pmid: 18311513].
1052 Dingfelder HE, Mandell DS. Bridging the research-to-practice gap in autism intervention: an application of diffusion of innovation theory. J Autism Dev Disord. May. 2011;41(5):597-609. X-1, X-2, X-3, X-4. [pmid: 20717714].
1053 DiPietro E, Luiselli JK, Campbell S, et al. A parent survey approach to evaluate public school education of children with autism/pervasive developmental disorder following center-based behavioral treatment. Spec Serv Schools. 2002;18(1–2):119-31. X-1, X-3, X-4.
1054 Dissanayake C, Shembrey J, Suddendorf T. Delayed video self-recognition in children with high Vo functioning autism and Asperger’s disorder. Autism. 2010;14(5):495-508. X-1, X-3, X-4. [pmid: 20926459].
1055 Ditterline J, Banner D, Oakland T, et al. Adaptive behavior profiles of students with disabilities. J Appl School Psychol. Jun. 2008;24(2):191-208. X-2, X-4.
1056 Dixon M, Baker JC, Sadowski KA. Applying Skinner’s anal verbal behavior to persons with dementia. Behav Ther. Mar. 2011;42(1):120-6. X-1, X-3, X-4. [pmid: 21292058].
1057 Dixon MR, Cummings A. Self-control in children with autism: response allocation during delays to reinforcement. J Appl Behav Anal. Winter. 2001;34(4):491-5. X-1, X-3, X-4. [pmid: 11800188].
1058 Dixon RS, Moore DW, Hartnett N, et al. Reducing inappropriate questioning behaviour in an adolescent with autism: A case study. Behav Change. 1995;12(3):163-6. X-3.
1059 Dobson S, Upadhyaya S, McNeil J, et al. Developing an information pack for the Asian carers of people with autism spectrum disorders. Int J Lang Commun Disord. Suppl. 2001;36:216-21. X-1, X-3, X-4. [pmid: 11340785].
1060 Dockrell JE, Lindsay G, Letchford B, et al. Educational provision for children with specific speech and language difficulties: perspectives of speech and language therapy service managers. Int J Lang Commun Disord. Jul–Aug. 2006;41(4):423-40. X-4. [pmid: 16815810].
1061 Dodd JL, Ocampo A, Kennedy KS. Perspective taking through narratives: an intervention for students with asd. Commun Disord Q. Nov. 2011;33(1):23-33. X-1, X-3, X-4.
1062 Dodds L, Spencer A, Shea S, et al. Validity of autism diagnoses using administrative health data. Chronic Dis Can. 2009;29(3):102-7. X-4. [pmid: 19527568].
1063 Doelling JE, Bryde S, Brunner J, et al. Collaborative planning for inclusion of a student with developmental disabilities. Middle School J. Jan. 1998;29(3):34-9. X-1, X-3, X-4.
1064 Doey T, Handelman K, Seabrook JA, et al. Survey of atypical antipsychotic prescribing by Canadian child psychiatrists and developmental pediatricians for patients aged under 18 years. Can J Psychiatry. Jun. 2007;52(6):363-8. X-4. [pmid: 17696022].
1065 Doherty K, Fitzgerald M, Matthews P. Services for autism in Ireland. Ir J Psychol. 2000;21(1–2):50-69. X-4.
1066 Dolan MA, Mace SE. Pediatric mental health emergencies in the emergency medical services system. Pediatrics. Oct. 2006;118(4):1764-7. X-2, X-4. [pmid: 17015573].
1067 Dolev S, Oppenheim D, Koren-Karie N, et al. Emotional availability in mother-child interaction: the case of children with autism spectrum disorders. Parent Sci Pract. 2009;9(3–4):183-97. X-1, X-3, X-4.
1068 Dollfus S, Petit M, Garnier JP, et al. Catecholamines in autistic disorder: effects of amisulpride and bromocriptine in a controlled crossover study. J Child Adolesc Psychopharmacol. Fal. 1993;3(3):145-56. X-3. [pmid: 19630674].
1069 Dollfus S, Petit M, Menard JF, et al. Amisulpride versus bromocriptine in infantile autism: a controlled crossover comparative study of two drugs with opposite effects on dopaminergic function. J Autism Dev Disord. Mar. 1992;22(1):47-60. X-3, X-4. [pmid: 1350581].
1070 Dolske MC, Spollen J, McKay S, et al. A preliminary trial of ascorbic acid as supplemental therapy for autism. Prog Neuropsychopharmacol Biol Psychiatry. Sep. 1993;17(5):765-74. X-3. [pmid: 8255984].
1071 Dolyniuk CA, Kamens MW, Corman H, et al. Students with developmental disabilities go to college: description of a collaborative transition project on a regular college campus. Focus Autism Dev Disabil. Win. 2002;17(4):236-41. X-3.
1072 Domes G, Heinrichs M, Michel A, et al. Oxytocin improves “mind-reading” in humans. Biol Psychiatry. Mar. 15. 2007;61(6):731-3. X-4. [pmid: 17137561].
1073 Donaldson AI, Heavner KS, Zwolan TA. Measuring progress in children with autism spectrum disorder who have cochlear implants. Arch Otolaryngol Head Neck Surg. May. 2004;130(5):666-71. [pmid: 15148195]. X-3.
1074 Donaldson AL, Olswang LB. Investigating requests for information in children with autism spectrum disorders: static versus dynamic assessment. Advances in Speech Language Pathology. 2007;9(4):297-311. X-1, X-3, X-4.
1075 Donaldson JB, Zager D. Mathematics interventions for students with high functioning autism/Asperger’s Syndrome. Teach Except Child. Jul–Aug. 2010;42(6):40-6. X-1, X-2, X-3, X-4.
1076 Dong D, Wilfond B, Rimal R. Causal attributions for autistic spectrum disorders: influences on perceived personal control. Presented abstracts from the Twenty-Fourth Annual Education Conference of the National Society of Genetic Counselors. Los Angeles, California. November 2005. J Genet Couns. 2006;15(1):17. X-4.
1077 Donnell NE. Messages through the music: musical dialogue as a means of communicative contact. Can J Music Ther. 2007;13(2):74-102. X-2.
1078 Donnellan AM, et al. Facilitated communication: beyond the quandary to the questions. Top Lang Disord. Aug. 1992;12(4):69-82. X-3.
1079 Donnellan AM, LaVigna GW, Zambito J, et al. A time-limited intensive intervention program model to support community placement for persons with severe behavior problems. J Assoc Pers Sev Handicaps. Fal. 1985;10(3):123-31. X-1, X-2, X-3, X-4.
1080 Donnelly JA, Altman R. The autistic savant: recognizing and serving the gifted student with autism. Roeper Rev. Jun. 1994;16(4):252-56. X-1, X-2, X-3, X-4.
1081 Donoghue K, Stallard P, Kucia J. The clinical practice of Cognitive Behavioural Therapy for children and young people with a diagnosis of Asperger’s Syndrome. Clin Child Psychol Psychiatry. Jan. 2011;16(1):89-102. X-1, X-2, X-3, X-4. [pmid: 20516059].
1082 Dooley P, Wilczenski FL, Torem C. Using an activity schedule to smooth school transitions. J Posit Behav Interv. Win. 2001;3(1):57-61. X-1, X-3, X-4.
1083 Dorahy MJ, Lewis CA. Absence of dissociative disorders in Irish Journals. Ir J Psychol Med. 2006;23(1):38-40. X-4.
1084 Dorminy KP, Luscre D, Gast DL. Teaching organizational skills to children with high functioning autism and Asperger’s syndrome. Educ Train Dev Disabil. Dec. 2009;44(4):538-50. X-1, X-3, X-4.
1085 Dosman CF, Brian JA, Drmic IE, et al. Children with autism: effect of iron supplementation on sleep and ferritin. Pediatr Neurol. Mar. 2007;36(3):152-8. X-1, X-3, X-4. [pmid: 17352947].
1086 Dosreis S, Weiner CL, Johnson L, et al. Autism spectrum disorder screening and management practices among general pediatric providers. J Dev Behav Pediatr. Apr. 2006;27(2 Suppl):S88-94. X-4. [pmid: 16685190].
1087 Dotger BH. from know how to do now: instructional applications of simulated interactions within teacher education. Teach Educ Prac. Spr. 2011;24(2):132-48. X-1, X-2, X-3, X-4.
1088 Dotto-Fojut KM, Reeve KF, Townsend DB, et al. Teaching adolescents with autism to describe a problem and request assistance during simulated vocational tasks. Res Autism Spectr Disord. Apr–Jun. 2011;5(2):826-33. X-3.
1089 Douglas EM. A personalized communication wallet. Am J Occup Ther. Feb. 1993;47(2):179-80. X-3. [pmid: 8470749].
1090 Douglas P. “Problematising” inclusion: education and the question of autism. Pedagogy Cult Soc. 2010;18(2):105-21. X-1, X-2, X-3.
1091 Dowd AM, Rinehart NJ, McGinley J. Motor function in children with autism: why is this relevant to psychologists?. Clin Psychol. Nov. 2010;14(3):90-6. X-1, X-2, X-3, X-4.
1092 Dowell LR, Mahone EM, Mostofsky SH. Associations of postural knowledge and basic motor skill with dyspraxia in autism: implication for abnormalities in distributed connectivity and motor learning. Neuropsychology. Sep. 2009;23(5):563-70. X-4. [pmid: 19702410].
1093 Downing JE, Morrison AP, Berecin-Rascon MA. Including elementary school students with autism and intellectual impairments in their typical classrooms: process and outcomes. Dev Disabil Bull. 1996;24(2):20-45. X-1, X-3, X-4.
1094 Downs A, Downs RC, Johansen M, et al. Using discrete trial teaching within a public preschool program to facilitate skill development in students with developmental disabilities. Educ Treat Children. Aug. 2007;30(3):1-27. X-1, X-3, X-4.
1095 Downs D, Schmidt B, Stephens TJ. Auditory behaviors of children and adolescents with pervasive developmental disorders. Semin Hear. 2005;26(4):226. X-4.
1096 Doyle AE, Biederman J, Ferreira MAR, et al. suggestive linkage of the child behavior checklist juvenile bipolar disorder phenotype to 1p21, 6p21, and 8q21. J Am Acad Child Adolesc Psychiatry. Apr. 2010;49(4):378-87. X-1, X-3, X-4. [pmid: 20410730].
1097 Doyle RL, Frazier J, Spencer TJ, et al. Donepezil in the treatment of ADHD-like symptoms in youths with pervasive developmental disorder: a case series. J Atten Disord. Feb. 2006;9(3):543-9. X-3. [pmid: 16481671].
1098 Doyle T, Arnedillo-Sánchez I. Using multimedia to reveal the hidden code of everyday behaviour to children with autistic spectrum disorders (ASDs). Comput Educ. Feb. 2011;56(2):357-69. X-3.
1099 Dozier CL, Carr JE, Enloe K, et al. Using fixed-time schedules to maintain behavior: a preliminary investigation. J Appl Behav Anal. Fal. 2001;34(3):337-40. X-1, X-3, X-4. [pmid: 11678529].
1100 Dozier CL, Iwata BA, Worsdell AS. Assessment and treatment of foot-shoe fetish displayed by a man with autism. J Appl Behav Anal. 2011;44(1):133-7. X-3. [pmid: 21541112].
1101 Drager KD, Postal VJ, Carrolus L, et al. The effect of aided language modeling on symbol comprehension and production in 2 preschoolers with autism. Am J Speech Lang Pathol. May. 2006;15(2):112-25. X-1, X-3, X-4. [pmid: 16782684].
1102 Drahota A, Wood JJ, Sze KM, et al. Effects of cognitive behavioral therapy on daily living skills in children with high-functioning autism and concurrent anxiety disorders. J Autism Dev Disord. Mar. 2011;41(3):257-65. X-1, X-3, X-4. [pmid: 20508979].
1103 Drapeau M, Beretta V, de Roten Y, et al. Defense styles of pedophilic offenders. Int J Offender Ther Comp Criminol. Apr. 2008;52(2):185-95. X-4. [pmid: 17875603].
1104 Drew A, Baird G, Baron-Cohen S, et al. A pilot randomised control trial of a parent training intervention for pre-school children with autism. Preliminary findings and methodological challenges. Eur Child Adolesc Psychiatry. Dec. 2002;11(6):266-72. X-1, X-3, X-4. [pmid: 12541005].
1105 Drew A, Baird G, Taylor E, et al. The Social Communication Assessment for Toddlers with Autism (SCATA): an instrument to measure the frequency, form and function of communication in toddlers with autism spectrum disorder. J Autism Dev Disord. Apr. 2007;37(4):648-66. X-4. [pmid: 17051443].
1106 Dube WV, McIlvane WJ. Reduction of stimulus overselectivity with nonverbal differential observing responses. J Appl Behav Anal. Spring. 1999;32(1):25-33. X-3. [pmid: 10201101].
1107 Duchan JF. Issues raised by facilitated communication for theorizing and research on autism. J Speech Hear Res. Dec. 1993;36(6):1108-19. X-2, X-4. [pmid: 7605401].
1108 Ducharme JM, Drain TL. Errorless academic compliance training: improving generalized cooperation with parental requests in children with autism. J Am Acad Child Adolesc Psychiatry. Feb. 2004;43(2):163-71. X-3. [pmid: 14726722].
1109 Ducharme JM, Lucas H, Pontes E. Errorless embedding in the reduction of severe maladaptive behavior during interactive and learning tasks. Behav Ther. Sum. 1994;25(3):489-501. X-1, X-3, X-4.
1110 Ducharme JM, Sanjuan E, Drain T. Errorless compliance training: Success-focused behavioral treatment of children with Asperger syndrome. Behav Modif. May. 2007;31(3):329-44. X-3. [pmid: 17438346].
1111 Dudley LL, Johnson C, Barnes RS. Decreasing rumination using a starchy food satiation procedure. Behav Interv. Jan–Mar. 2002;17(1):21-9. X-1, X-3, X-4.
1112 Dugan E, Kamps D, Leonard B. Effects of cooperative learning groups during social studies for students with autism and fourth-grade peers. J Appl Behav Anal. Summer. 1995;28(2):175-88. X-3. [pmid: 7601803].
1113 Duggal HS, Dutta S, Sinha VK. Mood stabilizers in Asperger’s syndrome. Aust N Z J Psychiatry. Jun. 2001;35(3):390-1. X-3. [pmid: 11437822].
1114 Duke TS. Lesbian, gay, bisexual, and transgender youth with disabilities: a meta-synthesis. J LGBT Youth. 2011;8(1):1-52. X-1, X-2, X-3, X-4.
1115 Duker PC, Douwenga H, Joosten S, et al. Effects of single and repeated shock on perceived pain and startle response in healthy volunteers. Res Dev Disabil. Jul–Aug. 2002;23(4):285-92. X-4. [pmid: 12365852].
1116 Duker PC, et al. Effects of fenfluramine on communicative, stereotypic, and inappropriate behaviors of autistic-type mentally handicapped individuals. J Autism Dev Disord. Sep. 1991;21(3):355-63. X-3. [pmid: 1938781].
1117 Duker PC, Hendriks C, Schroen J. Effect of wave frequency of clinical electric shock: pain sensation and startle response. Behav Interv. Apr. 2004;19(2):103-10. X-4.
1118 Duker PC, Schaapveld M. Increasing on-task behaviour through interruption-prompting. J Intellect Disabil Res. Aug. 1996;40(4):291-7. X-3. [pmid: 8884583].
1119 Duker PC, Welles K, Seys D, et al. Brief report: effects of fenfluramine on communicative, stereotypic, and inappropriate behaviors of autistic-type mentally handicapped individuals. J Autism Dev Disord. Sep. 1991;21(3):355-63. X-1, X-3, X-4. [pmid: 1938781].
1120 Dumerc C. Continuity and discontinuity in psychotherapy. Int J Ment Health. Fal. 1991;20(3):57-64. X-1, X-3, X-4.
1121 Dunlap G. The influence of task variation and maintenance tasks on the learning and affect of autistic children. J Exp Child Psychol. Feb. 1984;37(1):41-64. X-1, X-3, X-4. [pmid: 6707578].
1122 Dunlap G, Dyer K, Koegel RL. Autistic self-stimulation and intertrial interval duration. Am J Ment Defic. Sep. 1983;88(2):194-202. X-1, X-3, X-4. [pmid: 6638081].
1123 Dunlap G, Johnson J. Increasing the independent responding of autistic children with unpredictable supervision. J Appl Behav Anal. Fal. 1985;18(3):227-36. X-1, X-3, X-4. [pmid: 4044456].
1124 Dunlap G, Kern L, Worcester J. ABA and academic instruction. Focus Autism Dev Disabil. Sum. 2001;16(2):129-36. X-1, X-2, X-3, X-4.
1125 Dunlap G, Koegel RL. Motivating autistic children through stimulus variation. J Appl Behav Anal. Winter. 1980;13(4):619-27. X-1, X-3, X-4. [pmid: 7204282].
1126 Dunlap G, Koegel RL, Johnson J, et al. Maintaining performance of autistic clients in community settings with delayed contingencies. J Appl Behav Anal. Summer. 1987;20(2):185-91. X-1, X-3. [pmid: 3610898].
1127 Dunlap G, Newton JS, Fox L, et al. Family involvement in functional assessment and positive behavior support. Focus Autism Dev Disabil. Win. 2001;16(4):215-21. X-1, X-2, X-3, X-4.
1128 Dunlap G, Robbins FR, Darrow MA. Parents’ reports of their children’s challenging behaviors: results of a statewide survey. Ment Retard. Jun. 1994;32(3):206-12. X-4. [pmid: 8084272].
1129 Dunn ME, Burbine T, Bowers CA, et al. Moderators of stress in parents of children with autism. Community Ment Health J. Feb. 2001;37(1):39-52. X-1, X-4. [pmid: 11300666].
1130 Dunn W, Myles BS, Orr S. Sensory processing issues associated with Asperger syndrome: a preliminary investigation. Am J Occup Ther. Jan–Feb. 2002;56(1):97-102. X-4. [pmid: 11833406].
1131 Dunn W, Saiter J, Rinner L. Asperger Syndrome and sensory processing: a conceptual model and guidance for intervention planning. Focus Autism Dev Disabil. Fall. 2002;17(3):172-85. X-1, X-2, X-3, X-4.
1132 Dunne PB. Drama therapy techniques in one-to-one treatment with disturbed children and adolescents. Arts Psychother. Sum. 1988;15(2):139-49. X-1, X-2, X-3, X-4.
1133 Dunn-Geier J, Ho HH, Auersperg E, et al. Effect of secretin on children with autism: a randomized controlled trial. Dev Med Child Neurol. Dec. 2000;42(12):796-802. X-1, X-3, X-4. [pmid: 11132252].
1134 Dunst CJ, Trivette CM, Masiello T. Influence of the interests of children with autism on everyday learning opportunities. Psychol Rep. Aug. 2010;107(1):281-8. X-1, X-3, X-4. [pmid: 20923073].
1135 Dunst CJ, Trivette CM, Masiello T. Exploratory investigation of the effects of interest-based learning on the development of young children with autism. Autism. May. 2011;15(3):295-305. X-1, X-3, X-4. [pmid: 21430019].
1136 Dunstan E, Griffiths S. Sensory strategies: practical support to empower families. NZ J Occup Ther. 2008;55(1):5-13. X-3.
1137 Duran E. Nonsheltered vocational training for severely handicapped and severely handicapped autistic adolescents. J Instr Psychol. Jun. 1984;11(2):106-14. X-1.
1138 Duran E. Teaching functional reading in context to severely retarded and severely retarded autistic adolescents of limited English proficiency. Adolescence. Summer. 1985;20(78):433-9. X-1, X-3, X-4. [pmid: 4050577].
1139 Duran E. Teaching janitorial skills to autistic adolescents. Adolescence. Spring. 1985;20(77):225-32. X-3. [pmid: 3984810].
1140 Durán E. Teaching nonsheltered vocational skills to autistic adolescents and young adults. Psychology. 1984;21(3–4):49-54. X-1, X-2, X-3, X-4.
1141 Durán E. Teaching moderately and severely handicapped students of limited English proficiency to do competitive employment in nonsheltered sites. J Instr Psychol. Sep. 1985;12(3):127-31. X-1, X-3, X-4.
1142 Durand VM. Treating sleep terrors in children with autism. J Posit Behav Interv. Spr. 2002;4(2):66-72. X-1, X-3, X-4.
1143 Durand VM, Carr EG. Functional communication training to reduce challenging behavior: maintenance and application in new settings. J Appl Behav Anal. Summer. 1991;24(2):251-64. X-3. [pmid: 1890046].
1144 Durand VM, Carr EG. An analysis of maintenance following functional communication training. J Appl Behav Anal. Win. 1992;25(4):777-94. X-1, X-3, X-4. [pmid: 1478902].
1145 Durand VM, Christodulu KV, Koegel RL. Description of a sleep-restriction program to reduce bedtime disturbances and night waking. J Posit Behav Interv. Spr. 2004;6(2):83-91. X-1, X-3, X-4.
1146 Durand VM, Crimmins DB. Assessment and treatment of psychotic speech in an autistic child. J Autism Dev Disord. Mar. 1987;17(1):17-28. X-1, X-3, X-4. [pmid: 3571140].
1147 Durand VM, Merges E. functional communication training: a contemporary behavior analytic intervention for problem behaviors. Focus Autism Dev Disabil. Sum. 2001;16(2):110-19. 36. X-1, X-2, X-3, X-4.
1148 Dworzynski K, Ronald A, Hayiou-Thomas ME, et al. Developmental path between language and autistic-like impairments: a twin study. Infant Child Dev. 2008;17(2):121-36. X-1, X-3, X-4.
1149 Dybvik AC. Autism and the inclusion mandate. Educ Next. Win. 2004;4(1):42-9. X-2, X-4.
1150 Dyer K. The competition of autistic stereotyped behavior with usual and specially assessed reinforcers. Res Dev Disabil. 1987;8(4):607-26. X-3. [pmid: 3685547].
1151 Dyer K. The effects of preference on spontaneous verbal requests in individuals with autism. J Assoc Pers Sev Handicaps. Fal. 1989;14(3):184-9. X-1, X-3, X-4.
1152 Dyer K, Christian WP, Luce SC. The role of response delay in improving in the discrimination performance or autistic children. J Appl Behav Anal. Summer. 1982;15(2):231-40. X-3. [pmid: 7118756].
1153 Dyer K, Dunlap G, Winterling V. Effects of choice making on the serious problem behaviors of students with severe handicaps. J Appl Behav Anal. Winter. 1990;23(4):515-24. X-3. [pmid: 2074240].
1154 Dyer K, et al. Training teachers to use naturalistic communication strategies in classrooms for students with autism and other severe handicaps. Lang Speech Hear Serv Sch. Jan. 1991;22(1):313-21. X-1, X-3, X-4.
1155 Dyer K, Kneringer MJ, Luce SC. An efficient method of ensuring program quality for adults with developmental disabilities in community-based apartments. Consult Psychol J. Sum. 1996;48(3):171-9. X-1, X-3, X-4.
1156 Dyer K, Martino GM, Parvenski T. The River Street Autism Program: a case study of a regional service center behavioral intervention program. Behav Modif. Nov. 2006;30(6):925-43. X-1, X-3, X-4. [pmid: 17050771].
1157 Dyer K, Santarcangelo S, Luce SC. Developmental influences in teaching language forms to individuals with developmental disabilities. J Speech Hear Disord. Nov. 1987;52(4):335-47. X-3. [pmid: 3669631].
1158 Dykens E, Volkmar F, Glick M. Though disorder in high-functioning autistic adults. J Autism Dev Disord. Sep. 1991;21(3):291-301. X-3, X-4. [pmid: 1938775].
1159 Dymond SK, Gilson CL, Myran SP. Services for children with autism spectrum disorders: what needs to change?. J Disabil Pol Stud. 2007;18(3):133-47. X-4.
1160 Earles TL, Myles BS. Using behavioral interventions to decrease coprolalia in a student with Tourette’s syndrome and autism: a case study. Focus Autism Other Dev Disabil. Feb. 1994;8(6):1-10. X-1, X-3, X-4.
1161 Earles-Vollrath TL. Book review: teaching kids and adults with autism: building the framework for lifetime learning. Focus Autism Dev Disabil. Spr. 2001;16(1):64. X-1, X-2, X-3, X-4.
1162 Easterbrooks SR, Handley CM. Behavior change in a student with a dual diagnosis of deafness and pervasive development disorder: a case study. Am Ann Deaf. 2005;150(5):401-7. X-2, X-3. [pmid: 16610472].
1163 Eaves LC, Ho HH. School placement and academic achievement in children with autistic spectrum disorders. J Dev Phys Disabil. Dec. 1997;9(4):277-91. X-1, X-4.
1164 Eaves LC, Ho HH. The very early identification of autism: outcome to age 4 1/2--5. J Autism Dev Disord. Aug. 2004;34(4):367-78. X-1, X-3, X-4. [pmid: 15449513].
1165 Eaves LC, Ho HH. Young adult outcome of autism spectrum disorders. J Autism Dev Disord. Apr. 2008;38(4):739-47. X-1, X-3, X-4. [pmid: 17764027].
1166 Edelson SM, Edelson MG, Kerr DC, et al. Behavioral and physiological effects of deep pressure on children with autism: a pilot study evaluating the efficacy of Grandin’s Hug Machine. Am J Occup Ther. Mar–Apr. 1999;53(2):145-52. X-3. [pmid: 10200837].
1167 Edelson SM, Rimland B, Berger CL, et al. Evaluation of a mechanical hand-support for facilitated communication. J Autism Dev Disord. Apr. 1998;28(2):153-7. X-3. [pmid: 9586777].
1168 Edgerton CL. The effect of improvisational music therapy on the communicative behaviors of autistic children. J Music Ther. Spr. 1994;31(1):31-62. X-1, X-3, X-4.
1169 Edrisinha C, O’Reilly MF, Choi HY, et al. “Say Cheese”: teaching photography skills to adults with developmental disabilities. Res Dev Disabil. Mar–Apr. 2011;32(2):636-42. X-3. [pmid: 21227636].
1170 Egan CE, Barnes-Holmes D. Emergence of tacts following mand training in young children with autism. J Appl Behav Anal. Fall. 2009;42(3):691-6. X-1, X-3, X-4. [pmid: 20190930].
1171 Egan PJ, Zlomke LC, Bush BR. Utilizing functional assessment, behavioral consultation and videotape review of treatment to reduce aggression: a case study. Spec Serv Schools. 1993;7(1):27-37. X-1, X-3, X-4.
1172 Egel AL. The effects of constant vs varied reinforcer presentation on responding by autistic children. J Exp Child Psychol. Dec. 1980;30(3):455-63. X-1, X-3, X-4. [pmid: 7205141].
1173 Egel AL, Richman GS, Koegel RL. Normal peer models and autistic children’s learning. J Appl Behav Anal. Spring. 1981;14(1):3-12. X-3. [pmid: 7216930].
1174 Eide BL, Eide FF. The mislabeled child. New Atlantis. Spring. 2006;12:46-59. X-2. [pmid: 16832954].
1175 Eikeseth S. Outcome of comprehensive psycho-educational interventions for young children with autism. Res Dev Disabil. Jan–Feb. 2009;30(1):158-78. X-2. [pmid: 18385012].
1176 Eikeseth S, Hayward D, Gale C, et al. Intensity of supervision and outcome for preschool aged children receiving early and intensive behavioral interventions: a preliminary study. Res Autism Spectr Disord. Jan. 2009;3(1):67-73. X-1, X-3, X-4.
1177 Eikeseth S, Hayward DW. The discrimination of object names and object sounds in children with autism: a procedure for teaching verbal comprehension. J Appl Behav Anal. Winter. 2009;42(4):807-12. X-1, X-3, X-4. [pmid: 20514186].
1178 Eikeseth S, Jahr E. The UCLA reading and writing program: an evaluation of the beginning stages. Res Dev Disabil. Jul–Aug. 2001;22(4):289-307. [pmid: 11523953]. X-3.
1179 Eikeseth S, Lovaas OI. The autistic label and its potentially detrimental effect on the child’s treatment. J Behav Ther Exp Psychiatry. Sep. 1992;23(3):151-7. X-4. [pmid: 1487532].
1180 Eikeseth S, Smith T, Jahr E, et al. Intensive behavioral treatment at school for 4- to 7-year-old children with autism. A 1-year comparison controlled study. Behav Modif. Jan. 2002;26(1):49-68. X-1, X-3, X-4. [pmid: 11799654].
1181 Eikeseth S, Smith T, Jahr E, et al. Outcome for children with autism who began intensive behavioral treatment between ages 4 and 7: a comparison controlled study. Behav Modif. May. 2007;31(3):264-78. X-1, X-3, X-4. [pmid: 17438342].
1182 Eisermann MM, DeLaRaillere A, Dellatolas G, et al. Infantile spasms in Down syndrome--effects of delayed anticonvulsive treatment. Epilepsy Res. Jun–Jul. 2003;55(1–2):21-7. X-2. [pmid: 12948613].
1183 Eklund M, Ostman M. Belonging and doing: important factors for satisfaction with sexual relations as perceived by people with persistent mental illness. Int J Soc Psychiatry. Jul. 2010;56(4):336-47. X-4. [pmid: 19617283].
1184 Ekman G, Miranda-Linne F, Gillberg C, et al. Fenfluramine treatment of twenty children with autism. J Autism Dev Disord. Dec. 1989;19(4):511-32. X-1, X-3, X-4. [pmid: 2606882].
1185 Elchaar GM, Maisch NM, Augusto LM, et al. Efficacy and safety of naltrexone use in pediatric patients with autistic disorder. Ann Pharmacother. Jun. 2006;40(6):1086-95. X-1, X-2, X-3. [pmid: 16735648].
1186 Elder J, Kneipp S. Faculty receive million dollar NIH grants to continue their research. Fla Nurse. Dec. 2005;53(4):28. X-2. [pmid: 16382773].
1187 Elder JH. Beliefs held by parents of autistic children. J Child Adolesc Psychiatr Nurs. Jan–Mar. 1994;7(1):9-16. X-2. [pmid: 8000776].
1188 Elder JH. In-home communication intervention training for parents of multiply handicapped children. Sch Inq Nurs Pract. Spring. 1995;9(1):71-92. discussion 3–5. X-3. [pmid: 7777745].
1189 Elder JH. A follow-up study of beliefs held by parents of children with pervasive developmental delay. J Child Adolesc Psychiatr Nurs. Apr–Jun. 2001;14(2):55-60. X-1, X-3, X-4. [pmid: 11883624].
1190 Elder JH, D’Alessandro T. Supporting families of children with autism spectrum disorders: questions parents ask and what nurses need to know. Pediatr Nurs. Jul–Aug. 2009;35(4):240-5. 53. X-2. [pmid: 19785304].
1191 Elder JH, Valcante G, Groce S, et al. Social interactions of children with autism in father-child and mother-child play sessions. Pediatr Nurs. Nov–Dec. 2002;28(6):573-8. 81. X-1, X-3, X-4. [pmid: 12593342].
1192 Elder JH, Valcante G, Won D, et al. Effects of in-home training for culturally diverse fathers of children with autism. Issues Ment Health Nurs. Apr–May. 2003;24(3):273-95. X-1, X-3, X-4. [pmid: 12623686].
1193 Elder LM, Caterino LC, Chao J, et al. the efficacy of social skills treatment for children with asperger syndrome. Educ Treat Children. Nov. 2006;29(4):635-63. X-1, X-2, X-3, X-4.
1194 Eldevik S, Eikeseth S, Jahr E, et al. Effects of low-intensity behavioral treatment for children with autism and mental retardation. J Autism Dev Disord. Feb. 2006;36(2):211-24. X-1, X-3, X-4. [pmid: 16477514].
1195 Eldevik S, Hastings RP, Hughes JC, et al. Meta-analysis of early intensive behavioral intervention for children with autism. J Clin Child Adolesc Psychol. 2009;38(3):439-50. X-2. [pmid: 19437303].
1196 Eldevik S, Hastings RP, Hughes JC, et al. Using participant data to extend the evidence base for intensive behavioral intervention for children with autism. Am J Intellect Dev Disabil. Sep. 2010;115(5):381-405. X-2. [pmid: 20687823].
1197 Eldevik S, Jahr E, Eikeseth S, et al. Cognitive and adaptive behavior outcomes of behavioral intervention for young children with intellectual disability. Behav Modif. Jan. 2010;34(1):16-34. X-4. [pmid: 20051523].
1198 Elfert M, Mirenda P. The experiences of behavior interventionists who work with children with autism in families’ homes. Autism. Nov. 2006;10(6):577-91. X-4. [pmid: 17088274].
1199 el-Ghoroury NH, Romanczyk RG. Play interactions of family members towards children with autism. J Autism Dev Disord. Jun. 1999;29(3):249-58. X-4. [pmid: 10425587].
1200 Eliasoph E, Donnellan AM. A group therapy program for individuals identified as autistic who are without speech and use facilitated communication. Int J Group Psychother. Oct. 1995;45(4):549-60. X-1, X-3. [pmid: 7558507].
1201 El-Leithy S, Webb Z. A matter of distinction. Health Serv J. Mar. 12. 1998;108(5595):32-3. X-1, X-2, X-3, X-4. [pmid: 10184868].
1202 Ellenberg SS. Safety considerations for new vaccine development. Pharmacoepidemiol Drug Saf. Aug–Sep. 2001;10(5):411-5. X-2, X-4. [pmid: 11802587].
1203 Elliott RO Jr, Dobbin AR, Rose GD, et al. Vigorous, aerobic exercise versus general motor training activities: effects on maladaptive and stereotypic behaviors of adults with both autism and mental retardation. J Autism Dev Disord. Oct. 1994;24(5):565-76. X-3. [pmid: 7814306].
1204 Ellis CR, Lutz RE, Schaefer GB, et al. Physician collaboration involving students with autism spectrum disorders. Psychol Sch. Sep. 2007;44(7):737-47. X-2, X-4.
1205 Ellis EM, Ala’i-Rosales SS, Glenn SS, et al. The effects of graduated exposure, modeling, and contingent social attention on tolerance to skin care products with two children with autism. Res Dev Disabil. Nov–Dec. 2006;27(6):585-98. X-3. [pmid: 16242911].
1206 Emam MM, Farrell P. Tensions experienced by teachers and their views of support for pupils with autism spectrum disorders in mainstream schools. Eur J Spec Needs Educ. Nov. 2009;24(4):407-22. X-3, X-4.
1207 Emanuel L. Facing the damage together: Some reflections arising from the treatment in psychotherapy of a severely mentally handicapped child. J Child Psychother. Aug. 1997;23(2):279-302. X-1, X-3, X-4.
1208 Embregts P, van Nieuwenhuijzen M. Social information processing in boys with autistic spectrum disorder and mild to borderline intellectual disabilities. J Intellect Disabil Res. 2009;53(Part 11):922-31. X-4. [pmid: 19719515].
1209 Emerson E, Hatton C. Mental health of children and adolescents with intellectual disabilities in Britain. Br J Psychiatry. Dec. 2007;191:493-9. X-4. [pmid: 18055952].
1210 Emond A, Emmett P, Steer C, et al. Feeding symptoms, dietary patterns, and growth in young children with autism spectrum disorders. Pediatrics. Aug. 2010;126(2):e337-e42. X-1, X-3, X-4. [pmid: 20643716].
1211 English CL, Anderson CM. Effects of familiar versus unfamiliar therapists on responding in the analog functional analysis. Res Dev Disabil. Jan–Feb. 2004;25(1):39-55. X-3. [pmid: 14733975].
1212 Engstrom I, Ekstrom L, Emilsson B. Psychosocial functioning in a group of Swedish adults with Asperger syndrome or high-functioning autism. Autism. Mar. 2003;7(1):99-110. X-1, X-3, X-4. [pmid: 12638767].
1213 Enticott PG, Kennedy HA, Zangen A, et al. Deep repetitive transcranial magnetic stimulation associated with improved social functioning in a young woman with an autism spectrum disorder. JECT. Mar. 2011;27(1):41-3. X-3.
1214 Enticott PG, Rinehart NJ, Tonge BJ, et al. A preliminary transcranial magnetic stimulation study of cortical inhibition and excitability in high-functioning autism and Asperger disorder. Dev Med Child Neurol. Aug. 2010;52(8):e179-83. X-4. [pmid: 20370810].
1215 Epp KM. Outcome-based evaluation of a social skills program using art therapy and group therapy for children on the autism spectrum. Child Sch. Jan. 2008;30(1):27-36. X-1, X-3.
1216 Epperson CN, McDougle CJ, Anand A, et al. Lithium augmentation of fluvoxamine in autistic disorder: a case report. J Child Adolesc Psychopharmacol. Fal. 1994;4(3):201-7. X-3.
1217 Epstein LJ, Taubman MT, Lovaas OI. Changes in self-stimulatory behaviors with treatment. J Abnorm Child Psychol. Jun. 1985;13(2):281-93. X-3. [pmid: 4008756].
1218 Epstein N. A residence for autistic and schizophrenic adolescents. Soc Casework. Apr. 1982;63(4):209-14. X-1, X-2, X-3, X-4. [pmid: 10318544].
1219 Erba HW. Early intervention programs for children with autism: conceptual frameworks for implementation. Am J Orthopsychiatry. Jan. 2000;70(1):82-94. X-2, X-4. [pmid: 10702853].
1220 Erdmann J. Broad collaborations bring new energy to autism therapeutics. Chem Biol. Feb. 25. 2011;18(2):142-3. X-1, X-2, X-3, X-4. [pmid: 21338911].
1221 Erickson CA, Mullett JE, McDougle CJ. Open-label memantine in Fragile X Syndrome. J Autism Dev Disord. Dec. 2009;39(12):1629-35. X-1, X-3, X-4. [pmid: 19609663].
1222 Erickson CA, Mullett JE, McDougle CJ. Brief report: acamprosate in Fragile X Syndrome. J Autism Dev Disord. Nov. 2010;40(11):1412-6. X-1, X-3, X-4. [pmid: 20213249].
1223 Erickson CA, Posey DJ, Stigler KA, et al. A retrospective study of memantine in children and adolescents with pervasive developmental disorders. Psychopharmacology. Special Issue: Pediatric psychopharmacology: Mood, anxiety and disruptive behavior/pervasive developmental disorders. Mar. 2007;191(1):141-7. X-3. [pmid: 17016714].
1224 Erickson CA, Stigler KA, Corkins MR, et al. Gastrointestinal factors in autistic disorder: a critical review. J Autism Dev Disord. Dec. 2005;35(6):713-27. X-2, X-4. [pmid: 16267642].
1225 Ernst M. Commentary: considerations on the characterization and treatment of self-injurious behavior. J Autism Dev Disord. Oct. 2000;30(5):447-50. X-1, X-2, X-3, X-4. [pmid: 11098882].
1226 Ernst M, Devi L, Silva RR, et al. Plasma beta-endorphin levels, naltrexone, and haloperidol in autistic children. Psychopharmacol Bull. 1993;29(2):221-7. X-4. [pmid: 8290669].
1227 Ernst M, Magee HJ, Gonzalez NM, et al. Pimozide in autistic children. Psychopharmacol Bull. 1992;28(2):187-91. X-1, X-3, X-4. [pmid: 1513923].
1228 Erwin R, Van Lancker D, Guthrie D, et al. P3 responses to prosodic stimuli in adult autistic subjects. Electroencephalogr Clin Neurophysiol. Nov–Dec. 1991;80(6):561-71. X-4. [pmid: 1720733].
1229 Esbensen AJ, Greenberg JS, Seltzer MM, et al. A longitudinal investigation of psychotropic and non-psychotropic medication use among adolescents and adults with autism spectrum disorders. J Autism Dev Disord. Sep. 2009;39(9):1339-49. X-1, X-3, X-4. [pmid: 19434487].
1230 Esbenshade PH, Rosales-Ruiz J. Programming common stimuli to promote generalized question-asking: A case demonstration in a child with autism. J Posit Behav Interv. Fal. 2001;3(4):199-210. X-4.
1231 Escalona A, Field T, Singer-Strunck R, et al. Brief report: improvements in the behavior of children with autism following massage therapy. J Autism Dev Disord. Oct. 2001;31(5):513-6. X-1, X-3, X-4. [pmid: 11794416].
1232 Esch BE, Carr JE. Secretin as a treatment for autism: a review of the evidence. J Autism Dev Disord. Oct. 2004;34(5):543-56. X-2, X-4. [pmid: 15628608].
1233 Esch BE, Carr JE, Grow LL. Evaluation of an enhanced stimulus-stimulus pairing procedure to increase early vocalizations of children with autism. J Appl Behav Anal. Summer. 2009;42(2):225-41. X-1, X-3, X-4. [pmid: 19949511].
1234 Escribano Hernandez A, Hernandez Corral T, Ruiz-Martin E, et al. Results of a dental care protocol for mentally handicapped patients set in a primary health care area in Spain. Med Oral Patol Oral Cir Bucal. Dec. 2007;12(7):E492-5. X-3. [pmid: 17978772].
1235 Eskes GA, Bryson SE, McCormick TA. Comprehension of concrete and abstract words in autistic children. J Autism Dev Disord. Mar. 1990;20(1):61-73. X-4. [pmid: 2324056].
1236 Eskow K, Pineles L, Summers JA. Exploring the effect of autism waiver services on family outcomes. J Pol Prac Intellect Disabil. Mar. 2011;8(1):28-35. X-4.
1237 Esposito G, Venuti P. Understanding early communication signals in autism: a study of the perception of infants’ cry. J Intellect Disabil Res. 2010;54(Part 3):216-23. X-1, X-3, X-4. [pmid: 20136681].
1238 Estes A, Munson J, Dawson G, et al. Parenting stress and psychological functioning among mothers of preschool children with autism and developmental delay. Autism. Jul. 2009;13(4):375-87. X-4. [pmid: 19535467].
1239 Estes A, Rivera V, Bryan M, et al. Discrepancies between academic achievement and intellectual ability in higher-functioning school-aged children with autism spectrum disorder. J Autism Dev Disord. Aug. 2011;41(8):1044-52. X-1, X-3, X-4. [pmid: 21042871].
1240 Estes AM, Dawson G, Sterling L, et al. Level of intellectual functioning predicts patterns of associated symptoms in school-age children with autism spectrum disorder. Am J Ment Retard. Nov. 2007;112(6):439-49. X-1, X-3, X-4. [pmid: 17963435].
1241 Eto I, Bandy MD, Butterworth CE. Plasma and urinary levels of biopterin, neopterin, and related pterins and plasma levels of folate in infantile autism. J Autism Dev Disord. Jun. 1992;22(2):295-308. X-4. [pmid: 1624410].
1242 Etscheidt S. An analysis of legal hearings and cases related to individualized education programs for children with autism. Res Pract Persons Severe Disabl. Sum. 2003;28(2):51-69. X-1, X-2, X-3, X-4.
1243 Evangeliou A, Vlachonikolis I, Mihailidou H, et al. Application of a ketogenic diet in children with autistic behavior: pilot study. J Child Neurol. Feb. 2003;18(2):113-8. X-1, X-3, X-4. [pmid: 12693778].
1244 Evans C, Dunstan RH, Rothkirch T, et al. Altered amino acid excretion in children with autism. Nutr Neurosci. Feb. 2008;11(1):9-17. X-1, X-3, X-4. [pmid: 18510798].
1245 Evans G. Update on vaccine liability in the United States: presentation at the National Vaccine Program Office Workshop on strengthening the supply of routinely recommended vaccines in the United States. 12 February 2002. Clin Infect Dis. Mar. 1. Suppl 3. 2006;42:S130-7. [pmid: 16447135]. X-2, X-4.
1246 Evans M, Stoddart H, Condon L, et al. Parents’ perspectives on the MMR immunisation: a focus group study. Br J Gen Pract. Nov. 2001;51(472):904-10. X-4. [pmid: 11761204].
1247 Evers S. Music therapy in the treatment of autistic children. Medico-sociological data from the Federal Republic of Germany. Acta Paedopsychiatr. 1992;55(3):157-8. X-4. [pmid: 1414349].
1248 Faber A, Kalverdijk LJ, de Jong-van den Berg LT, et al. Co-morbidity and patterns of care in stimulant-treated children with ADHD in the Netherlands. Eur Child Adolesc Psychiatry. Feb. 2010;19(2):159-66. X-1, X-3, X-4. [pmid: 19894075].
1249 Faber S. International adoption: A four-year-old child with unusual behaviors adopted at six months of age: Dr. Scott Faber J Dev Behav Pediatr. Feb. 2003;24(1):64-5. X-1, X-3, X-4.
1250 Fabian KJ. Deep-feeling development gives autistics abstractions: when a young person has no abstractions, his or her thoughts or behaviors frequently seem autistic. Med Hypotheses. 2005;65(4):694-8. X-2, X-4. [pmid: 16019156].
1251 Fabrizio MA, Schirmer K, King A, et al. Precision teaching a foundational motor skill to a child with autism. J Precision Teach Celeration. 2007;23:16-8. X-3.
1252 Fabrizio MA, Schirmer K, Vu E, et al. Analog analysis of two variables related to the joint attention of a toddler with autism. J Precision Teach Celeration. Spr. 2003;19(1):41-4. X-1, X-3, X-4.
1253 Factor DC, Perry A, Freeman N. Stress, social support, and respite care use in families with autistic children. J Autism Dev Disord. Mar. 1990;20(1):139-46. X-1, X-3, X-4. [pmid: 2324052].
1254 Fahlvik-Planefeldt C, Herrstrom P. Dental care of autistic children within the non-specialized Public Dental Service. Swed Dent J. 2001;25(3):113-8. X-4. [pmid: 11813447].
1255 Faja S, Aylward E, Bernier R, et al. Becoming a face expert: a computerized face-training program for high-functioning individuals with autism spectrum disorders. Dev Neuropsychol. 2008;33(1):1-24. X-3. [pmid: 18443967].
1256 Falcomata TS, Roane HS, Feeney BJ, et al. Assessment and treatment of elopement maintained by access to stereotypy. J Appl Behav Anal. Fal. 2010;43(3):513-7. X-1, X-3, X-4. [pmid: 21358912].
1257 Falcomata TS, Roane HS, Hovanetz AN, et al. An evaluation of response cost in the treatment of inappropriate vocalizations maintained by automatic reinforcement. J Appl Behav Anal. Spr. 2004;37(1):83-7. X-1, X-3. [pmid: 15154219].
1258 Falcomata TS, Roane HS, Pabico RR. Unintentional stimulus control during the treatment of pica displayed by a young man with autism. Res Autism Spectr Disord. Oct–Dec. 2007;1(4):350-9. X-1, X-3, X-4.
1259 Falkmer T, Anund A, Sörensen G, et al. The transport mobility situation for children with autism spectrum disorders. Scand J Occup Ther. 2004;11(2):90-100. X-4.
1260 Fallon J. Could one of the most widely prescribed antibiotics amoxicillin/clavulanate “augmentin” be a risk factor for autism?. Med Hypotheses. 2005;64(2):312-5. X-4. [pmid: 15607562].
1261 Fankhauser MP, Karumanchi VC, German ML, et al. A double-blind, placebo-controlled study of the efficacy of transdermal clonidine in autism. J Clin Psychiatry. Mar. 1992;53(3):77-82. X-3. [pmid: 1548248].
1262 Fantuzzo JW, Smith C. Linking community-based treatment settings for a disturbed autistic child. Educ Train Ment Retard. Apr. 1984;19(2):102-7. X-1, X-3, X-4.
1263 Fantuzzo JW, Smith CS. Programmed generalization of dress efficiency across settings for a severely disturbed, autistic child. Psychol Rep. Dec. 1983;53(3, Pt 1):871-9. X-1, X-3, X-4. [pmid: 6657839].
1264 Farley MA, McMahon WM, Fombonne E, et al. Twenty-year outcome for individuals with autism and average or near-average cognitive abilities. Autism Res. Apr. 2009;2(2):109-18. X-1, X-3, X-4. [pmid: 19455645].
1265 Farmer C, Lecavalier L, Yu S, et al. Predictors and moderators of parent training efficacy in a sample of children with autism spectrum disorders and serious behavioral problems. J Autism Dev Disord. 2011. Aug. 6. X-1, X-3, X-4. [pmid: 21822762].
1266 Farmer JE, Clark MJ. Identification and evaluation of Missouri’s children with autism spectrum disorders: promoting a rapid response. Mo Med. Sep–Oct. 2008;105(5):384-9. X-2. [pmid: 18807359].
1267 Farmer S. Finding Amy’s voice: a case for inclusion. Voices from the Middle. Nov. 1996;3(4):27-31. X-3.
1268 Farmer-Dougan V. Increasing requests by adults with developmental disabilities using incidental teaching by peers. J Appl Behav Anal. Fall. 1994;27(3):533-44. X-3. [pmid: 7928794].
1269 Farr W, Yuill N, Raffle H. Social benefits of a tangible user interface for children with autistic spectrum conditions. Autism. May. 2010;14(3):237-52. X-1, X-3, X-4. [pmid: 20484323].
1270 Farrington CP, Miller E, Taylor B. MMR and autism: further evidence against a causal association. Vaccine. Jun. 14. 2001;19(27):3632-5. X-4. [pmid: 11395196].
1271 Farzin F, Scaggs F, Hervey C, et al. Reliability of eye tracking and pupillometry measures in individuals with Fragile X Syndrome. J Autism Dev Disord. Nov. 2011;41(11):1515-22. X-1, X-3, X-4. [pmid: 21267642].
1272 Fatemi SH, Realmuto GM, Khan L, et al. Fluoxetine in treatment of adolescent patients with autism: a longitudinal open trial. J Autism Dev Disord. Aug. 1998;28(4):303-7. X-3. [pmid: 9711486].
1273 Fava L, Strauss K. Multi-sensory rooms: comparing effects of the Snoezelen and the Stimulus Preference environment on the behavior of adults with profound mental retardation. Res Dev Disabil. Jan–Feb. 2010;31(1):160-71. X-1, X-3. [pmid: 19815373].
1274 Fay S. Outside in: reaching in to bring kids out. Reclaiming Child Youth. Sum. 2008;17(2):31-4. X-1, X-2, X-3, X-4.
1275 Fazlioglu Y, Baran G. A sensory integration therapy program on sensory problems for children with autism. Percept Mot Skills. Apr. 2008;106(2):415-22. X-1, X-3, X-4. [pmid: 18556898].
1276 Fecteau S, Agosta S, Oberman L, et al. Brain stimulation over Broca’s area differentially modulates naming skills in neurotypical adults and individuals with Asperger’s syndrome. Eur J Neurosci. Jul. 2011;34(1):158-64. X-3. [pmid: 21676037].
1277 Fecteau S, Mottron L, Berthiaume C, et al. Developmental changes of autistic symptoms. Autism. Sep. 2003;7(3):255-68. X-4. [pmid: 14516059].
1278 Feinberg E, Beyer J. Creating public policy in a climate of clinical indeterminancy: Lovaas as the case example du Jour. Infants Young Child. Jan. 1998;10(3):54-66. X-1, X-2, X-3, X-4.
1279 Feinberg E, Vacca J. The drama and trauma of creating policies on autism: critical issues to consider in the new millennium. Focus Autism Dev Disabil. Fall. 2000;15(3):130-37. X-1, X-2, X-3, X-4.
1280 Felce D, Kerr M, Hastings RP. A general practice-based study of the relationship between indicators of mental illness and challenging behaviour among adults with intellectual disabilities. J Intellect Disabil Res. Mar. 2009;53(3):243-54. X-1, X-3, X-4. [pmid: 19017165].
1281 Feldman HM, Kolmen BK, Gonzaga AM. Naltrexone and communication skills in young children with autism. J Am Acad Child Adolesc Psychiatry. May. 1999;38(5):587-93. X-1, X-3, X-4. [pmid: 10230191].
1282 Feng H, Lo Y-y, Tsai S, et al. The effects of theory-of-mind and social skill training on the social competence of a sixth-grade student with autism. J Posit Behav Interv. 2008;10(4):228-42. X-1, X-3, X-4.
1283 Ferguson AP, McKinlay IA, Hunt A. Care of adolescents with severe learning disability from tuberous sclerosis. Dev Med Child Neurol. Apr. 2002;44(4):256-62. X-4. [pmid: 11995894].
1284 Fernandes FD, Cardoso C, Sassi FC, et al. Language therapy and autism: results of three different models. Pro Fono. Oct–Dec. 2008;20(4):267-72. X-1, X-3, X-4. [pmid: 19142471].
1285 Fernell E, Barnevik-Olsson M, Bågenholm G, et al. Serum levels of 25-hydroxyvitamin D in mothers of Swedish and of Somali origin who have children with and without autism. Acta Paediatrica. May. 2010;99(5):743-7. X-1, X-3, X-4. [pmid: 20219032].
1286 Fernell E, Gillberg C. Autism spectrum disorder diagnoses in Stockholm preschoolers. Res Dev Disabil. May–Jun. 2010;31(3):680-5. X-1, X-3, X-4. [pmid: 20149593].
1287 Fernell E, Gillberg C, von Wendt L. Autistic symptoms in children with infantile hydrocephalus. Acta Paediatr Scand. Apr. 1991;80(4):451-7. X-4. [pmid: 2058395].
1288 Fernell E, Hedvall A, Norrelgen F, et al. Developmental profiles in preschool children with autism spectrum disorders referred for intervention. Res Dev Disabil. May–Jun. 2010;31(3):790-9. X-1, X-3, X-4. [pmid: 20207104].
1289 Fernell E, Hedvall A, Westerlund J, et al. early intervention in 208 Swedish Preschoolers with autism spectrum disorder. a prospective naturalistic study. Res Dev Disabil. Nov–Dec. 2011;32(6):2092-101. X-1, X-3, X-4. [pmid: 21985993].
1290 Fernell E, Watanabe Y, Adolfsson I, et al. Possible effects of tetrahydrobiopterin treatment in six children with autism--clinical and positron emission tomography data: a pilot study. Dev Med Child Neurol. May. 1997;39(5):313-8. X-1, X-3, X-4. [pmid: 9236697].
1291 Feroz-Nainar C, Roy M. Risperidone and late onset tics. Autism. May. 2006;10(3):302-7. X-6. [pmid: 16682400].
1292 Ferrara C, Hill SD. The responsiveness of autistic children to the predictability of social and nonsocial toys. J Autism Dev Disord. Mar. 1980;10(1):51-7. X-1, X-3, X-4. [pmid: 6927678].
1293 Ferrari M. Effects of praise and reprimand on the topography and probability of occurrence of stereotypies in autistic children. Psychol Rep. Apr. 1980;46(2):519-22. X-1, X-3, X-4. [pmid: 7384356].
1294 Ferrari M, Harris SL. The limits and motivating potential of sensory stimuli as reinforcers for autistic children. J Appl Behav Anal. Fall. 1981;14(3):339-43. X-3. [pmid: 7298542].
1295 Ferreri SJ, Tamm L, Wier KG. Using food aversion to decrease severe pica by a child with autism. Behav Modif. 2006;30(4):456-71. X-1, X-3, X-4. [pmid: 16723425].
1296 Ferri R, Elia M, Agarwal N, et al. The mismatch negativity and the P3a components of the auditory event-related potentials in autistic low-functioning subjects. Clin Neurophysiol. Sep. 2003;114(9):1671-80. X-4. [pmid: 12948796].
1297 Fertel-Daly D, Bedell G, Hinojosa J. Effects of a weighted vest on attention to task and self-stimulatory behaviors in preschoolers with pervasive developmental disorders. Am J Occup Ther. Nov–Dec. 2001;55(6):629-40. X-1, X-3, X-4. [pmid: 12959227].
1298 Fido A, Al-Saad S. Olanzapine in the treatment of behavioral problems associated with autism: an open-label trial in Kuwait. Med Princ Pract. 2008;17(5):415-8. X-1. [pmid: 18685284].
1299 Field T, Lasko D, Mundy P, et al. Brief report: autistic children’s attentiveness and responsivity improve after touch therapy. J Autism Dev Disord. Jun. 1997;27(3):333-8. X-1, X-3, X-4. [pmid: 9229263].
1300 Field T, Sanders C, Nadel J. Children with autism display more social behaviors after repeated imitation sessions. Autism. Sep. 2001;5(3):317-23. X-1, X-3, X-4. [pmid: 11708590].
1301 Fienup DM, Doepke K. Evaluation of a changing criterion intervention to increase fluent responding with an elementary age student with autism. Int J Behav Consult Ther. Special Issue: Applied behavior analysis in developmental disabilities. 2008;4(3):297-303. X-1, X-3, X-4.
1302 Fifer WP, Byrd DL, Kaku M, et al. Newborn infants learn during sleep. Proc Natl Acad Sci U S A. Jun. 1. 2010;107(22):10320-3. X-1, X-3, X-4. [pmid: 20479232].
1303 Filipo R, Bosco E, Mancini P, et al. Cochlear implants in special cases: deafness in the presence of disabilities and/or associated problems. Acta Otolaryngol Suppl. May. 2004;(552):74-80. X-2. [pmid: 15219052].
1304 Findling RL. Paediatric psychopharmacology: closing the gap between science and practice. Expert Opin Pharmacother. Apr. 2001;2(4):523-5. X-2. [pmid: 11336602].
1305 Findling RL, Kusumakar V, Daneman D, et al. Prolactin levels during long-term risperidone treatment in children and adolescents. J Clin Psychiatry. Nov. 2003;64(11):1362-9. X-1, X-3, X-4. [pmid: 14658952].
1306 Findling RL, Maxwell K, Scotese-Wojtila L, et al. High-dose pyridoxine and magnesium administration in children with autistic disorder: an absence of salutary effects in a double-blind, placebo-controlled study. J Autism Dev Disord. Aug. 1997;27(4):467-78. X-3, X-4. [pmid: 9261669].
1307 Findling RL, Maxwell K, Wiznitzer M. An open clinical trial of risperidone monotherapy in young children with autistic disorder. Psychopharmacol Bull. 1997;33(1):155-9. X-1, X-3, X-4. [pmid: 9133768].
1308 Findling RL, McNamara NK, Gracious BL, et al. Quetiapine in nine youths with autistic disorder. J Child Adolesc Psychopharmacol. Summer. 2004;14(2):287-94. X-1, X-3, X-4. [pmid: 15319025].
1309 Fine P, McGee JJ, Paden S. Autism in Nebraska: identification and treatment. Nebr Med J. Jun. 1981;66(6):127-9. X-1, X-2, X-3, X-4. [pmid: 7242742].
1310 Finegold SM. Therapy and epidemiology of autism--clostridial spores as key elements. Med Hypotheses. 2008;70(3):508-11. X-2, X-4. [pmid: 17904761].
1311 Finegold SM, Vaisanen ML, Molitoris DR, et al. Cetobacterium somerae sp. nov. from human feces and emended description of the genus Cetobacterium. Syst Appl Microbiol. Jun. 2003;26(2):177-81. X-4. [pmid: 12866843].
1312 Finke EH, McNaughton DB, Drager KD. “All children can and should have the opportunity to learn”: general education teachers’ perspectives on including children with autism spectrum disorder who require AAC. Augment Altern Commun. Jun. 2009;25(2):110-22. X-4. [pmid: 19444682].
1313 Finke EH, McNaughton DB, Drager KDR. “All children can and should have the opportunity to learn”: General education teacher’s perspectives on including children with autism spectrum disorder who require ACC. AAC: Augment Altern Commun. Jun. 2009;25(2):110-22. X-1, X-3, X-4.
1314 Finnigan E, Starr E. Increasing social responsiveness in a child with autism: A comparison of music and non-music interventions. Autism. Jul. 2010;14(4):321-48. X-1, X-3, X-4. [pmid: 20591958].
1315 Firth G, Elford H, Leeming C, et al. Intensive interaction as a novel approach in social care: care staff’s views on the practice change process. J Appl Res Intellect Disabil. Jan. 2008;21(1):58-69. X-2.
1316 Fisch GS, Cohen IL, Gross AC, et al. Folic acid treatment of fragile X males: a further study. Am J Med Genet. May–Jun;. 1988;30(1–2):393-9. X-1, X-3, X-4. [pmid: 3052065].
1317 Fisher M, Meyer LH. Development and social competence after two years for students enrolled in inclusive and self-contained educational programs. Res Pract Persons Severe Disabl. Fal. 2002;27(3):165-74. X-3.
1318 Fisher N, Happe F. A training study of theory of mind and executive function in children with autistic spectrum disorders. J Autism Dev Disord. Dec. 2005;35(6):757-71. X-1, X-3. [pmid: 16283087].
1319 Fisher P. Experiential knowledge challenges ‘normality’ and individualized citizenship: towards ‘another way of being’. Disabil Soc. 2007;22(3):283-98. X-1, X-2, X-3, X-4.
1320 Fisher SM. A Case Study of an Autistic Child: A Reappraisal. The Annual of Psychoanalysis. 2000;28:47-61. X-3.
1321 Fisher W, Burd L, Kerbeshian J. Markers for improvement in children with pervasive developmental disorders. J Ment Defic Res. Oct. 1988;32(Pt 5):357-69. X-1, X-2, X-3, X-4. [pmid: 3199430].
1322 Fisher W, Kerbeshian J, Burd L. A treatable language disorder: pharmacological treatment of pervasive developmental disorder. J Dev Behav Pediatr. Apr. 1986;7(2):73-6. X-3. [pmid: 3700663].
1323 Fisher WW, Adelinis JD, Volkert VM, et al. Assessing preferences for positive and negative reinforcement during treatment of destructive behavior with functional communication training. Res Dev Disabil. Mar–Apr. 2005;26(2):153-68. X-1, X-3, X-4. [pmid: 15590246].
1324 Fisher WW, et al. On the reinforcing effects of the content of verbal attention. J Appl Behav Anal. Sum. 1996;29(2):235-38. X-1, X-3, X-4. [pmid: 8682738].
1325 Fisher WW, Lindauer SE, Alterson CJ, et al. Assessment and treatment of destructive behavior maintained by stereotypic object manipulation. J Appl Behav Anal. Win. 1998;31(4):513-27. X-3. [pmid: 9891391].
1326 Fisman S, Steele M, Short J, et al. Case study: Anorexia nervosa and autistic disorder in an adolescent girl. J Am Acad Child Adolesc Psychiatry. Jul. 1996;35(7):937-40. X-3. [pmid: 8768355].
1327 Fisman S, Wolf L. The handicapped child: psychological effects of parental, marital, and sibling relationships. Psychiatr Clin North Am. Mar. 1991;14(1):199-217. X-2, X-4. [pmid: 1828565].
1328 Fitzgerald PB, Herring S, Hoy K, et al. A study of the effectiveness of bilateral transcranial magnetic stimulation in the treatment of the negative symptoms of schizophrenia. Brain Stimul. Jan. 2008;1(1):27-32. X-1, X-3, X-4. [pmid: 20633367].
1329 Fitzpatrick M. The end of the road for the campaign against MMR. Br J Gen Pract. Aug. 2007;57(541):679. X-2. [pmid: 17688775].
1330 Fitzpatrick M. Treating autism appropriately. Br J Gen Pract. May. 2009;59(562):379. X-2. [pmid: 19401028].
1331 Flagg EJ, Cardy JE, Roberts W, et al. Language lateralization development in children with autism: insights from the late field magnetoencephalogram. Neurosci Lett. Sep. 30. 2005;386(2):82-7. X-4. [pmid: 16046066].
1332 Flanders SC, Engelhart L, Whitworth J, et al. The economic burden of pervasive developmental disorders in a privately insured population. Manag Care Interface. 2006;19(8):39-45. X-4. [pmid: 16933527].
1333 Flannery KB, Horner RH. The relationship between predictability and problem behavior for students with severe disabilities. J Behav Educ. Jun. 1994;4(2):157-76. X-3.
1334 Flippin M, Crais ER. The need for more effective father involvement in early autism intervention: a systematic review and recommendations. J Early Interv. Mar. 2011;33(1):24-50. X-2, X-3.
1335 Flood WA, Lynn C, Mortensen J, et al. Behavioral assessment of an elimination diet to treat purported food sensitivity and problem behaviors in autism: a clinical case report. Behav Ther (N Y N Y). Sep. 2010;33(6):116-9. X-3.
1336 Flores MM, Ganz JB. Effectiveness of direct instruction for teaching statement inference, use of facts, and analogies to students with developmental disabilities and reading delays. Focus Autism Dev Disabil. Win. 2007;22(4):244-51. X-3.
1337 Floyd EF, McIntosh DE. Current practice in psychopharmacology for children and adolescents with autism spectrum disorders. Psychol Sch. Nov. 2009;46(9):905-9. X-2.
1338 Fodstad JC, Matson JL. A comparison of feeding and mealtime problems in adults with intellectual disabilities with and without autism. J Dev Phys Disabil. Dec. 2008;20(6):541-50. X-1, X-3, X-4.
1339 Foley BE, Staples AH. Developing augmentative and alternative communication (AAC) and literacy interventions in a supported employment setting. Top Lang Disord. Oct–Dec. 2003;23(4):325-43. X-3.
1340 Foley SM, Butterworth J, Heller A. Vocational rehabilitation interagency activity improving supported employment for people with severe disabilities. Focus Autism Dev Disabil. Spr. 2000;15(1):37-42. X-1, X-3, X-4.
1341 Fombonne E. Diagnostic assessment in a sample of autistic and developmentally impaired adolescents. J Autism Dev Disord. Dec. 1992;22(4):563-81. X-4. [pmid: 1483977].
1342 Fombonne E. Epidemiological surveys of autism and other pervasive developmental disorders: an update. J Autism Dev Disord. Aug. 2003;33(4):365-82. X-1, X-2, X-3, X-4. [pmid: 12959416].
1343 Fombonne E, Achard S. The Vineland Adaptive Behavior Scale in a sample of normal French children: a research note. J Child Psychol Psychiatry. Sep. 1993;34(6):1051-8. X-4. [pmid: 8408369].
1344 Fombonne E, Chakrabarti S. No evidence for a new variant of measles-mumps-rubella-induced autism. Pediatrics. Oct. 2001;108(4):E58. X-4. [pmid: 11581466].
1345 Fombonne E, Talan I, Bouchard F, et al. A follow-up study of childhood psychosis. Acta Paedopsychiatr. 1989;52(1):12-25. X-1, X-3, X-4. [pmid: 2626958].
1346 Fombonne E, Zakarian R, Bennett A, et al. Pervasive developmental disorders in Montreal, Quebec, Canada: prevalence and links with immunizations. Pediatrics. Jul. 2006;118(1):e139-50. X-4. [pmid: 16818529].
1347 Fong PL. Cognitive appraisals in high- and low-stress mothers of adolescents with autism. J Consult Clin Psychol. Jun. 1991;59(3):471-4. X-3, X-4. [pmid: 2071734].
1348 Fonseca VRJRM. The autistic dialogic style: a case of Asperger’s syndrome. J Child Psychother. Dec. 2009;35(3):250-61. X-4.
1349 Fontenelle LF, Mendlowicz MV, de Menezes GB, et al. Asperger syndrome, obsessive-compulsive disorder, and major depression in a patient with 45,X/46,XY Mosaicism. Psychopathology. May–Jun. 2004;37(3):105-9. X-4. [pmid: 15153741].
1350 Forbes F. Improving recognition and management of ADHD. Practitioner. Apr. 2010;254(1728):34-8. 3. X-1, X-2, X-3, X-4. [pmid: 20486482].
1351 Forbes J, Welbon H. Teacher/therapist collaboration: a Scottish higher education institution development. Int J Lang Commun Disord. Suppl. 2001;36:417-22. X-4. [pmid: 11340824].
1352 Ford L, et al. Facilitating desired behavior in the preschool child with autism: a case study. Contemp Educ. Apr. 1994;65(3):148-51. X-1, X-3, X-4.
1353 Ford RM, Rees EL. Representational drawing and the transition from intellectual to visual realism in children with autism. Br J Dev Psychol. 2008;26(Part 2):197-219. X-4.
1354 Forest EJ, Horner RH, Lewis-Palmer T, et al. Transitions for young children with autism from preschool to kindergarten. J Posit Behav Interv. 2004;6(2):103-12. X-1, X-2, X-3, X-4.
1355 Forsberg KA, Bjorkman T, Sandman PO, et al. Physical health--a cluster randomized controlled lifestyle intervention among persons with a psychiatric disability and their staff. Nord J Psychiatry. 2008;62(6):486-95. X-2. [pmid: 18843564].
1356 Forsyth R, Colver A, Alvanides S, et al. Participation of young severely disabled children is influenced by their intrinsic impairments and environment. Dev Med Child Neurol. May. 2007;49(5):345-9. X-4. [pmid: 17489807].
1357 Forsyth R, McNally R, James P, et al. Variation at local government level in the support for families of severely disabled children and the factors that affect it. Dev Med Child Neurol. Nov. 2010;52(11):e259-66. X-4. [pmid: 21175456].
1358 Foss-Feig JH, Kwakye LD, Cascio CJ, et al. An extended multisensory temporal binding window in autism spectrum disorders. Exp Brain Res. Jun. 2010;203(2):381-9. X-4. [pmid: 20390256].
1359 Foto Özdemir D, Ilgın Karabacak N, Akkaş BE, et al. Differences in cerebral blood flow following risperidone treatment in children with autistic disorder. Türk Psikiyatri Dergisi. 2009;20(4):1-9. X-1, X-3, X-4.
1360 Fox L, Dunlap G, Philbrick LA. Providing individual supports to young children with autism and their families. J Early Interv. Win. 1997;21(1):1-14. X-1, X-3, X-4.
1361 Fox MH, Foster CH, Zito JM. Building pharmacoepidemiological capacity to monitor psychotropic drug use among children enrolled in Medicaid. Am J Med Qual. Jul–Aug. 2000;15(4):126-36. X-4. [pmid: 10948784].
1362 Fox RA, Holtz CA, Moist AM. A community-based accommodation program for adults with autism and mental retardation. Educ Train Dev Disabil. Mar. 2009;44(1):118-26. X-1, X-3.
1363 Foxton JM, Stewart ME, Barnard L, et al. Absence of auditory ‘global interference’ in autism. Brain. Dec. 2003;126(Pt 12):2703-9. X-4. [pmid: 12937074].
1364 Foxx RM. Sapid effects awaiting independent replication. Am J Ment Retard. Jan. 1993;97(4):375-76. X-1, X-2, X-3, X-4.
1365 Foxx RM, Faw GD. Long-term follow-up of echolalia and question answering. J Appl Behav Anal. Fal. 1990;23(3):387-96. X-3. [pmid: 2249974].
1366 Foxx RM, Garito J. The long term successful treatment of the very severe behaviors of a preadolescent with autism. Behav Interv. Special Issue: The treatment and assessment of the severe behavior of individuals with autism and developmental disabilities. Feb. 2007;22(1):69-82. X-1, X-3, X-4.
1367 Foxx RM, Meindl J. The long term successful treatment of the aggressive/destructive behaviors of a preadolescent with autism. Behav Interv. Special Issue: The treatment and assessment of the severe behavior of individuals with autism and developmental disabilities. Feb. 2007;22(1):83-97. X-3.
1368 Fragala-Pinkham M, Haley SM, O’Neil ME. Group aquatic aerobic exercise for children with disabilities. Dev Med Child Neurol. Nov. 2008;50(11):822-7. X-1, X-3, X-4. [pmid: 19046177].
1369 Fragala-Pinkham MA, Haley SM, O’Neil ME. Group swimming and aquatic exercise programme for children with autism spectrum disorders: a pilot study. Dev Neurorehabil. 2011;14(4):230-41. X-3, X-4. [pmid: 21732807].
1370 Franch NJP. Transference and countertransference in the analysis of a child with autistic nuclei. Int J Psychoanal. Aug. 1996;77(4):773-86. X-1, X-3, X-4. [pmid: 8876335].
1371 Francis P, Mellor D, Firth L. Techniques and recommendations for the inclusion of users with autism in the design of assistive technologies. Assist Technol. Summer. 2009;21(2):57-68. X-4. [pmid: 19715250].
1372 Francisco MT, Borrero JC, Sy JR. Evaluation of absolute and relative reinforcer value using progressive-ratio schedules. J Appl Behav Anal. Summer. 2008;41(2):189-202. X-1, X-3, X-4. [pmid: 18595283].
1373 Franco JH, Lang RL, O’Reilly MF, et al. Functional analysis and treatment of inappropriate vocalizations using a speech-generating device for a child with autism. Focus Autism Dev Disabil. Sep. 2009;24(3):146-55. X-1, X-3, X-4.
1374 François D, Powell S, Dautenhahn K. A long-term study of children with autism playing with a robotic pet: Taking inspirations from non-directive play therapy to encourage children’s proactivity and initiative-taking. Interact Stud. Special Issue: Robots in the wild: Exploring human-robot interaction in naturalistic environments. 2009;10(3):324-73. X-3.
1375 Francois I. Chemical & biological therapeutic approaches to neurological disorders. Drug News Perspect. Oct. 2010;23(8):524-31. X-1, X-2, X-3, X-4. [pmid: 21031169].
1376 Frankel F, Myatt R, Feinberg D. Parent-assisted friendship training for children with autism spectrum disorders: effects of psychotropic medication. Child Psychiatry Hum Dev. Apr. 2007;37(4):337-46. X-1, X-3, X-4. [pmid: 17406973].
1377 Frankel F, Myatt R, Sugar C, et al. A randomized controlled study of parent-assisted Children’s Friendship Training with children having autism spectrum disorders. J Autism Dev Disord. Jul. 2010;40(7):827-42. X-1, X-4. [pmid: 20058059].
1378 Frankel FD, Gorospe CM, Chang Y-C, et al. Mothers’ reports of play dates and observation of school playground behavior of children having high-functioning autism spectrum disorders. J Child Psychol Psychiatry. May. 2011;52(5):571-9. X-1, X-3, X-4. [pmid: 20860756].
1379 Frankland PW, Wang Y, Rosner B, et al. Sensorimotor gating abnormalities in young males with fragile X syndrome and Fmr1-knockout mice. Mol Psychiatry. Apr. 2004;9(4):417-25. X-4. [pmid: 14981523].
1380 Franklin K, Mirenda P, Phillips G. Comparisons of five symbol assessment protocols with nondisabled preschoolers and learners with severe intellectual disabilities. Augment Altern Commun. 1996;12(2):63-77. X-1, X-3, X-4.
1381 Frazier JA, Meyer MC, Biederman J, et al. Risperidone treatment for juvenile bipolar disorder: a retrospective chart review. J Am Acad Child Adolesc Psychiatry. Aug. 1999;38(8):960-5. X-1, X-3, X-4. [pmid: 10434487].
1382 Frazier TW, Youngstrom EA, Haycook T, et al. Effectiveness of medication combined with intensive behavioral intervention for reducing aggression in youth with autism spectrum disorder. J Child Adolesc Psychopharmacol. Jun. 2010;20(3):167-77. X-1, X-4. [pmid: 20578929].
1383 Frea WD. Reducing stereotypic behavior by teaching orienting responses to environmental stimuli. J Assoc Pers Sev Handicaps. Spr. 1997;22(1):28-35. X-3.
1384 Frea WD, Arnold CL, Vittimberga GL. A demonstration of the effects of augmentative communication on the extreme aggressive behavior of a child with autism within an integrated preschool setting. J Posit Behav Interv. Fal. 2001;3(4):194-8. X-1, X-3, X-4.
1385 Frederickson N, Jones AP, Lang J. Inclusive provision options for pupils on the autistic spectrum. J Res Spec Educ Needs. Jun. 2010;10(2):63-73. X-4.
1386 Frederickson N, Warren L, Turner J. “Circle of Friends”--an exploration of impact over time. Educ Psychol Prac. Sep. 2005;21(3):197-217. X-3.
1387 Freeden I. A troll in the consulting room. Br J Psychother. Win. 2002;19(2):189-202. X-3.
1388 Freeman BJ. Guidelines for evaluating intervention programs for children with autism. J Autism Dev Disord. Dec. 1997;27(6):641-51. X-1, X-2, X-3, X-4. [pmid: 9455726].
1389 Freeman BJ, Del’Homme M, Guthrie D, et al. Vineland Adaptive Behavior Scale scores as a function of age and initial IQ in 210 autistic children. J Autism Dev Disord. Oct. 1999;29(5):379-84. X-4. [pmid: 10587884].
1390 Freeman BJ, Lucas JC, Forness SR, et al. Cognitive processing of high-functioning autistic children: comparing the K—ABC and the WISC—R. J Psychoeduc Assess. Dec. 1985;3(4):357-62. X-1, X-3, X-4.
1391 Freeman BJ, Rahbar B, Ritvo ER, et al. The stability of cognitive and behavioral parameters in autism: a twelve-year prospective study. J Am Acad Child Adolesc Psychiatry. May. 1991;30(3):479-82. X-4. [pmid: 2055886].
1392 Freeman BJ, Ritvo ER. The syndrome of autism: establishing the diagnosis and principles of management. Pediatr Ann. Apr. 1984;13(4):284-90. 94. 6. X-1, X-2, X-3, X-4. [pmid: 6203089].
1393 Freeman KA, Piazza CC. Combining stimulus fading, reinforcement, and extinction to treat food refusal. J Appl Behav Anal. Win. 1998;31(4):691-4. X-1, X-3, X-4. [pmid: 9891407].
1394 Freeman N, Perry A. Outcomes of intensive behavioural intervention in the Toronto Preschool Autism Service. J Dev Disab. 2010;16(2):17-32. X-1, X-3, X-4.
1395 Freeman NL, Perry A, Factor DC. Child behaviours as stressors: replicating and extending the use of the CARS as a measure of stress: a research note. J Child Psychol Psychiatry. Sep. 1991;32(6):1025-30. X-4. [pmid: 1744190].
1396 Freitag CM, Luders E, Hulst HE, et al. Total brain volume and corpus callosum size in medication-naïve adolescents and young adults with autism spectrum disorder. Biol Psychiatry. Aug. 2009;66(4):316-9. X-4. [pmid: 19409535].
1397 Friedman A, Luiselli JK. Excessive daytime sleep: Behavioral assessment and intervention in a child with autism. Behav Modif. Jul. 2008;32(4):548-55. X-3. [pmid: 18258994].
1398 Fristoe M, Lloyd LL. Planning an initial expressive sign lexicon for persons with severe communication impairment. J Speech Hear Disord. May. 1980;45(2):170-80. X-1, X-2, X-3, X-4. [pmid: 7442150].
1399 Froehlich W. Making a case to continue considering treatment with selective serotonin reuptake inhibitors for children with autism spectrum disorders. Curr Psychiatry Rep. Jun. 2011;13(3):170-3. INCLUDE, X-1, X-2, X-3, X-4. [pmid: 21404127].
1400 Frye RE, Butler I, Strickland D, et al. Electroencephalogram discharges in atypical cognitive development. J Child Neurol. May. 2010;25(5):556-66. X-1, X-3, X-4. [pmid: 20299700].
1401 Fucilla R. Post-crisis intervention for individuals with autism spectrum disorder. Reclaiming Child Youth. Spr. 2005;14(1). 44. X-2.
1402 Fudenberg HH. Dialysable lymphocyte extract (DLyE) in infantile onset autism: a pilot study. Biotherapy. 1996;9(1–3):143-7. X-6. [pmid: 8993773].
1403 Fuentes CT, Mostofsky SH, Bastian AJ. Children with autism show specific handwriting impairments. Neurology. Nov. 10. 2009;73(19):1532-7. X-4. [pmid: 19901244].
1404 Fugain C, Meyer B, Chabolle F, et al. Clinical results of the French multichannel cochlear implant. Acta Otolaryngol Suppl. 1984;411:237-46. X-1, X-3, X-4. [pmid: 6596848].
1405 Fujikawa-Brooks S, Isenberg AL, Osann K, et al. The effect of rate stress on the auditory brainstem response in autism: a preliminary report. Int J Audiol. Feb. 2010;49(2):129-40. X-1, X-3, X-4. [pmid: 20151887].
1406 Fujiwara T, Okuyama M, Funahashi K. Factors influencing time lag between first parental concern and first visit to child psychiatric services in children with autism spectrum disorders in Japan. Res Autism Spectr Disord. Jan–Mar. 2011;5(1):584-91. X-4.
1407 Fukuta O, Braham RL, Yanase H, et al. The sedative effect of intranasal midazolam administration in the dental treatment of patients with mental disabilities. Part 1. The effect of a 0.2 mg/kg dose. J Clin Pediatr Dent. Summer. 1993;17(4):231-7. X-1, X-3. [pmid: 8217888].
1408 Fullerton A, Coyne P. Developing skills and concepts for self-determination in young adults with autism. Focus Autism Dev Disabil. Spr. 1999;14(1):42-52. X-3.
1409 Funderburk SJ, Carter J, Tanguay P, et al. Parental reproductive problems and gestational hormonal exposure in autistic and schizophrenic children. J Autism Dev Disord. Sep. 1983;13(3):325-32. X-4. [pmid: 6643376].
1410 Furneaux B. Keeping the balance right. Spec Educ Forward Trends. Jun. 1984;11(2):15-6. X-1, X-2, X-3, X-4. [pmid: 6463757].
1411 Furniss GJ. Reflections on the historical narrative of Jessica Park, an artist with autism. Art Ther. 2010;27(4):190-4. X-1, X-2, X-3, X-4.
1412 Gabig CS. Phonological awareness and word recognition in reading by children with autism. Commun Disord Q. 2010;31(2):67-85. X-1, X-3, X-4.
1413 Gabriels RL, Hill DE, Pierce RA, et al. Predictons of treatment outcome in young children with autism: a retrospective study. Autism. Dec. 2001;5(4):399-406. X-1, X-3, X-4. [pmid: 11777256].
1414 Gabriels RL, Hill DE, Pierce RA, et al. Predictors of treatment outcome in young children with autism: a retrospective study. Autism. Dec. 2001;5(4):407-29. X-1, X-3, X-4. [pmid: 11777257].
1415 Gadberry AL. A survey of the use of aided augmentative and alternative communication during music therapy sessions with persons with autism spectrum disorders. J Music Ther. Spring. 2011;48(1):74-89. X-1, X-3, X-4. [pmid: 21866714].
1416 Gadow KD, DeVincent CJ, Schneider J. Comparative study of children with ADHD only, autism spectrum disorder + ADHD, and chronic multiple tic disorder + ADHD. J Atten Disord. 2009;12(5):474-85. X-4. [pmid: 19218544].
1417 Gadow KD, Sprafkin J, Nolan EE. DSM-IVSymptoms in community and clinic preschool children. J Am Acad Child Adolesc Psychiatry. Dec. 2001;40(12):1383-92. X-4. [pmid: 11765283].
1418 Gage NM, Siegel B, Callen M, et al. Cortical sound processing in children with autism disorder: an MEG investigation. Neuroreport. Nov. 14. 2003;14(16):2047-51. X-4. [pmid: 14600495].
1419 Gage NM, Siegel B, Roberts TP. Cortical auditory system maturational abnormalities in children with autism disorder: an MEG investigation. Brain Res Dev Brain Res. Sep. 10. 2003;144(2):201-9. X-4. [pmid: 12935917].
1420 Gagliano A, Germano E, Pustorino G, et al. Risperidone treatment of children with autistic disorder: effectiveness, tolerability, and pharmacokinetic implications. J Child Adolesc Psychopharmacol. Spring. 2004;14(1):39-47. X-1, X-3, X-4. [pmid: 15142390].
1421 Gaines R, Leaper C, Monahan C, et al. Language learning and retention in young language-disordered children. J Autism Dev Disord. Jun. 1988;18(2):281-96. X-1, X-3, X-4. [pmid: 3410815].
1422 Gal E, Dyck MJ, Passmore A. Relationships between stereotyped movements and sensory processing disorders in children with and without developmental or sensory disorders. Am J Occup Ther. May–Jun. 2010;64(3):453-61. X-4. [pmid: 20608276].
1423 Gale CM, Eikeseth S, Rudrud E. Functional assessment and behavioural intervention for eating difficulties in children with autism: a study conducted in the natural environment using parents and ABA tutors as therapists. J Autism Dev Disord. Oct. 2011;41(10):1383-96. X-3. [pmid: 21181250].
1424 Gale S, Ozonoff S, Lainhart J. Brief report: pitocin induction in autistic and nonautistic individuals. J Autism Dev Disord. Apr. 2003;33(2):205-08. X-1, X-3, X-4. [pmid: 12757361].
1425 Galiatsatos GT, Graff RB. Combining descriptive and functional analyses to assess and treat screaming. Behav Interv. Apr. 2003;18(2):123-38. X-3.
1426 Galinat K, Barcalow K, Krivda B. Caring for children with autism in the school setting. J Sch Nurs. 2005;21(4):208-17. X-1, X-2, X-3, X-4. [pmid: 16048365].
1427 Gallagher A, Theriault M, Maclin E, et al. Near-infrared spectroscopy as an alternative to the Wada test for language mapping in children, adults and special populations. Epileptic Disord. Sep. 2007;9(3):241-55. X-4. [pmid: 17884748].
1428 Gallagher CM, Goodman MS. Hepatitis B vaccination of male neonates and autism diagnosis, NHIS 1997–2002. J Toxicol Environ Health A. Jan. 2010;73(24):1665-77. X-1, X-3, X-4. [pmid: 21058170].
1429 Gallagher TE. Augmentation of special-needs services and information to students and teachers “ASSIST”--a telehealth innovation providing school-based medical interventions. Hawaii Med J. Oct. 2004;63(10):300-9. X-1, X-3, X-4. [pmid: 15570717].
1430 Gallate J, Chi R, Ellwood S, et al. Reducing false memories by magnetic pulse stimulation. Neurosci Lett. Jan. 16. 2009;449(3):151-4. X-4. [pmid: 19022348].
1431 Gallese V, Eagle MN, Migone P. Intentional attunement: mirror neurons and the neural underpinnings of interpersonal relations. J Am Psychoanal Assoc. Winter. 2007;55(1):131-76. X-2, X-4. [pmid: 17432495].
1432 Galletly SA, Knight BA. Differential disadvantage of anglophone weak readers due to english orthographic complexity and cognitive processing weakness. Australasian J Spec Educ. Jul. 2011;35(1):72-96. X-1, X-2, X-3, X-4.
1433 Galli Carminati G, Constantin N, Legay Y, et al. Evolution of 2 persons with severe disability over a period of 3 years: “Sonar Group” Underwater Music Therapy. Eur J Psychiatr. 2004;18:106-14. X-3.
1434 Galli-Carminati G, Deriaz N, Bertschy G. Melatonin in treatment of chronic sleep disorders in adults with autism: a retrospective study. Swiss Med Wkly. May. 16. 2009;139(19–20):293-6. X-3. [pmid: 19452292].
1435 Gallo MT. The little alien: links between mind and body in parent–infant psychotherapy. J Child Psychother. Aug. 1997;23(2):201-18. X-1, X-3, X-4.
1436 Gallucci G, Hackerman F, Schmidt CW. Gender identity disorder in an adult male with Asperger’s syndrome. Sex Disabil. Mar. 2005;23(1):35-40. X-1, X-3, X-4.
1437 Gandhi S, Rubinstein I, Tsueshita T, et al. Secretin self-assembles and interacts spontaneously with phospholipids in vitro. Peptides. Jan. 2002;23(1):201-4. X-1, X-3, X-4. [pmid: 11814635].
1438 Gantman A, Kapp SK, Orenski K, et al. Social skills training for young adults with high-functioning autism spectrum disorders: a randomized controlled pilot study. J Autism Dev Disord. 2011. Sep. 14. X-3. [pmid: 21915740].
1439 Ganz JB. Using visual script interventions to address communication skills. Teach Except Child. Nov–Dec. 2007;40(2):54-8. X-2, X-4.
1440 Ganz JB, Bourgeois BC, Flores MM, et al. Implementing visually cued imitation training with children with autism spectrum disorders and developmental delays. J Posit Behav Interv. 2008;10(1):56-66. X-1, X-3, X-4.
1441 Ganz JB, Earles-Vollrath TL, Cook KE. Video modeling: a visually based intervention for children with autism spectrum disorder. Teach Except Child. Jul–Aug. 2011;43(6):8-19. X-1, X-2, X-3, X-4.
1442 Ganz JB, Flores MM. The effectiveness of direct instruction for teaching language to children with autism spectrum disorders: identifying materials. J Autism Dev Disord. Jan. 2009;39(1):75-83. X-1, X-3, X-4. [pmid: 18563547].
1443 Ganz JB, Flores MM. Implementing visual cues for young children with autism spectrum disorders and their classmates. young children. May. 2010;65(3):78-83. X-1, X-2, X-3, X-4.
1444 Ganz JB, Flores MM. Supporting the play of preschoolers with autism spectrum disorders: implementation of visual scripts. Young Except Child. 2010;13(2):58-70. X-2.
1445 Ganz JB, Kaylor M, Bourgeois B, et al. The impact of social scripts and visual cues on verbal communication in three children with autism spectrum disorders. Focus Autism Dev Disabil. Jun. 2008;23(2):79-94. X-1, X-3, X-4.
1446 Ganz JB, Lashley E, Rispoli MJ. Non-responsiveness to intervention: children with autism spectrum disorders who do not rapidly respond to communication interventions. Dev Neurorehabil. 2010;13(6):399-407. X-1, X-3, X-4. [pmid: 21034281].
1447 Ganz JB, Sigafoos J. Self-monitoring: are young adults with MR and autism able to utilize cognitive strategies independently?. Educ Train Dev Disabil. Mar. 2005;40(1):24-33. X-3.
1448 Ganz JB, Sigafoos J, Simpson RL, et al. Generalization of a pictorial alternative communication system across instructors and distance. Augment Altern Commun. 2008;24(2):89-99. X-1, X-3, X-4. [pmid: 18465363].
1449 Ganz JB, Simpson RL. Effects on communicative requesting and speech development of the Picture Exchange Communication System in children with characteristics of autism. J Autism Dev Disord. Aug. 2004;34(4):395-409. X-1, X-3, X-4. [pmid: 15449515].
1450 Ganz ML. The lifetime distribution of the incremental societal costs of autism. Arch Pediatr Adolesc Med. Apr. 2007;161(4):343-9. X-4. [pmid: 17404130].
1451 Garcia-Perez RM, Hobson RP, Lee A. Narrative role-taking in autism. J Autism Dev Disord. Jan. 2008;38(1):156-68. X-4. [pmid: 17447130].
1452 Garfinkle AN, Schwartz IS. Peer imitation: increasing social interactions in children with autism and other developmental disabilities in inclusive preschool classrooms. Topics Early Child Spec Educ. Spr. 2002;22(1):26-38. X-1, X-3, X-4.
1453 Gargaro BA, Rinehart NJ, Bradshaw JL, et al. Autism and ADHD: how far have we come in the comorbidity debate?. Neurosci Biobehav Rev. Apr. 2011;35(5):1081-8. X-1, X-2, X-3, X-4. [pmid: 21093480].
1454 Garrison-Harrell L, Kamps D, Kravits T. The effects of peer networks on social-communicative behaviors for students with autism. Focus Autism Dev Disabil. Win. 1997;12(4):241-54. X-1, X-3, X-4.
1455 Garro A, Thurman SK, Kerwin ME, et al. Parent/caregiver stress during pediatric hospitalization for chronic feeding problems. J Pediatr Nurs. Aug. 2005;20(4):268-75. X-1, X-3, X-4. [pmid: 16030506].
1456 Garstang J, Wallis M. Randomized controlled trial of melatonin for children with autistic spectrum disorders and sleep problems. Child Care Health Dev. Sep. 2006;32(5):585-9. X-3. [pmid: 16919138].
1457 Gastaut H, Zifkin B, Rufo M. Compulsive respiratory stereotypies in children with autistic features: polygraphic recording and treatment with fenfluramine. J Autism Dev Disord. Sep. 1987;17(3):391-406. X-3. [pmid: 3654490].
1458 Gaynor JW, Nord AS, Wernovsky G, et al. Apolipoprotein E genotype modifies the risk of behavior problems after infant cardiac surgery. Pediatrics. Jul. 2009;124(1):241-50. X-4. [pmid: 19564306].
1459 Geier D, Geier MR. Neurodevelopmental disorders following thimerosal-containing childhood immunizations: a follow-up analysis. Int J Toxicol. Nov–Dec. 2004;23(6):369-76. X-4. [pmid: 15764492].
1460 Geier DA, Geier MR. A comparative evaluation of the effects of MMR immunization and mercury doses from thimerosal-containing childhood vaccines on the population prevalence of autism. Med Sci Monit. Mar. 2004;10(3):PI33-9. X-4. [pmid: 14976450].
1461 Geier DA, Geier MR. An evaluation of serious neurological disorders following immunization: a comparison of whole-cell pertussis and acellular pertussis vaccines. Brain Dev. Aug. 2004;26(5):296-300. X-4. [pmid: 15165669].
1462 Geier DA, Geier MR. A clinical trial of combined anti-androgen and anti-heavy metal therapy in autistic disorders. Neuro Endocrinol Lett. Dec. 2006;27(6):833-8. X-3. [pmid: 17187010].
1463 Geier DA, Geier MR. Early downward trends in neurodevelopmental disorders following removal of thimerosal-containing vaccines. J Am Physicians Surg. 2006;11(1):8-13. X-1, X-3, X-4.
1464 Geier DA, Geier MR. A prospective assessment of androgen levels in patients with autistic spectrum disorders: biochemical underpinnings and suggested therapies. Neuro Endocrinol Lett. Oct. 2007;28(5):565-73. X-4. [pmid: 17984958].
1465 Geier DA, Geier MR. A prospective study of mercury toxicity biomarkers in autistic spectrum disorders. J Toxicol Environ Health A. Oct. 2007;70(20):1723-30. X-4. [pmid: 17885929].
1466 Geier DA, Kern JK, Davis G, et al. A prospective double-blind, randomized clinical trial of levocarnitine to treat autism spectrum disorders. Med Sci Monit. Jun. 2011;17(6):PI15-23. X-1, X-3, X-4. [pmid: 21629200].
1467 Geier MR, Geier DA. The potential importance of steroids in the treatment of autistic spectrum disorders and other disorders involving mercury toxicity. Med Hypotheses. 2005;64(5):946-54. X-2, X-4. [pmid: 15780490].
1468 Geller E. An investigation of communication breakdowns and repairs in verbal autistic children. Br J Dev Disabil. 1998;44(Part 2(87)):71-85. X-3, X-4.
1469 Gena A. The effects of prompting and social reinforcement on establishing social interactions with peers during the inclusion of four children with autism in preschool. Int J Psychol. Dec. 2006;41(6):541-54. X-1, X-3, X-4.
1470 Gena A, Couloura S, Kymissis E. Modifying the affective behavior of preschoolers with autism using in-vivo or video modeling and reinforcement contingencies. J Autism Dev Disord. Oct. 2005;35(5):545-56. X-1, X-3, X-4. [pmid: 16163569].
1471 Gena A, Krantz PJ, McClannahan LE, et al. Training and generalization of affective behavior displayed by youth with autism. J Appl Behav Anal. Fall. 1996;29(3):291-304. X-3. [pmid: 8926222].
1472 Gena A, Kymissis E. Assessing and setting goals for the attending and communicative behavior of three preschoolers with autism in inclusive kindergarten settings. J Dev Phys Disabil. Mar. 2001;13(1):11-26. X-1, X-3, X-4.
1473 Gencer O, Emiroglu FN, Miral S, et al. Comparison of long-term efficacy and safety of risperidone and haloperidol in children and adolescents with autistic disorder. An open label maintenance study. Eur Child Adolesc Psychiatry. Jun. 2008;17(4):217-25. X-1. [pmid: 18026891].
1474 Genuis SJ. Is autism reversible?. Acta Paediatr. Oct. 2009;98(10):1575-8. X-2. [pmid: 19843021].
1475 Gerber F, Baud MA, Giroud M, et al. Quality of life of adults with pervasive developmental disorders and intellectual disabilities. J Autism Dev Disord. Oct. 2008;38(9):1654-65. X-1. [pmid: 18266098].
1476 Gerber F, Bessero S, Robbiani B, et al. Comparing residential programmes for adults with autism spectrum disorders and intellectual disability: outcomes of challenging behaviour and quality of life. J Intellect Disabil Res. Sep. 2011;55(9):918-32. X-1, X-3. [pmid: 21806693].
1477 Gerber S. A developmental perspective on language assessment and intervention for children on the autistic spectrum. Top Lang Disord. Apr–Jun. 2003;23(2):74-94. X-3.
1478 Gerdtz J. Evaluating behavioral treatment of disruptive classroom behaviors of an adolescent with autism. Res Soc Work Pract. Jan. 2000;10(1):98-110. X-3.
1479 Gergely G. The obscure object of desire: "Nearly, but clearly not, like me': contingency preference in normal children versus children with autism. Bull Menninger Clin. Special Issue: Cognitive and interactional foundations of attachment. Sum. 2001;65(3):411-26. X-1, X-3, X-4. [pmid: 11531136].
1480 Gerhardt P, et al. Social policy on the use of aversive interventions: empirical, ethical, and legal considerations. J Autism Dev Disord. Sep. 1991;21(3):265-77. X-1, X-2, X-3, X-4. [pmid: 1938773].
1481 Gerritsen J. The effect of tomatis therapy on children with autism: eleven case studies. Int J Listening. 2010;24(1):50-68. X-3.
1482 Gevers C, Clifford P, Mager M, et al. Brief report: a theory-of-mind-based social-cognition training program for school-aged children with pervasive developmental disorders: an open study of its effectiveness. J Autism Dev Disord. May. 2006;36(4):567-71. X-1, X-3, X-4. [pmid: 16586154].
1483 Ghanizadeh A. Methionine sulfoximine may improve inflammation in autism, a novel hypothesized treatment for autism. Arch Med Res. Nov. 2010;41(8):651-2. X-1, X-2, X-3, X-4. [pmid: 21199736].
1484 Ghanizadeh A. Targeting of glycine site on NMDA receptor as a possible new strategy for autism treatment. Neurochem Res. May. 2011;36(5):922-3. X-1, X-2, X-3, X-4. [pmid: 21210221].
1485 Ghaziuddin M, Alessi N, Greden JF. Life events and depression in children with pervasive developmental disorders. J Autism Dev Disord. Oct. 1995;25(5):495-502. X-3, X-4. [pmid: 8567595].
1486 Ghaziuddin M, et al. Haloperidol treatment of Trichotillomania in a boy with autism and mental retardation. J Autism Dev Disord. Sep. 1991;21(3):365-71. X-1, X-3, X-4. [pmid: 1938782].
1487 Ghaziuddin M, Quinlan P, Ghaziuddin N. Catatonia in autism: a distinct subtype?. J Intellect Disabil Res. Jan. 2005;49(1):102-5. X-2, X-4. [pmid: 15634317].
1488 Ghaziuddin M, Tsai L, Ghaziuddin N. Clonidine for autism. J Child Adolesc Psychopharmacol. Win. 1992;2(4):239-40. X-1, X-3, X-4. [pmid: 19630636].
1489 Ghaziuddin M, Tsai LY, Ghaziuddin N. Brief report: Haloperidol treatment of trichotillomania in a boy with autism and mental retardation. J Autism Dev Disord. Sep. 1991;21(3):365-71. X-1, X-3, X-4. [pmid: 1938782].
1490 Ghika J. Paleoneurology: neurodegenerative diseases are age-related diseases of specific brain regions recently developed by Homo sapiens. Med Hypotheses. Nov. 2008;71(5):788-801. X-2, X-4. [pmid: 18703290].
1491 Ghuman JK, Aman MG, Lecavalier L, et al. Randomized, placebo-controlled, crossover study of methylphenidate for attention-deficit/hyperactivity disorder symptoms in preschoolers with developmental disorders. J Child Adolesc Psychopharmacol. Aug. 2009;19(4):329-39. X-1, X-3, X-4. [pmid: 19702485].
1492 Ghuman JK, Cataldo MD, Beck MH, et al. Behavioral training for pill-swallowing difficulties in young children with autistic disorder. J Child Adolesc Psychopharmacol. Winter. 2004;14(4):601-11. X-1, X-3, X-4. [pmid: 15662153].
1493 Giangreco MF, Broer SM. Questionable utilization of paraprofessionals in inclusive schools: are we addressing symptoms or causes?. Focus Autism Dev Disabil. Mar. 2005;20(1):10-26. X-2, X-4.
1494 Giangreco MF, Broer SM. School-based screening to determine overreliance on paraprofessionals. Focus Autism Dev Disabil. Fall. 2007;22(3):149-58. X-4.
1495 Giannotti F, Cortesi F, Cerquiglini A, et al. An open-label study of controlled-release melatonin in treatment of sleep disorders in children with autism. J Autism Dev Disord. Aug. 2006;36(6):741-52. X-1, X-3, X-4. [pmid: 16897403].
1496 Giarelli E, Souders M, Pinto-Martin J, et al. Intervention pilot for parents of children with autistic spectrum disorder. Pediatr Nurs. Sep–Oct. 2005;31(5):389-99. X-1, X-3, X-4. [pmid: 16295154].
1497 Gibbons MM, Goins S. Getting to know the child with Asperger syndrome. Sch Couns. Jun. 2008;11(5):347-52. X-1, X-2, X-3, X-4.
1498 Gibbs V, Toth-Cohen S. Family-centered occupational therapy and telerehabilitation for children with autism spectrum disorders. Occup Ther Health Care. 2011;25(4):298-314. X-3.
1499 Gibson JA, Grey IM, Hastings RP. Supervisor support as a predictor of burnout and therapeutic self-efficacy in therapists working in ABA schools. J Autism Dev Disord. Jul. 2009;39(7):1024-30. X-4. [pmid: 19291383].
1500 Gibson JL, Pennington RC, Stenhoff DM, et al. Using desktop videoconferencing to deliver interventions to a preschool student with autism. Topics Early Child Spec Educ. 2010;29(4):214-25. X-1, X-3, X-4.
1501 Gidley Larson JC, Bastian AJ, Donchin O, et al. Acquisition of internal models of motor tasks in children with autism. Brain. Nov. 2008;131(Pt 11):2894-903. X-1, X-3, X-4. [pmid: 18819989].
1502 Gilby KL, Jans J, McIntyre DC. Chronic omega-3 supplementation in seizure-prone versus seizure-resistant rat strains: a cautionary tale. Neuroscience. Oct. 20. 2009;163(3):750-8. X-2, X-4. [pmid: 19596053].
1503 Gillberg C. The treatment of epilepsy in autism. J Autism Dev Disord. Mar. 1991;21(1):61-77. X-2. [pmid: 2037550].
1504 Gillberg C. Endogenous opioids and opiate antagonists in autism: brief review of empirical findings and implications for clinicians. Dev Med Child Neurol. Mar. 1995;37(3):239-45. X-2, X-4. [pmid: 7890130].
1505 Gillberg C. The ESSENCE in child psychiatry: Early Symptomatic Syndromes Eliciting Neurodevelopmental Clinical Examinations. Res Dev Disabil. Nov–Dec. 2010;31(6):1543-51. X-1, X-2, X-3, X-4. [pmid: 20634041].
1506 Gillberg C, Johansson M, Steffenburg S, et al. Auditory integration training in children with autism. Autism. Jul. 1997;1(1):97-100. X-3.
1507 Gillberg C, Wahlstrom J, Johansson R, et al. Folic acid as an adjunct in the treatment of children with the autism fragile-X syndrome (AFRAX). Dev Med Child Neurol. Oct. 1986;28(5):624-7. X-3. [pmid: 3536640].
1508 Gillberg IC, Gillberg C, Rastam M, et al. The cognitive profile of anorexia nervosa: a comparative study including a community-based sample. Compr Psychiatry. Jan–Feb. 1996;37(1):23-30. X-4. [pmid: 8770522].
1509 Gillberg IC, Rastam M, Gillberg C. Anorexia nervosa 6 years after onset: Part I. Personality disorders. Compr Psychiatry. Jan–Feb. 1995;36(1):61-9. X-4. [pmid: 7705090].
1510 Gillis JM. Screening practices of family physicians and pediatricians in 2 Southern states. Inf Young Child. 2009;22(4):321-31. X-1, X-3, X-4.
1511 Gillis JM, Hammond Natof T, Lockshin SB, et al. Fear of routine physical exams in children with autism spectrum disorders: prevalence and intervention effectiveness. Focus Autism Dev Disabil. 2009;24(3):156-68. X-1, X-4.
1512 Gillott A, Furniss F, Walter A. Theory of mind ability in children with specific language impairment. Child Lang Teach Ther. 2004;20(1):1-11. X-1, X-3, X-4.
1513 Gilson BB. One-stop career centers: will they be used by people with disabilities?. Focus Autism Dev Disabil. Spr. 2000;15(1):30-6. X-2, X-3.
1514 Girolametto L, Sussman F, Weitzman E. Using case study methods to investigate the effects of interactive intervention for children with autism spectrum disorders. J Commun Disord. Nov–Dec. 2007;40(6):470-92. X-1, X-3, X-4. [pmid: 17169368].
1515 Given J, Slevin E. Being heard: aiding public participation in decision making. Learn Diabil Res Pract. 2011;14(8):26-30. X-3, X-4.
1516 Gjaerum RG, Ineland J, Sauer L. The story about theater organizations, the public's approval, and the actors' identity formation in Nordic disability theater. J Soc Work Disabil Rehabil. 2010;9(4):254-73. X-4. [pmid: 21104515].
1517 Gjevik E, Eldevik S, Fjæran-Granum T, et al. Kiddie-SADS reveals high rates of DSM-IV disorders in children and adolescents with autism spectrum disorders. J Autism Dev Disord. Jun. 2011;41(6):761-9. X-4. [pmid: 20824493].
1518 Glaeser BC, Pierson MR, Fritschmann N. Comic strip conversation: a positive behavioral support strategy. Teach Except Child. Nov–Dec. 2003;36(2):14-9. X-1, X-2, X-3, X-4.
1519 Glashan L, Mackay G, Grieve A. Teachers' experience of support in the mainstream education of pupils with autism. Improving Schools. 2004;7(1):49-60. X-1, X-3, X-4.
1520 Glazebrook CM, Elliott D, Lyons J. Temporal judgements of internal and external events in persons with and without autism. Conscious Cogn. Mar. 2008;17(1):203-9. X-4. [pmid: 17433718].
1521 Glogowska M, Roulstone S, Peters TJ, et al. Early speech- and language-impaired children: linguistic, literacy, and social outcomes. Dev Med Child Neurol. Jun. 2006;48(6):489-94. X-4. [pmid: 16700942].
1522 Glover AC, Roane HS, Kadey HJ, et al. Preference for reinforcers under progressive- and fixed-ratio schedules: a comparison of single and concurrent arrangements. J Appl Behav Anal. Summer. 2008;41(2):163-76. X-2. [pmid: 18595281].
1523 Goin-Kochel RP, Mackintosh VH, Myers BJ. Parental reports on the efficacy of treatments and therapies for their children with autism spectrum disorders. Res Autism Spectr Disord. Apr–Jun. 2009;3(2):528-37. X-1, X-3, X-4.
1524 Goin-Kochel RP, Myers BJ, Mackintosh VH. Parental reports on the use of treatments and therapies for children with autism spectrum disorders. Res Autism Spectr Disord. Jul–Sep. 2007;1(3):195-209. X-1, X-3, X-4.
1525 Golan O, Ashwin E, Granader Y, et al. Enhancing emotion recognition in children with autism spectrum conditions: an intervention using animated vehicles with real emotional faces. J Autism Dev Disord. Mar. 2010;40(3):269-79. X-1, X-3, X-4. [pmid: 19763807].
1526 Golden RR, Campbell M, Perry R. A taxometric method for diagnosis of tardive dyskinesia. J Psychiatr Res. 1987;21(3):233-41. X-1, X-3, X-4. [pmid: 2890764].
1527 Goldman GS, Yazbak FE. An investigation of the association between MMR vaccination and autism in Denmark. J Am Physicians Surg. 2004;9(3):70-5. X-4.
1528 Goldsmith HH, Van Hulle CA, Arneson CL, et al. A population-based twin study of parentally reported tactile and auditory defensiveness in young children. J Abnorm Child Psychol. Jun. 2006;34(3):393-407. X-1, X-3, X-4. [pmid: 16649001].
1529 Goldsmith TR, LeBlanc LA, Sautter RA. Teaching intraverbal behavior to children with autism. Res Autism Spectr Disord. Jan–Mar. 2007;1(1):1-13. X-3.
1530 Goldstein G, Minshew NJ, Siegel DJ. Age differences in academic achievement in high-functioning autistic individuals. J Clin Exp Neuropsychol. Oct. 1994;16(5):671-80. X-4. [pmid: 7836490].
1531 Goldstein H. Commentary: interventions to facilitate auditory, visual, and motor integration: "Show Me the Data". J Autism Dev Disord. Oct. 2000;30(5):423-25. X-1, X-2, X-3, X-4. [pmid: 11098878].
1532 Goldstein H. Communication intervention for children with autism: a review of treatment efficacy. J Autism Dev Disord. Oct. 2002;32(5):373-96. X-1, X-2, X-3, X-4. [pmid: 12463516].
1533 Goldstein H, Cisar CL. Promoting interaction during sociodramatic play: teaching scripts to typical preschoolers and classmates with disabilities. J Appl Behav Anal. Summer. 1992;25(2):265-80. X-3. [pmid: 1386068].
1534 Goldstein H, Kaczmarek L, Pennington R, et al. Peer-mediated intervention: attending to, commenting on, and acknowledging the behavior of preschoolers with autism. J Appl Behav Anal. Summer. 1992;25(2):289-305. X-1, X-3, X-4. [pmid: 1634424].
1535 Goldstein H, Schneider N, Thiemann K. Peer-mediated social communication intervention: when clinical expertise informs treatment development and evaluation. Top Lang Disord. Apr–Jun. 2007;27(2):182. X-4.
1536 Goldstein R, Joja O, Psatta DM, et al. Vasotocin improves intelligence and attention in mentally retarded children. Physiol Behav. Dec. 1989;46(6):967-70. X-1, X-3, X-4. [pmid: 2634261].
1537 Golnik A, Ireland M, Borowsky IW. Medical homes for children with autism: a physician survey. Pediatrics. Mar. 2009;123(3):966-71. X-2, X-4. [pmid: 19255027].
1538 Golnik A, Scal P, Wey A, et al. Autism-specific primary care medical home intervention. J Autism Dev Disord. 2011. Aug. 19. X-6. [pmid: 21853373].
1539 Golnik AE, Ireland M. Complementary alternative medicine for children with autism: a physician survey. J Autism Dev Disord. Jul. 2009;39(7):996-1005. X-4. [pmid: 19280328].
1540 Golomb C, Schmeling J. Drawing development in autistic and mentally retarded children. Visual Arts Research. Fall. 1996;22(44):5-18. X-3, X-4.
1541 Golubchik P, Sever J, Weizman A. Low-dose quetiapine for adolescents with autistic spectrum disorder and aggressive behavior: open-label trial. Clin Neuropharmacol. Nov. 2011;34(6):216-9. X-3. [pmid: 21996644].
1542 Gombosi PG. Parents of autistic children. Some thoughts about trauma, dislocation, and tragedy. Psychoanal Study Child. 1998;53:254-75. X-1, X-2, X-3, X-4. [pmid: 9990834].
1543 Gomes E, Rotta NT, Pedroso FS, et al. Auditory hypersensitivity in children and teenagers with autistic spectrum disorder. Arq Neuropsiquiatr. Sep. 2004;62(3B):797-801. X-4. [pmid: 15476072].
1544 Gomot M, Belmonte MK, Bullmore ET, et al. Brain hyper-reactivity to auditory novel targets in children with high-functioning autism. Brain. Sep. 2008;131(Pt 9):2479-88. X-4. [pmid: 18669482].
1545 Gomot M, Bernard FA, Davis MH, et al. Change detection in children with autism: an auditory event-related fMRI study. Neuroimage. Jan. 15. 2006;29(2):475-84. X-3, X-4. [pmid: 16115783].
1546 Gomot M, Giard MH, Adrien JL, et al. Hypersensitivity to acoustic change in children with autism: electrophysiological evidence of left frontal cortex dysfunctioning. Psychophysiology. Sep. 2002;39(5):577-84. X-4. [pmid: 12236323].
1547 Gonzalez A, Stombaugh J, Lozupone C, et al. The mind-body-microbial continuum. Dialogues Clin Neurosci. 2011;13(1):55-62. X-1, X-2, X-3, X-4. [pmid: 21485746].
1548 Gonzalez NM, Campbell M, Small AM, et al. Naltrexone plasma levels, clinical response and effect on weight in autistic children. Psychopharmacol Bull. 1994;30(2):203-8. X-1, X-3, X-4. [pmid: 7831456].
1549 Goodlin-Jones BL, Sitnick SL, Tang K, et al. The Children's Sleep Habits Questionnaire in toddlers and preschool children. J Dev Behav Pediatr. Apr. 2008;29(2):82-8. X-4. [pmid: 18478627].
1550 Goodman JF, Cecil HS, Barker WF. Early intervention with retarded children: some encouraging results. Dev Med Child Neurol. Feb. 1984;26(1):47-55. X-1, X-3, X-4. [pmid: 6698326].
1551 Goodman JI, Brady MP, Duffy ML, et al. The effects of "bug-in-ear" supervision on special education teachers' delivery of learn units. Focus Autism Dev Disabil. 2008;23(4):207-16. X-4.
1552 Goodman MJ, Nordin J. Vaccine adverse event reporting system reporting source: a possible source of bias in longitudinal studies. Pediatrics. Feb. 2006;117(2):387-90. X-2, X-4. [pmid: 16452357].
1553 Goodwin MS. Enhancing and accelerating the pace of autism research and treatment: the promise of developing innovative technology. Focus Autism Dev Disabil. 2008;23(2):125-8. X-2, X-4.
1554 Gor RA, Fuhrer J, Schober JM. A retrospective observational study of enuresis, daytime voiding symptoms, and response to medical therapy in children with attention deficit hyperactivity disorder and autism spectrum disorder. J Pediatr Urol. 2010. Dec. 3. X-1, X-3, X-4. [pmid: 21131234].
1555 Gordon B. Commentary: a neural systems perspective for improving behavioral treatments for autism. J Autism Dev Disord. Oct. 2000;30(5):503-8. X-2, X-4. [pmid: 11098892].
1556 Gordon CT. Commentary: considerations on the pharmacological treatment of compulsions and stereotypies with serotonin reuptake inhibitors in pervasive developmental disorders. J Autism Dev Disord. Oct. 2000;30(5):437-8. X-2, X-4. [pmid: 11098880].
1557 Gordon CT, Frazier JA, McKenna K, et al. Childhood-onset schizophrenia: an NIMH study in progress. Schizophr Bull. 1994;20(4):697-712. X-4. [pmid: 7701277].
1558 Gordon CT, Rapoport JL, Hamburger SD, et al. Differential response of seven subjects with autistic disorder to clomipramine and desipramine. Am J Psychiatry. Mar. 1992;149(3):363-6. X-3. [pmid: 1536276].
1559 Gordon CT, State RC, Nelson JE, et al. A double-blind comparison of clomipramine, desipramine, and placebo in the treatment of autistic disorder. Arch Gen Psychiatry. Jun. 1993;50(6):441-7. X-1, X-4. [pmid: 8498878].
1560 Gordon K, Pasco G, McElduff F, et al. a communication-based intervention for nonverbal children with autism: what changes? who benefits?. J Consult Clin Psychol. Aug. 2011;79(4):447-57. X-1, X-3, X-4. [pmid: 21787048].
1561 Gordon R, Handleman JS, Harris SL. The effects of contingent versus non-contingent running on the out-of-seat behavior of an autistic boy. Child Fam Behav Ther. Fal. 1986;8(3):37-44. X-1, X-3, X-4.
1562 Gorham M, Barnes-Holmes Y, Barnes-Holmes D, et al. Derived comparative and transitive relations in young children with and without autism. Psychological Record. Spr. 2009;59(2):221-46. X-1, X-3, X-4.
1563 Gorman JM, Akande E, Xenitidis K, et al. Autism or schizophrenia: a diagnostic dilemma in adults with intellectual disabilities. J Psychiatr Pract. May. 2004;10(3):190-5. X-2, X-4. [pmid: 15330227].
1564 Gornick MC, Addington AM, Sporn A, et al. Dysbindin (DTNBP1, 6p22.3) is associated with childhood-onset psychosis and endophenotypes measured by the Premorbid Adjustment Scale (PAS). J Autism Dev Disord. Dec. 2005;35(6):831-8. X-4. [pmid: 16283082].
1565 Gothelf D, Goraly O, Avni S, et al. Psychiatric morbidity with focus on obsessive-compulsive disorder in an Israeli cohort of adolescents with mild to moderate mental retardation. J Neural Transm. Jun. 2008;115(6):929-36. X-1, X-3, X-4. [pmid: 18351287].
1566 Gottschalk JM, Libby ME, Graff RB. The effects of establishing operations on preference assessment outcomes. J Appl Behav Anal. Spring. 2000;33(1):85-8. X-3, X-4. [pmid: 10738955].
1567 Goulet M, Shiromani PJ, Ware CM, et al. A secretin i.v. infusion activates gene expression in the central amygdala of rats. Neuroscience. 2003;118(4):881-8. X-4. [pmid: 12732234].
1568 Graetz JE. Autism grows up: opportunities for adults with autism. Disabil Soc. Jan. 2010;25(1):33-47. X-4.
1569 Graff RB, Gibson L. Using pictures to assess reinforcers in individuals with developmental disabilities. Behav Modif. Sep. 2003;27(4):470-83. X-4. [pmid: 12971123].
1570 Graff RB, Gibson L, Galiatsatos GT. The impact of high- and low-preference stimuli on vocational and academic performances of youths with severe disabilities. J Appl Behav Anal. Spring. 2006;39(1):131-5. X-3. [pmid: 16602393].
1571 Graff RB, Green G. Two methods for teaching simple visual discriminations to learners with severe disabilities. Res Dev Disabil. May–Jun. 2004;25(3):295-307. X-3. [pmid: 15134794].
1572 Graff RB, Green G, Libby ME. Effects of two levels of treatment intensity on a young child with severe disabilities. Behav Interv. Feb. 1998;13(1):21-41. X-1, X-3, X-4.
1573 Graff RB, Lineman GT, Libby ME, et al. Functional analysis and treatment of screaming in a young girl with severe disabilities. Behav Interv. Oct–Dec. 1999;14(4):233-9. X-1, X-3, X-4.
1574 Graham G. Music and autism. J Aesthetic Educ. Sum. 2001;35(2):39-47. X-2, X-4.
1575 Gralton EJ, James DH, Lindsey MP. Antipsychotic medication, psychiatric diagnosis and children with intellectual disability: a 12-year follow-up study. J Intellect Disabil Res. Feb. 1998;42(Pt 1):49-57. X-4. [pmid: 9534115].
1576 Granat T, Nordgren I, Rein G, et al. Group intervention for siblings of children with disabilities: a pilot study in a clinical setting. Disabil Rehabil. 2011. Aug. 30. X-6. [pmid: 21877903].
1577 Grandin T. Brief report: response to National Institutes of Health report. J Autism Dev Disord. Apr. 1996;26(2):185-7. X-2, X-4. [pmid: 8744482].
1578 Granpeesheh D, Dixon DR, Tarbox J, et al. The effects of age and treatment intensity on behavioral intervention outcomes for children with autism spectrum disorders. Res Autism Spectr Disord. Oct–Dec. 2009;3(4):1014-22. X-1, X-3, X-4.
1579 Granpeesheh D, Tarbox J, Dixon DR, et al. Retrospective analysis of clinical records in 38 cases of recovery from autism. Ann Clin Psychiatry. Oct–Dec. 2009;21(4):195-204. X-1, X-3, X-4. [pmid: 19917210].
1580 Granpeesheh D, Tarbox J, Dixon DR, et al. Randomized trial of hyperbaric oxygen therapy for children with autism. Res Autism Spectr Disord. Apr–Jun. 2010;4(2):268-75. X-1, X-3, X-4.
1581 Gray DE. Negotiating autism: relations between parents and treatment staff. Soc Sci Med. Apr. 1993;36(8):1037-46. X-4. [pmid: 8475419].
1582 Gray DE. ‘Everybody just freezes. Everybody is just embarrassed’: felt and enacted stigma among parents of children with high functioning autism. Sociol Health Illn. 2002;24(6):734-49. X-4.
1583 Gray DE. Ten years on: a longitudinal study of families of children with autism. J Intellect Dev Disabil. 2002;27(3):215-22. X-1, X-3, X-4.
1584 Gray DE, Holden WJ. Psycho-social well-being among the parents of children with autism. J Intellect Dev Disabil. 1992;18(2):83-93. X-4.
1585 Gray K, Jenkins AC, Heberlein AS, et al. Distortions of mind perception in psychopathology. Proc Natl Acad Sci U S A. Jan. 11. 2011;108(2):477-9. X-2, X-4. [pmid: 21187372].
1586 Gray LA, Msall ER, Msall ME. Communicating about autism: decreasing fears and stresses through parent-professional partnerships. Inf Young Child. 2008;21(4):256-71. X-1, X-2, X-3, X-4.
1587 Greeff AP, van der Walt KJ. Resilience in families with an autistic child. Educ Train Autism Dev Disabil. Sep. 2010;45(3):347-55. X-4.
1588 Green G, Brennan LC, Fein D. Intensive behavioral treatment for a toddler at high risk for autism. Behav Modif. Special Issue: Autism, Part 2. Jan. 2002;26(1):69-102. X-1, X-3, X-4. [pmid: 11799655].
1589 Green G, Striefel S. Response restriction and substitution with autistic children. J Exp Anal Behav. Jul. 1988;50(1):21-32. X-3. [pmid: 3171473].
1590 Green H. Intonation in Hebrew-speaking children with high functioning autism. Asia Pac J Speech Lang Hear. 2009;12(2):187-98. X-1, X-3, X-4.
1591 Green H, Tobin Y. Prosodic analysis is difficult ... but worth it: a study in high functioning autism. Int J Speech Lang Pathol. 2009;11(4):308-15. X-1, X-3, X-4.
1592 Green J, Charman T, McConachie H, et al. Parent-mediated communication-focused treatment in children with autism (PACT): a randomised controlled trial. Lancet. Jun. 19. 2010;375(9732):2152-60. X-1, X-3, X-4. [pmid: 20494434].
1593 Green SA, Ben-Sasson A. Anxiety disorders and sensory over-responsivity in children with autism spectrum disorders: is there a causal relationship?. J Autism Dev Disord. Dec. 2010;40(12):1495-504. X-2, X-4. [pmid: 20383658].
1594 Green VA. Parental experience with treatments for autism. J Dev Phys Disabil. Apr. 2007;19(2):91-101. X-3.
1595 Green VA, Pituch KA, Itchon J, et al. Internet survey of treatments used by parents of children with autism. Res Dev Disabil. Jan–Feb. 2006;27(1):70-84. X-1, X-3, X-4. [pmid: 15919178].
1596 Greenberg JS, Seltzer MM, Krauss MW, et al. The effect of quality of the relationship between mothers and adult children with schizophrenia, autism, or down syndrome on maternal well-being: the mediating role of optimism. Am J Orthopsychiatry. Jan. 2004;74(1):14-25. X-4. [pmid: 14769105].
1597 Greenberger C, Serper MR. Examination of clinical and cognitive insight in acute schizophrenia patients. J Nerv Ment Dis. Jul. 2010;198(7):465-9. X-1, X-3, X-4. [pmid: 20611048].
1598 Grela BG, McLaughlin KS. Focused stimulation for a child with autism spectrum disorder: a treatment study. J Autism Dev Disord. Aug. 2006;36(6):753-6. X-3. [pmid: 16838131].
1599 Grenwelge CH. Test Review. Woodcock RW, Schrank FA, Mather N, McGrew KS, editors. 2007. Woodcock-Johnson III Tests of Achievement, Form C/Brief Battery. Rolling Meadows, IL. Riverside. J Psychoeduc Assess. 2009;27(4):345–50. X-1, X-2, X-3, X-4.
1600 Gresham FM, Macmillan DL. Autistic recovery? An analysis and critique of the empirical evidence on the early intervention project. Behav Disord. Aug. 1997;22(4):185-201. X-1, X-2, X-3, X-4.
1601 Gresham FM, MacMillan DL. Denial and defensiveness in the place of fact and reason: rejoinder to Smith and Lovass. Behav Disord. Aug. 1997;22(4):219-30. X-1, X-2, X-3, X-4.
1602 Gresham FM, MacMillan DL. Early intervention project: can its claims be substantiated and its effects replicated?. J Autism Dev Disord. Feb. 1998;28(1):5-13. X-1, X-3, X-4. [pmid: 9546297].
1603 Grether JK, Li SX, Yoshida CK, et al. Antenatal ultrasound and risk of autism spectrum disorders. J Autism Dev Disord. Feb. 2010;40(2):238-45. X-4. [pmid: 19728066].
1604 Grey IM, Bruton C, Honan R, et al. Co-operative learning for children with an autistic spectrum disorder (asd) in mainstream and special class settings: an exploratory study. Educ Psychol Prac. Dec. 2007;23(4):317-27. X-1, X-3, X-4.
1605 Grey IM, Honan R, McClean B, et al. Evaluating the effectiveness of teacher training in Applied Behaviour Analysis. J Intellect Disabil. Sep. 2005;9(3):209-27. X-3. [pmid: 16144826].
1606 Grieco A, Bloom R. Psychotherapy with hallucinogenic adjuncts from a learning perspective. Int J Addict. Jul. 1981;16(5):801-27. X-1, X-2, X-3, X-4. [pmid: 7327766].
1607 Griffin HC, Griffin LW, Fitch CW, et al. educational interventions for individuals with asperger syndrome. Interv School Clinic. Jan. 2006;41(3):150-5. X-1, X-2, X-3, X-4.
1608 Griffin JC, Ricketts RW, Williams DE, et al. A community survey of self-injurious behavior among developmentally disabled children and adolescents. Hosp Community Psychiatry. Sep. 1987;38(9):959-63. X-1, X-3, X-4. [pmid: 3679101].
1609 Griffith GM, Hastings RP, Oliver C, et al. Psychological well-being in parents of children with Angelman, Cornelia de Lange and Cri du Chat syndromes. J Intellect Disabil Res. Apr. 2011;55(4):397-410. X-1, X-3, X-4. [pmid: 21323782].
1610 Grimaldi BL. The central role of magnesium deficiency in Tourette's syndrome: causal relationships between magnesium deficiency, altered biochemical pathways and symptoms relating to Tourette's syndrome and several reported comorbid conditions. Med Hypotheses. Jan. 2002;58(1):47-60. X-2. [pmid: 11863398].
1611 Grindle CF, Kovshoff H, Hastings RP, et al. Parents' experiences of home-based applied behavior analysis programs for young children with autism. J Autism Dev Disord. Jan. 2009;39(1):42-56. X-1, X-3, X-4. [pmid: 18535893].
1612 Grindle CF, Remington B. Teaching children with autism using conditioned cue-value and response-marking procedures: a socially valid procedure. Res Dev Disabil. Sep–Oct. 2004;25(5):413-29. X-1, X-3, X-4. [pmid: 15217671].
1613 Grindle CF, Remington B. Teaching children with autism when reward is delayed. The effects of two kinds of marking stimuli. J Autism Dev Disord. Dec. 2005;35(6):839-50. X-3. [pmid: 16283081].
1614 Gringras P, Santosh P, Baird G. Development of an Internet-based real-time system for monitoring pharmacological interventions in children with neurodevelopmental and neuropsychiatric disorders. Child Care Health Dev. Sep. 2006;32(5):591-600. X-2, X-4. [pmid: 16919139].
1615 Grizenko N, Cvejic H, Vida S, et al. Behaviour problems of the mentally retarded. Can J Psychiatry. Dec. 1991;36(10):712-7. X-4. [pmid: 1790515].
1616 Groden G, Groden J, Dondey M, et al. Effects of fenfluramine on the behavior of autistic individuals. Res Dev Disabil. 1987;8(2):203-11. X-3. [pmid: 3313552].
1617 Groden J, Cautela J. Procedures to increase social interaction among adolescents with autism: a multiple baseline analysis. J Behav Ther Exp Psychiatry. Jun. 1988;19(2):87-93. X-3. [pmid: 3209701].
1618 Groen WB, van Orsouw L, Huurne N, et al. Intact spectral but abnormal temporal processing of auditory stimuli in autism. J Autism Dev Disord. May. 2009;39(5):742-50. X-2. [pmid: 19148738].
1619 Groen WB, van Orsouw L, Zwiers M, et al. Gender in voice perception in autism. J Autism Dev Disord. Nov. 2008;38(10):1819-26. X-4. [pmid: 18415010].
1620 Groen Y, Wijers AA, Mulder LJM, et al. Error and feedback processing in children with ADHD and children with autistic spectrum disorder: An EEG event-related potential study. Clin Neurophysiol. Nov. 2008;119(11):2476-93. X-1, X-3, X-4. [pmid: 18824404].
1621 Groft-Jones M, Block ME. Strategies for teaching children with autism in physical education. Teach Elementary Phys Educ. Nov. 2006;17(6):25-8. X-2, X-4.
1622 Groskreutz NC, Groskreutz MP, Higbee TS. Effects of varied levels of treatment integrity on appropriate toy manipulation in children with autism. Res Autism Spectr Disord. Oct–Dec. 2011;5(4):1358-69. X-1, X-3, X-4.
1623 Groskreutz NC, Karsina A, Miguel CF, et al. Using complex auditory-visual samples to produce emergent relations in children with autism. J Appl Behav Anal. Mar. 2010;43(1):131-6. X-3. [pmid: 20808504].
1624 Gross M. Pursuing the puzzle of autism. Curr Biol. Oct. 15. 2002;12(20):R679. X-2. [pmid: 12401179].
1625 Grossman RB, Schneps MH, Tager-Flusberg H. Slipped lips: onset asynchrony detection of auditory-visual language in autism. J Child Psychol Psychiatry. Apr. 2009;50(4):491-7. X-4. [pmid: 19207623].
1626 Grow LL, Carr JE, Kodak TM, et al. A comparison of methods for teaching receptive labeling to children with autism spectrum disorders. J Appl Behav Anal. Fall. 2011;44(3):475-98. X-1, X-3, X-4. [pmid: 21941380].
1627 Grow LL, Kelley ME, Roane HS, et al. Utility of extinction-induced response variability for the selection of mands. J Appl Behav Anal. Spring. 2008;41(1):15-24. X-1, X-3, X-4. [pmid: 18468276].
1628 Guardino CA. Identification and placement for deaf students with multiple disabilities: choosing the path less followed. Am Ann Deaf. Spring. 2008;153(1):55-64. X-2, X-4. [pmid: 18619069].
1629 Guastella AJ, Einfeld SL, Gray KM, et al. Intranasal oxytocin improves emotion recognition for youth with autism spectrum disorders. Biol Psychiatry. Apr. 1. 2010;67(7):692-4. X-3. [pmid: 19897177].
1630 Gudarzi SS, Yasamy M, Akhondzadeh S. Cyproheptadine in treatment of autism. Eur Psychiatry. Jul. 2002;17(4):230-1. X-3. [pmid: 12231270].
1631 Guillem P, Cans C, Guinchat V, et al. Trends, perinatal characteristics, and medical conditions in pervasive developmental disorders. Dev Med Child Neurol. Nov. 2006;48(11):896-900. X-4. [pmid: 17044957].
1632 Guilloteau D, Chalon S. PET and SPECT exploration of central monoaminergic transporters for the development of new drugs and treatments in brain disorders. Curr Pharm Des. 2005;11(25):3237-45. X-2, X-4. [pmid: 16250852].
1633 Guimaraes Filho PD. A hypothesis about the determining process of autistic states. Int J Psychoanal. 1990;71(Pt 3):393-402. X-2, X-4. [pmid: 2228439].
1634 Guldberg K, Parsons S, MacLeod A, et al. Implications for practice from “International review of the evidence on best practice in educational provision for children on the autism spectrum”. Eur J Spec Needs Educ. Feb. 2011;26(1):65-70. X-1, X-2, X-3, X-4.
1635 Gulsrud AC, Jahromi LB, Kasari C. The co-regulation of emotions between mothers and their children with autism. J Autism Dev Disord. Feb. 2010;40(2):227-37. X-1, X-3, X-4. [pmid: 19714458].
1636 Gulsrud AC, Kasari C, Freeman S, et al. Children with autism's response to novel stimuli while participating in interventions targeting joint attention or symbolic play skills. Autism. Nov. 2007;11(6):535-46. X-1, X-3, X-4. [pmid: 17947289].
1637 Gunnar MR. A commentary on "Deprivation-specific psychological patterns: effects of institutional deprivation". Monogr Soc Res Child Dev. Apr. 2010;75(1):232-47. X-1, X-2, X-3, X-4. [pmid: 20500642].
1638 Gunter P, et al. The reduction of aberrant vocalizations with auditory feedback and resulting collateral behavior change of two autistic boys. Behav Disord. Aug. 1984;9(4):254-63. X-3.
1639 Gunter PL, Fox JJ, McEvoy MA, et al. A case study of the reduction of aberrant, repetitive responses of an adolescent with autism. Educ Treat Children. May. 1993;16(2):187-97. X-3.
1640 Gupta A, Singhal N. Language and learning skills and symptoms in children with autistic spectrum disorders. Asia Pac Disabil Rehab J. 2009;20(2):59-83. X-4.
1641 Gupta S. Immunological treatments for autism. J Autism Dev Disord. Oct. 2000;30(5):475-9. X-2, X-4. [pmid: 11098887].
1642 Gupta S. Antibodies: basic mechanisms and emerging concepts. J Clin Immunol. May. Suppl 1. 2010;30:S1-3. X-1, X-3, X-4. [pmid: 20387105].
1643 Gupta S, Aggarwal S, Heads C. Dysregulated immune system in children with autism: beneficial effects of intravenous immune globulin on autistic characteristics. J Autism Dev Disord. Aug. 1996;26(4):439-52. X-3. [pmid: 8863094].
1644 Guptill JT, Booker AB, Gibbs TT, et al. [[superscript 3]H]-Flunitrazepam-labeled benzodiazepine binding sites in the hippocampal formation in autism: a multiple concentration autoradiographic study. J Autism Dev Disord. May. 2007;37(5):911-20. X-4. [pmid: 17019626].
1645 Gura GF, Champagne MT, Blood-Siegfried JE. Autism spectrum disorder screening in primary care. J Dev Behav Pediatr. Jan. 2011;32(1):48-51. X-1, X-3, X-4. [pmid: 21160437].
1646 Guralnick MJ. Early childhood intervention: evolution of a system. Focus Autism Dev Disabil. Sum. 2000;15(2):68-79. X-2, -3, X-4.
1647 Gurney JG, Fritz MS, Ness KK, et al. Analysis of prevalence trends of autism spectrum disorder in Minnesota. Arch Pediatr Adolesc Med. Jul. 2003;157(7):622-7. X-4. [pmid: 12860781].
1648 Gurney JG, McPheeters ML, Davis MM. Parental report of health conditions and health care use among children with and without autism: National Survey of Children's Health. Arch Pediatr Adolesc Med. Aug. 2006;160(8):825-30. X-4. [pmid: 16894082].
1649 Gus L. Autism: promoting peer understanding. Educ Psychol Prac. Dec. 2000;16(4):461-8. X-3.
1650 Gustafsson C, Ojehagen A, Hansson L, et al. Effects of psychosocial interventions for people with intellectual disabilities and mental health problems: a survey of systematic reviews. Res Soc Work Pract. 2009;19(3):281-90. X-2, X-4.
1651 Gutierrez A Jr, Vollmer TR, Dozier CL, et al. Manipulating establishing operations to verify and establish stimulus control during mand training. J Appl Behav Anal. Win. 2007;40(4):645-58. X-3, X-4. [pmid: 18189096].
1652 Gutman SA, Raphael EI, Ceder LM, et al. The effect of a motor-based, social skills intervention for adolescents with high-functioning autism: two single-subject design cases. Occup Ther Int. 2010;17(4):188-97. X-3. [pmid: 20672254].
1653 Gutstein SE, Burgess AF, Montfort K. Evaluation of the relationship development intervention program. Autism. Sep. 2007;11(5):397-411. X-3. [pmid: 17942454].
1654 Guzzetta F, Battaglia D, Di Rocco C, et al. Symptomatic epilepsy in children with poroencephalic cysts secondary to perinatal middle cerebral artery occlusion. Childs Nerv Syst. Aug. 2006;22(8):922-30. X-4. [pmid: 16816980].
1655 Haag G, Tordjman S, Duprat A, et al. Psychodynamic assessment of changes in children with autism under psychoanalytic treatment. Int J Psychoanal. Apr. 2005;86(Pt 2):335-52. X-2. [pmid: 16089194].
1656 Hackett L, Shaikh S, Theodosiou L. Parental perceptions of the assessment of autistic spectrum disorders in a tier three service. Child Adolesc Ment Health. Sep. 2009;14(3):127-32. X-1, X-3, X-4.
1657 Hadjikhani N. Serotonin, pregnancy and increased autism prevalence: is there a link?. Med Hypotheses. May. 2010;74(5):880-3. X-1, X-2, X-3, X-4. [pmid: 20018455].
1658 Hadwin J, Baron-Cohen S, Howlin P, et al. Can we teach children with autism to understand emotions, belief, or pretence?. Dev Psychopathol. Spr. 1996;8(2):345-65. X-1, X-3, X-4.
1659 Hadwin J, Baron-Cohen S, Howlin P, et al. Does teaching theory of mind have an effect on the ability to develop conversation in children with autism?. J Autism Dev Disord. Oct. 1997;27(5):519-37. X-1, X-3, X-4. [pmid: 9403370].
1660 Hadwin J, Hutley G. Detecting features of autism in children with severe learning difficulties: a brief report. Autism. Sep. 1998;2(3):269-80. X-1, X-3, X-4.
1661 Hagerman RJ, Jackson C, Amiri K, et al. Girls with fragile X syndrome: physical and neurocognitive status and outcome. Pediatrics. Mar. 1992;89(3):395-400. X-4. [pmid: 1741210].
1662 Hagermoser Sanetti LM, Luiselli JK, Handler MW. Effects of verbal and graphic performance feedback on behavior support plan implementation in a public elementary school. Behav Modif. Jul. 2007;31(4):454-65. X-1, X-3, X-4. [pmid: 17548540].
1663 Hagiwara T, Myles BS. A multimedia social story intervention: teaching skills to children with autism. Focus Autism Dev Disabil. Sum. 1999;14(2):82-95. X-1, X-3, X-4.
1664 Hagner D, Cooney BF. “I Do That for Everybody”: supervising employees with autism. Focus Autism Dev Disabil. Sum. 2005;20(2):91-7. X-3, X-4.
1665 Hagopian LP, Bruzek JL, Bowman LG, et al. Assessment and treatment of problem behavior occasioned by interruption of free-operant behavior. J Appl Behav Anal. Spr. 2007;40(1):89-103. X-3. [pmid: 17471795].
1666 Hagopian LP, Farrell DA, Amari A. Treating total liquid refusal with backward chaining and fading. J Appl Behav Anal. Win. 1996;29(4):573-5. X-1, X-3, X-4. [pmid: 8995838].
1667 Hagopian LP, Kuhn DE, Strother GE. Targeting social skills deficits in an adolescent with pervasive developmental disorder. J Appl Behav Anal. Winter. 2009;42(4):907-11. X-3. [pmid: 20514202].
1668 Hagopian LP, Thompson RH. Reinforcement of compliance with respiratory treatment in a child with cystic fibrosis. J Appl Behav Anal. Sum. 1999;32(2):233-6. X-1, X-3, X-4. [pmid: 10396778].
1669 Hagopian LP, Toole LM. Effects of response blocking and competing stimuli on stereotypic behavior. Behav Interv. Apr. 2009;24(2):117-25. X-1, X-3, X-4.
1670 Hagopian LP, Wilson DM, Wilder DA. Assessment and treatment of problem behavior maintained by escape from attention and access to tangible items. J Appl Behav Anal. Sum. 2001;34(2):229-32. X-1, X-3, X-4. [pmid: 11421317].
1671 Hah M, Lotspeich LJ, Phillips JM, et al. Twins with KBG syndrome and autism. Skjei KL, Martin MM, Slavotinek AM, editors. KBG syndrome: report of twins, neurological characteristics, and delineation of diagnostic criteria. Am J Med Genetics, Part A. 2007;143:292-300. J Autism Dev Disord. 2009;39(12):1744–6. X-1, X-2, X-3, X-4.
1672 Hainsworth T. The prevalence and causes of autistic spectrum disorders. Nurs Times. Aug. 1–7. 2006;102(31):23-4. X-2, X-4. [pmid: 16913517].
1673 Hairston MP. Analyses of responses of mentally retarded autistic and mentally retarded nonautistic children to art therapy and music therapy. J Music Ther. Fal. 1990;27(3):137-50. X-1, X-3, X-4.
1674 Halacheva K, Dimova S, Tolev T, et al. Elevated anticardiolipin antibodies in schizophrenic patients before and during neuroleptic medication. Psychiatry Res. Aug. 30. 2009;169(1):51-5. X-4. [pmid: 19596154].
1675 Haley JL, Heick PF, Luiselli JK. Use of an antecedent intervention to decrease vocal stereotypy of a student with autism in the general education classroom. Child Fam Behav Ther. Oct. 2010;32(4):311-21. X-3.
1676 Halko MA, Eldaief MC, Horvath JC, et al. Combining transcranial magnetic stimulation and FMRI to examine the default mode network. J Vis Exp. 2010;(46). X-1, X-2, X-3, X-4. [pmid: 21248684].
1677 Hall HR, Graff JC. The relationships among adaptive behaviors of children with autism, family support, parenting stress, and coping. Issues Compr Pediatr Nurs. 2011;34(1):4-25. X-1, X-3, X-4. [pmid: 21341964].
1678 Hall LJ. Effective behavioural strategies for the defining characteristics of autism. Behav Change. 1997;14(3):139-54. X-2.
1679 Hall LJ, Grundon GS, Pope C, et al. Training paraprofessionals to use behavioral strategies when educating learners with autism spectrum disorders across environments. Behav Interv. Feb. 2010;25(1):37-51. X-1, X-3, X-4.
1680 Hall SS. Treatments for fragile X syndrome: a closer look at the data. Dev Disabil Res Rev. 2009;15(4):353-60. X-2, X-4. [pmid: 20014373].
1681 Halpin J, Nugent B. Health visitors' perceptions of their role in autism spectrum disorder. Community Pract. Jan. 2007;80(1):18-22. X-1, X-3, X-4. [pmid: 17334114].
1682 Hamad CD, Serna RW, Morrison L, et al. Extending the reach of early intervention training for practitioners: A preliminary investigation of an online curriculum for teaching behavioral intervention knowledge in autism to families and service providers. Infants Young Child. Jul–Sep. 2010;23(3):195-208. X-1, X-3, X-4.
1683 Hamdan-Allen G. Brief report: Trichotillomania in an autistic male. J Autism Dev Disord. Mar. 1991;21(1):79-82. X-3. [pmid: 2037551].
1684 Hameury L, Roux S, Barthelemy C, et al. Quantified multidimensional assessment of autism and other pervasive developmental disorders. Application for bioclinical research. Eur Child Adolesc Psychiatry. Apr. 1995;4(2):123-35. X-4. [pmid: 7796250].
1685 Hameury L, Roux S, Lenoir P, et al. Longitudinal study of autism and other pervasive developmental disorders: Review of 125 cases. Dev Brain Dysfunct. Jan–Feb. 1995;8(1):51-65. X-1, X-3, X-4.
1686 Hamilton A, Marshal MP, Murray PJ. Autism spectrum disorders and menstruation. J Adolesc Health. Oct. 2011;49(4):443-5. X-3, X-4. [pmid: 21939879].
1687 Hamilton JD. The practical search. J Am Acad Child Adolesc Psychiatry. Mar. 2007;46(3):418-22. X-2. [pmid: 17314728].
1688 Hammer LD, Curry ES, Harlor AD, et al. Increasing immunization coverage. Pediatrics. Jun. 2010;125(6):1295-304. X-1, X-2, X-3, X-4. [pmid: 20513736].
1689 Hammerschlag CA. Autistic rider. Caring. Aug. 2009;28(8):62. X-1, X-2, X-3, X-4. [pmid: 19772030].
1690 Hammock R, Levine WR, Schroeder SR. Brief report: effects of clozapine on self-injurious behavior of two risperidone nonresponders with mental retardation. J Autism Dev Disord. Feb. 2001;31(1):109-13. X-3. [pmid: 11439749].
1691 Hammock RG, et al. The effect of clozapine on self-injurious behavior. J Autism Dev Disord. Dec. 1995;25(6):611-26. X-3. [pmid: 8720030].
1692 Hampson DR, Adusei DC, Pacey LK. The neurochemical basis for the treatment of autism spectrum disorders and Fragile X Syndrome. Biochem Pharmacol. May. 1. 2011;81(9):1078-86. X-1, X-2, X-3, X-4. [pmid: 21333634].
1693 Hancock TB, Kaiser AP. The effects of trainer-implemented Enhanced Milieu Teaching on the social communication of children with autism. Topics Early Child Spec Educ. Spr. 2002;22(1):39-54. X-1, X-3, X-4.
1694 Handen BL. Pharmacotherapy in mental retardation and autism. School Psych Rev. 1993;22(2):162-83. X-1, X-2, X-3, X-4.
1695 Handen BL, Apolito PM, Seltzer GB. Use of differential reinforcement of low rates of behavior to decrease repetitive speech in an autistic adolescent. J Behav Ther Exp Psychiatry. Dec. 1984;15(4):359-64. X-3. [pmid: 6526947].
1696 Handen BL, Hofkosh D. Secretin in children with autistic disorder: a double-blind, placebo-controlled trial. J Dev Phys Disabil. Jun. 2005;17(2):95-106. X-3.
1697 Handen BL, Johnson CR, Lubetsky M. Efficacy of methylphenidate among children with autism and symptoms of attention-deficit hyperactivity disorder. J Autism Dev Disord. Jun. 2000;30(3):245-55. X-1, X-3, X-4. [pmid: 11055460].
1698 Handen BL, Johnson CR, McAuliffe-Bellin S, et al. Safety and efficacy of donepezil in children and adolescents with autism: neuropsychological measures. J Child Adolesc Psychopharmacol. Feb. 2011;21(1):43-50. X-1, X-4. [pmid: 21309696].
1699 Handen BL, Lubetsky M. Pharmacotherapy in autism and related disorders. Sch Psychol Q. Sum. 2005;20(2):155-71. X-2.
1700 Handen BL, Melmed RD, Hansen RL, et al. A double-blind, placebo-controlled trial of oral human immunoglobulin for gastrointestinal dysfunction in children with autistic disorder. J Autism Dev Disord. May. 2009;39(5):796-805. X-3. [pmid: 19148734].
1701 Handen BL, Sahl R, Hardan AY. Guanfacine in children with autism and/or intellectual disabilities. J Dev Behav Pediatr. Aug. 2008;29(4):303-8. X-1, X-2, X-4. [pmid: 18552703].
1702 Handlan S, Bloom LA. The effect of educational curricula and modeling/coaching on the interactions of kindergarten children with their peers with autism. Focus Autism Other Dev Disabil. Jun. 1993;8(2):1-11. X-1, X-3, X-4.
1703 Handleman JS. Mainstreaming the autistic-type child. Exceptional Child. Mar. 1984;31(1):33-8. X-1, X-2, X-3, X-4.
1704 Handleman JS. Providing effective consultation to students with severe developmental disabilities and their families. J Educ Psychol Consult. 1990;1(2):137-47. X-3.
1705 Handleman JS, et al. Mothers, fathers, teachers, and speech therapists as assessors of treatment outcome for children with autism. Educ Treat Children. May. 1990;13(2):153-58. X-1, X-3, X-4.
1706 Handleman JS, et al. A specialized program for preschool children with autism. Lang Speech Hear Serv Sch. 1991;22(3):107-10. X-1, X-2, X-3, X-4.
1707 Handleman JS, Powers MD, Harris SL. Teaching of labels: an analysis of concrete and pictorial representations. Am J Ment Defic. May. 1984;88(6):625-9. X-3. [pmid: 6742000].
1708 Hankin CS, Koran LM, Bronstone A, et al. Adequacy of pharmacotherapy among medicaid-enrolled patients newly diagnosed with obsessive-compulsive disorder. CNS Spectr. Dec. 2009;14(12):695-703. X-4. [pmid: 20394177].
1709 Hanser GA, Erickson KA. Integrated word identification and communication instruction for students with complex communication needs: preliminary results. Focus Autism Dev Disabil. 2007;22(4):268-78. X-3.
1710 Hanson E, Kalish LA, Bunce E, et al. Use of complementary and alternative medicine among children diagnosed with autism spectrum disorder. J Autism Dev Disord. Apr. 2007;37(4):628-36. X-4. [pmid: 16977497].
1711 Happe F. Theory of mind and the self. Ann N Y Acad Sci. Oct. 2003;1001:134-44. X-2, X-4. [pmid: 14625359].
1712 Happe F, Charlton RA. Aging in autism spectrum disorders: a mini-review. Gerontology. 2011. Aug. 24. X-1, X-2, X-3, X-4. [pmid: 21865667].
1713 Happe FG. An advanced test of theory of mind: understanding of story characters' thoughts and feelings by able autistic, mentally handicapped, and normal children and adults. J Autism Dev Disord. Apr. 1994;24(2):129-54. X-3, X-4. [pmid: 8040158].
1714 Harada Y, Tunoda M, Kanbayashi Y, et al. A case report of pervasive developmental disorder who fulfill the diagnostic criteria of attention-deficit/hyperactivity disorder. J Ment Health No. 2002;48:67-70. X-1, X-3, X-4.
1715 Harchik AE, Harchik AJ, Luce SC, et al. Teaching autistic and severely handicapped children to recruit praise: acquisition and generalization. Res Dev Disabil. 1990;11(1):77-95. X-1, X-3. [pmid: 2300688].
1716 Hardan AY, Handen BL. A retrospective open trial of adjunctive donepezil in children and adolescents with autistic disorder. J Child Adolesc Psychopharmacol. Fall. 2002;12(3):237-41. X-3. [pmid: 12427297].
1718 Hardan AY, Jou RJ, Handen BL. A retrospective assessment of topiramate in children and adolescents with pervasive developmental disorders. J Child Adolesc Psychopharmacol. Fall. 2004;14(3):426-32. X-3. [pmid: 15650499].
1719 Hardan AY, Jou RJ, Handen BL. Retrospective study of quetiapine in children and adolescents with pervasive developmental disorders. J Autism Dev Disord. Jun. 2005;35(3):387-91. X-3. [pmid: 16119479].
1720 Harding JW, Wacker DP, Berg WK, et al. Assessment and treatment of severe behavior problems using choice-making procedures. Educ Treat Children. Feb. 2002;25(1):26-46. X-1, X-3, X-4.
1721 Hare DJ. The use of cognitive-behavioral therapy with people with Asperger syndrome: a case study. Autism. Nov. 1997;1(2):215-25. X-3.
1722 Hare DJ, Chapman M, Fraser J, et al. The prevalence of autistic spectrum disorders in people using a community learning disabilities service. J Learn Disabil (14690047). 2003;7(3):267-81. X-4.
1723 Hare DJ, Jones JPR, Paine C. Approaching reality: the use of personal construct assessment in working with people with Asperger syndrome. Autism. Jun. 1999;3(2):165-76. X-3.
1724 Hare DJ, Jones S, Evershed K. Objective investigation of the sleep-wake cycle in adults with intellectual disabilities and autistic spectrum disorders. J Intellect Disabil Res. Oct. 2006;50(Pt 10):701-10. X-1, X-3, X-4. [pmid: 16961699].
1725 Hare DJ, Pratt C, Burton M, et al. The health and social care needs of family carers supporting adults with autistic spectrum disorders. Autism. Dec. 2004;8(4):425-44. X-3, X-4. [pmid: 15556960].
1726 Harel-Hochfeld M. Practicing choice theory and reality therapy in Israel: a case study. Int Journal of Reality Ther. Fal. 1999;19(1):32-4. X-1, X-3, X-4.
1727 Haring TG, Breen CG. A peer-mediated social network intervention to enhance the social integration of persons with moderate and severe disabilities. J Appl Behav Anal. Sum. 1992;25(2):319-33. X-3. [pmid: 1634425].
1728 Haring TG, Breen CG, Pitts-Conway V, et al. Use of differential reinforcement of other behavior during dyadic instruction to reduce stereotyped behavior of autistic students. Am J Ment Defic. May. 1986;90(6):694-702. X-3. [pmid: 3717225].
1729 Haring TG, Breen CG, Weiner J, et al. Using videotape modeling to facilitate generalized purchasing skills. J Behav Educ. Mar. 1995;5(1):29-53. X-3.
1730 Haring TG, Kennedy CH. Contextual control of problem behavior in students with severe disabilities. J Appl Behav Anal. Summer. 1990;23(2):235-43. X-3. [pmid: 2142682].
1731 Haring TG, Neetz JA, Lovinger L, et al. Effects of four modified incidental teaching procedures to create opportunities for communication. J Assoc Pers Sev Handicaps. Fal. 1987;12(3):218-26. X-1, X-3, X-4.
1732 Harish T, Gangadharan S, Bhaumik S, et al. Adults with Asperger syndrome at a Neuropsychiatric Centre in India. Br J Dev Disabil. Jul. 2010;56(111, Pt2):159-65. X-2.
1733 Harnryd C, Bjerkenstedt L, Bjork K, et al. Clinical evaluation of sulpiride in schizophrenic patients--a double-blind comparison with chlorpromazine. Acta Psychiatr Scand Suppl. 1984;311:7-30. X-1, X-3, X-4. [pmid: 6367364].
1734 Harpaz-Rotem I, Rosenheck RA. Changes in outpatient psychiatric diagnosis in privately insured children and adolescents from 1995 to 2000. Child Psychiatry Hum Dev. Summer. 2004;34(4):329-40. X-4. [pmid: 15039605].
1735 Harper CB, Symon JB, Frea WD. Recess is time-in: using peers to improve social skills of children with autism. J Autism Dev Disord. May. 2008;38(5):815-26. X-1, X-3, X-4. [pmid: 17874290].
1736 Harrington JW, Patrick PA, Edwards KS, et al. Parental beliefs about autism: implications for the treating physician. Autism. Sep. 2006;10(5):452-62. X-4. [pmid: 16940312].
1737 Harrington JW, Rosen L, Garnecho A, et al. Parental perceptions and use of complementary and alternative medicine practices for children with autistic spectrum disorders in private practice. J Dev Behav Pediatr. Apr. 2006;27(2 Suppl):S156-61. X-4. [pmid: 16685182].
1738 Harris KM, Mahone EM, Singer HS. Nonautistic motor stereotypies: clinical features and longitudinal follow-up. Pediatr Neurol. Apr. 2008;38(4):267-72. X-4. [pmid: 18358406].
1739 Harris SL. The family and the autistic child: a behavioral perspective. Family Relations. Jan. 1984;33(1):127-34. X-1, X-2, X-3, X-4.
1740 Harris SL. The family of the autistic child: a behavioral-systems view. Clin Psychol Rev. 1984;4(3):227-39. X-1, X-2, X-3, X-4.
1741 Harris SL. Intervention planning for the family of the autistic child: a multilevel assessment of the family system. J Marital Fam Ther. Apr. 1984;10(2):157-66. X-1, X-2, X-3, X-4.
1742 Harris SL. A 4- to 7-year questionnaire follow-up of participants in a training program for parents of autistic children. J Autism Dev Disord. Sep. 1986;16(3):377-83. X-1, X-3, X-4. [pmid: 3558294].
1743 Harris SL. Parents as teachers: a four to seven year follow up of parents of children with autism. Child Fam Behav Ther. Win. 1986;8(4):39-47. X-4.
1744 Harris SL. Adolescent with autistic spectrum disorder and some obsessive-compulsive disorder behavior. J Autism Dev Disord. Dec. 2003;33(6):709. X-1. [pmid: 14714938].
1745 Harris SL. My 19-year-old son has autism and moderate mental retardation. What can I do to make him less passive?. J Autism Dev Disord. Feb. 2005;35(1):137. X-1, X-2, X-3, X-4. [pmid: 15796130].
1746 Harris SL. Setting up a home-based program for our 3-year-old son who has autism. J Autism Dev Disord. Feb. 2006;36(2):293. X-2. [pmid: 16763777].
1747 Harris SL, Glasberg B, Ricca D. Pervasive developmental disorders: distinguishing among subtypes. School Psych Rev. 1996;25(3):308-15. X-1, X-2, X-3, X-4.
1748 Harris SL, Handleman JS. Age and IQ at intake as predictors of placement for young children with autism: a four- to six-year follow-up. J Autism Dev Disord. Apr. 2000;30(2):137-42. X-1, X-3, X-4. [pmid: 10832778].
1749 Harris SL, Handleman JS, Alessandri M. Teaching youths with autism to offer assistance. J Appl Behav Anal. Fall. 1990;23(3):297-305. X-3. [pmid: 2249966].
1750 Harris SL, Handleman JS, Fong PL. Imitation of self-stimulation: impact on the autistic child's behavior and affect. Child Fam Behav Ther. Spr-Sum. 1987;9(1–2):1-21. X-1, X-3, X-4.
1751 Harris SL, Handleman JS, Gill MJ, et al. Does punishment hurt? The impact of aversives on the clinician. Res Dev Disabil. 1991;12(1):17-24. X-4. [pmid: 2017584].
1752 Harris SL, Handleman JS, Gordon R, et al. Changes in cognitive and language functioning of preschool children with autism. J Autism Dev Disord. Sep. 1991;21(3):281-90. X-1, X-3, X-4. [pmid: 1938774].
1753 Harris SL, Handleman JS, Kristoff B, et al. Changes in language development among autistic and peer children in segregated and integrated preschool settings. J Autism Dev Disord. Mar. 1990;20(1):23-31. X-1, X-3, X-4. [pmid: 2324053].
1754 Harris SL, Wolchik SA, Milch RE. Changing the speech of autistic children and their parents. Child Fam Behav Ther. Sum-Fal. 1982;4(2–3):151-73. X-1, X-3, X-4.
1755 Harris SL, Wolchik SA, Weitz S. The acquisition of language skills by autistic children: can parents do the job?. J Autism Dev Disord. Dec. 1981;11(4):373-84. X-1, X-3, X-4. [pmid: 7052814].
1756 Harris TA, Peterson SL, Filliben TL, et al. Evaluating a more cost-efficient alternative to providing in-home feedback to parents: the use of spousal feedback. J Appl Behav Anal. Spring. 1998;31(1):131-4. X-1, X-3, X-4. [pmid: 9532757].
1757 Harrison Elder J, Shankar M, Shuster J, et al. The gluten-free, casein-free diet in autism: results of a preliminary double blind clinical trial. J Autism Dev Disord. Apr. 2006;36(3):413-20. X-3. [pmid: 16555138].
1758 Harrison JR, Barabasz AF. Effects of restricted environmental stimulation therapy on the behavior of children with autism. Child Study Journal. 1991;21(3):153-66. X-3.
1759 Harrison S, Berry L. Valuing people: health visiting and people with learning disabilities. Community Pract. Feb. 2006;79(2):56-9. X-2, X-4. [pmid: 16493981].
1760 Hart C. Can we, can't we, can we, can't we, can we help him join the dance? The need for multimodal processing in the move towards meaningful communication. J Child Psychother. Apr. 2011;37(1):16-30. X-1, X-2, X-3, X-4.
1761 Hart JE, Whalon KJ. Creating social opportunities for students with autism spectrum disorder in inclusive settings. Interv School Clinic. May. 2011;46(5):273-9. X-1, X-2, X-3.
1762 Harte HA. What teachers can learn from mothers of children with autism. Teach Except Child. Sep–Oct. 2009;42(1):24-30. X-3, X-4.
1763 Hartley SL, Seltzer MM, Raspa M, et al. Exploring the adult life of men and women with fragile X syndrome: results from a national survey. Am J Intellect Dev Disabil. Jan. 2011;116(1):16-35. X-1, X-3, X-4. [pmid: 21291308].
1764 Hartley SL, Sikora DM. Sex differences in autism spectrum disorder: an examination of developmental functioning, autistic symptoms, and coexisting behavior problems in toddlers. J Autism Dev Disord. 2009;39(12):1715-22. X-1, X-3, X-4. [pmid: 19582563].
1765 Hartshorn K, Olds L, Field T, et al. Creative movement therapy benefits children with autism. Early Child Dev Care. 2001;166:1-5. X-1, X-3, X-4.
1766 Hartshorne TS, Cypher AD. Challenging behavior in CHARGE syndrome. Mental Health Asp Dev Disab. 2004;7(2):41-52. X-1, X-3, X-4.
1767 Hartshorne TS, Herr MD. An Adlerian approach to autism. Individ Psychol. Dec. 1983;39(4):394-401. X-1, X-3, X-4.
1768 Hartshorne TS, Heussler HS, Dailor AN, et al. Sleep disturbances in CHARGE syndrome: types and relationships with behavior and caregiver well-being. Dev Med Child Neurol. Feb. 2009;51(2):143-50. X-1, X-3, X-4. [pmid: 19018833].
1769 Hartshorne TS, Nicholas J, Grialou TL, et al. Executive function in CHARGE syndrome. Child Neuropsychol. Jul. 2007;13(4):333-44. X-1, X-3, X-4. [pmid: 17564850].
1770 Harvey RJ, Cooray SE. The effective treatment of severe repetitive behaviour with fluvoxamine in a 20 year old autistic female. Int Clin Psychopharmacol. Sep. 1995;10(3):201-3. X-1. [pmid: 8675975].
1771 Hasselbusch A, Penman M. Working together: an occupational therapy perspective on collaborative consultation. Kairaranga. 2008;9(1):24-31. X-1, X-3, X-4.
1772 Hastings RP. Behavioral adjustment of siblings of children with autism engaged in applied behavior analysis early intervention programs: the moderating role of social support. J Autism Dev Disord. Apr. 2003;33(2):141-50. X-1, X-3, X-4. [pmid: 12757353].
1773 Hastings RP, Brown T. Behavioural knowledge, causal beliefs and self-efficacy as predictors of special educators' emotional reactions to challenging behaviours. J Intellect Disabil Res. Feb. 2002;46(2):144-50. X-1, X-3, X-4. [pmid: 11869385].
1774 Hastings RP, Johnson E. Stress in UK families conducting intensive home-based behavioral intervention for their young child with autism. J Autism Dev Disord. Jun. 2001;31(3):327-36. X-1, X-3, X-4. [pmid: 11518485].
1775 Hastings RP, Symes MD. Early intensive behavioral intervention for children with autism: parental therapeutic self-efficacy. Res Dev Disabil. Sep–Oct. 2002;23(5):332-41. X-1, X-3, X-4. [pmid: 12401484].
1776 Hatton C, Emerson E, Robertson J, et al. The Resident Choice Scale: a measure to assess opportunities for self-determination in residential settings. J Intellect Disabil Res. Feb. 2004;48(Pt 2):103-13. X-4. [pmid: 14723653].
1777 Hatton DD, Wheeler AC, Skinner ML, et al. Adaptive behavior in children with fragile X syndrome. Am J Ment Retard. Nov. 2003;108(6):373-90. X-4. [pmid: 14561110].
1778 Haugaard JJ. Recognizing and treating rare behavioral and emotional disorders in children and adolescents who have been severely maltreated: schizophrenia. Child Maltreat. May. 2004;9(2):161-8. X-2, X-4. [pmid: 15104885].
1779 Hausman N, Kahng S, Farrell E, et al. Idiosyncratic functions: severe problem behavior maintained by access to ritualistic behaviors. Educ Treat Children. Feb. 2009;32(1):77-87. X-1, X-3, X-4.
1780 Hawkins AH. Influencing leisure choices of autisticlike children. J Autism Dev Disord. Dec. 1982;12(4):359-66. X-3. [pmid: 7161237].
1781 Hay I, Winn S. Students with Asperger's syndrome in an inclusive secondary school environment: teachers', parents', and students' perspectives. Australas J Spec Educ. 2005;29(2):140-54. X-3, X-4.
1782 Hayashi E. Effect of melatonin on sleep-wake rhythm: the sleep diary of an autistic male. Psychiatry Clin Neurosci. Jun. 2000;54(3):383. X-3. [pmid: 11186124].
1783 Hayes S, McGuire B, O'Neill M, et al. Low mood and challenging behaviour in people with severe and profound intellectual disabilities. J Intellect Disabil Res. Feb. 2011;55(2):182-9. X-4. [pmid: 21129068].
1784 Hayward D, Eikeseth S, Gale C, et al. Assessing progress during treatment for young children with autism receiving intensive behavioural interventions. Autism. Nov. 2009;13(6):613-33. [pmid: 19933766]. X-1, X-3, X-4.
1785 Hazell PL, Tarren-Sweeney M, Vimpani GV, et al. Children with disruptive behaviours I: service utilization. J Paediatr Child Health. Feb. 2002;38(1):27-31. X-4. [pmid: 11869397].
1786 Hazell PL, Tarren-Sweeney M, Vimpani GV, et al. Children with disruptive behaviours II: clinical and community service needs. J Paediatr Child Health. Feb. 2002;38(1):32-40. X-4. [pmid: 11869398].
1787 Head-Dylla C. How can i learn with all this commotion?. J Cases Educ Leadersh. 2009;12(3):33-51. X-1, X-2, X-3, X-4.
1788 Healey JJ, Ahearn WH, Graff RB, et al. Extended analysis and treatment of self-injurious behavior. Behav Interv. Jul–Sep. 2001;16(3):181-95. X-3.
1789 Heaton P, Allen R, Williams K, et al. Do social and cognitive deficits curtail musical understanding? Evidence from autism and Down syndrome. Br J Dev Psychol. 2008;26(Part 2):171-82. X-4.
1790 Hedbring C, Newsom C. Visual overselectivity: a comparison of two instructional remediation procedures with autistic children. J Autism Dev Disord. Mar. 1985;15(1):9-22. X-1, X-3, X-4. [pmid: 3980432].
1791 Hedenbro M, Tjus T. A case study of parent-child interactions of a child with autistic spectrum disorder 3–48 months) and comparison with typically-developing peers. Child Lang Teach Ther. 2007;23(2):201-22. X-1, X-3, X-4.
1792 Hediger ML, England LJ, Molloy CA, et al. Reduced bone cortical thickness in boys with autism or autism spectrum disorder. J Autism Dev Disord. May. 2008;38(5):848-56. X-1, X-3, X-4. [pmid: 17879151].
1793 Heidgerken AD, Geffken G, Modi A, et al. A survey of autism knowledge in a health care setting. J Autism Dev Disord. Jun. 2005;35(3):323-30. X-4. [pmid: 16119473].
1794 Heikkinen J, Jansson-Verkasalo E, Toivanen J, et al. Perception of basic emotions from speech prosody in adolescents with Asperger's syndrome. Logoped Phoniatr Vocol. 2010;35(3):113-20. X-3, X-4. [pmid: 19883170].
1795 Heilbrun AB Jr, Blum N, Goldreyer N. Defensive projection. An investigation of its role in paranoid conditions. J Nerv Ment Dis. Jan. 1985;173(1):17-25. X-1, X-3, X-4. [pmid: 3965607].
1796 Heiman T, Berger O. Parents of children with Asperger syndrome or with learning disabilities: family environment and social support. Res Dev Disabil. Jul–Aug. 2008;29(4):289-300. X-4. [pmid: 17604952].
1797 Heimann M, Laberg KE, Nordøen B. Imitative interaction increases social interest and elicited imitation in non-verbal children with autism. Infant Child Dev. Special Issue: Imitation and Socio-Emotional Processes: Implications for Communicative Development and Interventions. May–Jun. 2006;15(3):297-309. X-1, X-3, X-4.
1798 Heimann M, Nelson KE, Tjus T, et al. Increasing reading and communication skills in children with autism through an interactive multimedia computer program. J Autism Dev Disord. Oct. 1995;25(5):459-80. X-1, X-3, X-4. [pmid: 8567593].
1799 Heinrich H, Gevensleben H, Strehl U. Annotation: neurofeedback - train your brain to train behaviour. J Child Psychol Psychiatry. Jan. 2007;48(1):3-16. X-4. [pmid: 17244266].
1800 Held MF, Thoma CA, Thomas K. "The John Jones Show": how one teacher facilitated self-determined transition planning for a young man with autism. Focus Autism Dev Disabil. Fal. 2004;19(3):177-88. X-3.
1801 Hellemans H, Colson K, Verbraeken C, et al. Sexual behavior in high-functioning male adolescents and young adults with autism spectrum disorder. J Autism Dev Disord. Feb. 2007;37(2):260-9. X-4. [pmid: 16868848].
1802 Hellemans H, Roeyers H, Leplae W, et al. Sexual behavior in male adolescents and young adults with autism spectrum disorder and borderline/mild mental retardation. Sex Disabil. 2010;28(2):93-104. X-4.
1803 Hellings JA, Boehm D, Yeh HW, et al. Long-term aripiprazole in youth with developmental disabilities including autism. J Ment Health Res Intellect Disabil. 2011;4(1):40-52. X-3.
1804 Hellings JA, Cardona AM, Schroeder SR. Long-term safety and adverse events of risperidone in children, adolescents, and adults with pervasive developmental disorders. J Ment Health Res Intellect Disabil. Jul. 2010;3(3):132-44. X-3.
1805 Hellings JA, Kelley LA, Gabrielli WF, et al. Sertraline response in adults with mental retardation and autistic disorder. J Clin Psychiatry. Aug. 1996;57(8):333-6. X-3. [pmid: 8778118].
1806 Hellings JA, Nickel EJ, Weckbaugh M, et al. The overt aggression scale for rating aggression in outpatient youth with autistic disorder: preliminary findings. J Neuropsychiatry Clin Neurosci. Winter. 2005;17(1):29-35. X-3, X-4. [pmid: 15746480].
1807 Hellings JA, Weckbaugh M, Nickel EJ, et al. A double-blind, placebo-controlled study of valproate for aggression in youth with pervasive developmental disorders. J Child Adolesc Psychopharmacol. Aug. 2005;15(4):682-92. X-1. [pmid: 16190799].
1808 Hellings JA, Zarcone JR, Crandall K, et al. Weight gain in a controlled study of risperidone in children, adolescents and adults with mental retardation and autism. J Child Adolesc Psychopharmacol. Fall. 2001;11(3):229-38. X-3. [pmid: 11642473].
1809 Hellings JA, Zarcone JR, Valdovinos MG, et al. Risperidone-induced prolactin elevation in a prospective study of children, adolescents, and adults with mental retardation and pervasive developmental disorders. J Child Adolesc Psychopharmacol. Dec. 2005;15(6):885-92. X-1, X-3, X-4. [pmid: 16379508].
1810 Helverschou SB, Bakken TL, Martinsen H. Identifying symptoms of psychiatric disorders in people with autism and intellectual disability: an empirical conceptual analysis. Mental Health Asp Dev Disab. 2008;11(4):105-15. X-1, X-3, X-4.
1811 Hendren RL, Hodde-Vargas JE, Vargas LA, et al. Magnetic resonance imaging of severely disturbed children--a preliminary study. J Am Acad Child Adolesc Psychiatry. May. 1991;30(3):466-70. X-4. [pmid: 2055885].
1812 Hendricks DR, Wehman P. Transition from school to adulthood for youth with autism spectrum disorders: review and recommendations. Focus Autism Dev Disabil. 2009;24(2):77-88. X-1, X-2, X-3.
1813 Hendy HM, Williams KE, Riegel K, et al. Parent mealtime actions that mediate associations between children's fussy-eating and their weight and diet. Appetite. Feb. 2010;54(1):191-5. X-4. [pmid: 19887094].
1814 Henley D. Emotional handicaps in low-functioning children: art educational/art therapeutic interventions. Arts Psychother. Spr. 1986;13(1):35-44. X-3.
1815 Henley D. Naming the enemy: an art therapy intervention for children with bipolar and comorbid disorders. Art Therapy. 2007;24(3):104-10. X-1, X-3, X-4.
1816 Hennessy MJ, Haas RH. The orthopedic management of Rett syndrome. J Child Neurol. Suppl. 1988;3:S43-7. X-1, X-3, X-4. [pmid: 3198902].
1817 Henning OJ, Nakken KO. Psychiatric comorbidity and use of psychotropic drugs in epilepsy patients. Acta Neurol Scand Suppl. 2010;(190):18-22. X-1, X-3, X-4. [pmid: 20586730].
1818 Henry CA, Shervin D, Neumeyer A, et al. Retrial of selective serotonin reuptake inhibitors in children with pervasive developmental disorders: a retrospective chart review. J Child Adolesc Psychopharmacol. Apr. 2009;19(2):111-7. X-1, X-3, X-4. [pmid: 19364289].
1819 Henry CA, Steingard R, Venter J, et al. Treatment outcome and outcome associations in children with pervasive developmental disorders treated with selective serotonin reuptake inhibitors: a chart review. J Child Adolesc Psychopharmacol. Feb–Apr. 2006;16(1–2):187-95. X-1, X-3, X-4. [pmid: 16553539].
1820 Hepburn SL, MacLean WE. Maladaptive and repetitive behaviors in children with down syndrome and autism spectrum disorders: implications for screening. J Ment Health Res Intellect Disabil. 2009;2(2):67-88. X-4.
1821 Herbert M. Martha Herbert, MD: transcending the gaps in autism research. Interview by Frank Lampe and Suzanne Snyder. Altern Ther Health Med. Nov–Dec. 2007;13(6):62-73. X-2. [pmid: 17985813].
1822 Herbrecht E, Poustka F, Birnkammer S, et al. Pilot evaluation of the Frankfurt Social Skills Training for children and adolescents with autism spectrum disorder. Eur Child Adolesc Psychiatry. Jun. 2009;18(6):327-35. X-3. [pmid: 19165532].
1823 Herman BH, Asleson GS, Powell A, et al. Cardiovascular and other physical effects of acute administration of naltrexone in autistic children. J Child Adolesc Psychopharmacol. Fal. 1993;3(3):157-68. X-1, X-3, X-4. [pmid: 19630675].
1824 Herman BH, Hammock MK, Arthur-Smith A, et al. Effects of acute administration of naltrexone on cardiovascular function, body temperature, body weight and serum concentrations of liver enzymes in autistic children. Dev Pharmacol Ther. 1989;12(3):118-27. X-1, X-3, X-4. [pmid: 2721334].
1825 Hernandez P, Ikkanda Z. Applied behavior analysis: behavior management of children with autism spectrum disorders in dental environments. J Am Dent Assoc. Mar. 2011;142(3):281-7. X-1, X-2, X-3, X-4. [pmid: 21357862].
1826 Herndon AC, DiGuiseppi C, Johnson SL, et al. Does nutritional intake differ between children with autism spectrum disorders and children with typical development?. J Autism Dev Disord. Feb. 2009;39(2):212-22. X-4. [pmid: 18600441].
1827 Herrera G, Alcantud F, Jordan R, et al. Development of symbolic play through the use of virtual reality tools in children with autistic spectrum disorders: two case studies. Autism. 2008;12(2):143-57. X-3. [pmid: 18308764].
1828 Herring S, Gray K, Taffe J, et al. Behaviour and emotional problems in toddlers with pervasive developmental disorders and developmental delay: associations with parental mental health and family functioning. J Intellect Disabil Res. Dec. 2006;50(12):874-82. X-4. [pmid: 17100948].
1829 Hertzman M. Galantamine in the treatment of adult autism: a report of three clinical cases. Int J Psychiatry Med. 2003;33(4):395-8. X-4. [pmid: 15152789].
1830 Hess J, Matson J, Neal D, et al. A comparison of psychotropic drug side effect profiles in adults diagnosed with intellectual disabilities and autism spectrum disorders. J Ment Health Res Intellect Disabil. 2010;3(2):85-96. X-1.
1831 Hess K. Keep the change: a hard-earned success. Young Child. Jul. 2003;58(4):30-2. X-1, X-2, X-3, X-4.
1832 Hess KL, Morrier MJ, Heflin LJ, et al. Autism treatment survey: services received by children with autism spectrum disorders in public school classrooms. J Autism Dev Disord. May. 2008;38(5):961-71. X-1, X-3, X-4. [pmid: 17929155].
1833 Hess L. I would like to play but i don't know how: a case study of pretend play in autism. Child Lang Teach Ther. 2006;22(1):97-116. X-1, X-3, X-4.
1834 Hetherington SA, Durant-Jones L, Johnson K, et al. The lived experiences of adolescents with disabilities and their parents in transition planning. Focus Autism Dev Disabil. Sep. 2010;25(3):163-72. X-3, X-4.
1835 Hetzroni OE, Tannous J. Effects of a computer-based intervention program on the communicative functions of children with autism. J Autism Dev Disord. Apr. 2004;34(2):95-113. X-3. [pmid: 15162930].
1836 Hewitt LE. A social interactionist view of autism and its clinical management. J Commun Disord. Mar–Apr. 1998;31(2):87-92. X-1, X-2, X-3, X-4. [pmid: 9549668].
1837 Hickling EJ, Blanchard EB, Kuhn E. Brief, early treatment for ASD/PTSD following motor vehicle accidents. Cogn Behav Pract. Aut. 2005;12(4):461-7. X-4.
1838 Higbee TS, Carr JE, Patel MR. The effects of interpolated reinforcement on resistance to extinction in children diagnosed with autism: a preliminary investigation. Res Dev Disabil. Jan–Feb. 2002;23(1):61-78. X-1, X-3, X-4. [pmid: 12071396].
1839 Higgins DJ, Bailey SR, Pearce JC. Factors associated with functioning style and coping strategies of families with a child with an autism spectrum disorder. Autism. May. 2005;9(2):125-37. X-1, X-3, X-4. [pmid: 15857858].
1840 Higgins KK, Koch LC, Boughfman EM, et al. School-to-work transition and Asperger Syndrome. Work. 2008;31(3):291-8. X-2. [pmid: 19029670].
1841 Hill BK, Balow EA, Bruininks RH. A national study of prescribed drugs in institutions and community residential facilities for mentally retarded people. Psychopharmacol Bull. 1985;21(2):279-84. X-1, X-3, X-4. [pmid: 4001292].
1842 Hill DA, Martin ED Jr, Nelson-Head C. Examination of case law 2007–2008 regarding autism spectrum disorder and violations of the Individuals with Disabilities Education Act. Prev School Failure. 2011;55(4):214-25. X-1, X-2, X-3, X-4.
1843 Hillier A, Campbell H, Keillor J, et al. Decreased false memory for visually presented shapes and symbols among adults on the autism spectrum. J Clin Exp Neuropsychol. Aug. 2007;29(6):610-6. X-4. [pmid: 17691033].
1844 Hillier A, Campbell H, Mastriani K, et al. Two-year evaluation of a vocational support program for adults on the autism spectrum. Career Dev Except Individuals. Spr. 2007;30(1):35-47. X-3.
1845 Hillier A, Fish T, Cloppert P, et al. Outcomes of a social and vocational skills support group for adolescents and young adults on the autism spectrum. Focus Autism Dev Disabil. Sum. 2007;22(2):107-15. X-3.
1846 Hillock AR, Powers AR, Wallace MT. Binding of sights and sounds: age-related changes in multisensory temporal processing. Neuropsychologia. Feb. 2011;49(3):461-7. X-1, X-3, X-4. [pmid: 21134385].
1847 Hilton JC, Seal BC. Brief report: comparative ABA and DIR trials in twin brothers with autism. J Autism Dev Disord. Jul. 2007;37(6):1197-201. X-3. [pmid: 17072747].
1848 Hilton S, Hunt K, Langan M, et al. Reporting of MMR evidence in professional publications: 1988–2007. Arch Dis Child. Nov. 2009;94(11):831-3. X-2, X-4. [pmid: 19414434].
1849 Hilton S, Hunt K, Petticrew M. MMR: marginalised, misrepresented and rejected? Autism: a focus group study. Arch Dis Child. Apr. 2007;92(4):322-7. X-4. [pmid: 17376937].
1850 Hintzen A, Delespaul P, van Os J, et al. Social needs in daily life in adults with Pervasive Developmental Disorders. Psychiatry Res. Aug. 30. 2010;179(1):75-80. X-3, X-4. [pmid: 20638732].
1851 Hirose M, Kijima R, Shirakawa K, et al. Development of a virtual sand box: an application of virtual environment for psychological treatment. Stud Health Technol Inform. 1997;44:113-20. X-2, X-4. [pmid: 10184810].
1852 Hirsch N, Myles BS. The use of a pica box in reducing pica behavior in a student with autism. Focus Autism Dev Disabil. Win. 1996;11(4):222-5. 34. X-1, X-3, X-4.
1853 Hittner JB. Case study: the combined use of imipramine and behavior modification to reduce aggression in an adult male diagnosed as having autistic disorder. Behav Interv. Apr. 1994;9(2):123-39. X-3.
1854 Ho HH, Lockitch G, Eaves L, et al. Blood serotonin concentrations and fenfluramine therapy in autistic children. J Pediatr. Mar. 1986;108(3):465-9. X-1, X-3. [pmid: 2936877].
1855 Ho HH, Miller A, Armstrong RW. Parent-professional agreement on diagnosis and recommendations for children with developmental disorders. Child Health Care. Spring. 1994;23(2):137-48. X-1, X-3, X-4. [pmid: 10146014].
1856 Hobson RP. Explaining autism: ten reasons to focus on the developing self. Autism. Sep. 2010;14(5):391-407. X-1, X-2, X-3, X-4. [pmid: 20926456].
1857 Hodgetts S, Magill-Evans J, Misiaszek JE. Weighted vests, stereotyped behaviors and arousal in children with autism. J Autism Dev Disord. Jun. 2011;41(6):805-14. X-3. [pmid: 20839040].
1858 Hoekstra PJ, Troost PW, Lahuis BE, et al. Risperidone-induced weight gain in referred children with autism spectrum disorders is associated with a common polymorphism in the 5-hydroxytryptamine 2C receptor gene. J Child Adolesc Psychopharmacol. Dec. 2010;20(6):473-7. X-3, X-4. [pmid: 21186965].
1859 Hoffman CD, Sweeney DP, Gilliam JE, et al. Sleep problems and symptomology in children with autism. Focus Autism Dev Disabil. Win. 2005;20(4):194-200. X-1, X-3, X-4.
1860 Hoffman CD, Sweeney DP, Hodge D, et al. Parenting stress and closeness: mothers of typically developing children and mothers of children with autism. Focus Autism Dev Disabil. 2009;24(3):178-87. X-4.
1861 Hofvander B, Delorme R, Chaste P, et al. Psychiatric and psychosocial problems in adults with normal-intelligence autism spectrum disorders. BMC Psychiatry. 2009;9:35. X-4. [pmid: 19515234].
1862 Hoksbergen R, ter Laak J, Rijk K, et al. Post-institutional autistic syndrome in Romanian adoptees. J Autism Dev Disord. Oct. 2005;35(5):615-23. X-4. [pmid: 16167089].
1863 Holburn CS. Counter the mistreatments for autism with professional integrity. Intellect Dev Disabil. Apr. 2007;45(2):136-7. X-2, X-4. [pmid: 17428138].
1864 Holck U. Interaction themes in music therapy: definition and delimitation. Nord J Music Ther. 2004;13(1):3-19. X-2, X-4.
1865 Holcomb MJ, Pufpaff LA, McIntosh DE. Obesity rates in special populations of children and potential interventions. Psychol Sch. Sep. 2009;46(8):797-804. X-2.
1866 Holding E, Bray MA, Kehle TJ. Does speed matter? A comparison of the effectiveness of fluency and discrete trial training for teaching noun labels to children with autism. Psychol Sch. Feb. 2011;48(2):166-83. X-1, X-3, X-4.
1867 Holifield C, Goodman J, Hazelkorn M, et al. Using self-monitoring to increase attending to task and academic accuracy in children with autism. Focus Autism Dev Disabil. Dec. 2010;25(4):230-8. X-1, X-3, X-4.
1868 Holland CD. Autism, insurance, and the idea: providing a comprehensive legal framework. Cornell Law Rev. Sep. 2010;95(6):1253-82. X-1, X-2, X-3, X-4. [pmid: 20939148].
1869 Hollander A, Hebborn-Brass U. Termination of long term treatment in a residential home: quotas, conditions and additional comments. Acta Paedopsychiatr. 1989;52(4):243-53. X-1, X-3, X-4. [pmid: 2518648].
1870 Hollander E, Bartz J, Chaplin W, et al. Oxytocin increases retention of social cognition in autism. Biol Psychiatry. Feb. 15. 2007;61(4):498-503. X-3. [pmid: 16904652].
1871 Hollander E, Chaplin W, Soorya L, et al. Divalproex sodium vs placebo for the treatment of irritability in children and adolescents with autism spectrum disorders. Neuropsychopharmacology. Mar. 2010;35(4):990-8. X-1, X-3, X-4. [pmid: 20010551].
1872 Hollander E, Dolgoff-Kaspar R, Cartwright C, et al. An open trial of divalproex sodium in autism spectrum disorders. J Clin Psychiatry. Jul. 2001;62(7):530-4. X-3. [pmid: 11488363].
1873 Hollander E, Kaplan A, Cartwright C, et al. Venlafaxine in children, adolescents, and young adults with autism spectrum disorders: an open retrospective clinical report. J Child Neurol. Feb. 2000;15(2):132-5. X-3. [pmid: 10695900].
1874 Hollander E, Novotny S, Allen A, et al. The relationship between repetitive behaviors and growth hormone response to sumatriptan challenge in adult autistic disorder. Neuropsychopharmacology. Feb. 2000;22(2):163-7. X-3. [pmid: 10649829].
1875 Hollander E, Novotny S, Hanratty M, et al. Oxytocin infusion reduces repetitive behaviors in adults with autistic and Asperger's disorders. Neuropsychopharmacology. Jan. 2003;28(1):193-8. X-1, X-3. [pmid: 12496956].
1876 Hollander E, Phillips A, Chaplin W, et al. A placebo controlled crossover trial of liquid fluoxetine on repetitive behaviors in childhood and adolescent autism. Neuropsychopharmacology. Mar. 2005;30(3):582-9. X-1, X-3, X-4. [pmid: 15602505].
1877 Hollander E, Soorya L, Wasserman S, et al. Divalproex sodium vs. placebo in the treatment of repetitive behaviours in autism spectrum disorder. Int J Neuropsychopharmacol. Apr. 2006;9(2):209-13. X-1, X-3. [pmid: 16316486].
1878 Hollander E, Wasserman S, Swanson EN, et al. A double-blind placebo-controlled pilot study of olanzapine in childhood/adolescent pervasive developmental disorder. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):541-8. X-1, X-3, X-4. [pmid: 17069543].
1879 Hollenweger J. MHADIE's matrix to analyse the functioning of education systems. Disabil Rehabil. Suppl 1. 2010;32:S116-24. X-1, X-2, X-3, X-4. [pmid: 20874661].
1880 Holmes DL. Community-based services for children and adults with autism: the Eden Family of Programs. J Autism Dev Disord. Sep. 1990;20(3):339-51. X-2. [pmid: 2228916].
1881 Holmes E, Willoughby T. Play behaviour of children with autism spectrum disorders. J Intellect Dev Disabil. 2005;30(3):156-64. X-1, X-3, X-4.
1882 Holmes N, Carr J. The pattern of care in families of adults with a mental handicap: a comparison between families of autistic adults and Down syndrome adults. J Autism Dev Disord. Jun. 1991;21(2):159-76. X-2, X-3. [pmid: 1830876].
1883 Holmes N, Hemsley R, Rickett J, et al. Parents as cotherapists: their perceptions of a home-based behavioral treatment for autistic children. J Autism Dev Disord. Dec. 1982;12(4):331-42. X-1, X-3, X-4. [pmid: 7161235].
1884 Holmstrom C. Autism. Can J Psychiatr Nurs. Jul–Sep. 1989;30(3):6-8. X-1, X-2, X-3, X-4. [pmid: 2766115].
1885 Holtmann M, Steiner S, Hohmann S, et al. Neurofeedback in autism spectrum disorders. Dev Med Child Neurol. Nov. 2011;53(11):986-93. X-1, X-2, X-3, X-4. [pmid: 21752020].
1886 Holttum JR, Lubetsky MJ, Eastman LE. Comprehensive management of trichotillomania in a young autistic girl. J Am Acad Child Adolesc Psychiatry. May. 1994;33(4):577-81. X-1, X-2, X-3, X-4. [pmid: 8005911].
1887 Holzer L, Mihailescu R, Rodrigues-Degaeff C, et al. Community introduction of practice parameters for autistic spectrum disorders: advancing early recognition. J Autism Dev Disord. Feb. 2006;36(2):249-62. X-4. [pmid: 16447011].
1888 Honda H, Shimizu Y. Early intervention system for preschool children with autism in the community: the DISCOVERY approach in Yokohama, Japan. Autism. Sep. 2002;6(3):239-57. X-2, X-4. [pmid: 12212916].
1889 Honda H, Shimizu Y, Imai M, et al. Cumulative incidence of childhood autism: a total population study of better accuracy and precision. Dev Med Child Neurol. Jan. 2005;47(1):10-8. X-4. [pmid: 15686284].
1890 Honda H, Shimizu Y, Nitto Y, et al. Extraction and Refinement Strategy for detection of autism in 18-month-olds: a guarantee of higher sensitivity and specificity in the process of mass screening. J Child Psychol Psychiatry. Aug. 2009;50(8):972-81. X-4. [pmid: 19298465].
1891 Honda H, Shimizu Y, Rutter M. No effect of MMR withdrawal on the incidence of autism: a total population study. J Child Psychol Psychiatry. Jun. 2005;46(6):572-9. X-4. [pmid: 15877763].
1892 Honey E, McConachie H, Randle V, et al. One-year change in repetitive behaviours in young children with communication disorders including autism. J Autism Dev Disord. Sep. 2008;38(8):1439-50. X-1, X-2, X-3, X-4. [pmid: 16900401].
1893 Honeycutt N, Belcher JR. Schizophrenia and social skills: an 'identify and train' approach. Community Ment Health J. Feb. 1991;27(1):57-68. X-2, X-4. [pmid: 2019099].
1894 Hong WC, Ping LCW. The relationship of language function of adults with autism to the speech of their mothers. Br J Dev Disabil. 2001;47(part 2(93)):73-85. X-4.
1895 Honig AS, McCarron PA. Prosocial behaviors of handicapped and typical peers in an integrated preschool. Early Child Dev Care. Special Issue: Optimizing early child care and education. 1988;33(1–4):113-25. X-1, X-3, X-4.
1896 Honomichl RD, Goodlin-Jones BL, Burnham MM, et al. Secretin and sleep in children with autism. Child Psychiatry Hum Dev. Winter. 2002;33(2):107-23. X-1, X-3, X-4. [pmid: 12462350].
1897 Hopkins IM, Gower MW, Perez TA, et al. Avatar assistant: improving social skills in students with an asd through a computer-based intervention. J Autism Dev Disord. 2011. Feb. 2. X-1. [pmid: 21287255].
1898 Hopkins IM, Gower MW, Perez TA, et al. Avatar assistant: improving social skills in students with an asd through a computer-based intervention. J Autism Dev Disord. Nov. 2011;41(11):1543-55. X-1, X-3. [pmid: 21287255].
1899 Horner RH. Positive behavior supports. Focus Autism Dev Disabil. Sum. 2000;15(2):97-105. X-2.
1900 Horner RH, Budd CM. Acquisition of manual sign use: collateral reduction of maladaptive behavior, and factors limiting generalization. Educ Train Ment Retard. Mar. 1985;20(1):39-47. X-1, X-3, X-4.
1901 Horner RH, Carr EG, Halle J, et al. The use of single-subject research to identify evidence-based practice in special education. Except Child. Win. 2005;71(2):165-79. X-1, X-2, X-3, X-4.
1902 Horner RH, Carr EG, Strain PS, et al. Problem behavior interventions for young children with autism: a research synthesis. J Autism Dev Disord. Oct. 2002;32(5):423-46. X-2, X-4. [pmid: 12463518].
1903 Horowitz LT. Early intervention in autism 0–3/South Carolina services and how to access them. J S C Med Assoc. Oct. 2006;102(8):282-4. X-2. [pmid: 17319245].
1904 Horrigan JP, Barnhill LJ. More on melatonin. J Am Acad Child Adolesc Psychiatry. Aug. 1997;36(8):1014. X-3. [pmid: 9256575].
1905 Horrigan JP, Barnhill LJ. Risperidone and explosive aggressive autism. J Autism Dev Disord. Jun. 1997;27(3):313-23. X-3. [pmid: 9229261].
1906 Horrocks JL, White G, Roberts L. Principals' attitudes regarding inclusion of children with autism in Pennsylvania public schools. J Autism Dev Disord. Sep. 2008;38(8):1462-73. X-1, X-4. [pmid: 18256916].
1907 Hoshino Y, Kaneko M, Yashima Y, et al. Self-mutilative behavior and its treatment in autistic children. Fukushima J Med Sci. Jul. 1983;29(3–4):133-40. X-1, X-3, X-4. [pmid: 6678779].
1908 Hoshino Y, Kumashiro H, Yashima Y, et al. Early symptoms of autistic children and its diagnostic significance. Folia Psychiatr Neurol Jpn. 1982;36(4):367-74. X-4. [pmid: 7169196].
1909 Hoshino Y, Murata S, Endo M, et al. A consideration of the effectiveness of a training camp for autistic children--by means of the new check-list method. Fukushima J Med Sci. Jul. 1983;29(3–4):125-32. INCLUDE, X-1, X-3, X-4. [pmid: 6678778].
1910 Hoshino Y, Watanabe H, Yashima Y, et al. An investigation on sleep disturbance of autistic children. Folia Psychiatr Neurol Jpn. 1984;38(1):45-51. X-4. [pmid: 6537391].
1911 Houghton S, Douglas G, Brigg J, et al. An empirical evaluation of an interactive multi-sensory environment for children with disability. J Intellect Dev Disabil. Dec. 1998;23(4):267-78. X-3.
1912 Houlihan D, Jacobson L, Brandon PK. Replication of a high-probability request sequence with varied interprompt times in a preschool setting. J Appl Behav Anal. Special Issue: Integrating basic and applied research. Win. 1994;27(4):737-8. X-1, X-3, X-4. [pmid: 16795848].
1913 Hourigan R, Hourigan A. Teaching music to children with autism: understandings and perspectives. Music Educ J. 2009;96(1):40-5. X-2, X-4.
1914 Houzel D. Precipitation anxiety and the dawn of aesthetic feelings. J Child Psychother. 1989;15(2):103-14. X-1, X-3, X-4.
1915 Houzel D. The psychoanalysis of infantile autism. J Child Psychother. 2004;30(2):225-37. X-1, X-2, X-3, X-4.
1916 Howard JS, Sparkman CR, Cohen HG, et al. A comparison of intensive behavior analytic and eclectic treatments for young children with autism. Res Dev Disabil. Jul–Aug. 2005;26(4):359-83. X-1, X-2, X-3, X-4. [pmid: 15766629].
1917 Howell EJ, Pierson MR. Parents' perspectives on the participation of their children with autism in Sunday school. J Relig Disabil Health. 2010;14(2):153-66. X-3, X-4.
1918 Howlin P. The results of a home-based language training programme with autistic children. Br J Disord Commun. Sep. 1981;16(2):73-88. X-1, X-3, X-4. [pmid: 7326212].
1919 Howlin P. A brief report on the elimination of long term sleeping problems in a 6-yr-old autistic boy. Behav Psychother. Jul. 1984;12(3):257-60. X-1, X-3, X-4.
1920 Howlin P. Can early interventions alter the course of autism?. Novartis Found Symp. 2003;251:250-9. discussion 60–5, 81–97. X-2, X-4. [pmid: 14521197].
1921 Howlin P, Clements J. Is it possible to assess the impact of abuse on children with pervasive developmental disorders?. J Autism Dev Disord. Aug. 1995;25(4):337-54. X-4. [pmid: 7592248].
1922 Howlin P, Goode S, Hutton J, et al. Adult outcome for children with autism. J Child Psychol Psychiatry. Feb. 2004;45(2):212-29. X-4. [pmid: 14982237].
1923 Howlin P, Gordon RK, Pasco G, et al. The effectiveness of Picture Exchange Communication System (PECS) training for teachers of children with autism: a pragmatic, group randomised controlled trial. J Child Psychol Psychiatry. May. 2007;48(5):473-81. X-1, X-2, X-3, X-4. [pmid: 17501728].
1924 Howlin P, Magiati I, Charman T. Systematic review of early intensive behavioral interventions for children with autism. Am J Intellect Dev Disabil. Jan. 2009;114(1):23-41. X-1, X-2, X-3, X-4. [pmid: 19143460].
1925 Howlin P, Mawhood L, Rutter M. Autism and developmental receptive language disorder--a follow-up comparison in early adult life. II: social, behavioural, and psychiatric outcomes. J Child Psychol Psychiatry. Jul. 2000;41(5):561-78. X-4. [pmid: 10946749].
1926 Howlin P, Rutter M. Mothers' speech to autistic children: a preliminary causal analysis. J Child Psychol Psychiatry. Nov. 1989;30(6):819-43. X-1, X-3, X-4. [pmid: 2592467].
1927 Howlin P, Wing L, Gould J. The recognition of autism in children with Down syndrome: Implications for intervention and some speculations about pathology. Dev Med Child Neurol. May. 1995;37(5):406-13. X-1, X-2, X-3, X-4. [pmid: 7768340].
1928 Howlin P, Wing L, Gould J. The recognition of autism in children with Down syndrome: implications for intervention and some speculations about pathology. Annu Prog Child Psychiatr Child Dev. 1996:280-94. X-1, X-2, X-3, X-4.
1929 Howlin P, Yates P. The potential effectiveness of social skills groups for adults with autism. Autism. Sep. 1999;3(3):299-307. X-3.
1930 Howlin PA. The effectiveness of operant language training with autistic children. J Autism Dev Disord. Mar. 1981;11(1):89-105. X-1, X-3, X-4. [pmid: 6927701].
1931 Hoy JA, Hatton C, Hare D. Weak central coherence: a cross-domain phenomenon specific to autism?. Autism. Sep. 2004;8(3):267-81. X-4. [pmid: 15358870].
1932 Hubel M, Hagell P, Sivberg B. Brief report: development and initial testing of a questionnaire version of the Environmental Rating Scale (ERS) for assessment of residential programs for individuals with autism. J Autism Dev Disord. Jul. 2008;38(6):1178-83. X-1. [pmid: 17987373].
1933 Huemer SV, Mann V. A comprehensive profile of decoding and comprehension in autism spectrum disorders. J Autism Dev Disord. 2010;40(4):485-93. X-4.
1934 Hughes C, Soares-Boucaud I, Hochmann J, et al. Social behaviour in pervasive developmental disorders: effects of informant, group and "theory-of-mind". Eur Child Adolesc Psychiatry. Dec. 1997;6(4):191-8. X-4. [pmid: 9442997].
1935 Hughes DM, Cunningham MM, Libretto SE. Risperidone in children and adolescents with autistic disorder and aggressive behaviour. Br J Dev Disabil. Jul. 2002;48(95,Pt2):113-22. X-3.
1936 Hughes JR, Melyn M. EEG and seizures in autistic children and adolescents: further findings with therapeutic implications. Clin EEG Neurosci. Jan. 2005;36(1):15-20. X-4. [pmid: 15683193].
1937 Hughes V, Wolery MR, Neel RS. Teacher verbalizations and task performance with autistic children. J Autism Dev Disord. Sep. 1983;13(3):305-16. X-3. [pmid: 6643375].
1938 Hui KK, Marina O, Liu J, et al. Acupuncture, the limbic system, and the anticorrelated networks of the brain. Auton Neurosci. Oct. 28. 2010;157(1–2):81-90. X-1, X-2, X-3, X-4. [pmid: 20494627].
1939 Humble M, Bejerot S, Bergqvist PB, et al. Reactivity of serotonin in whole blood: relationship with drug response in obsessive-compulsive disorder. Biol Psychiatry. Feb. 15. 2001;49(4):360-8. X-4. [pmid: 11239907].
1940 Hume K, Bellini S, Pratt C. The usage and perceived outcomes of early intervention and early childhood programs for young children with autism spectrum disorder. Topics Early Child Spec Educ. Win. 2005;25(4):195-207. X-1, X-3, X-4.
1941 Hume K, Boyd B, McBee M, et al. Assessing implementation of comprehensive treatment models for young children with ASD: reliability and validity of two measures. Res Autism Spectr Disord. Oct–Dec. 2011;5(4):1430-40. X-1, X-2, X-3, X-4.
1942 Hume K, Loftin R, Lantz J. Increasing independence in autism spectrum disorders: a review of three focused interventions. J Autism Dev Disord. Sep. 2009;39(9):1329-38. X-2. [pmid: 19430897].
1943 Hume K, Odom S. Effects of an individual work system on the independent functioning of students with autism. J Autism Dev Disord. Jul. 2007;37(6):1166-80. X-1, X-4. [pmid: 17072746].
1944 Humphrey N, Lewis S. ‘Make me normal’: the views and experiences of pupils on the autistic spectrum in mainstream secondary schools. Autism. Jan. 2008;12(1):23-46. X-3, X-4. [pmid: 18178595].
1945 Humphrey N, Lewis S. What does 'inclusion' mean for pupils on the autistic spectrum in mainstream secondary schools?. J Res Spec Educ Needs. Oct. 2008;8(3):132-40. X-3, X-4.
1946 Humphrey N, Parkinson G. Research on interventions for children and young people on the autistic spectrum: a critical perspective. J Res Spec Educ Needs. May. 2006;6(2):76-86. X-1, X-2, X-3, X-4.
1947 Humphrey N, Symes W. Peer interaction patterns among adolescents with autistic spectrum disorders (ASDs) in mainstream school settings. Autism. Jul. 2011;15(4):397-419. X-4. [pmid: 21454385].
1948 Humphrey N, Symes W. Perceptions of social support and experience of bullying among pupils with autistic spectrum disorders in mainstream secondary schools. Eur J Spec Needs Educ. Feb. 2010;25(1):77-91. X-4.
1949 Humphrey N, Symes W. Responses to bullying and use of social support among pupils with autism spectrum disorders (asds) in mainstream schools: a qualitative study. J Res Spec Educ Needs. Jun. 2010;10(2):82-90. X-1, X-2, X-3, X-4.
1950 Hung DW. Training and generalization of yes and no as mands in two autistic children. J Autism Dev Disord. Jun. 1980;10(2):139-52. X-3. [pmid: 6927683].
1951 Hung DW, Rotman Z, Cosentino A, et al. Cost and effectiveness of an educational program for autistic children using a systems approach. Educ Treat Children. Win. 1983;6(1):47-68. X-1, X-3, X-4.
1952 Hunt A. A comparison of the abilities, health and behaviour of 23 people with tuberous sclerosis at Age 5 and as adults. J Appl Res Intellect Disabil. 1998;11(3):227-38. X-4.
1953 Hunt P, Goetz L. Teaching spontaneous communication in natural settings through interrupted behavior chains. Top Lang Disord. Dec. 1988;9(1):58-71. X-1, X-2, X-3, X-4.
1954 Hupp SDA, Reitman D. Parent-assisted modification of pivotal social skills for a child diagnosed with PDD: A clinical replication. J Posit Behav Interv. Sum. 2000;2(3):183-7. X-1, X-2, X-3, X-4.
1955 Hurlbutt K, Chalmers L. Employment and adults with Asperger syndrome. PRO-ED, Inc. 8700 Shoal Creek Boulevard, Austin, Texas 78757-6897. Tel: 800-897-3202 (Toll Free). 2004:215-22.
1956 Hurlbutt KS, Handler BR. High school students with Asperger syndrome: A Career Path Binder Project. Interv School Clinic. Sep. 2010;46(1):46-50. X-1, X-2, X-3, X-4.
1957 Hurley AD, Folstein M, Lam N. Patients with and without intellectual disability seeking outpatient psychiatric services: diagnoses and prescribing pattern. J Intellect Disabil Res. Jan. 2003;47(Pt 1):39-50. X-4. [pmid: 12558694].
1958 Hurth J, Shaw E, Izeman SG, et al. Areas of agreement about effective practices among programs serving young children with autism spectrum disorders. Infants Young Child. Oct. 1999;12(2):17-26. X-1, X-2, X-3, X-4.
1959 Hutman T, Rozga A, DeLaurentis AD, et al. Response to distress in infants at risk for autism: a prospective longitudinal study. J Child Psychol Psychiatry. Sep. 2010;51(9):1010-20. X-1, X-3, X-4. [pmid: 20546081].
1960 Hutton AM, Caron SL. Experiences of families with children with autism in rural New England. Focus Autism Dev Disabil. Fall. 2005;20(3):180-9. X-4.
1961 Huws JC P. Missing voices: representations of autism in British newspapers, 1999–2008. Brit J Learn Disab. 2011;39(2):98-104. X-1, X-3, X-4.
1962 Huws JC, Jones RSP. 'They just seem to live their lives in their own little world': lay perceptions of autism. Disabil Soc. 2010;25(3):331-44. X-1, X-3, X-4.
1963 Huynen KB, Lutzker JR, Bigelow KM, et al. Planned activities training for mothers of children with developmental disabilities. Community generalization and follow-up. Behav Modif. Oct. 1996;20(4):406-27. X-1, X-3, X-4. [pmid: 8875813].
1964 Hwang B, Hughes C. The effects of social interactive training on early social communication skills of children with autism. J Autism Dev Disord. Aug. 2000;30(4):331-43. X-1, X-2, X-3, X-4. [pmid: 11039859].
1965 Hwang SK, Charnley H. Making the familiar strange and making the strange familiar: understanding Korean children’s experiences of living with an autistic sibling. Disabil Soc. 2010;25(5):579-92. X-3, X-4.
1966 Hwang SS, Chang JS, Lee KY, et al. Causal model of insight and psychopathology based on the PANSS factors: 1-year cross-sectional and longitudinal revalidation. Int Clin Psychopharmacol. Jul. 2009;24(4):189-98. X-4. [pmid: 19521247].
1967 Hyman M. Standing at Sinai with autism: a young man’s bar mitzvah journey. J Posit Behav Interv. 2009;11(3):186-92. X-2.
1968 Hyman MH. The impact of mercury on human health and the environment. Altern Ther Health Med. Nov–Dec. 2004;10(6):70-5. X-2, X-4. [pmid: 15645598].
1969 Hyman SL, Levy SE. Introduction: novel therapies in developmental disabilities--hope, reason, and evidence. Ment Retard Dev Disabil Res Rev. 2005;11(2):107-9. X-2, X-4. [pmid: 15977317].
1970 Iancu I, Strous R, Poreh A, et al. Psychiatric inpatients’ reactions to the SARS epidemic: an Israeli survey. Isr J Psychiatry Relat Sci. 2005;42(4):258-62. X-4. [pmid: 16618059].
1971 Iarocci G, Rombough A, Yager J, et al. Visual influences on speech perception in children with autism. Autism. Jul. 2010;14(4):305-20. X-4. [pmid: 20591957].
1972 Igo M, French R, Kinnison L. From the field. Influence of modeling and selected reinforcement on improving cooperative play skills of children with autism. Clin Kinesiology. 1997;51(1):16-21. X-3, X-4.
1973 Ihrig K, Wolchik SA. Peer versus adult models and autistic children’s learning: acquisition, generalization, and maintenance. J Autism Dev Disord. Mar. 1988;18(1):67-79. X-3. [pmid: 3372460].
1974 Ijichi S, Ijichi N. Beyond negative data in autism randomized trials. Autism. Mar. 2004;8(1):111-2. X-2. [pmid: 15070551].
1975 Ijichi S, Ijichi N. Computerized lifelong mentoring support using robot for autistic individuals. Med Hypotheses. 2007;68(3):493-8. X-2, X-4. [pmid: 17023117].
1976 Infantino J, Hempenstall K. Effects of a decoding program on a child with autism spectrum disorder. Australas J Spec Educ. 2006;30(2):126-44. X-2, X-3.
1977 Ingenmey R, Van Houten R. Using time delay to promote spontaneous speech in an autistic child. J Appl Behav Anal. Fal. 1991;24(3):591-6. X-1, X-2, X-3, X-4. [pmid: 1752846].
1978 Ingersoll B. Pilot randomized controlled trial of Reciprocal Imitation Training for teaching elicited and spontaneous imitation to children with autism. J Autism Dev Disord. Sep. 2010;40(9):1154-60. X-1, X-3, X-4. [pmid: 20155309].
1979 Ingersoll B. The differential effect of three naturalistic language interventions on language use in children with autism. J Posit Behav Interv. Apr. 2011;13(2):109-18. X-1, X-2, X-3, X-4.
1980 Ingersoll B, Dvortcsak A. Including parent training in the early childhood special education curriculum for children with autism spectrum disorders. Topics Early Child Spec Educ. Fall. 2006;26(3):179-87. X-1, X-2, X-3, X-4.
1981 Ingersoll B, Dvortcsak A, Whalen C, et al. The effects of a developmental, social-pragmatic language intervention on rate of expressive language production in young children with autistic spectrum disorders. Focus Autism Dev Disabil. Win. 2005;20(4):213-22. X-1.
1982 Ingersoll B, Gergans S. The effect of a parent-implemented imitation intervention on spontaneous imitation skills in young children with autism. Res Dev Disabil. Mar–Apr. 2007;28(2):163-75. X-1, X-3. [pmid: 16603337].
1983 Ingersoll B, Lalonde K. The impact of object and gesture imitation training on language use in children with autism spectrum disorder. J Speech Lang Hear Res. Aug. 2010;53(4):1040-51. X-3, X-4. [pmid: 20631228].
1984 Ingersoll B, Lewis E, Kroman E. Teaching the imitation and spontaneous use of descriptive gestures in young children with autism using a naturalistic behavioral intervention. J Autism Dev Disord. Sep. 2007;37(8):1446-56. X-1, X-3. [pmid: 17033930].
1985 Ingersoll B, Schreibman L. Teaching reciprocal imitation skills to young children with autism using a naturalistic behavioral approach: effects on language, pretend play, and joint attention. J Autism Dev Disord. May. 2006;36(4):487-505. X-1, X-3. [pmid: 16568355].
1986 Ingersoll B, Schreibman L, Stahmer A. Brief report: differential treatment outcomes for children with autistic spectrum disorder based on level of peer social avoidance. J Autism Dev Disord. Jun. 2001;31(3):343-9. X-1, X-3, X-4. [pmid: 11518487].
1987 Ingersoll BR. Teaching social communication: a comparison of naturalistic behavioral and development, social pragmatic approaches for children with autism spectrum disorders. J Posit Behav Interv. 2010;12(1):33-43. X-2.
1988 Inglese MD. Pain perception and communication in children with autism spectrum disorder: new parental insights. South Online J Nurs Res. 2008;8(2):2. X-1, X-3, X-4.
1989 Ingvarsson ET, Hollobaugh T. Acquisition of intraverbal behavior: teaching children with autism to mand for answers to questions. J Appl Behav Anal. Spr. 2010;43(1):1-17. X-3. [pmid: 20808492].
1990 Ingvarsson ET, Hollobaugh T. A comparison of prompting tactics to establish intraverbals in children with autism. J Appl Behav Anal. Fall. 2011;44(3):659-64. X-1, X-3, X-4. [pmid: 21941400].
1991 Insel TR. Mouse models for autism: report from a meeting. Mamm Genome. Oct. 2001;12(10):755-7. X-2, X-4. [pmid: 11678137].
1992 Irvin DS. Using analog assessment procedures for determining the effects of a gluten-free and casein-free diet on rate of problem behaviors for an adolescent with autism. Behav Interv. Nov. 2006;21(4):281-6. X-3.
1993 Isbell JS, Jolivette K. Stop, think, proceed: solving problems in the real world. Interv School Clinic. Sep. 2011;47(1):31-8. X-6.
1994 Ishii T, Ishii A, Ishii T, et al. Drawings by an autistic adult chronicling a day in his childhood. Vis Arts Res. Fall. 1996;22(44):47-55. X-2, X-3, X-4.
1995 Itzchak EB, Zachor DA. Change in autism classification with early intervention: predictors and outcomes. Res Autism Spectr Disord. Oct–Dec. 2009;3(4):967-76. X-1, X-4.
1996 Ivancic Jokic N, Majstorovic M, Bakarcic D, et al. Dental caries in disabled children. Coll Antropol. Mar. 2007;31(1):321-4. X-4. [pmid: 17598418].
1997 Ivanov I, Klein M, Green WH, et al. The challenges of psychopharmacological management of children with severe developmental disabilities. J Child Adolesc Psychopharmacol. Dec. 2006;16(6):793-9. X-1, X-2, X-3, X-4. [pmid: 17201623].
1998 Ivey JK. Outcomes for students with autism spectrum disorders: what is important and likely according to teachers?. Educ Train Dev Disabil. Mar. 2007;42(1):3-13. X-1, X-3, X-4.
1999 Ivey ML, Heflin LJ, Alberto P. The Use of social stories to promote independent behaviors in novel events for children with PDD-NOS. Focus Autism Dev Disabil. Fal. 2004;19(3):164-76. X-1, X-2, X-3, X-4.
2000 Jackett JM. Transition and beyond for individuals with autism spectrum disorders (ASD): a New Jersey case study of the adult service sector, its inherent shortcomings, and hope for the future. Seton Hall Law Rev. 2010;40(4):1733-74. X-1, X-2, X-3, X-4. [pmid: 21280391].
2001 Jackson C. A life of his own. Ment Health Care. Feb. 1998;1(6):186-7. X-3. [pmid: 9791407].
2002 Jackson HJ. Current trends in the treatment of phobias in autistic and mentally retarded persons. Aust NZ J Dev Disabil. Dec. 1983;9(4):191-208. X-1, X-2, X-3, X-4.
2003 Jacobson JW, Ackerman LJ. Differences in adaptive functioning among people with autism or mental retardation. J Autism Dev Disord. Jun. 1990;20(2):205-19. X-4. [pmid: 2347820].
2004 Jacobson L, Stenstrom I. Visually impairing ROP in children born in Sweden 1975–89. Acta Ophthalmol Suppl. 1993;(210):16-9. X-4. [pmid: 8329946].
2005 Jacquemont S, Hagerman RJ, Hagerman PJ, et al. Fragile-X syndrome and fragile X-associated tremor/ataxia syndrome: two faces of FMR1. Lancet Neurol. Jan. 2007;6(1):45-55. X-2, X-4. [pmid: 17166801].
2006 Jafferany M, Shireen F, Ibrahim A. An open-label trial of topiramate in the treatment of skin picking in pervasive developmental disorder not otherwise specified. Prim Care Companion J Clin Psychiatry. 2010;12(2). X-1, X-2, X-3, X-4. [pmid: 20694122].
2007 Jahr E. Teaching children with autism to answer novel wh-questions by utilizing a multiple exemplar strategy. Res Dev Disabil. Sep–Oct. 2001;22(5):407-23. X-3. [pmid: 11580167].
2008 Jahr E, Eikeseth S, Eldevik S, et al. Frequency and latency of social interaction in an inclusive kindergarten setting: a comparison between typical children and children with autism. Autism. 2007;11(4):349-63. X-1, X-3, X-4. [pmid: 17656399].
2009 Jahr E, Eldevik S, Eikeseth S. Teaching children with autism to initiate and sustain cooperative play. Res Dev Disabil. Mar–Apr. 2000;21(2):151-69. X-1, X-3, X-4. [pmid: 10817421].
2010 Jahromi LB, Kasari CL, McCracken JT, et al. Positive effects of methylphenidate on social communication and self-regulation in children with pervasive developmental disorders and hyperactivity. J Autism Dev Disord. Mar. 2009;39(3):395-404. X-1, X-3, X-4. [pmid: 18752063].
2011 Jambaque I, Chiron C, Dumas C, et al. Mental and behavioural outcome of infantile epilepsy treated by vigabatrin in tuberous sclerosis patients. Epilepsy Res. Feb. 2000;38(2–3):151-60. X-4. [pmid: 10642043].
2012 James SJ, Cutler P, Melnyk S, et al. Metabolic biomarkers of increased oxidative stress and impaired methylation capacity in children with autism. Am J Clin Nutr. Dec. 2004;80(6):1611-7. X-4. [pmid: 15585776].
2013 James SJ, Melnyk S, Fuchs G, et al. Efficacy of methylcobalamin and folinic acid treatment on glutathione redox status in children with autism. Am J Clin Nutr. Jan. 2009;89(1):425-30. X-1, X-3, X-4. [pmid: 19056591].
2014 James WH. Behavioural and biological determinants of human sex ratio at birth. J Biosoc Sci. Sep. 2010;42(5):587-99. X-1, X-2, X-3, X-4. [pmid: 20519063].
2015 Jamieson S. Creating an educational program for young children who are blind and who have autism. RE:view. Win. 2004;35(4):165. X-2, X-4.
2016 Janeslatt G, Granlund M, Kottorp A, et al. Patterns of time processing ability in children with and without developmental disabilities. J Appl Res Intellect Disabil. May. 2010;23(3):250-62. X-4.
2017 Janicki MP, Jacobson JW. The character of developmental disabilities in New York state: preliminary observations. Int J Rehabil Res. Jun. 1982;5(2):191-202. X-4. [pmid: 7118336].
2018 Janicki MP, Jacobson JW. Selected clinical features and service characteristics of autistic adults. Psychol Rep. Apr. 1983;52(2):387-90. X-4. [pmid: 6878537].
2019 Janicki MP, Lubin RA, Friedman E. Variations in characteristics and service needs of persons with autism. J Autism Dev Disord. Mar. 1983;13(1):73-85. X-4. [pmid: 6602125].
2020 Jansson AB. Becoming a narrator: A case study in the dynamics of learning based on the theories/methods of Vygotsky. Mind, Culture, and Activity. Jan. 2011;18(1):5-25. X-2, X-3, X-4.
2021 Jansson-Verkasalo E, Ceponiene R, Kielinen M, et al. Deficient auditory processing in children with asperger syndrome, as indexed by event-related potentials. Neurosci Lett. Mar. 6. 2003;338(3):197-200. X-4. [pmid: 12581830].
2022 Jansson-Verkasalo E, Kujala T, Jussila K, et al. Similarities in the phenotype of the auditory neural substrate in children with asperger syndrome and their parents. Eur J Neurosci. Aug. 2005;22(4):986-90. X-4. [pmid: 16115221].
2023 Janusis GM, Weyandt LL. An exploratory study of substance use and misuse among college students with and without ADHD and other disabilities. J Atten Disord. Nov. 2010;14(3):205-15. X-4. [pmid: 20479474].
2024 Jarbrink K. The economic consequences of autistic spectrum disorder among children in a Swedish municipality. Autism. Sep. 2007;11(5):453-63. X-4. [pmid: 17942458].
2025 Jarbrink K, Fombonne E, Knapp M. Measuring the parental, service and cost impacts of children with autistic spectrum disorder: a pilot study. J Autism Dev Disord. Aug. 2003;33(4):395-402. X-1, X-3, X-4. [pmid: 12959418].
2026 Jarbrink K, McCrone P, Fombonne E, et al. Cost-impact of young adults with high-functioning autistic spectrum disorder. Res Dev Disabil. Jan–Feb. 2007;28(1):94-104. X-3, X-4. [pmid: 16551499].
2027 Jarocka-Cyrta E, Wasilewska J, Kaczmarski MG. Brief report: eosinophilic esophagitis as a cause of feeding problems in autistic boy. The first reported case. J Autism Dev Disord. Mar. 2011;41(3):372-4. X-3, X-4. [pmid: 20625807].
2028 Jarusiewicz B. Efficacy of neurofeedback for children in the autistic spectrum: a pilot study. J Neurother. 2002;6(4):39-49. X-1, X-3, X-4.
2029 Jarvinen-Pasley A, Wallace GL, Ramus F, et al. Enhanced perceptual processing of speech in autism. Dev Sci. Jan. 2008;11(1):109-21. X-4. [pmid: 18171373].
2030 Jaselskis CA, Cook EH Jr, Fletcher KE, et al. Clonidine treatment of hyperactive and impulsive children with autistic disorder. J Clin Psychopharmacol. Oct. 1992;12(5):322-7. X-1, X-3, X-4. [pmid: 1479049].
2031 Jasmin E, Couture M, McKinley P, et al. Sensorimotor and daily living skills of preschool children with autism spectrum disorders. J Autism Dev Disord. Feb. 2009;39(2):231-41. X-4. [pmid: 18629623].
2032 Jegatheesan B, Fowler S, Miller PJ. From symptom recognition to services: how South Asian muslim immigrant families navigate autism. Disabil Soc. Dec. 2010;25(7):797-811. X-1, X-3, X-4.
2033 Jelleyman T, Ure A. Attitudes to immunisation: a survey of health professionals in the Rotorua district. N Z Med J. Feb. 20. 2004;117(1189):U769. X-4. [pmid: 15014558].
2034 Jennett HK, Harris SL, Mesibov GB. Commitment to philosophy, teacher efficacy, and burnout among teachers of children with autism. J Autism Dev Disord. Dec. 2003;33(6):583-93. X-4. [pmid: 14714928].
2035 Jensen CC, McConnachie G, Pierson T. Long-term multicomponent intervention to reduce severe problem behavior: A 63-month evaluation. J Posit Behav Interv. Fal. 2001;3(4):225-36. 50. X-1, X-3, X-4.
2036 Jensen PS, Youngstrom EA, Steiner H, et al. Consensus report on impulsive aggression as a symptom across diagnostic categories in child psychiatry: implications for medication studies. J Am Acad Child Adolesc Psychiatry. Mar. 2007;46(3):309. X-2, X-4. [pmid: 17314717].
2037 Jensen VK, Sinclair LV. Treatment of autism in young children: behavioral intervention and applied behavior analysis. infants and young children. Apr. 2002;14(4):42-52. X-1, X-2, X-3, X-4.
2038 Jenson WR, et al. Intervention projects in school psychology at the university of utah. School psychology review. 1991;20(4):462-71. X-1, X-2, X-3, X-4.
2039 Jenson WR, Rovner L, Cameron S, et al. Reduction of self-injurious behavior in an autistic girl using a multifaceted treatment program. J Behav Ther Exp Psychiatry. Mar. 1985;16(1):77-80. X-1, X-3, X-4. [pmid: 3998179].
2040 Jepsen RH, VonThaden K. The effect of cognitive education on the performance of students with neurological developmental disabilities. NeuroRehabilitation. 2002;17(3):201-9. X-3. [pmid: 12237500].
2041 Jepson B, Granpeesheh D, Tarbox J, et al. Controlled evaluation of the effects of hyperbaric oxygen therapy on the behavior of 16 children with autism spectrum disorders. J Autism Dev Disord. May. 2011;41(5):575-88. X-1, X-3, X-4. [pmid: 20680427].
2042 Jerome J, Frantino EP, Sturmey P. The effects of errorless learning and backward chaining on the acquisition of internet skills in adults with developmental disabilities. J Appl Behav Anal. Spring. 2007;40(1):185-9. X-3. [pmid: 17471803].
2043 Jerome J, Sturmey P. Reinforcing efficacy of interactions with preferred and nonpreferred staff under progressive-ratio schedules. J Appl Behav Anal. Summer. 2008;41(2):221-5. X-1, X-3, X-4. [pmid: 18595285].
2044 Jeste SS, Nelson CA III. Event related potentials in the understanding of autism spectrum disorders: an analytical review. J Autism Dev Disord. Mar. 2009;39(3):495-510. X-2, X-4. [pmid: 18850262].
2045 Jocelyn LJ, Casiro OG, Beattie D, et al. Treatment of children with autism: a randomized controlled trial to evaluate a caregiver-based intervention program in community day-care centers. J Dev Behav Pediatr. Oct. 1998;19(5):326-34. X-1, X-3, X-4. [pmid: 9809262].
2046 Johansson M, Billstedt E, Danielsson S, et al. Autism spectrum disorder and underlying brain mechanism in the oculoauriculovertebral spectrum. Dev Med Child Neurol. Apr. 2007;49(4):280-8. X-4. [pmid: 17376139].
2047 Johnson CR, Butter EM, Handen BL, et al. Standardised observation analogue procedure (SOAP) for assessing parent and child behaviours in clinical trials. J Intellect Dev Disabil. Sep. 2009;34(3):230-8. X-4. [pmid: 19681003].
2048 Johnson CR, Handen BL, Mayer-Costa M, et al. Eating habits and dietary status in young children with autism. J Dev Phys Disabil. Oct. 2008;20(5):437-48. X-4.
2049 Johnson CR, Handen BL, Zimmer M, et al. Effects of gluten free/casein free diet in young children with autism: A pilot study. J Dev Phys Disabil. Jun. 2011;23(3):213-25. X-1, X-3, X-4.
2050 Johnson CR, Handen BL, Zimmer M, et al. Polyunsaturated fatty acid supplementation in young children with autism. J Dev Phys Disabil. Feb. 2010;22(1):1-10. X-1, X-3, X-4.
2051 Johnson DP, Penn DL, Bauer DJ, et al. Predictors of the therapeutic alliance in group therapy for individuals with treatment-resistant auditory hallucinations. Br J Clin Psychol. Jun. 2008;47(Pt 2):171-83. X-4. [pmid: 17900393].
2052 Johnson E, Hastings RP. Facilitating factors and barriers to the implementation of intensive home-based behavioural intervention for young children with autism. Child Care Health Dev. Mar. 2002;28(2):123-9. X-2. [pmid: 11952647].
2053 Johnson JL, Brown S, Chang C, et al. The cost of serving infants and toddlers under part C. Infants Young Child. Jan–Mar. 2011;24(1):101-13. X-1, X-3, X-4.
2054 Johnson K, Johnson CR, Sahl RA. Behavioral and naltrexone treatment of self-injurious behavior. J Dev Phys Disabil. Special Issue: Pharmacotherapy: II. Jun. 1994;6(2):193-202. X-1, X-3, X-4.
2055 Johnson L, McComas J, Thompson A, et al. Obtained versus programmed reinforcement: practical considerations in the treatment of escape-reinforced aggression. J Appl Behav Anal. Sum. 2004;37(2):239-42. X-3. [pmid: 15293645].
2056 Johnson M, Ostlund S, Fransson G, et al. Omega-3/omega-6 fatty acids for attention deficit hyperactivity disorder: a randomized placebo-controlled trial in children and adolescents. J Atten Disord. Mar. 2009;12(5):394-401. X-1, X-3. [pmid: 18448859].
2057 Johnson MH, Siddons F, Frith U, et al. Can autism be predicted on the basis of infant screening tests?. Dev Med Child Neurol. Apr. 1992;34(4):316-20. X-4. [pmid: 1572517].
2058 Johnson N, Frenn M, Feetham S, et al. Autism spectrum disorder: parenting stress, family functioning and health-related quality of life. Fam Syst Health. Sep. 2011;29(3):232-52. X-4. [pmid: 21928891].
2059 Johnson SA, Filliter JH, Murphy RR. Discrepancies between self- and parent-perceptions of autistic traits and empathy in high functioning children and adolescents on the autism spectrum. J Autism Dev Disord. 2009;39(12):1706-14. X-4. [pmid: 19626433].
2060 Johnston MV. Commentary: potential neurobiologic mechanisms through which metabolic disorders could relate to autism. J Autism Dev Disord. Oct. 2000;30(5):471-73. X-1, X-2, X-3, X-4. [pmid: 11098886].
2061 Johnston S, Nelson C, Evans J, et al. The use of visual supports in teaching young children with autism spectrum disorder to initiate interactions. [corrected] [published erratum appears in AAC Augment Altern Commun 2004 Jun;20(2):123]. AAC: Augment Altern Commun. 2003;19(2):86-103. X-1, X-3, X-4.
2062 Johnston SS, Buchanan S, Davenport L. Comparison of fixed and gradual array when teaching sound-letter correspondence to two children with autism who use AAC. AAC: Augment Altern Commun. 2009;25(2):136-44. X-1, X-3, X-4.
2063 Johnston SS, O’Neill RE. Searching for effectiveness and efficiency in conducting functional assessments: a review and proposed process for teachers and other practitioners. Focus Autism Dev Disabil. Win. 2001;16(4):205-14. X-1, X-2, X-3, X-4.
2064 Jolivette K, Gallagher PA, Morrier MJ, et al. Preventing problem behaviors in young children with disabilities. Exceptionality. Apr. 2008;16(2):78-92. X-2, X-4.
2065 Jones AP, Frederickson N. Multi-informant predictors of social inclusion for students with autism spectrum disorders attending mainstream school. J Autism Dev Disord. Sep. 2010;40(9):1094-103. X-1, X-3, X-4. [pmid: 20148296].
2066 Jones CR, Happe F, Baird G, et al. Auditory discrimination and auditory sensory behaviours in autism spectrum disorders. Neuropsychologia. Nov. 2009;47(13):2850-8. X-4. [pmid: 19545576].
2067 Jones EA, Carr EG. Joint attention in children with autism: theory and intervention. Focus Autism Dev Disabil. Mar. 2004;19(1):13-26. X-2, X-4.
2068 Jones EA, Carr EG, Feeley KM. Multiple effects of joint attention intervention for children with autism. Behav Modif. Nov. 2006;30(6):782-834. X-1, X-3, X-4. [pmid: 17050765].
2069 Jones EA, Feeley KM, Takacs J. Teaching spontaneous responses to young children with autism. J Appl Behav Anal. Fall. 2007;40(3):565-70. X-1, X-3, X-4. [pmid: 17970271].
2070 Jones G, Hack E. Individual budgets and direct payments: issues, challenges and future implications for the strategic management of SEN: policy paper 3, 6th series, April 2008: chapter 3: parent/carer involvement in the commissioning of services for children and young people with autism spectrum disorder in the East Midlands. J Res Spec Educ Needs. Oct. 2008;8(3):171-3. X-4.
2071 Jones K, Howley M. An investigation into an interaction programme for children on the autism spectrum: outcomes for children, perceptions of schools and a model for training. J Res Spec Educ Needs. Jun. 2010;10(2):115-23. X-1, X-3, X-4.
2072 Jones KJ, Block ME. Including an autistic middle school child in general physical education: a case study. Strategies. Mar–Apr. 2006;19(4):13-6. X-1, X-3, X-4.
2073 Jones S, Cooper SA, Smiley E, et al. Prevalence of, and factors associated with, problem behaviors in adults with intellectual disabilities. J Nerv Ment Dis. Sep. 2008;196(9):678-86. X-1, X-3, X-4. [pmid: 18791429].
2074 Jonsson CO, Sjosward E. Favourite objects of autistic children. Scand J Psychol. Sep. 1993;34(3):237-45. X-4. [pmid: 8378753].
2075 Joosten A. Evidence-based occupational therapy with children with autism: using information about sensory processing to increase the child’s participation in daily life... Occupational Therapy Australia. 24th National Conference and Exhibition. 29 June - 1 July 2011. Aust Occup Ther J. 2011;58:93. X-1, X-2, X-3, X-4.
2076 Joosten AV, Bundy AC. Sensory processing and stereotypical and repetitive behaviour in children with autism and intellectual disability. Aust Occup Ther J. 2010;57(6):366-72. X-1, X-2, X-3, X-4. [pmid: 21091701].
2077 Jordan CJ. Evolution of autism support and understanding via the world wide web. Intellect Dev Disabil. Jun. 2010;48(3):220-7. X-1, X-2, X-3, X-4. [pmid: 20597733].
2078 Jordan R. Meeting the Needs of Children with Autistic Spectrum Disorders in the Early Years. Aust J Early Child. Sep. 2004;29(3):1-7. X-2, X-4.
2079 Jose PE, Cohen DJ. The effect of unfamiliar tasks and teachers on autistic children’s negativism. J Am Acad Child Psychiatry. Winter. 1980;19(1):78-89. X-1, X-3, X-4. [pmid: 7365171].
2080 Josefi O, Ryan V. Non-directive play therapy for young children with autism: a case study. Clin Child Psychol Psychiatry. Oct. 2004;9(4):533-51. X-1, X-3, X-4.
2081 Joshi G, Petty C, Wozniak J, et al. The heavy burden of psychiatric comorbidity in youth with autism spectrum disorders: a large comparative study of a psychiatrically referred population. J Autism Dev Disord. Nov. 2010;40(11):1361-70. X-4. [pmid: 20309621].
2082 Joshi PT, Capozzoli JA, Coyle JT. Low-dose neuroleptic therapy for children with childhood-onset pervasive developmental disorder. Am J Psychiatry. Mar. 1988;145(3):335-8. X-1, X-3, X-4. [pmid: 3344846].
2083 Jou RJ, Handen BL, Hardan AY. Retrospective assessment of atomoxetine in children and adolescents with pervasive developmental disorders. J Child Adolesc Psychopharmacol. Apr. 2005;15(2):325-30. X-1, X-3, X-4. [pmid: 15910217].
2084 Joyce PR. The medical model-why psychiatry is a branch of medicine. Aust N Z J Psychiatry. Dec. 1980;14(4):269-78. X-1, X-2, X-3, X-4. [pmid: 6945093].
2085 Jull S, Mirenda P. Parents as play date Facilitators for preschoolers with autism. J Posit Behav Interv. Jan. 2011;13(1):17-30. X-1, X-3, X-4.
2086 Jung KE, Lee HJ, Lee YS, et al. Efficacy of sensory integration treatment based on virtual reality - tangible interaction for children with autism. Annu Rev CyberTher Telemed. 2006;4:45-9. X-1, X-3, X-4.
2087 Jung S, Sainato DM, Davis CA. Using high-probability request sequences to increase social interactions in young children with autism. J Early Interv. 2008;30(3):163-87. X-1, X-3, X-4.
2088 Jurgens A, Anderson A, Moore DW. The effect of teaching PECS to a child with autism on verbal behaviour, play, and social functioning. Behav Change. May. 2009;26(1):66-81. X-1, X-3, X-4.
2089 Juul-Dam N, Townsend J, Courchesne E. Prenatal, perinatal, and neonatal factors in autism, pervasive developmental disorder-not otherwise specified, and the general population. Pediatrics. Apr. 2001;107(4):E63. X-4. [pmid: 11335784].
2090 Jyonouchi H. Autism spectrum disorders and allergy: observation from a pediatric allergy/immunology clinic. Expert Rev Clin Immunol. May. 2010;6(3):397-411. X-1, X-2, X-3, X-4. [pmid: 20441426].
2091 Jyonouchi H, Geng L, Ruby A, et al. Dysregulated innate immune responses in young children with autism spectrum disorders: their relationship to gastrointestinal symptoms and dietary intervention. Neuropsychobiology. Mar. 2005;51(2):77-85. X-1, X-3, X-4. [pmid: 15741748].
2092 Jyonouchi H, Sun S, Itolazu N. Innate immunity associated with inflammatory responses and cytokine production against common dietary proteins in patients with autism spectrum disorder. Neuropsychobiology. Aug. 2002;46(2):76-84. X-4. [pmid: 12378124].
2093 Jyonouchi H, Sun S, Le H. Proinflammatory and regulatory cytokine production associated with innate and adaptive immune responses in children with autism spectrum disorders and developmental regression. J Neuroimmunol. Nov. 1. 2001;120(1–2):170-9. X-4. [pmid: 11694332].
2094 Kagohara DM, van der Meer L, Achmadi D, et al. Behavioral intervention promotes successful use of an iPod-based communication device by an adolescent with autism. Clin Case Stud. Oct. 2010;9(5):328-38. X-2, X-3.
2095 Kalachnik JE, Hanzel TE, Sevenich R, et al. Brief report: clonazepam behavioral side effects with an individual with mental retardation. J Autism Dev Disord. Jun. 2003;33(3):349-54. X-3. [pmid: 12908837].
2096 Kalmanson B, Pekarsky JH. Infant-parent psychotherapy with an autistic toddler. Zero Three. Feb. 1987;7(3):1-6. X-1, X-3, X-4.
2097 Kalmanson B, Pekarsky JH. Infant-parent psychotherapy with an autistic toddler. Infant Ment Health J. Win. 1987;8(4):382-97. X-1, X-3, X-4.
2098 Kaluzna-Czaplinska J, Michalska M, Rynkowski J. Vitamin supplementation reduces the level of homocysteine in the urine of autistic children. Nutr Res. Apr. 2011;31(4):318-21. X-4. [pmid: 21530806].
2099 Kalyva E, Avramidis E. Improving communication between children with autism and their peers through the “circle of friends”: A Small-Scale Intervention Study. J Appl Res Intellect Disabil. Sep. 2005;18(3):253-61. X-1, X-3, X-4.
2100 Kamen BA, Chukoskie L. Autism Speaks: meeting on folate metabolism and Autism spectrum disorders. March 19–20, 2009. Washington, DC. J Pediatr Hematol Oncol. Apr. 2011;33(3):208-15. [pmid: 21427559]. X-2, X-4.
2101 Kamen S, Skier J. Dental management of the autistic child. Spec Care Dentist. Jan–Feb. 1985;5(1):20-3. X-1, X-3, X-4. [pmid: 3156428].
2102 Kamio Y. Self-injurious and aggressive behavior in adolescents with intellectual disabilities: A comparison of adolescents with and without autism. Jpn J Spec Educ. Mar. 2002;39(6):143-54. X-4.
2103 Kamio Y, Toichi M. Memory illusion in high-functioning autism and asperger’s disorder. J Autism Dev Disord. May. 2007;37(5):867-76. X-2, X-4. [pmid: 17031448].
2104 Kamp-Becker I, Schroder J, Muehlan H, et al. Health-related quality of life in children and adolescents with autism spectrum disorder. Z Kinder Jugendpsychiatr Psychother. Mar. 2011;39(2):123-31. X-3, X-4. [pmid: 21442600].
2105 Kamps D, Walker D, Maher J, et al. Academic and environmental effects of small group arrangements in classrooms for students with autism and other developmental disabilities. J Autism Dev Disord. Jun. 1992;22(2):277-93. X-1, X-3, X-4. [pmid: 1624409].
2106 Kamps DM, Barbetta PM, Leonard BR, et al. Classwide peer tutoring: an integration strategy to improve reading skills and promote peer interactions among students with autism and general education peers. J Appl Behav Anal. Spring. 1994;27(1):49-61. X-3. [pmid: 8188563].
2107 Kamps DM, Dugan EP, Leonard BR, et al. Enhanced small group instruction using choral responding and student interaction for children with autism and developmental disabilities. Am J Ment Retard. Jul. 1994;99(1):60-73. X-1, X-3, X-4. [pmid: 7946254].
2108 Kamps DM, et al. Cooperative learning groups in reading: an integration strategy for students with autism and general classroom peers. Behav Disord. Nov. 1995;21(1):89-109. X-1, X-3, X-4.
2109 Kamps DM, Kravits T, Gonzalez Lopez A, et al. What do the peers think? Social validity of peer-mediated programs. Educ Treat Children. May. 1998;21(2):107-34. X-1, X-3, X-4.
2110 Kamps DM, Leonard BR, Vernon S, et al. Teaching social skills to students with autism to increase peer interactions in an integrated first-grade classroom. J Appl Behav Anal. Summer. 1992;25(2):281-8. X-1, X-3, X-4. [pmid: 1634423].
2111 Kanai C, Iwanami A, Ota H, et al. Clinical characteristics of adults with asperger’s syndrome assessed with self-report questionnaires. Res Autism Spectr Disord. Jan–Mar. 2011;5(1):185-90. X-4.
2112 Kane M, Connell JE, Pellecchia M. A quantitative analysis of language interventions for children with autism. Behav Anal Today. 2010;11(2):128-44. X-2, X-3.
2113 Kanner AM. Commentary: the treatment of seizure disorders and eeg abnormalities in children with autistic spectrum disorders: are we getting ahead of ourselves?. J Autism Dev Disord. Oct. 2000;30(5):491-95. X-1, X-2, X-3, X-4. [pmid: 11098890].
2114 Kanner L. Follow-up study of eleven autistic children originally reported in 1943. Focus on Autistic Behavior. Dec. 1992;7(5):1-11. X-3.
2115 Kantavong P, Sivabaedya S. A professional learning program for enhancing the competency of students with special needs. Int J Whole Schooling. 2010;6(1):53-62. X-1, X-3, X-4.
2116 Kapetanovic S. Oxcarbazepine in youths with autistic disorder and significant disruptive behaviors. Am J Psychiatry. May. 2007;164(5):832-3. X-3. [pmid: 17475749].
2117 Kaplan H, Clopton M, Kaplan M, et al. Snoezelen multi-sensory environments: task engagement and generalization. Res Dev Disabil. Jul–Aug. 2006;27(4):443-55. X-3. [pmid: 16122905].
2118 Kaplan M, Carmody DP, Gaydos A. Postural orientation modifications in autism in response to ambient lenses. Child Psychiatry Hum Dev. Winter. 1996;27(2):81-91. X-4. [pmid: 8936794].
2119 Kaplan M, Edelson SM, Seip JA. Behavioral changes in autistic individuals as a result of wearing ambient transitional prism lenses. Child Psychiatry Hum Dev. Fall. 1998;29(1):65-76. X-3. [pmid: 9735531].
2120 Kaplan-Reimer H, Sidener TM, Reeve KF, et al. Using stimulus control procedures to teach indoor rock climbing to children with autism. Behav Int. Feb. 2011;26(1):1-22. X-3.
2121 Kapur SO. Infantile autism: Case studies. NIMHANS J. Jan. 1989;7(1):87-90. X-1, X-3, X-4.
2122 Karanth P, Shaista S, Srikanth N. Efficacy of communication DEALL--an indigenous early intervention program for children with autism spectrum disorders. Indian J Pediatr. Sep. 2010;77(9):957-62. X-1, X-3, X-4. [pmid: 20821283].
2123 Karasik J. Breakfast at midnight. Health Aff (Millwood). Sep–Oct. 2007;26(5):1431-6. X-1, X-2, X-3, X-4. [pmid: 17848455].
2124 Karsten AM, Carr JE. The effects of differential reinforcement of unprompted responding on the skill acquisition of children with autism. J Appl Behav Anal. Summer. 2009;42(2):327-34. X-4. [pmid: 19949520].
2125 Kasa-Hendrickson C, Kluth P. “We have to start with inclusion and work it out as we go”: purposeful inclusion for non-verbal students with autism. Int J Whole Schooling. Oct. 2005;2(1):2-14. X-1, X-3, X-4.
2126 Kasai K, Hashimoto O, Kawakubo Y, et al. Delayed automatic detection of change in speech sounds in adults with autism: a magnetoencephalographic study. Clin Neurophysiol. Jul. 2005;116(7):1655-64. X-3, X-4. [pmid: 15899591].
2127 Kasari C. Assessing change in early intervention programs for children with autism. J Autism Dev Disord. Oct. 2002;32(5):447-61. X-2. [pmid: 12463519].
2128 Kasari C, Freeman S, Paparella T. Joint attention and symbolic play in young children with autism: a randomized controlled intervention study. J Child Psychol Psychiatry. Jun. 2006;47(6):611-20. X-1, X-3, X-4. [pmid: 16712638].
2129 Kasari C, Freeman SFN, Bauminger N, et al. Parental perspectives on inclusion: effects of autism and down syndrome. J Autism Dev Disord. Aug. 1999;29(4):297-305. X-4. [pmid: 10478729].
2130 Kasari C, Gulsrud AC, Wong C, et al. Randomized controlled caregiver mediated joint engagement intervention for toddlers with autism. J Autism Dev Disord. Sep. 2010;40(9):1045-56. X-1, X-3, X-4. [pmid: 20145986].
2131 Kasari C, Paparella T, Freeman S, et al. Language outcome in autism: randomized comparison of joint attention and play interventions. J Consult Clin Psychol. Feb. 2008;76(1):125-37. X-1, X-3, X-4. [pmid: 18229990].
2132 Kashinath S, Woods J, Goldstein H. Enhancing generalized teaching strategy use in daily routines by parents of children with autism. J Speech Lang Hear Res. Jun. 2006;49(3):466-85. X-1, X-3, X-4. [pmid: 16787891].
2133 Kastner JL, Gellin BG. Measles-mumps-rubella vaccine and autism: the rise (and fall?) of a hypothesis. Pediatr Ann. Jul. 2001;30(7):408-15. X-2, X-4. [pmid: 11469172].
2134 Katagiri J. The effect of background music and song texts on the emotional understanding of children with autism. J Music Ther. Spring. 2009;46(1):15-31. X-3. [pmid: 19256729].
2135 Katagiri M, Inada N, Kamio Y. Mirroring effect in 2- and 3-year-olds with autism spectrum disorder. Res Autism Spectr Disord. Jul–Sep. 2010;4(3):474-8. X-1, X-3, X-4.
2136 Katz RC, Cacciapaglia H, Cabral K. Labeling bias and attitudes toward behavior modification revisited. J Behav Ther Exp Psychiatry. Mar. 2000;31(1):67-72. X-4. [pmid: 10983748].
2137 Kauffmann C, Vance HB, Pumariega AJ, et al. Fluvoxamine treatment of a child with severe PDD: a single case study. Psychiatry. Fal. 2001;64(3):268-77. X-1, X-3, X-4. [pmid: 11708052].
2138 Kaur P, Chavan BS, Lata S, et al. Early intervention in developmental delay. Indian J Pediatr. May. 2006;73(5):405-8. X-4. [pmid: 16741325].
2139 Kavon NM, McLaughlin TF. Interventions for echolalic behaviour for children with autism: a review of verbal prompts and the cues pause point procedure. Int J Spec Educ. Dec. 1995;19(2–3):39-45. X-1, X-2, X-3, X-4.
2140 Kay BR. Bittersweet farms. J Autism Dev Disord. Sep. 1990;20(3):309-21. X-2, X-4. [pmid: 2228914].
2141 Kay S, Harchik AE, Luiselli JK. Elimination of drooling by an adolescent student with autism attending public high school. J Posit Behav Interv. 2006;8(1):24-8. X-3.
2142 Kayser JE, Billingsley FF, Neel RS. A comparison of in-context and traditional instructional approaches: total task, single trial versus backward chaining, multiple trials. J Assoc Pers Sev Handicaps. Spr. 1986;11(1):28-38. X-1, X-3, X-4.
2143 Kazdin AE. Replication and extension of behavioral treatment of autistic disorder. Am J Ment Retard. Jan. 1993;97(4):377-79. X-1, X-2, X-3, X-4.
2144 Keats L. Doug: The rhythm in his world. Can J Music Ther. Fal. 1995;3(1):53-69. X-1, X-3, X-4.
2145 Keel JH, Mesibov GB, Woods AV. TEACCH-supported employment program. J Autism Dev Disord. Feb. 1997;27(1):3-9. X-1, X-2, X-3. [pmid: 9018578].
2146 Keeling K, Myles BS, Gagnon E, et al. Using the power card strategy to teach sportsmanship skills to a child with autism. Focus Autism Dev Disabil. Sum. 2003;18(2):105-11. X-1, X-3, X-4.
2147 Keen D. Engagement of children with autism in learning. Australas J Spec Educ. Oct. 2009;33(2):130-40. X-1, X-2, X-3, X-4.
2148 Keen D, Rodger S, Doussin K, et al. A pilot study of the effects of a social-pragmatic intervention on the communication and symbolic play of children with autism. Autism. Jan. 2007;11(1):63-71. X-1, X-3, X-4. [pmid: 17175574].
2149 Keen D, Sigafoos J, Woodyatt G. Replacing prelinguistic behaviors with functional communication. J Autism Dev Disord. Aug. 2001;31(4):385-98. X-1, X-3, X-4. [pmid: 11569585].
2150 Keen D, Ward S. Autistic spectrum disorder. Autism. Mar. 2004;8(1):39-48. X-4. [pmid: 15070546].
2151 Keen D, Woodyatt G, Sigafoos J. Verifying teacher perceptions of the potential communicative acts of children with autism. Commun Disord Q. 2002;23(3):133-42. X-3, X-4.
2152 Keenan M, Dillenburger K, Doherty A, et al. The experiences of parents during diagnosis and forward planning for children with autism spectrum disorder. J Appl Res Intellect Disabil. Jul. 2010;23(4):390-7. X-1, X-3, X-4.
2153 Keglon J. Camp Thunderbird: taking flight with dance and physical education for special populations. J Phys Educ Recreat Dance. 38. Feb. 2011;82(2):32-4. X-2, X-4.
2154 Kelley ME, Shillingsburg MA, Castro MJ, et al. Further evaluation of emerging speech in children with developmental disabilities: training verbal behavior. J Appl Behav Anal. Fall. 2007;40(3):431-45. X-3. [pmid: 17970258].
2155 Kellman J. Making sense of seeing: autism and David Marr. Vis Arts Res. Fall. 1996;22(44):76-89. X-1, X-2, X-3, X-4.
2156 Kellman J. Drawing with peter: autobiography, narrative, and the art of a child with autism. Stud Art Educ. Spr. 1999;40(3):258-74. X-1, X-2, X-3, X-4.
2157 Kellner MH, Strickarz B. Exit plans for students with disabilities attending separate approved special education programs in the private sector. Career Dev Except Individuals. Spr. 2003;26(1):85-97. X-1, X-3, X-4.
2158 Kellner MH, Tutin J. A school-based anger management program for developmentally and emotionally disabled high school students. Adolescence. Winter. 1995;30(120):813-25. X-1, X-3. [pmid: 8588518].
2159 Kelly A. What works for one: practice considerations for supporting a child or young person with autism spectrum disorder, drawn from participatory action research. Kairaranga. 2008;9(spec iss):54-60. X-1, X-2, X-3, X-4.
2160 Kelly AB, Garnett MS, Attwood T, et al. Autism spectrum symptomatology in children: the impact of family and peer relationships. J Abnorm Child Psychol. Oct. 2008;36(7):1069-81. X-4. [pmid: 18437549].
2161 Kelly S, Green G, Sidman M. Visual identity matching and auditory-visual matching: a procedural note. J Appl Behav Anal. Summer. 1998;31(2):237-43. X-1, X-3, X-4. [pmid: 9652102].
2162 Kemner C, Lamme VA, Kovacs I, et al. Integrity of lateral and feedbackward connections in visual processing in children with pervasive developmental disorder. Neuropsychologia. Mar. 25. 2007;45(6):1293-8. X-4. [pmid: 17101159].
2163 Kemner C, Oranje B, Verbaten MN, et al. Normal P50 gating in children with autism. J Clin Psychiatry. Mar. 2002;63(3):214-7. X-4. [pmid: 11926720].
2164 Kemner C, Verbaten MN, Koelega HS, et al. Are abnormal event-related potentials specific to children with ADHD? A comparison with two clinical groups. Percept Mot Skills. Dec. 1998;87(3 Pt 1):1083-90. X-4. [pmid: 9885081].
2165 Kemner C, Willemsen-Swinkels SH, de Jonge M, et al. Open-label study of olanzapine in children with pervasive developmental disorder. J Clin Psychopharmacol. Oct. 2002;22(5):455-60. X-1. [pmid: 12352267].
2166 Kemp DC, Carr EG. Reduction of severe problem behavior in community employment using an hypothesis-driven multicomponent intervention approach. J Assoc Pers Sev Handicaps. Win. 1995;20(4):229-47. X-3.
2167 Kennedy CH. Manipulating antecedent conditions to alter the stimulus control of problem behavior. J Appl Behav Anal. Spring. 1994;27(1):161-70. X-3. [pmid: 8188556].
2168 Kennedy CH, Haring TG. Combining reward and escape DRO to reduce the problem behavior of students with severe disabilities. J Assoc Pers Sev Handicaps. Sum. 1993;18(2):85-92. X-3.
2169 Kennedy CH, Juarez AP, Becker A, et al. Children with severe developmental disabilities and behavioral disorders have increased special healthcare needs. Dev Med Child Neurol. Dec. 2007;49(12):926-30. X-4. [pmid: 18039240].
2170 Kenny MC, Winick CB. An integrative approach to play therapy with an autistic girl. Int J Play Ther. 2000;9(1):11-33. X-1, X-3, X-4.
2171 Kerby DS, Dawson BL. Autistic features, personality, and adaptive behavior in males with the fragile X syndrome and no autism. Am J Ment Retard. Jan. 1994;98(4):455-62. X-4. [pmid: 8148122].
2172 Keret D, Bassett GS, Bunnell WP, et al. Scoliosis in rett syndrome. J Pediatr Orthop. Mar–Apr. 1988;8(2):138-42. X-1, X-3, X-4. [pmid: 3350946].
2173 Kern JK, Garver CR, Grannemann BD, et al. Response to vestibular sensory events in autism. Res Autism Spectr Disord. Jan–Mar. 2007;1(1):67-74. X-4.
2174 Kern JK, Miller VS, Cauller PL, et al. Effectiveness of N, N-dimethylglycine in autism and pervasive developmental disorder. J Child Neurol. Mar. 2001;16(3):169-73. X-1, X-3, X-4. [pmid: 11305684].
2175 Kern JK, Van Miller S, Evans PA, et al. Efficacy of porcine secretin in children with autism and pervasive developmental disorder. J Autism Dev Disord. Jun. 2002;32(3):153-60. X-1, X-3, X-4. [pmid: 12108616].
2176 Kern L, Bailin D, Mauk JE. Effects of a topical anesthetic on non-socially maintained self-injurious behavior. Dev Med Child Neurol. Nov. 2003;45(11):769-71. X-4. [pmid: 14580133].
2177 Kern L, Carberry N, Haidara C. Analysis and intervention with two topographies of challenging behavior exhibited by a young woman with autism. Res Dev Disabil. Jul–Aug. 1997;18(4):275-87. X-3. [pmid: 9216027].
2178 Kern L, Koegel RL, Dunlap G. The influence of vigorous versus mild exercise on autistic stereotyped behaviors. J Autism Dev Disord. Mar. 1984;14(1):57-67. X-1, X-3, X-4. [pmid: 6706897].
2179 Kern L, Koegel RL, Dyer K, et al. The effects of physical exercise on self-stimulation and appropriate responding in autistic children. J Autism Dev Disord. Dec. 1982;12(4):399-419. X-3. [pmid: 7161239].
2180 Kern L, Marder TJ. A comparison of simultaneous and delayed reinforcement as treatments for food selectivity. J Appl Behav Anal. Sum. 1996;29(2):243-46. X-1, X-3, X-4. [pmid: 8682740].
2181 Kern L, Starosta K, Adelman BE. Reducing pica by teaching children to exchange inedible items for edibles. Behav Modif. Mar. 2006;30(2):135-58. X-3. [pmid: 16464843].
2182 Kern P, Aldridge D. Using embedded music therapy interventions to support outdoor play of young children with autism in an inclusive community-based child care program. J Music Ther. Winter. 2006;43(4):270-94. X-1, X-3, X-4. [pmid: 17348756].
2183 Kern P, Wakeford L, Aldridge D. Improving the performance of a young child with autism during self-care tasks using embedded song interventions: a case study. Music Ther Perspect. 2007;25(1):43-51. X-1, X-3, X-4.
2184 Kern P, Wolery M, Aldridge D. Use of songs to promote independence in morning greeting routines for young children with autism. J Autism Dev Disord. Aug. 2007;37(7):1264-71. X-1, X-3, X-4. [pmid: 17120150].
2185 Kerns KA, MacSween J, Vander Wekken S, et al. Investigating the efficacy of an attention training programme in children with foetal alcohol spectrum disorder. Dev Neurorehabil. Dec. 2010;13(6):413-22. X-1, X-3, X-4. [pmid: 21034284].
2186 Kerr KP, Mulhern F, McDowell C. Applied behaviour analysis. It works, it’s positive; now what’s the problem?. Early Child Dev Care. Aug. 2000;163:125-31. X-1, X-2, X-3, X-4.
2187 Kerwin MLE, Eicher PS, Gelsinger J. Parental report of eating problems and gastrointestinal symptoms in children with pervasive developmental disorders. Child Health Care. 2005;34(3):217-34. X-4.
2188 Keselyak NT, Simmer-Beck M, Bray KK, et al. Evaluation of an academic service-learning course on special needs patients for dental hygiene students: a qualitative study. J Dent Educ. Mar. 2007;71(3):378-92. X-4. [pmid: 17389573].
2189 Ketelaars MP, Cuperus J, Jansonius K, et al. Pragmatic language impairment and associated behavioural problems. Int J Lang Commun Disord. 2010;45(2):204-14. X-1, X-3, X-4. [pmid: 22748032].
2190 Khalfa S, Bruneau N, Roge B, et al. Increased perception of loudness in autism. Hear Res. Dec. 2004;198(1–2):87-92. X-4. [pmid: 15617227].
2191 Khanna R, Madhavan SS, Smith MJ, et al. Assessment of health-related quality of life among primary caregivers of children with autism spectrum disorders. J Autism Dev Disord. Sep. 2011;41(9):1214-27. X-4. [pmid: 21103917].
2192 Khorshid KA, Sweat RW, Zemba DA Jr, et al. Clinical efficacy of upper cervical versus full spine chiropractic care on children with autism: a randomized clinical trial. JVSR. 2006:1-7. X-3, X-4.
2193 Kielinen M, Hjelmquist E, Moilanen I, et al. Intervention, treatmentand care in autistic disorder. Challenging case reports from northern Finland. Int J Circumpolar Health. Feb. 2005;64(1):65-76. X-1, X-3, X-4. [pmid: 15776994].
2194 Kielinen M, Linna SL, Moilanen I. Some aspects of treatment and habilitation of children and adolescents with autistic disorder in Northern-Finland. Int J Circumpolar Health. Suppl 2. 2002;61:69-79. X-6. [pmid: 12585822].
2195 Kientz MA, Dunn W. A comparison of the performance of children with and without autism on the sensory profile. Am J Occup Ther. Jul–Aug. 1997;51(7):530-7. X-4. [pmid: 9242859].
2196 Kiernan C. The use of nonvocal communication techniques with autistic individuals. J Child Psychol Psychiatry. Jul. 1983;24(3):339-75. X-1, X-2, X-3, X-4. [pmid: 6874783].
2197 Kiernan C, Reid B. The use of augmentative communication systems in schools and units for autistic and aphasic children in the United Kingdom. Br J Disord Commun. Apr. 1984;19(1):47-61. X-1, X-3, X-4. [pmid: 6733032].
2198 Kiernan W. Where we are now: perspectives on employment of persons with mental retardation. Focus Autism Dev Disabil. Sum. 2000;15(2):90-6. 115. X-1, X-2, X-3, X-4.
2199 Kilchenstein MW, Schuerholz L. Autistic defenses and the impairment of cognitive development. Bull Menninger Clin. Fall. 1995;59(4):443-59. X-4. [pmid: 8535384].
2200 Kilham C. Online wiki collaboration by teachers of students with autism spectrum disorders. Australas J Spec Educ. Oct. 2009;33(2):117-29. X-1, X-3, X-4.
2201 Killion SW, McCarthy SM. Part I: assessment. Hospitalization of the autistic child. MCN Am J Matern Child Nurs. Nov–Dec. 1980;5(6):413-7. X-1, X-2, X-3, X-4. [pmid: 6776376].
2202 Killoran I, Tymon D, Frempong G. Disabilities and inclusive practices within toronto preschools. Int J Inclusive Educ. Jan. 2007;11(1):81-95. X-4.
2203 Kim J, Wigram T, Gold C. The effects of improvisational music therapy on joint attention behaviors in autistic children: a randomized controlled study. J Autism Dev Disord. Oct. 2008;38(9):1758-66. X-1, X-3, X-4. [pmid: 18592368].
2204 Kim J, Wigram T, Gold C. Emotional, motivational and interpersonal responsiveness of children with autism in improvisational music therapy. Autism. Jul. 2009;13(4):389-409. X-3. [pmid: 19535468].
2205 Kim S-Y, Yun J. Determining daily physical activity levels of youth with developmental disabilities: days of monitoring required?. Adapt Phys Activ Q. Jul. 2009;26(3):220-35. X-4. [pmid: 19799095].
2206 Kim Y, Cho SC, Shin MS, et al. Retrospective case series of aripiprazole augmentation in pervasive developmental disorders. Psychiatry Investig. Sep. 2010;7(3):220-3. X-1, X-3, X-4. [pmid: 20927312].
2207 Kim YS, Kumar S. Cross-cultural examination of social interactions during a one-week dousa-hou (japanese psychorehabilitation) camp. Psychol Rep. Dec. 2004;95(3,Part1):1050-4. X-4. [pmid: 15666954].
2208 King B, Zwi K, Nunn K, et al. Use of risperidone in a paediatric population: an observational study. J Paediatr Child Health. Sep–Oct. 2003;39(7):523-7. X-1, X-3, X-4. [pmid: 12969207].
2209 King BH. Pharmacological treatment of mood disturbances, aggression, and self-injury in persons with pervasive developmental disorders. J Autism Dev Disord. Oct. 2000;30(5):439-45. X-2. [pmid: 11098881].
2210 King BH, Davanzo P. Buspirone treatment of aggression and self-injury in autistic and nonautistic persons with severe mental retardation. Dev Brain Dysfunct. Jan–Feb. 1996;90(1):22-31. X-1.
2211 King BH, Hollander E, Sikich L, et al. Lack of efficacy of citalopram in children with autism spectrum disorders and high levels of repetitive behavior: citalopram ineffective in children with autism. Arch Gen Psychiatry. Jun. 2009;66(6):583-90. X-1, X-3. [pmid: 19487623].
2212 King BH, Wright DM, Handen BL, et al. Double-blind, placebo-controlled study of amantadine hydrochloride in the treatment of children with autistic disorder. J Am Acad Child Adolesc Psychiatry. Jun. 2001;40(6):658-65. X-1, X-3, X-4. [pmid: 11392343].
2213 King CR. A novel embryological theory of autism causation involving endogenous biochemicals capable of initiating cellular gene transcription: a possible link between twelve autism risk factors and the autism ‘epidemic’. Med Hypotheses. May. 2011;76(5):653-60. X-1, X-2, X-3, X-4. [pmid: 21388746].
2214 King GA, Zwaigenbaum L, King S, et al. A qualitative investigation of changes in the belief systems of families of children with autism or down syndrome. Child Care Health Dev. May. 2006;32(3):353-69. X-4. [pmid: 16634980].
2215 King MJ, Valdovinos MG. Social validity of behavioral practices in the treatment of autism—A review of the Super Nanny. Res Autism Spectr Disord. Jan. 2009;3(1):173-8. X-1, X-3, X-4.
2216 Kinnell HG. “Addiction” to a strait jacket: a case report of treatment of self-injurious behaviour in an autistic child. J Ment Defic Res. Mar. 1984;28(1):77-9. X-3. [pmid: 6716459].
2217 Kistner J, Robbins F, Haskett M. Assessment and skill remediation of hyperlexic children. J Autism Dev Disord. Jun. 1988;18(2):191-205. X-1, X-3, X-4. [pmid: 3410810].
2218 Kjelgaard MM, Tager-Flusberg H. An investigation of language impairment in autism: implications for genetic subgroups. Lang Cogn Process. 2001;16(2/3):287-308. X-4. [pmid: 16703115].
2219 Klaeger D, McDougle CJ. Secretin in autism—a parent’s perspective. J Autism Dev Disord. Feb. 2000;30(1):72-3. X-1, X-3, X-4. [pmid: 10819124].
2220 Klauber T. The significance of trauma in work with the parents of severely disturbed children, and its implications for work with parents in general. J Child Psychother. Apr. 1998;24(1):85-107. X-2, X-4.
2221 Klecan-Aker JS, Gill C. Teaching language organization to a child with pervasive developmental disorder: a case study. Child Lang Teach Ther. Feb. 2005;21(1):60-74. X-1, X-3, X-4.
2222 Kleeberger V, Mirenda P. Teaching generalized imitation skills to a preschooler with autism using video modeling. J Posit Behav Interv. 2010;12(2):116-27. X-1, X-3, X-4.
2223 Klein S. Autistic phenomena in neurotic patients. Int J Psychoanal. 1980;61(3):395-402. X-1, X-2, X-3, X-4. [pmid: 7440079].
2224 Klein U, Nowak AJ. Characteristics of patients with autistic disorder (AD) presenting for dental treatment: a survey and chart review. Spec Care Dentist. Sep–Oct. 1999;19(5):200-7. X-4. [pmid: 10765886].
2225 Klin A. Listening preferences in regard to speech in four children with developmental disabilities. J Child Psychol Psychiatry. May. 1992;33(4):763-9. X-4. [pmid: 1376327].
2226 Klin A, Lin DJ, Gorrindo P, et al. Two-year-olds with autism orient to non-social contingencies rather than biological motion. Nature. May. 14. 2009;459(7244):257-61. X-4. [pmid: 19329996].
2227 Klin A, Volkmar FR. Asperger syndrome. Child Adolesc Psychiatr Clin N Am. Jan. 2003;12(1):xiii-xvi. X-2. [pmid: 12512394].
2228 Klintwall L, Holm A, Eriksson M, et al. Sensory abnormalities in autism: A brief report. Res Dev Disabil: A Multidisciplinary Journal. Mar–Apr. 2011;32(2):795-800. X-1, X-3, X-4.
2229 Klykylo WM, et al. Clinical effects of fenfluramine in ten autistic subjects. J Autism Dev Disord. Dec. 1985;15(4):417-23. X-3. [pmid: 4077816].
2230 Knabe R, Bovier P. Pharmacological treatment of extreme self-injurious behavior in autism. European Psychiatry. 1992;7(6):297-8. X-3.
2231 Knabe R, Schulz P, Richard J. Initial aggravation of self-injurious behavior in autistic patients receiving naltrexone treatment. J Autism Dev Disord. Dec. 1990;20(4):591-3. X-2. [pmid: 2279977].
2232 Knapp M, Romeo R, Beecham J. Economic cost of autism in the UK. Autism. May. 2009;13(3):317-36. X-2. [pmid: 19369391].
2233 Knezevic B, Thompson L, Thompson M. Pilot project to ascertain the utility of Tower of London test to assess outcomes of neurofeedback in clients with asperger’s syndrome. J Neurother. Jan. 2010;14(1):3-19. X-3.
2234 Knivsberg AM, Reichelt KL, Hoien T, et al. A randomised, controlled study of dietary intervention in autistic syndromes. Nutr Neurosci. Sep. 2002;5(4):251-61. X-1, X-3, X-4. [pmid: 12168688].
2235 Knivsberg A-M, Reichelt K-L, Høien T, et al. Effect of a dietary intervention on autistic behavior. Focus Autism Dev Disabil. Win. 2003;18(4):247-56. X-1, X-3, X-4.
2236 Knivsberg A-M, Wiig K, Lind G, et al. Dietary intervention in autistic syndromes. Brain Dysfunction. Nov–Dec. 1990;3(5–6):315-27. X-3.
2237 Knoester M, Helmerhorst FM, van der Westerlaken LA, et al. Matched follow-up study of 5 8-year-old ICSI singletons: child behaviour, parenting stress and child (health-related) quality of life. Hum Reprod. Dec. 2007;22(12):3098-107. X-1, X-3, X-4. [pmid: 17905745].
2238 Kobayahi R. Affective communication of infants with autistic spectrum disorder and internal representation of their mothers. Psychiatry Clin Neurosci. Apr. 2000;54(2):235-43. X-1, X-3, X-4. [pmid: 10803821].
2239 Kobayashi R, Murata T, Yoshinaga K. A follow-up study of 201 children with autism in Kyushu and Yamaguchi areas, Japan. J Autism Dev Disord. Sep. 1992;22(3):395-411. X-4. [pmid: 1383189].
2240 Kodak T, Clements A. Acquisition of mands and tacts with concurrent echoic training. J Appl Behav Anal. Winter. 2009;42(4):839-43. X-1, X-3, X-4. [pmid: 20514191].
2241 Kodak T, Fisher WW, Clements A, et al. Functional assessment of instructional variables: linking assessment and treatment. Res Autism Spectr Disord. Jul–Sep. 2011;5(3):1059-77. X-3, X-4.
2242 Kodak T, Lerman DC, Volkert VM, et al. Further examination of factors that influence preference for positive versus negative reinforcement. J Appl Behav Anal. Spring. 2007;40(1):25-44. X-1, X-3, X-4. [pmid: 17471792].
2243 Kodak T, Miltenberger RG, Romaniuk C. The effects of differential negative reinforcement of other behavior and noncontingent escape on compliance. J Appl Behav Anal. Fall. 2003;36(3):379-82. X-1, X-3, X-4. [pmid: 14596581].
2244 Kodak T, Northup J, Kelley ME. An evaluation of the types of attention that maintain problem behavior. J Appl Behav Anal. Spring. 2007;40(1):167-71. X-1, X-3, X-4. [pmid: 17471800].
2245 Kodish S, Kulinna PH, Martin J, et al. Determinants of physical activity in an inclusive setting. Adapt Phys Activ Q. 2006;23(4):390-409. X-1, X-3, X-4.
2246 Koegel LK. Interventions to facilitate communication in autism. J Autism Dev Disord. Oct. 2000;30(5):383-91. X-2. [pmid: 11098873].
2247 Koegel LK, Carter CM, Koegel RL. Teaching children with autism self-initiations as a pivotal response. Top Lang Disord. Apr–Jun. 2003;23(2):134-45. X-3.
2248 Koegel LK, Koegel RL, Frea W, et al. Priming as a method of coordinating educational services for students with autism. Lang Speech Hear Serv Sch. Jul. 2003;34(3):228-35. X-3.
2249 Koegel LK, Koegel RL, Frea WD, et al. Identifying early intervention targets for children with autism in inclusive school settings. Behav Modif. Special Issue: Autism, Part 1. Oct. 2001;25(5):745-61. X-1, X-3, X-4. [pmid: 11573338].
2250 Koegel LK, Koegel RL, Green-Hopkins I, et al. Brief report: question-asking and collateral language acquisition in children with autism. J Autism Dev Disord. 2010;40(4):509-15. X-1, X-3, X-4.
2251 Koegel LK, Koegel RL, Hurley C, et al. Improving social skills and disruptive behavior in children with autism through self-management. J Appl Behav Anal. Summer. 1992;25(2):341-53. X-1, X-3, X-4. [pmid: 1634427].
2252 Koegel LK, Koegel RL, Nefdt N, et al. First S.T.E.P.: a model for the early identification of children with autism spectrum disorders. J Posit Behav Interv. 2005;7(4):247-52. X-2.
2253 Koegel LK, Koegel RL, Shoshan Y, et al. Pivotal response intervention II: preliminary long-term outcomes data. J Assoc Pers Sev Handicaps. Fal. 1999;24(3):186-98. X-1, X-3, X-4.
2254 Koegel LK, Singh AK, Koegel RL. Improving motivation for academics in children with autism. J Autism Dev Disord. Sep. 2010;40(9):1057-66. X-1, X-3, X-4. [pmid: 20221791].
2255 Koegel RL. Social development in individuals with high functioning autism and asperger disorder. Res Pract Persons Severe Disabl. Sum. 2007;32(2):140-1. X-2.
2256 Koegel RL, Bimbela A, Schreibman L. Collateral effects of parent training on family interactions. J Autism Dev Disord. Jun. 1996;26(3):347-59. X-1, X-3, X-4. [pmid: 8792265].
2257 Koegel RL, Camarata S, Koegel LK, et al. Increasing speech intelligibility in children with autism. J Autism Dev Disord. Jun. 1998;28(3):241-51. X-1, X-3, X-4. [pmid: 9656136].
2258 Koegel RL, Dunlap G, Dyer K. Intertrial interval duration and learning in autistic children. J Appl Behav Anal. Spring. 1980;13(1):91-9. X-1, X-3, X-4. [pmid: 7364701].
2259 Koegel RL, Egel AL, Williams JA. Behavioral contrast and generalization across settings in the treatment of autistic children. J Exp Child Psychol. Dec. 1980;30(3):422-37. X-1, X-3, X-4. [pmid: 7205139].
2260 Koegel RL, Frea WD. Treatment of social behavior in autism through the modification of pivotal social skills. J Appl Behav Anal. Fal. 1993;26(3):369-77. X-3. [pmid: 8407685].
2261 Koegel RL, Koegel LK. Extended reductions in stereotypic behavior of students with autism through a self-management treatment package. J Appl Behav Anal. Spring. 1990;23(1):119-27. X-1, X-3. [pmid: 2335483].
2262 Koegel RL, Koegel LK, Surratt A. Language intervention and disruptive behavior in preschool children with autism. J Autism Dev Disord. Jun. 1992;22(2):141-53. X-1, X-3, X-4. [pmid: 1378049].
2263 Koegel RL, O’Dell M, Dunlap G. Producing speech use in nonverbal autistic children by reinforcing attempts. J Autism Dev Disord. Dec. 1988;18(4):525-38. X-1, X-3, X-4. [pmid: 3215880].
2264 Koegel RL, O’Dell MC, Koegel LK. A natural language teaching paradigm for nonverbal autistic children. J Autism Dev Disord. Jun. 1987;17(2):187-200. X-1, X-3, X-4. [pmid: 3610995].
2265 Koegel RL, Openden D, Koegel LK. A systematic desensitization paradigm to treat hypersensitivity to auditory stimuli in children with autism in family contexts. Res Pract Persons Severe Disabl. Special Issue: Family and Disability. Sum. 2004;29(2):122-34. X-1, X-3, X-4.
2266 Koegel RL, Schreibman L, Loos LM, et al. Consistent stress profiles in mothers of children with autism. J Autism Dev Disord. Jun. 1992;22(2):205-16. X-4. [pmid: 1624405].
2267 Koegel RL, Shirotova L, Koegel LK. Antecedent stimulus control: using orienting cues to facilitate first-word acquisition for nonresponders with autism. Behav Anal. Fall. 2009;32(2):281-4. X-3, X-4. [pmid: 22478527].
2268 Koegel RL, Shirotova L, Koegel LK. Brief report: using individualized orienting cues to facilitate first-word acquisition in non-responders with autism. J Autism Dev Disord. Nov. 2009;39(11):1587-92. X-1, X-3, X-4. [pmid: 19488847].
2269 Koegel RL, Vernon TW, Koegel LK. Improving social initiations in young children with autism using reinforcers with embedded social interactions. J Autism Dev Disord. Sep. 2009;39(9):1240-51. X-1, X-3, X-4. [pmid: 19357942].
2270 Koegel RL, Werner GA, Vismara LA, et al. The effectiveness of contextually supported play date interactions between children with autism and typically developing peers. Res Pract Persons Severe Disabl. Sum. 2005;30(2):93-102. X-1, X-3, X-4.
2271 Koegel RL, Williams JA. Direct versus indirect response-reinforcer relationships in teaching autistic children. J Abnorm Child Psychol. Dec. 1980;8(4):537-47. X-1, X-3, X-4. [pmid: 7462531].
2272 Koenig K, De Los Reyes A, Cicchetti D, et al. Group intervention to promote social skills in school-age children with pervasive developmental disorders: reconsidering efficacy. J Autism Dev Disord. Aug. 2009;39(8):1163-72. X-2. [pmid: 19326199].
2273 Koenig K, White SW, Pachler M, et al. Promoting social skill development in children with pervasive developmental disorders: a feasibility and efficacy study. J Autism Dev Disord. Oct. 2010;40(10):1209-18. X-1, X-3, X-4. [pmid: 20204689].
2274 Koenig KP, Bleiweiss J, Brennan S, et al. The ASD Nest Program: a model for inclusive public education for students with autism spectrum disorders. Teach Except Child. Sep–Oct. 2009;42(1):6-13. X-2.
2275 Kogan MD, Strickland BB, Blumberg SJ, et al. A national profile of the health care experiences and family impact of autism spectrum disorder among children in the United States, 2005–2006. Pediatrics. Dec. 2008;122(6):e1149-58. X-4. [pmid: 19047216].
2276 Kohen-Raz R. Application of tetra-ataxiametric posturography in clinical and developmental diagnosis. Percept Mot Skills. Oct. 1991;73(2):635-56. X-4. [pmid: 1766798].
2277 Kohen-Raz R, Volkmar FR, Cohen DJ. Postural control in children with autism. J Autism Dev Disord. Sep. 1992;22(3):419-32. X-4. [pmid: 1383190].
2278 Kohler FW. Examining the services received by young children with autism and their families: a survey of parent responses. Focus Autism Dev Disabil. Fal. 1999;14(3):150-8. X-1, X-3, X-4.
2279 Kohler FW, Anthony LJ, Steighner SA, et al. Teaching social interaction skills in the integrated preschool: an examination of naturalistic tactics. Topics Early Child Spec Educ. Sum. 2001;21(2):93-103. 13. X-1, X-3, X-4.
2280 Kohler FW, Greteman C, Raschke D, et al. Using a buddy skills package to increase the social interactions between a preschooler with autism and her peers. Topics Early Child Spec Educ. Fall. 2007;27(3):155-63. X-1, X-3, X-4.
2281 Kohler FW, Strain PS, Hoyson M, et al. Using a group-oriented contingency to increase social interactions between children with autism and their peers. A preliminary analysis of corollary supportive behaviors. Behav Modif. Jan. 1995;19(1):10-32. X-1, X-3, X-4. [pmid: 7880156].
2282 Kohler FW, Strain PS, Hoyson M, et al. Merging naturalistic teaching and peer-based strategies to address the IEP objectives of preschoolers with autism: an examination of structural and child behavior outcomes. Focus Autism Dev Disabil. Win. 1997;12(4):196-206. X-1, X-3, X-4.
2283 Kohler FW, Strain PS, Maretsky S, et al. Promoting positive and supportive interactions between preschoolers: an analysis of group-oriented contingencies. J Early Interv. Fal. 1990;14(4):327-41. X-1, X-3, X-4.
2284 Kohler FW, Strain PS, Shearer DD. The overtures of preschool social skill intervention agents. Differential rates, forms, and functions. Behav Modif. Oct. 1992;16(4):525-42. X-4. [pmid: 1417712].
2285 Kohler JA, Shortland G, Rolles CJ. Effect of fenfluramine on autistic symptoms. Br Med J (Clin Res Ed). Oct. 10. 1987;295(6603):885. X-1. [pmid: 3119086].
2286 Kok AJ, Kong TY, Bernard-Opitz V. A comparison of the effects of structured play and facilitated play approaches on preschoolers with autism. A case study. Autism. Jun. 2002;6(2):181-96. X-1, X-3, X-4. [pmid: 12083284].
2287 Kokina A, Kern L. Social Story[TM] interventions for students with autism spectrum disorders: a meta-analysis. J Autism Dev Disord. Jul. 2010;40(7):812-26. X-1, X-2, X-3, X-4. [pmid: 20054628].
2288 Kokkinos CM, Davazoglou AM. Special education teachers under stress: evidence from a Greek national study. Educ Psychol. Jul. 2009;29(4):407-24. X-4.
2289 Kokubun M, Haishi K, Okuzumi H, et al. Factors affecting age of walking by children with mental retardation. Percept Mot Skills. Apr. 1995;80(2):547-52. X-1, X-3, X-4. [pmid: 7675588].
2290 Kolakowska T, Gadhvi H, Molyneux S. An open clinical trial of fenfluramine in chronic schizophrenia: a pilot study. Int Clin Psychopharmacol. Jan. 1987;2(1):83-8. X-3. [pmid: 2889761].
2291 Kolmen BK, Feldman HM, Handen BL, et al. Naltrexone in young autistic children: a double-blind, placebo-controlled crossover study. J Am Acad Child Adolesc Psychiatry. Feb. 1995;34(2):223-31. X-1, X-3, X-4. [pmid: 7896655].
2292 Kolmen BK, Feldman HM, Handen BL, et al. Naltrexone in young autistic children: replication study and learning measures. J Am Acad Child Adolesc Psychiatry. Nov. 1997;36(11):1570-8. X-1, X-3, X-4. [pmid: 9394942].
2293 Komori H, Matsuishi T, Yamada S, et al. Cerebrospinal fluid biopterin and biogenic amine metabolites during oral R-THBP therapy for infantile autism. J Autism Dev Disord. Apr. 1995;25(2):183-93. X-3. [pmid: 7559284].
2294 Komoto J, Usui S, Hirata J. Infantile autism and affective disorder. J Autism Dev Disord. Mar. 1984;14(1):81-4. X-3. [pmid: 6706898].
2295 Koning C, Magill-Evans J. Social and language skills in adolescent boys with asperger syndrome. Autism. Mar. 2001;5(1):23-36. X-4. [pmid: 11708387].
2296 Konstantareas M, et al. Variables related to parental choice to medicate their autistic children. J Autism Dev Disord. Aug. 1995;25(4):443-52. X-3, X-4. [pmid: 7592254].
2297 Konstantareas M, Homatidis S, Cesaroni L. Brief report: variables related to parental choice to medicate their autistic children. J Autism Dev Disord. Aug. 1995;25(4):443-52. X-4. [pmid: 7592254].
2298 Konstantareas M, Rios A, Ramnarace C. Intensive behavioural intervention (IBI) training: cooperation and its relationship to language and social competence in children with autism spectrum disorder (ASD). J Dev Disabil. 2010;16(2):67-8. X-3.
2299 Konstantareas MM. Autistic children exposed to simultaneous communication training: a follow-up. J Autism Dev Disord. Mar. 1987;17(1):115-31. X-3. [pmid: 3571136].
2300 Konstantareas MM, Gravelle G. Facilitated communication. Autism. Dec. 1998;2(4):389-414. X-3.
2301 Konstantareas MM, Homatidis S, Plowright CM. Assessing resources and stress in parents of severely dysfunctional children through the Clarke modification of Holroyd’s questionnaire on resources and stress. J Autism Dev Disord. Jun. 1992;22(2):217-34. X-4. [pmid: 1624406].
2302 Kontu E, Pirttimaa R. The assessment of severely intellectually disabled students. Eur J Spec Needs Educ. Feb. 2008;23(1):75-80. X-4.
2303 Kopp S, Beckung E, Gillberg C. Developmental coordination disorder and other motor control problems in girls with autism spectrum disorder and/or attention-deficit/hyperactivity disorder. Res Dev Disabil. Mar–Apr. 2010;31(2):350-61. X-1, X-3, X-4. [pmid: 19910158].
2304 Koppenhaver DA, Erickson KA. Natural emergent literacy supports for preschoolers with autism and severe communication impairments. Top Lang Disord. 2003;23(4):283. X-1, X-3, X-4.
2305 Koritsas S, Iacono T. Limitations in life participation and independence due to secondary conditions. Am J Intellect Dev Disabil. Nov. 2009;114(6):437-48. X-4. [pmid: 19792060].
2306 Korpilahti P, Jansson-Verkasalo E, Mattila ML, et al. Processing of affective speech prosody is impaired in asperger syndrome. J Autism Dev Disord. Sep. 2007;37(8):1539-49. X-4. [pmid: 17086440].
2307 Koshelev M, Lohrenz T, Vannucci M, et al. Biosensor approach to psychopathology classification. PLoS Comput Biol. 2010;6(10):e1000966. X-4. [pmid: 20975934].
2308 Koshes RJ, Rock NL. Use of clonidine for behavioral control in an adult patient with autism. Am J Psychiatry. Nov. 1994;151(11):1714. X-3. [pmid: 7943466].
2309 Koskentausta T, Iivanainen M, Almqvist F. Psychiatric disorders in children with intellectual disability. Nord J Psychiatry. 2002;56(2):126-31. X-4. [pmid: 11960565].
2310 Kostka MJ. A comparison of selected behaviors of a student with autism in special education and regular music classes. Music Ther Perspect. 1993;11(2):57-60. X-1, X-3, X-4.
2311 Kottorp A, Bernspang B, Fisher AG. Validity of a performance assessment of activities of daily living for people with developmental disabilities. J Intellect Disabil Res. Nov. 2003;47(Pt 8):597-605. X-4. [pmid: 14641807].
2312 Kouijzer MEJ, de Moor JMH, Gerrits BJL, et al. Long-term effects of neurofeedback treatment in autism. Res Autism Spectr Disord. Apr–Jun. 2009;3(2):496-501. X-1, X-3, X-4.
2313 Kouijzer MEJ, van Schie HT, de Moor JMH, et al. Neurofeedback treatment in autism. Preliminary findings in behavioral, cognitive, and neurophysiological functioning. Res Autism Spectr Disord. Jul–Sep. 2010;4(3):386-99. X-1, X-3, X-4.
2314 Kover ST, Abbeduto L. Expressive language in male adolescents with fragile X syndrome with and without comorbid autism. J Intellect Disabil Res. 2010;54(Part 3):246-65. X-3, X-4. [pmid: 20146742].
2315 Kovshoff H, Hastings RP, Remington B. Two-year outcomes for children with autism after the cessation of early intensive behavioral intervention. Behav Modif. Sep. 2011;35(5):427-50. X-1, X-3, X-4. [pmid: 21586502].
2316 Kowalski E, Lieberman LJ, Daggett S. Getting involved in the IEP process. J Phys Educ Recreat Dance. Sep. 2006;77(7):35-9. X-2.
2317 Koyama T, Wang HT. Use of activity schedule to promote independent performance of individuals with autism and other intellectual disabilities: a review. Res Dev Disabil: A Multidisciplinary Journal. Nov–Dec. 2011;32(6):2235-42. X-1, X-2, X-3, X-4.
2318 Kozima H, Michalowski MP, Nakagawa C. Keepon: A playful robot for research, therapy, and entertainment. Int J Social Robot. Jan. 2009;1(1):3-18. X-1, X-3, X-4.
2319 Kozima H, Nakagawa C, Yasuda Y. Children-robot interaction: a pilot study in autism therapy. Prog Brain Res. 2007;164:385-400. X-1, X-3, X-4. [pmid: 17920443].
2320 Kozleski EB. Reflections on “Visual symbol acquisition by students with autism”. Exceptionality. 1991;2(4):223-9. X-3.
2321 Kozleski EB. Visual symbol acquisition by students with autism. Exceptionality. 1991;2(4):173-94. X-3.
2322 Kozulin A, Lebeer J, Madella-Noja A, et al. Cognitive modifiability of children with developmental disabilities: a multicentre study using Feuerstein’s Instrumental Enrichment--Basic program. Res Dev Disabil. Mar–Apr. 2010;31(2):551-9. X-1, X-3, X-4. [pmid: 20056377].
2323 Krabe R, Bovier P. Norepinephrine antidepressants may increase self-injurious behavior in autistic syndromes. European Psychiatry. 1994;9(6):309-11. X-3.
2324 Kraemer BR, Cook CR, Browning-Wright D, et al. Effects of training on the use of the behavior support plan quality evaluation guide with autism educators. A preliminary investigation examining positive behavior support plans. J Posit Behav Interv. Jul. 2008;10(3):179-89. X-4.
2325 Kramer DA. The autistic moment in psychotherapy. Contemp Fam Ther: An International Journal. Special Issue: Contemp Fam Ther. Spr–Sum. 1987;9(1–2):79-89. X-3.
2326 Kramer DA, Anderson RB, Westman JC. The corrective autistic experience: An application of the models of Tinbergen and Mahler. Child Psychiatry Hum Dev. Win. 1984;15(2):104-20. X-1, X-3, X-4. [pmid: 6534639].
2327 Krantz PJ. Commentary: interventions to facilitate socialization. J Autism Dev Disord. Oct. 2000;30(5):411-3. X-2. [pmid: 11098876].
2328 Krantz PJ, MacDuff MT, McClannahan LE. Programming participation in family activities for children with autism: parents’ use of photographic activity schedules. J Appl Behav Anal. Spring. 1993;26(1):137-8. X-3. [pmid: 8473254].
2329 Krantz PJ, McClannahan LE. Teaching children with autism to initiate to peers: effects of a script-fading procedure. J Appl Behav Anal. Spring. 1993;26(1):121-32. X-1, X-3, X-4. [pmid: 8473251].
2330 Krantz PJ, McClannahan LE. Social interaction skills for children with autism: a script-fading procedure for beginning readers. J Appl Behav Anal. Summer. 1998;31(2):191-202. X-1, X-3, X-4. [pmid: 9652099].
2331 Krasny L, Williams BJ, Provencal S, et al. Social skills interventions for the autism spectrum: essential ingredients and a model curriculum. Child Adolesc Psychiatr Clin N Am. Jan. 2003;12(1):107-22. X-2. [pmid: 12512401].
2332 Kratochvil CJ, Findling RL, McDougle CJ, et al. Pharmacological management of agitation and aggression in an adolescent with autism. J Am Acad Child Adolesc Psychiatry. Aug. 2005;44(8):829. X-2. [pmid: 16034286].
2333 Krause M, Vainio L, Zwetchkenbaum S, et al. Dental education about patients with special needs: a survey of U.S. and Canadian dental schools. J Dent Educ. Nov. 2010;74(11):1179-89. X-1, X-3, X-4. [pmid: 21045222].
2334 Krauss MW, Gulley S, Sciegaj M, et al. Access to specialty medical care for children with mental retardation, autism, and other special health care needs. Ment Retard. Oct. 2003;41(5):329-39. X-4. [pmid: 12962535].
2335 Krauss MW, Seltzer MM, Jacobson HT. Adults with autism living at home or in non-family settings: positive and negative aspects of residential status. J Intellect Disabil Res. Feb. 2005;49(Pt 2):111-24. X-4. [pmid: 15634320].
2336 Kravits TR, Kamps DM, Kemmerer K, et al. Brief report: increasing communication skills for an elementary-aged student with autism using the picture exchange communication system. J Autism Dev Disord. Jun. 2002;32(3):225-30. X-1, X-3, X-4. [pmid: 12108624].
2337 Kring SR, Greenberg JS, Seltzer MM. The impact of health problems on behavior problems in adolescents and adults with autism spectrum disorders: implications for maternal burden. Soc Work Ment Health. Jan–Feb. 8. 2010;2010(1):54-71. X-4. [pmid: 20657702].
2338 Krishnamurthy V. A clinical experience of autism in India. J Dev Behav Pediatr. Aug. 2008;29(4):331-3. X-2. [pmid: 18698197].
2339 Kroeger K, Sorensen R. A parent training model for toilet training children with autism. J Intellect Disabil Res. Jun. 2010;54(6):556-67. X-1, X-3, X-4. [pmid: 20576064].
2340 Kroeger KA, Schultz JR, Newsom C. A comparison of two group-delivered social skills programs for young children with autism. J Autism Dev Disord. May. 2007;37(5):808-17. X-1, X-3, X-4. [pmid: 16927011].
2341 Kuban KC, O’Shea TM, Allred EN, et al. Positive screening on the modified checklist for autism in toddlers (M-CHAT) in extremely low gestational age newborns. J Pediatr. Apr. 2009;154(4):535-40. e1. X-4. [pmid: 19185317].
2342 Kuhn DE, DeLeon IG, Fisher WW, et al. Clarifying an ambiguous functional analysis with matched and mismatched extinction procedures. J Appl Behav Anal. Spring. 1999;32(1):99-102. X-1, X-3, X-4. [pmid: 10201106].
2343 Kuhn DE, Hardesty SL, Sweeney NM. Assessment and treatment of excessive straightening and destructive behavior in an adolescent diagnosed with autism. J Appl Behav Anal. Summer. 2009;42(2):355-60. X-3. [pmid: 19949524].
2344 Kuhn G, Kourkoulou A, Leekam SR. How magic changes our expectations about autism. Psychol Sci. Oct. 1. 2010;21(10):1487-93. X-4. [pmid: 20855904].
2345 Kuhn JC, Carter AS. Maternal self-efficacy and associated parenting cognitions among mothers of children with autism. Am J Orthopsychiatry. Oct. 2006;76(4):564-75. X-1, X-3, X-4. [pmid: 17209724].
2346 Kuhn SA, Lerman DC, Vorndran CM, et al. Analysis of factors that affect responding in a two-response chain in children with developmental disabilities. J Appl Behav Anal. Fall. 2006;39(3):263-80. X-1, X-3, X-4. [pmid: 17020209].
2347 Kujala T, Aho E, Lepisto T, et al. Atypical pattern of discriminating sound features in adults with asperger syndrome as reflected by the mismatch negativity. Biol Psychol. Apr. 2007;75(1):109-14. X-1, X-3, X-4. [pmid: 17257732].
2348 Kujala T, Kuuluvainen S, Saalasti S, et al. Speech-feature discrimination in children with asperger syndrome as determined with the multi-feature mismatch negativity paradigm. Clin Neurophysiol. Sep. 2010;121(9):1410-9. X-1, X-3, X-4. [pmid: 20382070].
2349 Kumandas S, Çaksen H, Çiftçi A, et al. Lamotrigine in two cases of Rett syndrome. Brain Dev. Jul. 2001;23(4):240-2. X-1, X-3, X-4. [pmid: 11377003].
2350 Kumar S, Alexander M, Gnanamuthu C. Recent experience with Rett syndrome at a tertiary care center. Neurol India. Dec. 2004;52(4):494-5. X-4. [pmid: 15626843].
2351 Kumar S, Kim YS, Oh KS. Development of a social interaction questionnaire for the trainers and mothers of children with disabilities participating in Dousa-hou (Japanese psycho-rehabilitation) camps. Psychol Rep. Oct. 2006;99(2):591-8. X-1, X-3, X-4. [pmid: 17153831].
2352 Kumsta R, Kreppner J, Rutter M, et al. Deprivation-specific psychological patterns. Monogr Soc Res Child Dev. Apr. 2010;75(1):48-78. X-1, X-2, X-3, X-4. [pmid: 20500633].
2353 Kuoch H, Mirenda P. Social story interventions for young children with autism spectrum disorders. Focus Autism Dev Disabil. Win. 2003;18(4):219-27. X-1, X-3, X-4.
2354 Kurita H. Brief Report: delusional disorder in a male adolescent with high-functioning PDDNOS. J Autism Dev Disord. Oct. 1999;29(5):419-23. X-3. [pmid: 10587888].
2355 Kurita H, Nakayasu N. An autistic male presenting seasonal affective disorder (SAD) and trichotillomania. J Autism Dev Disord. Oct. 1994;24(5):687-92. X-1, X-2, X-3, X-4. [pmid: 7814314].
2356 Kurt O, Tekin-Iftar E. A comparison of constant time delay and simultaneous prompting within embedded instruction on teaching leisure skills to children with autism. Topics Early Child Spec Educ. May. 2008;28(1):53-64. X-1, X-2, X-3, X-4.
2357 Kurth J, Mastergeorge AM. Individual education plan goals and services for adolescents with autism: impact of age and educational setting. J Spec Educ. Nov. 2010;44(3):146-60. X-3.
2358 Kurtz PF, Boelter EW, Jarmolowicz DP, et al. An analysis of functional communication training as an empirically supported treatment for problem behavior displayed by individuals with intellectual disabilities. Res Dev Disabil: A Multidisciplinary Journal. Nov–Dec. 2011;32(6):2935-42. X-1, X-2, X-3, X-4.
2359 Kusaga A, Yamashita Y, Koeda T, et al. Increased urine phenylethylamine after methylphenidate treatment in children with ADHD. Ann Neurol. Sep. 2002;52(3):372-4. X-1, X-3, X-4. [pmid: 12205654].
2360 Kvinsberg A-M, Reichelt KL, Nødland M, et al. Autistic syndromes and diet: A follow-up study. Scan J Educ Res. Sep. 1995;39(3):223-36. X-1, X-2, X-3, X-4.
2361 Lacava PG, Golan O, Baron-Cohen S, et al. Using assistive technology to teach emotion recognition to students with asperger syndrome: a pilot study. Remedial Spec Educ. May–Jun. 2007;28(3):174-81. X-1, X-3, X-4.
2362 Lacava PG, Rankin A, Mahlios E, et al. A single case design evaluation of a software and tutor intervention addressing emotion recognition and social interaction in four boys with ASD. Autism. 2010;14(3):161-78. X-3. [pmid: 20488823].
2363 Ladd MV, Luiselli JK, Baker L. Continuous access to competing stimulation as intervention for self-injurious skin picking in a child with autism. Child Fam Behav Ther. 2009;31(1):54-60. X-1, X-3, X-4.
2364 Laine F, Rauzy S, Tardif C, et al. Slowing down the presentation of facial and body movements enhances imitation performance in children with severe autism. J Autism Dev Disord. Aug. 2011;41(8):983-96. X-1, X-3, X-4. [pmid: 20960040].
2365 Lainhart JE, Folstein SE. Affective disorders in people with autism: a review of published cases. J Autism Dev Disord. Oct. 1994;24(5):587-602. X-1, X-2, X-3, X-4. [pmid: 7814308].
2366 Lal R. Effect of inclusive education on language and social development of children with autism. Asia Pac Disabil Rehab J. 2005;16(1):77-84. X-1, X-3, X-4.
2367 Lal R. Effect of alternative and augmentative communication on language and social behavior of children with autism. Educ Res Rev. Mar. 2010;5(3):119-25. X-1, X-3, X-4.
2368 Lal R, Bali M. Effect of visual strategies on development of communication skills in children with autism. Asia Pac Disabil Rehab J. 2007;18(2):120-30. IX-1, X-3, X-4.
2369 Lalli JS, et al. Reducing escape behavior and increasing task completion with functional communication training, extinction, and response chaining. J Appl Behav Anal. Fall. 1995;28(3):261-68. X-1, X-3, X-4. [pmid: 7592143].
2370 Lalli JS, Mace FC, Wohn T, et al. Identification and modification of a response-class hierarchy. J Appl Behav Anal. Win. 1995;28(4):551-9. X-3. [pmid: 16795881].
2371 Lam MK, Rao N. Developing a Chinese version of the psychoeducational profile (CPEP) to assess autistic children in Hong Kong. J Autism Dev Disord. Jun. 1993;23(2):273-9. X-4. [pmid: 8331048].
2372 Lam SF, Wong BP, Leung D, et al. How parents perceive and feel about participation in community activities. The comparison between parents of preschoolers with and without autism spectrum disorders. Autism. Jul. 2010;14(4):359-77. X-1, X-3, X-4. [pmid: 20591960].
2373 Lamm N, Greer RD. A systematic replication and a comparative analysis of CABAS. J Behav Educ. Dec. 1991;1(4):427-44. X-1, X-3, X-4.
2374 Lancioni GE. Using pictorial representations as communication means with low-functioning children. J Autism Dev Disord. Mar. 1983;13(1):87-105. X-3. [pmid: 6853441].
2375 Lancioni GE, Markus S, Behrendt M. A portable vibratory-feedback device for reducing excessive vocal loudness: A case study. Behav Cogn Psychother. Oct. 1998;26(4):371-6. X-3.
2376 Lancioni GE, Singh NN, O’Reilly MF, et al. Microswitch- and VOCA-assisted programs for two post-coma persons with minimally conscious state and pervasive motor disabilities. Res Dev Disabil: A Multidisciplinary Journal. Nov–Dec. 2009;30(6):1459-67. X-1, X-3, X-4.
2377 Landa RJ, Holman KC, O’Neill AH, et al. Intervention targeting development of socially synchronous engagement in toddlers with autism spectrum disorder: a randomized controlled trial. J Child Psychol Psychiatry. Jan. 2011;52(1):13-21. X-1, X-3, X-4. [pmid: 21126245].
2378 Landsberger SA, Diaz DR. Inpatient psychiatric treatment of deaf adults: demographic and diagnostic comparisons with hearing inpatients. Psychiatr Serv. Feb. 2010;61(2):196-9. X-4. [pmid: 20123828].
2379 Lane AE, Young RL, Baker AEZ, et al. Sensory processing subtypes in autism: association with adaptive behavior. J Autism Dev Disord. Jan. 2010;40(1):112-22. X-4. [pmid: 19644746].
2380 Lang R, Davis T, O’Reilly M, et al. Functional analysis and treatment of elopement across two school settings. J Appl Behav Anal. Spr. 2010;43(1):113-8. X-1, X-3, X-4. [pmid: 20808501].
2381 Lang R, O’Reilly M, Lancioni G, et al. Discrepancy in functional analysis results across two settings: implications for intervention design. J Appl Behav Anal. Sum. 2009;42(2):393-7. X-4. [pmid: 19949530].
2382 Lang R, O’Reilly M, Sigafoos J, et al. Enhancing the effectiveness of a play intervention by abolishing the reinforcing value of stereotypy: a pilot study. J Appl Behav Anal. Winter. 2009;42(4):889-94. X-4. [pmid: 20514199].
2383 Lang R, O’Reilly M, Sigafoos J, et al. The effects of an abolishing operation intervention component on play skills, challenging behavior, and stereotypy. Behav Modif. Jul. 2010;34(4):267-89. X-3. [pmid: 20562321].
2384 Lang R, Shogren KA, Machalicek W, et al. Video self-modeling to teach classroom rules to two students with asperger’s. Res Autism Spectr Disord. Apr–Jun. 2009;3(2):483-8. X-3.
2385 Langdon NA, Carr EG, Owen-Deschryver JS. Functional analysis of precursors for serious problem behavior and related intervention. Behav Modif. Nov. 2008;32(6):804-27. X-3. [pmid: 18456900].
2386 Langford F, Brooks P, Byrne A, et al. Autism research: evaluating parents’ perspectives of the autistic spectrum disorder diagnostic process in County Mayo, Ireland. Rehabilitation and Therapy Research Society Fourth Annual Conference. Phys Ther Rev. 2008;13(3):216. X-1, X-2, X-3, X-4.
2387 Langstrom N, Grann M, Ruchkin V, et al. Risk factors for violent offending in autism spectrum disorder: a national study of hospitalized individuals. J Interpers Violence. Aug. 2009;24(8):1358-70. X-4. [pmid: 18701743].
2388 Langworthy-Lam KS, Aman MG, Van Bourgondien ME. Prevalence and patterns of use of psychoactive medicines in individuals with autism in the Autism Society of North Carolina. J Child Adolesc Psychopharmacol. Winter. 2002;12(4):311-21. X-2. [pmid: 12625991].
2389 Lanovaz MJ, Fletcher SE, Rapp JT. Identifying stimuli that alter immediate and subsequent levels of vocal stereotypy: a further analysis of functionally matched stimulation. Behav Modif. Sep. 2009;33(5):682-704. X-4. [pmid: 19864321].
2390 Lanquetot R. The effectiveness of peer modeling with autistic children. J Dev Phys Disabil. Mar. 1989;2(1):25-34. X-1, X-3, X-4.
2391 Lanter E, Watson LR. Promoting literacy in students with ASD: the basics for the SLP. Lang Speech Hear Serv Sch. Jan. 2008;39(1):33-43. X-2, X-4. [pmid: 18162646].
2392 Lanyado M. Asymbolic and symbolic play: Developmental perspectives in the treatment of disturbed children. J Child Psychother. 1987;13(2):33-44. X-1, X-3, X-4.
2393 LaPerchia P. Behavioral disorders, learning disabilities and megavitamin therapy. Adolescence. Fall. 1987;22(87):729-38. X-1, X-2, X-3, X-4. [pmid: 2963502].
2394 Larkin AS, Gurry S. Brief report: progress reported in three children with autism using daily life therapy. J Autism Dev Disord. Aug. 1998;28(4):339-42. X-1, X-2, X-3, X-4. [pmid: 9711491].
2395 Larsen FW, Mouridsen SE. The outcome in children with childhood autism and asperger syndrome originally diagnosed as psychotic. A 30-year follow-up study of subjects hospitalized as children. Eur Child Adolesc Psychiatry. Dec. 1997;6(4):181-90. X-1, X-2, X-3, X-4. [pmid: 9442996].
2396 Larson E. Caregiving and autism: how does children’s propensity for routinization influence participation in family activities?. OTJR. 2006;26(2):69-79. X-3, X-4.
2397 Larson E. Ever vigilant: maternal support of participation in daily life for boys with autism. Phys Occup Ther Pediatr. Feb. 2010;30(1):16-27. X-3. [pmid: 20170429].
2398 Larson HJ, Cooper LZ, Eskola J, et al. Addressing the vaccine confidence gap. Lancet. Aug. 6. 2011;378(9790):526-35. X-1, X-2, X-3, X-4. [pmid: 21664679].
2399 Laski KE, Charlop MH, Schreibman L. Training parents to use the natural language paradigm to increase their autistic children’s speech. J Appl Behav Anal. Winter. 1988;21(4):391-400. X-3. [pmid: 3225256].
2400 Latif A, Heinz P, Cook R. Iron deficiency in autism and asperger syndrome. Autism. Mar. 2002;6(1):103-14. X-4. [pmid: 11918106].
2401 Lattimore LP, Parsons MB, Reid DH. A prework assessment of task preferences among adults with autism beginning a supported job. J Appl Behav Anal. Spring. 2002;35(1):85-8. X-3. [pmid: 11936551].
2402 Lattimore LP, Parsons MB, Reid DH. Assessing preferred work among adults with autism beginning supported jobs: identification of constant and alternating task preferences. Behav Int. Jul. 2003;18(3):161-77. X-3.
2403 Lattimore LP, Parsons MB, Reid DH. Enhancing job-site training of supported workers with autism: a reemphasis on simulation. J Appl Behav Anal. Spring. 2006;39(1):91-102. X-3. [pmid: 16602388].
2404 Lattimore LP, Parsons MB, Reid DH. Simulation training of community job skills for adults with autism: A further analysis. Behav Anal Pract. Spr. 2008;1(1):24-9. X-3. [pmid: 22477676].
2405 Lattimore LP, Parsons MB, Reid DH. Rapid training of a community job skill to nonvocal adults with autism: An extension of intensive teaching. Behav Anal Pract. Spr. 2009;2(1):34-42. X-1, X-3, X-4. [pmid: 22477694].
2406 Laud RB, Girolami PA, Boscoe JH, et al. Treatment outcomes for severe feeding problems in children with autism spectrum disorder. Behav Modif. Sep. 2009;33(5):520-36. X-1, X-3, X-4. [pmid: 19748900].
2407 Lauritsen MB, Mors O, Mortensen PB, et al. Medical disorders among inpatients with autism in Denmark according to ICD-8: a nationwide register-based study. J Autism Dev Disord. Apr. 2002;32(2):115-9. X-4. [pmid: 12058839].
2408 Laushey KM, Heflin LJ. Enhancing social skills of kindergarten children with autism through the training of multiple peers as tutors. J Autism Dev Disord. Jun. 2000;30(3):183-93. X-1, X-3, X-4. [pmid: 11055455].
2409 Laushey KM, Heflin LJ, Shippen M, et al. Concept mastery routines to teach social skills to elementary children with high functioning autism. J Autism Dev Disord. Oct. 2009;39(10):1435-48. X-1, X-3, X-4. [pmid: 19472042].
2410 Lavie T, Sturmey P. Training staff to conduct a paired-stimulus preference assessment. J Appl Behav Anal. Summer. 2002;35(2):209-11. X-4. [pmid: 12102143].
2411 Layton TL. Language training with autistic children using four different modes of presentation. J Commun Disord. Aug. 1988;21(4):333-50. X-1, X-3, X-4. [pmid: 3170784].
2412 Le Couteur A, Bailey A, Goode S, et al. A broader phenotype of autism: the clinical spectrum in twins. J Child Psychol Psychiatry. Oct. 1996;37(7):785-801. X-4. [pmid: 8923222].
2413 Le Couteur A, Haden G, Hammal D, et al. Diagnosing Autism Spectrum Disorders in Pre-School Children Using Two Standardised Assessment Instruments: The ADI-R and the ADOS. J Autism Dev Disord. Feb. 2008;38(2):362-72. X-4. [pmid: 17605097].
2414 Leach D, Duffy ML. Supporting Students with Autism Spectrum Disorders in Inclusive Settings. Interv School Clinic. 2009;45(1):31-7. X-2.
2415 Leach D, LaRocque M. Increasing Social Reciprocity in Young Children with Autism. Interv School Clinic. Jan. 2011;46(3):150-6. X-1, X-2, X-3, X-4.
2416 Leaf RB, Taubman MT, McEachin JJ, et al. 6604. Educ Treat Children. May. 2011;34(2):259-85. X-6.
2417 Leask J. Vaccination and risk communication: summary of a workshop. Arlington Virginia, USA. 5–6 October 2000. J Paediatr Child Health. Apr. 2002;38(2):124-8. [pmid: 12030991]. X-2, X-4.
2418 Lebedinskaya KS, Nikolskaya OS. Analysis of Autism and Its Treatment in Modern Russian Defectology. J Autism Dev Disord. Dec. 1993;23(4):675-79. X-1, X-2, X-3, X-4. [pmid: 8106307].
2419 Lebedinskaya KS, Nikolskaya OS. Brief report: analysis of autism and its treatment in modern Russian defectology. J Autism Dev Disord. Dec. 1993;23(4):675-9. X-1, X-3, X-4. [pmid: 8106307].
2420 LeBlanc LA, Carr JE, Crossett SE, et al. Intensive Outpatient Behavioral Treatment of Primary Urinary Incontinence of Children With Autism. Focus Autism Dev Disabil. Sum. 2005;20(2):98-105. X-1, X-3, X-4.
2421 LeBlanc LA, Coates AM, Daneshvar S, et al. Using video modeling and reinforcement to teach perspective-taking skills to children with autism. J Appl Behav Anal. Summer. 2003;36(2):253-7. X-3. [pmid: 12858990].
2422 Leblanc LA, Geiger KB, Sautter RA, et al. Using the Natural Language Paradigm (NLP) to increase vocalizations of older adults with cognitive impairments. Res Dev Disabil. Jul–Sep. 2007;28(4):437-44. X-1, X-3, X-4. [pmid: 16889934].
2423 Leblanc M-P, Ricciardi JN, Luiselli JK. Improving discrete trial instruction by paraprofessional staff through an abbreviated performance feedback intervention. Educ Treat Children. Feb. 2005;28(1):76-82. X-4.
2424 Leboyer M, Bouvard MP, Launay JM, et al. Brief report: a double-blind study of naltrexone in infantile autism. J Autism Dev Disord. Jun. 1992;22(2):309-19. X-1, X-3, X-4. [pmid: 1345670].
2425 Leboyer M, Bouvard MP, Launay J-M, et al. A double-blind study of naltrexone in infantile autism. J Autism Dev Disord. Jun. 1992;22(2):309-19. X-3. [pmid: 1345670].
2426 Leboyer M, Bouvard MP, Lensing P, et al. Opioid excess hypothesis of autism: A double-blind study of naltrexone. Brain Dysfunction. Nov–Dec. 1990;3(5–6):285-98. X-1, X-2, X-3, X-4.
2427 Lecavalier L, Leone S, Wiltz J. The impact of behaviour problems on caregiver stress in young people with autism spectrum disorders. J Intellect Disabil Res. Mar. 2006;50(Pt 3):172-83. X-4. [pmid: 16430729].
2428 Lechago SA, Carr JE. Recommendations for reporting independent variables in outcome studies of early and intensive behavioral intervention for autism. Behav Modif. Jul. 2008;32(4):489-503. X-2. [pmid: 18525063].
2429 Lechago SA, Carr JE, Grow LL, et al. Mands for information generalize across establishing operations. J Appl Behav Anal. Fall. 2010;43(3):381-95. X-3. [pmid: 21358900].
2430 Ledford JR, Gast DL. Feeding Problems in Children with Autism Spectrum Disorders: A Review. Focus Autism Dev Disabil. Fall. 2006;21(3):153-66. X-2, X-4.
2431 Ledford JR, Gast DL, Luscre D, et al. Observational and incidental learning by children with autism during small group instruction. J Autism Dev Disord. Jan. 2008;38(1):86-103. X-3, X-4. [pmid: 17347879].
2432 Lee A, Duggan ES, Schuntermann P. Autistic symptoms in a 21-year-old college student: Perspectives on diagnosis and treatment. Harvard Review of Psychiatry. Mar–Apr. 1999;6(6):313-21. X-3. [pmid: 10370438].
2433 Lee A, Hobson RP. Drawing self and others: how do children with autism differ from those with learning difficulties?. Br J Dev Psychol. 2006;24(Part 3):547-65. X-3, X-4.
2434 Lee A, Hobson RP, Chiat S. I, you, me, and autism: an experimental study. J Autism Dev Disord. Apr. 1994;24(2):155-76. X-4. [pmid: 8040159].
2435 Lee LC, Harrington RA, Chang JJ, et al. Increased risk of injury in children with developmental disabilities. Res Dev Disabil. May–Jun. 2008;29(3):247-55. X-1, X-3, X-4. [pmid: 17582739].
2436 Lee L-C, David AB, Rusyniak J, et al. Performance of the Social Communication Questionnaire in children receiving preschool special education services. Res Autism Spectr Disord. Apr–Jun. 2007;1(2):126-38. X-1, X-3, X-4.
2437 Lee M, Martin-Ruiz C, Graham A, et al. Nicotinic receptor abnormalities in the cerebellar cortex in autism. Brain: A Journal of Neurology. Jul. 2002;125(7):1483-95. X-4. [pmid: 12076999].
2438 Lee R, Sturmey P. The effects of lag schedules and preferred materials on variable responding in students with autism. J Autism Dev Disord. Apr. 2006;36(3):421-8. X-3. [pmid: 16568357].
2439 Lee S, Odom SL, Loftin R. Social Engagement with Peers and Stereotypic Behavior of Children with Autism. J Posit Behav Interv. 2007;9(2):67-79. X-1, X-3, X-4.
2440 Lee S-H, Poston D, Poston AJ. Lessons learned through implementing a positive behavior support intervention at home: A case study on self-management with a student with autism and his mother. Educ Train Dev Disabil. Dec. 2007;42(4):418-27. X-3.
2441 Lee S-H, Simpson RL, Shogren KA. Effects and Implications of Self-Management for Students with Autism: A Meta-Analysis. Focus Autism Dev Disabil. Spr. 2007;22(1):2-13. X-2.
2442 Lee-Dukes G. Infantile autism. Am Fam Physician. Jun. 1986;33(6):149-55. X-1, X-2, X-3, X-4. [pmid: 3716967].
2443 Leekam SR, Prior MR, Uljarevic M. Restricted and Repetitive Behaviors in Autism Spectrum Disorders: A Review of Research in the Last Decade. Psychological Bulletin. Jul. 2011;137(4):562-93. X-1, X-2, X-3, X-4. [pmid: 21574682].
2444 Leew SV, Stein NG, Gibbard WB. Weighted vests’ effect on social attention for toddlers with Autism Spectrum Disorders. Can J Occup Ther. Apr. 2010;77(2):113-24. X-1, X-3, X-4. [pmid: 20464896].
2445 Lefebvre D, Strain PS. Effects of a group contingency on the frequency of social interactions among autistic and nonhandicapped preschool children: Making LRE efficacious. J Early Interv. Fal. 1989;13(4):329-41. X-1, X-3, X-4.
2446 LeGoff DB. Use of LEGO as a therapeutic medium for improving social competence. J Autism Dev Disord. Oct. 2004;34(5):557-71. X-1, X-3. [pmid: 15628609].
2447 Legoff DB, Sherman M. Long-term outcome of social skills intervention based on interactive LEGO play. Autism. Jul. 2006;10(4):317-29. X-1, X-3, X-4. [pmid: 16908476].
2448 Leighton J, Bird G, Charman T, et al. Weak imitative performance is not due to a functional ‘mirroring’ deficit in adults with autism spectrum disorders. Neuropsychologia. 2008;46(4):1041-9. X-4. [pmid: 18177677].
2449 Leiman M. Ogden’s matrix of transference and the concept of sign. Br J Med Psychol. Sep. 2000;73(Pt 3):385-97. X-2. [pmid: 11003379].
2450 Lelord G, Barthélémy C, Martineau J, et al. Free acquisition, free imitation, physiological curiosity and exchange and development therapies in autistic children. Brain Dysfunction. Nov–Dec. 1991;4(6):335-47. X-1, X-3, X-4.
2451 Lelord G, Callaway E, Muh JP. Clinical and biological effects of high doses of vitamin B6 and magnesium on autistic children. Acta Vitaminol Enzymol. 1982;4(1–2):27-44. X-1, X-3. [pmid: 7124567].
2452 Lelord G, Muh JP, Barthelemy C, et al. Effects of pyridoxine and magnesium on autistic symptoms--initial observations. J Autism Dev Disord. Jun. 1981;11(2):219-30. X-1, X-3. [pmid: 6765503].
2453 Lemmon ME, Gregas M, Jeste SS. Risperidone use in autism spectrum disorders: a retrospective review of a clinic-referred patient population. J Child Neurol. Apr. 2011;26(4):428-32. X-1, X-3, X-4. [pmid: 20929907].
2454 Lemonnier E, Ben-Ari Y. The diuretic bumetanide decreases autistic behaviour in five infants treated during 3 months with no side effects. Acta Paediatr. Dec. 2010;99(12):1885-8. X-1, X-3, X-4. [pmid: 20608900].
2455 Lemos RR, Castelletti CH, Lima Filho JL, et al. In silico identification of new genetic variations as potential risk factors for Alzheimer’s disease in a microarray-oriented simulation. J Mol Neurosci. Sep. 2009;39(1–2):242-7. X-1, X-2, X-3, X-4. [pmid: 19290494].
2456 Lensing P, Klingler D, Lampl C, et al. Naltrexone open trial with a 5-year-old-boy. A social rebound reaction. Acta Paedopsychiatr. 1992;55(3):169-73. X-1, X-3, X-4. [pmid: 1414352].
2457 Leonard H, Nassar N, Bourke J, et al. Relation between intrauterine growth and subsequent intellectual disability in a ten-year population cohort of children in Western Australia. Am J Epidemiol. Jan. 1. 2008;167(1):103-11. X-4. [pmid: 17898000].
2458 Lepage JF, Tremblay S, Theoret H. Early non-specific modulation of corticospinal excitability during action observation. Eur J Neurosci. Mar. 2010;31(5):931-7. X-1, X-3, X-4. [pmid: 20374291].
2459 Lepisto T, Kajander M, Vanhala R, et al. The perception of invariant speech features in children with autism. Biol Psychol. Jan. 2008;77(1):25-31. X-4. [pmid: 17919805].
2460 Lepisto T, Kuitunen A, Sussman E, et al. Auditory stream segregation in children with Asperger syndrome. Biol Psychol. Dec. 2009;82(3):301-7. X-4. [pmid: 19751798].
2461 Lepisto T, Kujala T, Vanhala R, et al. The discrimination of and orienting to speech and non-speech sounds in children with autism. Brain Res. Dec. 20. 2005;1066(1–2):147-57. X-4. [pmid: 16325159].
2462 Lepisto T, Nieminen-von Wendt T, von Wendt L, et al. Auditory cortical change detection in adults with asperger syndrome. Neurosci Lett. Mar. 6. 2007;414(2):136-40. X-4. [pmid: 17197079].
2463 Lepisto T, Silokallio S, Nieminen-von Wendt T, et al. Auditory perception and attention as reflected by the brain event-related potentials in children with Asperger syndrome. Clin Neurophysiol. Oct. 2006;117(10):2161-71. X-4. [pmid: 16890012].
2464 Lerer E, Levi S, Salomon S, et al. Association between the oxytocin receptor (OXTR) gene and autism: relationship to Vineland Adaptive Behavior Scales and cognition. Mol Psychiatry. Oct. 2008;13(10):980-8. X-4. [pmid: 17893705].
2465 Lerman DC, Kelley ME, Vorndran CM, et al. Collateral effects of response blocking during the treatment of stereotypic behavior. J Appl Behav Anal. Spr. 2003;36(1):119-23. X-3. [pmid: 12723875].
2466 Lerman DC, Sansbury T, Hovanetz A, et al. Using behavior analysis to examine the outcomes of unproven therapies: an evaluation of hyperbaric oxygen therapy for children with autism. Behav Anal Pract. Win. 2008;1(2):50-8. X-1, X-3, X-4. [pmid: 22477688].
2467 Lerman DC, Tetreault A, Hovanetz A, et al. Further evaluation of a brief, intensive teacher-training model. J Appl Behav Anal. Summer. 2008;41(2):243-8. X-1, X-3, X-4. [pmid: 18595288].
2468 Lerman DC, Vorndran CM, Addison L, et al. Preparing Teachers in Evidence-Based Practices for Young Children with Autism. School Psychology Review. 2004;33(4):510-26. X-1, X-3, X-4.
2469 Lerner MD, Mikami AY, Levine K. Socio-dramatic affective-relational intervention for adolescents with Asperger syndrome & high functioning autism: Pilot study. Autism. Jan. 2011;15(1):21-42. X-3. [pmid: 20923890].
2470 Lerner V, Miodownik C, Kaptsan A, et al. Vitamin B6 as add-on treatment in chronic schizophrenic and schizoaffective patients: a double-blind, placebo-controlled study. J Clin Psychiatry. Jan. 2002;63(1):54-8. X-1, X-3, X-4. [pmid: 11838627].
2471 Leslie DL, Martin A. Health care expenditures associated with autism spectrum disorders. Arch Pediatr Adolesc Med. Apr. 2007;161(4):350-5. X-4. [pmid: 17404131].
2472 Leu RM, Beyderman L, Botzolakis EJ, et al. Relation of Melatonin to Sleep Architecture in Children with Autism. J Autism Dev Disord. Apr. 2011;41(4):427-33. X-2, X-3, X-4. [pmid: 20683768].
2473 Leung JP, Wu KI. Teaching receptive naming of Chinese characters to children with autism by incorporating echolalia. J Appl Behav Anal. Spring. 1997;30(1):59-68. X-1, X-3, X-4. [pmid: 9157099].
2474 Leung J-P, Chan OT. Teaching spontaneous verbal requests to Chinese children with autism using a time delay procedure. Bull Hong Kong Psychol Soc No. 1993;30(31–47):58. X-3.
2475 Leventhal BL, Cook EH Jr, Morford M, et al. Clinical and neurochemical effects of fenfluramine in children with autism. J Neuropsychiatry Clin Neurosci. Summer. 1993;5(3):307-15. X-3, X-4. [pmid: 8369641].
2476 Levin L, Carr EG. Food selectivity and problem behavior in children with developmental disabilities. Analysis and intervention. Behav Modif. Jul. 2001;25(3):443-70. X-1, X-3, X-4. [pmid: 11428248].
2477 Levin R, Heresco-Levy U, Bachner-Melman R, et al. Association between arginine vasopressin 1a receptor (AVPR1a) promoter region polymorphisms and prepulse inhibition. Psychoneuroendocrinology. Jul. 2009;34(6):901-8. X-4. [pmid: 19195791].
2478 Levine J. Controlled trials of inositol in psychiatry. Eur Neuropsychopharmacol. May. 1997;7(2):147-55. X-1, X-3, X-4. [pmid: 9169302].
2479 Levine J, Aviram A, Holan A, et al. Inositol treatment of autism. J Neural Transm. 1997;104(2–3):307-10. X-3. [pmid: 9203092].
2480 Levine JE. Behavior management principles: Incorporating a biopsychosocial perspective. Child Adolesc Social Work J. Aug. 2001;18(4):253-61. X-1, X-2, X-3.
2481 Levine K, Shane HC, Wharton RH. What if...: a plea to professionals to consider the risk-benefit ratio of facilitated communication. Ment Retard. Aug. 1994;32(4):300-4. discussion 14–7. X-1, X-2, X-3, X-4. [pmid: 7968563].
2482 Levinson LJ RG. The effects of exercise intensity on the stereotypic behaviors of individuals with autism. Adapt Phys Act Q. 1993;10:255-68. X-3.
2483 Levy A, Perry A. Transition of children with autism from intensive behavioural intervention programs into the school system. J Dev Disabil. 2008;14(1):1-10. X-1, X-2, X-3, X-4.
2484 Levy ML, Levy KM, Hoff D, et al. Vagus nerve stimulation therapy in patients with autism spectrum disorder and intractable epilepsy: results from the vagus nerve stimulation therapy patient outcome registry. J Neurosurg Pediatr. Jun. 2010;5(6):595-602. X-1, X-4. [pmid: 20515333].
2485 Levy S, Kim A-H, Olive ML. Interventions for young children with autism: a synthesis of the literature. Focus Autism Dev Disabil. Spr. 2006;21(1):55-62. X-2, X-4.
2486 Levy SE, Hyman SL. Alternative/complementary approaches to treatment of children with autism spectrum disorders. Infants Young Child. Jan. 2002;14(3):33-42. X-1, X-2, X-3, X-4.
2487 Levy SE, Hyman SL. Use of complementary and alternative treatments for children with autistic spectrum disorders is increasing. Pediatr Ann. Oct. 2003;32(10):685-91. X-2. [pmid: 14606219].
2488 Levy SE, Mandell DS, Merhar S, et al. Use of complementary and alternative medicine among children recently diagnosed with autistic spectrum disorder. J Dev Behav Pediatr. Dec. 2003;24(6):418-23. X-4. [pmid: 14671475].
2489 Levy SE, Souders MC, Ittenbach RF, et al. Relationship of dietary intake to gastrointestinal symptoms in children with autistic spectrum disorders. Biol Psychiatry. Feb. 15. 2007;61(4):492-7. X-1, X-3, X-4. [pmid: 17207470].
2490 Levy SE, Souders MC, Wray J, et al. Children with autistic spectrum disorders. I: comparison of placebo and single dose of human synthetic secretin. Arch Dis Child. Aug. 2003;88(8):731-6. X-1, X-3, X-4. [pmid: 12876177].
2491 Lewis JE. Are adolescents being hospitalized unnecessarily? The current use of hospitalization in psychiatric treatment. J Child Adolesc Psychiatr Ment Health Nurs. Oct–Dec. 1989;2(4):134-8. X-1, X-2, X-3, X-4. [pmid: 2585252].
2492 Lewis MH. Brief report: psychopharmacology of autism spectrum disorders. J Autism Dev Disord. Apr. 1996;26(2):231-35. X-1, X-2, X-3, X-4. [pmid: 8744491].
2493 Lewis MJ, Dictenberg JB. Genes, brain, and behavior: development gone awry in autism? A report on the 23rd Annual International Symposium of the Center for the Study of Gene Structure and Function. Ann N Y Acad Sci. Sep. Suppl 1. 2010;1205:E21-36. X-1, X-2, X-3, X-4. [pmid: 20860674].
2494 Li A. Identification and intervention for students who are visually impaired and who have autism spectrum disorders. Teach Except Child. Mar–Apr. 2009;41(4):22-32. X-2.
2495 Liakos AM, Bradley NK, Magram G, et al. Hydrocephalus and the reproductive health of women: the medical implications of maternal shunt dependency in 70 women and 138 pregnancies. Neurol Res. Jan. 2000;22(1):69-88. X-4. [pmid: 10672583].
2496 Liber DB, Frea WD, Symon JBG. Using time-delay to improve social play skills with peers for children with autism. J Autism Dev Disord. Feb. 2008;38(2):312-23. X-3. [pmid: 17546488].
2497 Licciardello CC, Harchik AE, Luiselli JK. Social skills intervention for children with autism during interactive play at a public elementary school. Educ Treat Children. 2008;31(1):27-37. X-1, X-3, X-4.
2498 Liddle EB, Batty MJ, Goodman R. The Social Aptitudes Scale: an initial validation. Soc Psychiatry Psychiatr Epidemiol. Jun. 2009;44(6):508-13. X-4. [pmid: 18979221].
2499 Liddle K. Implementing the picture exchange communication system (PECS). Int J Lang Commun Disord. Suppl. 2001;36:391-5. X-1, X-3, X-4. [pmid: 11340818].
2500 Lienemann J, Walker FD. Naltrexone for treatment of self-injury. Am J Psychiatry. Dec. 1989;146(12):1639-40. X-3. [pmid: 2589564].
2501 Lifter K, Ellis J, Cannon B, et al. Developmental specificity in targeting and teaching play activities to children with pervasive developmental disorders. J Early Interv. Sum. 2005;27(4):247-67. X-3.
2502 Light JC, Roberts B, Dimarco R, et al. Augmentative and alternative communication to support receptive and expressive communication for people with autism. J Commun Disord. Special Issue: Autism: New Perspectives on Assessment and Intervention. Mar–Apr. 1998;31(2):153-80. X-1, X-2, X-3, X-4. [pmid: 9549672].
2503 Lightdale JR, Hayer C, Duer A, et al. Effects of intravenous secretin on language and behavior of children with autism and gastrointestinal symptoms: a single-blinded, open-label pilot study. Pediatrics. Nov. 2001;108(5):E90. X-1, X-3, X-4. [pmid: 11694674].
2504 Lilly JD, Reed D. Perceptions of psychological contract violations in school districts that serve children with autism spectrum disorder: an exploratory qualitative study. J Appl School Psychol. Jun. 2004;20(1):27-45. X-3, X-4.
2505 Lim HA. Effect of “developmental speech and language training through music” on speech production in children with autism spectrum disorders. J Music Ther. Spring. 2010;47(1):2-26. X-1, X-3, X-4. [pmid: 20635521].
2506 Lim SM, Kattapuram A, Lian WB. Evaluation of a pilot clinic-based social skills Group. Br J Occup Ther. Jan. 2007;70(1):35-9. X-1, X-3, X-4.
2507 Lincoln AJ, Courchesne E, Harms L, et al. Contextual probability evaluation in autistic, receptive developmental language disorder, and control children: event-related brain potential evidence. J Autism Dev Disord. Mar. 1993;23(1):37-58. X-4. [pmid: 8463201].
2508 Lincoln AJ, Courchesne E, Harms L, et al. Sensory modulation of auditory stimuli in children with autism and receptive developmental language disorder: event-related brain potential evidence. J Autism Dev Disord. Oct. 1995;25(5):521-39. X-4. [pmid: 8567597].
2509 Lincoln AJ, Dickstein P, Courchesne E, et al. Auditory processing abilities in non-retarded adolescents and young adults with developmental receptive language disorder and autism. Brain Lang. Nov. 1992;43(4):613-22. X-3, X-4. [pmid: 1483193].
2510 Linday LA. Oral famotidine: a potential treatment for children with autism. Med Hypotheses. May. 1997;48(5):381-6. X-2, X-4. [pmid: 9185122].
2511 Linday LA, Tsiouris JA, Cohen IL, et al. Famotidine treatment of children with autistic spectrum disorders: pilot research using single subject research design. J Neural Transm. 2001;108(5):593-611. X-1, X-3, X-4. [pmid: 11459079].
2512 Lindsay G. The collection and analysis of data on children with speech, language and communication needs: the challenge to education and health services. Child Lang Teach Ther. Jun. 2011;27(2):135-50. X-1, X-3, X-4.
2513 Lindsay G, Hannon P, Hannon V. Independent psychological opinions. Educ Child Psychol. 1986;3(3):123-9. X-1, X-3, X-4.
2514 Lindsay RL, Aman MG. Pharmacologic therapies aid treatment for autism. Pediatr Ann. Oct. 2003;32(10):671-6. X-2, X-4. [pmid: 14606217].
2515 Lindsay RL, Eugene Arnold L, Aman MG, et al. Dietary status and impact of risperidone on nutritional balance in children with autism: a pilot study. J Intellect Dev Disabil. Dec. 2006;31(4):204-9. X-1, X-3, X-4. [pmid: 17178532].
2516 Lindsay WR, Michie AM, Marshall I, et al. The effects of behaviour relaxation training on adults with profound multiple disabilities: a preliminary study on treatment effectiveness. Br J Learn Disabil. 1996;24(3):119-23. X-3.
2517 Lindstrom K, Lagerroos P, Gillberg C, et al. Teenage outcome after being born at term with moderate neonatal encephalopathy. Pediatr Neurol. Oct. 2006;35(4):268-74. X-4. [pmid: 16996401].
2518 Link HM. Auditory integration training (AIT): sound therapy? Case studies of three boys with autism who received AIT. Br J Learn Disabil. 1997;25(3):106-10. X-3.
2519 Links PS, Stockwell M, Abichandani F, et al. Minor physical anomalies in childhood autism. Part I. Their relationship to pre- and perinatal complications. J Autism Dev Disord. Sep. 1980;10(3):273-85. X-4. [pmid: 6927654].
2520 Linscheid TR, Hartel F, Cooley N. Are aversive procedures durable? A five year follow-up of three individuals treated with contingent electric shock. Child Adolesc Ment Health Care. Special Issue: Aversives: II. Fal. 1993;3(2):67-76. X-4.
2521 Lionello-DeNolf KM, da Silva Barros R, McIllvane WJ. A novel method for teaching the first instances of simple discrimination to nonverbal children with autism in a laboratory environment. Psychol Rec. Spr. 2008;58(2):229-44. X-1, X-3, X-4. [pmid: 19606260].
2522 Lionello-DeNolf KM, Dube WV, McIlvane WJ. Evaluation of resistance to change under different disrupter conditions in children with autism and severe intellectual disability. J Exp Anal Behav. May. 2010;93(3):369-83. X-1, X-3, X-4. [pmid: 21119851].
2523 Lippiello PM. Nicotinic cholinergic antagonists: a novel approach for the treatment of autism. Med Hypotheses. 2006;66(5):985-90. X-2, X-4. [pmid: 16406687].
2524 Liptak GS, Benzoni LB, Mruzek DW, et al. Disparities in diagnosis and access to health services for children with autism: data from the National Survey of Children’s Health. J Dev Behav Pediatr. Jun. 2008;29(3):152-60. X-4. [pmid: 18349708].
2525 Liptak GS, Orlando M, Yingling JT, et al. Satisfaction with primary health care received by families of children with developmental disabilities. J Pediatr Health Care. Jul–Aug. 2006;20(4):245-52. X-4. [pmid: 16831632].
2526 Liptak GS, Stuart T, Auinger P. Health care utilization and expenditures for children with autism: data from U.S. national samples. J Autism Dev Disord. Oct. 2006;36(7):871-9. X-4. [pmid: 16855879].
2527 Lisboa FL, Butterfield SA, Reif G, et al. ALT-PE by children with autism placed in regular, reversed mainstreamed, and adapted physical education classes. Percept Mot Skills. Apr. 1995;80(2):553-4. X-1, X-3. [pmid: 7675589].
2528 Little L. Differences in stress and coping for mothers and fathers of children with asperger’s syndrome and nonverbal learning disorders. Pediatr Nurs. Nov–Dec. 2002;28(6):565-70. X-1, X-2, X-3, X-4. [pmid: 12593341].
2529 Little L, Clark RR. Wonders and worries of parenting a child with Asperger syndrome & nonverbal learning disorder. MCN Am J Matern Child Nurs. Jan–Feb. 2006;31(1):39-44. X-4. [pmid: 16371824].
2530 Liu C, Conn K, Sarkar N, et al. Physiology-based affect recognition for computer-assisted intervention of children with Autism Spectrum Disorder. International Journal of Human-Computer Studies. Sep. 2008;66(9):662-77. X-4.
2531 Liu KY, King M, Bearman PS. Social influence and the autism epidemic. AJS. Mar. 2010;115(5):1387-434. X-1, X-3, X-4. [pmid: 20503647].
2531 Liu-Gitz L, Banda DR. A replication of the RIRD strategy to decrease vocal stereotypy in a student with autism. Behav Int. Feb. 2010;25(1):77-87. X-3.
2532 Livanis A, Mouzakitis A. The treatment validity of autism screening instruments. Assess Eff Interv. Sep. 2010;35(4):206-17. X-1, X-2, X-3, X-4.
2534 Lloyd H, Dallos R. Solution-focused brief therapy with families who have a child with intellectual disabilities: A description of the content of initial sessions and the processes. Clin Child Psychol Psychiatry. Jul. 2006;11(3):367-86. X-4. [pmid: 17080774].
2535 Lloyd H, Paintin K, Botting N. Performance of children with different types of communication impairment on the clinical evaluation of language fundamentals (CELF). Child Lang Teach Ther. 2006;22(1):47-67. X-1, X-3, X-4.
2536 Locascio JJ, Malone RP, Small AM, et al. Factors related to haloperidol response and dyskinesias in autistic children. Psychopharmacol Bull. 1991;27(2):119-26. X-4. [pmid: 1924657].
2537 Lochbaum M, Crews D. Viability of cardiorespiratory and muscular strength programs for the adolescent with autism. Complement Health Pract Rev. 2003;8(3):225-33. X-3.
2538 Locke J, Ishijima EH, Kasari C, et al. Loneliness, friendship quality and the social networks of adolescents with high-functioning autism in an inclusive school setting. J Res Spec Educ Needs. Jun. 2010;10(2):74-81. X-3.
2539 Loebl D, Willems B, Nordin M. Database analysis of injury patterns in an institution for developmental disabilities. J Occup Rehabil. Sep. 1995;5(3):169-84. X-4.
2540 Loftin RL, Odom SL, Lantz JF. Social interaction and repetitive motor behaviors. J Autism Dev Disord. Jul. 2008;38(6):1124-35. X-1, X-3, X-4. [pmid: 18064552].
2541 Lohiya GS, Tan-Figueroa L, Iannucci A. Identification of low bone mass in a developmental center: finger bone mineral density measurement in 562 residents. J Am Med Dir Assoc. Nov–Dec. 2004;5(6):371-6. X-4. [pmid: 15530174].
2542 Lomas JE, Fisher WW, Kelley ME. The effects of variable-time delivery of food items and praise on problem behavior reinforced by Escape. J Appl Behav Anal. Fall. 2010;43(3):425-35. X-1, X-3, X-4. [pmid: 21358903].
2543 Long D. Predicting length of service provision in school-based occupational therapy. Phys Occup Ther Pediatr. 2003;23(4):79-93. X-1, X-2, X-3, X-4. [pmid: 14750310].
2544 Long K, Wood H, Holmes N. Presentation, assessment and treatment of depression in a young woman with learning disability and autism. Br J Learn Disabil. Sep. 2000;28(3):102-8. X-1, X-2, X-3, X-4.
2545 Longhurst J, Richards D, Copenhaver J, et al. “Outside In”: group treatment of youth with asperger’s. Reclaiming Child Youth. 2010;19(3):40-4. X-1, X-2, X-3, X-4.
2546 Longo N, Ardon O, Vanzo R, et al. Disorders of creatine transport and metabolism. Am J Med Genet C Semin Med Genet. Feb. 15. 2011;157(1):72-8. X-1, X-2, X-3, X-4. [pmid: 21308988].
2547 Longtin SE, Fabus RL. The use of videotape self-monitoring to facilitate interactive intervention in speech-language therapy with preschool children with autism. Clin Superv. 2008;27(1):111-33. X-4.
2548 Lonsdale D, Shamberger RJ. A clinical study of secretin in autism and pervasive developmental delay. J Nutr Environ Med. 2000;10(4):271-80. X-1, X-3, X-4.
2549 Lonsdale D, Shamberger RJ, Audhya T. Treatment of autism spectrum children with thiamine tetrahydrofurfuryl disulfide: a pilot study. Neuro Endocrinol Lett. Aug. 2002;23(4):303-8. X-3. [pmid: 12195231].
2550 Loo CY, Graham RM, Hughes CV. The caries experience and behavior of dental patients with autism spectrum disorder. J Am Dent Assoc. Nov. 2008;139(11):1518-24. X-4. [pmid: 18978390].
2551 Loo CY, Graham RM, Hughes CV. Behaviour guidance in dental treatment of patients with autism spectrum disorder. Int J Paediatr Dent. Nov. 2009;19(6):390-8. X-4. [pmid: 19619200].
2552 Lopata C, Thomeer ML, Volker MA, et al. Effectiveness of a cognitive-behavioral treatment on the social behaviors of children with asperger disorder. Focus Autism Dev Disabil. Win. 2006;21(4):237-44. X-1, X-3, X-4.
2553 Lopata C, Thomeer ML, Volker MA, et al. Effectiveness of a manualized summer social treatment program for high-functioning children with autism spectrum disorders. J Autism Dev Disord. May. 2008;38(5):890-904. X-1, X-3, X-4. [pmid: 18058012].
2554 Lopata C, Thomeer ML, Volker MA, et al. RCT of a manualized social treatment for high-functioning autism spectrum disorders. J Autism Dev Disord. Nov. 2010;40(11):1297-310. X-1, X-3, X-4. [pmid: 20232240].
2555 Lord C. What is melatonin? Is it a useful treatment for sleep problems in autism?. J Autism Dev Disord. Aug. 1998;28(4):345-6. X-2. [pmid: 9711493].
2556 Lord C, Merrin DJ, Vest LO, et al. Communicative behavior of adults with an autistic four-year-old boy and his nonhandicapped twin brother. J Autism Dev Disord. Mar. 1983;13(1):1-17. X-1, X-3, X-4. [pmid: 6853435].
2557 Lord C, Schopler E. Stability of assessment results of autistic and non-autistic language-impaired children from preschool years to early school age. J Child Psychol Psychiatry. Jul. 1989;30(4):575-90. X-1, X-3, X-4. [pmid: 2768359].
2558 Lord C, Wagner A, Rogers S, et al. Challenges in evaluating psychosocial interventions for Autistic Spectrum Disorders. J Autism Dev Disord. Dec. 2005;35(6):695-708. discussion 9–11. X-2, X-4. [pmid: 16496206].
2559 Lorence D. Examining online chat within a domain of uncertainty: the case of asperger’s syndrome. Health Info Libr J. Jun. 2007;24(2):128-36. X-4. [pmid: 17584216].
2560 Loth E, Happe F, Gomez JC. Variety is not the spice of life for people with autism spectrum disorders: frequency ratings of central, variable and inappropriate aspects of common real-life events. J Autism Dev Disord. Jun. 2010;40(6):730-42. X-1, X-4. [pmid: 20066484].
2561 Lounds J, Seltzer MM, Greenberg JS, et al. Transition and change in adolescents and young adults with autism: longitudinal effects on maternal well-being. Am J Ment Retard. Nov. 2007;112(6):401-17. X-4. [pmid: 17963433].
2562 Loutzenhiser L, Hadjistavropoulos H. Enhancing interprofessional patient-centered practice for children with autism spectrum disorders: a pilot project with pre-licensure health students. J Interprof Care. Aug. 2008;22(4):429-31. X-2. [pmid: 18800283].
2563 Lovaas I, Newsom C, Hickman C. Self-stimulatory behavior and perceptual reinforcement. J Appl Behav Anal. Spring. 1987;20(1):45-68. X-1, X-2, X-3, X-4. [pmid: 3583964].
2564 Lovaas OI. Behavioral treatment and normal educational and intellectual functioning in young autistic children. J Consult Clin Psychol. Feb. 1987;55(1):3-9. X-1, X-3, X-4. [pmid: 3571656].
2565 Lovaas OI. The development of a treatment-research project for developmentally disabled and autistic children. J Appl Behav Anal. Winter. 1993;26(4):617-30. X-1, X-2, X-3, X-4. [pmid: 8307839].
2566 Lovaas OI, Smith T, McEachin JJ. Clarifying comments on the young autism study: reply to Schopler, Short, and Mesibov. J Consult Clin Psychol. Feb. 1989;57(1):165-7. X-1, X-2, X-3, X-4. [pmid: 2925969].
2567 Love JR, Carr JE, Almason SM, et al. Early and intensive behavioral intervention for autism: A survey of clinical practices. Res Autism Spectr Disord. Apr–Jun. 2009;3(2):421-8. X-4.
2568 Love SR, Matson JL, West D. Mothers as effective therapists for autistic children’s phobias. J Appl Behav Anal. Fall. 1990;23(3):379-85. X-3. [pmid: 2249973].
2569 Loveland KA, Kelley ML. Development of adaptive behavior in adolescents and young adults with autism and down syndrome. Am J Ment Retard. Jul. 1988;93(1):84-92. X-4. [pmid: 2970861].
2570 Loveland KA, Kelley ML. Development of adaptive behavior in preschoolers with autism or down syndrome. Am J Ment Retard. Jul. 1991;96(1):13-20. X-4. [pmid: 1831619].
2571 Low J, Goddard E, Melser J. Generativity and imagination in autism spectrum disorder: evidence from individual differences in children’s impossible entity drawings. Br J Dev Psychol. 2009;27(Part 2):425-44. X-4. [pmid: 19998539].
2572 Lowe K, Felce D, Perry J, et al. The characteristics and residential situations of people with severe intellectual disability and the most severe challenging behaviour in Wales. J Intellect Disabil Res. Oct. 1998;42(Pt 5):375-89. X-4. [pmid: 9828069].
2573 Lowe O, Lindemann R. Assessment of the autistic patient’s dental needs and ability to undergo dental examination. ASDC J Dent Child. Jan–Feb. 1985;52(1):29-35. X-1, X-3, X-4. [pmid: 3156901].
2574 Lowery EF. Autistic aloofness reconsidered: Case reports of two children in play therapy. Bull Menninger Clin. Mar. 1985;49(2):135-50. X-1, X-3, X-4. [pmid: 3978303].
2575 Lozzi-Toscano B. The “dance” of communication: Counseling families and children with asperger’s syndrome. Fam J Alex Va. Jan. 2004;12(1):53-7. X-2, X-4.
2576 Lu L, Petersen F, Lacroix L, et al. Stimulating creative play in children with autism through sandplay. Arts Psychother. Feb. 2010;37(1):56-64. X-1, X-3, X-4.
2577 Lubetsky MJ, Mueller L, Madden K, et al. Family-centered/interdisciplinary team approach to working with families of children who have mental retardation. Ment Retard. Aug. 1995;33(4):251-6. X-3. [pmid: 7565148].
2578 Lubin R, Jacobson JW, Kiely M. Projected impact of the functional definition of developmental disabilities: the categorically disabled population and service eligibility. Am J Ment Defic. Jul. 1982;87(1):73-9. X-1, X-2, X-3, X-4. [pmid: 6181686].
2579 Luby J, Mrakotsky C, Stalets MM, et al. Risperidone in preschool children with autistic spectrum disorders: an investigation of safety and efficacy. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):575-87. X-1, X-3, X-4. [pmid: 17069546].
2580 Lucarelli S, Frediani T, Zingoni AM, et al. Food allergy and infantile autism. Panminerva Med. Sep. 1995;37(3):137-41. X-1, X-3, X-4. [pmid: 8869369].
2581 Luce SC, Christian WP, Anderson SR, et al. Development of a continuum of services for children and adults with autism and other severe behavior disorders. Res Dev Disabil. 1992;13(1):9-25. X-2. [pmid: 1585026].
2582 Luce SC, Dyer K. Providing effective transitional programming to individuals with autism. Behav Disord. Nov. 1995;21(1):36-52. X-2, X-3, X-4.
2583 Luckett T, Bundy A, Roberts J. Do behavioural approaches teach children with autism to play or are they pretending?. Autism. 2007;11(4):365-88. X-2, X-4. [pmid: 17656400].
2584 Lucyshyn JM, Albin RW, Horner RH, et al. Family implementation of positive behavior support for a child with autism: Longitudinal, single-case, experimental, and descriptive replication and extension. J Posit Behav Interv. Sum. 2007;9(3):131-50. X-3.
2585 Lucyshyn JM, Irvin LK, Blumberg ER, et al. Validating the construct of coercion in family routines: expanding the unit of analysis in behavioral assessment with families of children with developmental disabilities. Res Pract Persons Severe Disabl. Sum. 2004;29(2):104-21. X-1, X-2, X-3, X-4.
2586 Luisell JK, Campbell S, Cannon B, et al. Assessment instruments used in the education and treatment of persons with autism: brief report of a survey of national service centers. Res Dev Disabil. Sep–Oct. 2001;22(5):389-98. X-4. [pmid: 11580165].
2587 Luiselli JK. Case demonstration of a fading procedure to promote school attendance of a child with Asperger’s disorder. J Posit Behav Interv. Win. 2000;2(1):47-52. X-1, X-2, X-3, X-4.
2588 Luiselli JK, Blew P, Keane J, et al. Pharamcotherapy for severe aggression in a child with autism: “open-label” evaluation of multiple medications on response frequency and intensity of behavioral intervention. J Behav Ther Exp Psychiatry. Sep–Dec. 2000;31(3–4):219-30. X-1, X-2, X-3, X-4. [pmid: 11494958].
2589 Luiselli JK, Blew P, Thibadeau S. Therapeutic effects and long-term efficacy of antidepressant medication for persons with developmental disabilities: behavioral assessment in two cases of treatment-resistant aggression and self-injury. Behav Modif. Jan. 2001;25(1):62-78. X-3. [pmid: 11151486].
2590 Luiselli JK, Cannon BOM, Ellis JT, et al. Home-based behavioral interventions for young children with autism/pervasive developmental disorder: A preliminary evaluation of outcome in relation to child age and intensity of service delivery. Autism. Dec. 2000;4(4):426-38. X-1, X-2, X-3, X-4.
2591 Luiselli JK, Cochran ML, Huber SA. Effects of otitis media on a child with autism receiving behavioral intervention for self-injury. Child Fam Behav Ther. 2005;27(2):51-6. X-1, X-2, X-3, X-4.
2592 Luiselli JK, Kane A, Treml T, et al. Behavioral intervention to reduce physical restraint of adolescents with developmental disabilities. Behav Int. Oct–Dec. 2000;15(4):317-30. X-3.
2593 Luiselli JK, Medeiros J, Jasinowski C, et al. Behavioral medicine treatment of ruminative vomiting and associated weight loss in an adolescent with autism. J Autism Dev Disord. Oct. 1994;24(5):619-29. X-3, X-4. [pmid: 7814310].
2594 Luiselli JK, Ricciardi JN, Gilligan K. Liquid fading to establish milk consumption by a child with autism. Behav Int. Apr. 2005;20(2):155-63. X-1, X-2, X-3, X-4.
2595 Luiselli JK, Ricciardi JN, Schmidt S, et al. Brief functional analysis and intervention evaluation for treatment of saliva-play. Child Fam Behav Ther. 2004;26(3):53-61. X-1, X-2, X-3, X-4.
2596 Luiselli JK, Suskin L, Slocumb PR. Application of immobilization time-out in management programming with developmentally disabled children. Child Fam Behav Ther. Spr. 1984;6(1):1-15. X-1, X-2, X-3, X-4.
2597 Luiselli JK, Wolongevicz J, Egan P, et al. The family support program: description of a preventive, community-based behavioral intervention for children with pervasive developmental disorders. Child Fam Behav Ther. 1999;21(1):1-18. X-2, X-3.
2598 Luman M, Van Meel CS, Oosterlaan J, et al. Does reward frequency or magnitude drive reinforcement-learning in attention-deficit/hyperactivity disorder?. Psychiatry Res. Aug. 15. 2009;168(3):222-9. X-1, X-2, X-3, X-4. [pmid: 19545907].
2599 Lund C, Oosthuizen P, Flisher AJ, et al. Care among people with schizophrenia spectrum disorders in South Africa. Psychiatric Services. Mar. 2010;61(3):235-40. X-1, X-2, X-3, X-4. [pmid: 20194399].
2600 Lund J. Treatment of psychiatric morbidity in the mentally retarded adult. Acta Psychiatr Scand. Apr. 1986;73(4):429-36. X-3, X-4. [pmid: 2873716].
2601 Lundqvist L-O, Andersson G, Viding J. Effects of vibroacoustic music on challenging behaviors in individuals with autism and developmental disabilities. Res Autism Spectr Disord. Apr–Jun. 2009;3(2):390-400. X-1.
2602 Lunsky Y, Gracey C, Bradley E. Adults with autism spectrum disorders using psychiatric hospitals in Ontario: clinical profile and service needs. Res Autism Spectr Disord. Oct–Dec. 2009;3(4):1006-13. X-4.
2603 Luong J, Yoder MK, Canham D. Southeast Asian parents raising a child with autism: a qualitative investigation of coping styles. J Sch Nurs. Jun. 2009;25(3):222-9. X-3, X-4. [pmid: 19364878].
2604 Luscre DM, Center DB. Procedures for reducing dental fear in children with autism. J Autism Dev Disord. Oct. 1996;26(5):547-56. X-3. [pmid: 8906455].
2605 Luther EH, Canham DL, Young Cureton V. Coping and social support for parents of children with autism. J Sch Nurs. Feb. 2005;21(1):40-7. X-1, X-2, X-3, X-4. [pmid: 15660493].
2606 Luthy KE, Beckstrand RL, Callister LC. Parental hesitation in immunizing children in Utah. Public Health Nurs. Jan–Feb. 2010;27(1):25-31. X-4. [pmid: 20055965].
2607 Luyster RJ, Kadlec MB, Carter A, et al. Language assessment and development in toddlers with autism spectrum disorders. J Autism Dev Disord. Sep. 2008;38(8):1426-38. X-4. [pmid: 18188685].
2608 Lynch E. Making sense of autism. Nurs Stand. Sep. 15–21. 2010;25(2):18-9. X-1, X-2, X-3, X-4. [pmid: 20949817].
2609 Lynch S. Intensive behavioural intervention with a 7-year-old girl with autism. Autism. Jun. 1998;2(2):181-97. X-1, X-3, X-4.
2610 Lynch SL, Irvine AN. Inclusive education and best practice for children with autism spectrum disorder: an integrated approach. Int J Inclusive Educ. Dec. 2009;13(8):845-59. X-2, X-4.
2611 Ma HH. The effectiveness of intervention on the behavior of individuals with autism: a meta-analysis using percentage of data points exceeding the median of baseline phase (PEM). Behav Modif. 2009;33(3):339-59. X-2, X-4. [pmid: 19282505].
2612 Ma YC, Nagler J, Lee MH, et al. Impact of music therapy on the communication skills of toddlers with pervasive developmental disorder. Ann N Y Acad Sci. Jun. 2001;930:445-7. X-1, X-3, X-4. [pmid: 11458864].
2613 Maa Antonissen ACF, Knoors H, et al. Differentiating characteristics of deafblindness and autism in people with congenital deafblindness and profound intellectual disability. J Intellect Disabil Res. 2009;53(Part 6):548-58. X-3, X-4. [pmid: 19457155].
2614 Maag JW, Katsiyannis A. Recent legal and policy developments in special education. NASSP Bulletin. Feb. 2000;84(613):1-8. X-2, X-3, X-4.
2615 Maag JW, Rutherford RB, Wolchik SA, et al. Comparison of two short overcorrection procedures on the stereotypic behavior of autistic children. J Autism Dev Disord. Mar. 1986;16(1):83-7. X-1, X-3, X-4. [pmid: 3957861].
2616 Maag JW, Rutherford RB, Wolchik SA, et al. Sensory extinction and overcorrection in suppressing self-stimulation: A preliminary comparison of efficacy and generalization. Educ Treat Children. Aug. 1986;9(3):189-201. X-1, X-3, X-4.
2617 Maag JW, Wolchik SA, Rutherford RB, et al. Response covariation on self-stimulatory behaviors during sensory extinction procedures. J Autism Dev Disord. Jun. 1986;16(2):119-32. X-1, X-3, X-4. [pmid: 3722114].
2618 MacDonald C, Jones K, Istone M. Positive Behavioral Support. Teach Elem Phys Educ. Nov. 2006;17(6):20-4. X-2.
2619 Macdonald H, Henderson R, Oates K. Low uptake of immunisation: contributing factors. Community Pract. 2004;77(3):95-100. X-4.
2620 MacDonald R, Green G, Mansfield R, et al. Stereotypy in young children with autism and typically developing children. Res Dev Disabil. May–Jun. 2007;28(3):266-77. X-4. [pmid: 16814515].
2621 MacDuff GS, Krantz PJ, MacDuff MA, et al. Providing incidental teaching for autistic children: a rapid training procedure for therapists. Educ Treat Children. Aug. 1988;11(3):205-17. X-3.
2622 MacDuff GS, Krantz PJ, McClannahan LE. Teaching children with autism to use photographic activity schedules: maintenance and generalization of complex response chains. J Appl Behav Anal. Spring. 1993;26(1):89-97. X-1, X-2, X-3, X-4. [pmid: 8473261].
2623 Mace AB, Shapiro ES, Mace FC. Effects of warning stimuli for reinforcer withdrawal and task onset on self-injury. J Appl Behav Anal. Win. 1998;31(4):679-82. X-1, X-2, X-3, X-4. [pmid: 9891405].
2624 Mace FC, Mauro BC, Boyajian AE, et al. Effects of reinforcer quality on behavioral momentum: coordinated applied and basic research. J Appl Behav Anal. Spring. 1997;30(1):1-20. X-1, X-3, X-4. [pmid: 9157095].
2625 Mace FC, Pratt JL, Prager KL, et al. An evaluation of three methods of saying “no” to avoid an escalating response class hierarchy. J Appl Behav Anal. Spring. 2011;44(1):83-94. X-2, X-3. [pmid: 21541139].
2626 MacFabe DF, Cain NE, Boon F, et al. Effects of the enteric bacterial metabolic product propionic acid on object-directed behavior, social behavior, cognition, and neuroinflammation in adolescent rats: Relevance to autism spectrum disorder. Behav Brain Res. Feb. 2. 2011;217(1):47-54. X-1, X-3, X-4. [pmid: 20937326].
2627 MacFarlane JR, Kanaya T. What does it mean to be autistic? Inter-state variation in special education criteria for autism services. J Child Fam Stud. Dec. 2009;18(6):662-9. X-2, X-4.
2628 Machalicek W, O’Reilly M, Chan JM, et al. Using videoconferencing to support teachers to conduct preference assessments with students with autism and developmental disabilities. Res Autism Spectr Disord. Jan. 2009;3(1):32-41. X-3.
2629 Macintosh K, Dissanayake C. Social skills and problem behaviours in school aged children with high-functioning autism and asperger’s disorder. J Autism Dev Disord. Nov. 2006;36(8):1065-76. X-1, X-3, X-4. [pmid: 16865549].
2630 MacKay G, Anderson C, Baldry H, et al. Educational provision for pupils with disorders of language and communication in West Central Scotland. Scott Edu Rev. Nov. 1997;29(2):154-62. X-1, X-2, X-3, X-4.
2631 MacKay G, Shaw A. A comparative study of figurative language in children with autistic spectrum disorders. Child Lang Teach Ther. 2004;20(1):13-32. X-1, X-3, X-4.
2632 Mackay T, Knott F, Dunlop AW. Developing social interaction and understanding in individuals with autism spectrum disorder: a groupwork intervention. J Intellect Dev Disabil. Dec. 2007;32(4):279-90. X-6. [pmid: 18049972].
2633 MacLean JE, Szatmari P, Jones MB, et al. Familial factors influence level of functioning in pervasive developmental disorder. J Am Acad Child Adolesc Psychiatry. Jun. 1999;38(6):746-53. X-4. [pmid: 10361794].
2634 Macleod A. The Birmingham community support scheme for adults with asperger syndrome. Autism. Jun. 1999;3(2):177-92. X-3.
2635 Maenner MJ, Durkin MS. Trends in the prevalence of autism on the basis of special education data. Pediatrics. Nov. 2010;126(5):e1018-25. X-4. [pmid: 20974790].
2636 Maes B, Fryns JP, Van Walleghem M, et al. Fragile-X syndrome and autism: a prevalent association or a misinterpreted connection?. Genet Couns. 1993;4(4):245-63. X-4. [pmid: 8110411].
2637 Magana S, Ghosh S. Latina mothers caring for a son or daughter with autism or schizophrenia: similarities, differences, and the relationship between co-residency and maternal well-being. J Fam Soc Work. 2010;13(3):227-50. X-4. [pmid: 20640047].
2638 Magiati I, Charman T, Howlin P. A two-year prospective follow-up study of community-based early intensive behavioural intervention and specialist nursery provision for children with autism spectrum disorders. J Child Psychol Psychiatry. Aug. 2007;48(8):803-12. X-1, X-2, X-3, X-4. [pmid: 17683452].
2639 Magiati I, Howlin P. Monitoring the progress of preschool children with autism enrolled in early intervention programmes: problems in cognitive assessment. Autism. Dec. 2001;5(4):399-406. X-4. [pmid: 11777256].
2640 Magiati I, Howlin P. A pilot evaluation study of the Picture exchange communication system (PECS) for children with autistic spectrum disorders. Autism. Sep. 2003;7(3):297-320. X-1, X-3, X-4. [pmid: 14516062].
2641 Magiati I, Moss J, Yates R, et al. Is the autism treatment evaluation checklist a useful tool for monitoring progress in children with autism spectrum disorders?. J Intellect Disabil Res. Mar. 2011;55(3):302-12. X-1, X-3, X-4. [pmid: 21199043].
2642 Magnee MJ, Oranje B, van Engeland H, et al. Cross-sensory gating in schizophrenia and autism spectrum disorder: EEG evidence for impaired brain connectivity?. Neuropsychologia. Jun. 2009;47(7):1728-32. X-4. [pmid: 19397868].
2643 Magnusson M, Rasmussen F, Sundelin C. Early identification of children with communication disabilities--evaluation of a screening programme in a Swedish county. Acta Paediatr. Nov. 1996;85(11):1319-26. X-4. [pmid: 8955459].
2644 Mahone EM, Bridges D, Prahme C, et al. Repetitive arm and hand movements (complex motor stereotypies) in children. J Pediatr. Sep. 2004;145(3):391-5. X-4. [pmid: 15343197].
2645 Mahoney G, Kim JM, Lin C. Pivotal behavior model of development learning. Infants Young Child: An Interdisciplinary Journal of Special Care Practices. 2007;20(4):311-25. X-4.
2646 Mahoney G, Perales F. Using relationship-focused intervention to enhance the social-emotional functioning of young children with autism spectrum disorders. Topics Early Child Spec Educ. Sum. 2003;23(2):77-89. X-1, X-2, X-3, X-4.
2647 Mahoney G, Perales F. Relationship-focused early intervention with children with pervasive developmental disorders and other disabilities: a comparative study. J Dev Behav Pediatr. Apr. 2005;26(2):77-85. X-1, X-2, X-3, X-4. [pmid: 15827458].
2648 Mahoney G, Wheeden CA, Perales F. Relationship of preschool special education outcomes to instructional practices and parent-child interaction. Res Dev Disabil. Nov–Dec. 2004;25(6):539-58. X-1, X-2, X-3, X-4. [pmid: 15541631].
2649 Maimburg RD, Vaeth M. Perinatal risk factors and infantile autism. Acta Psychiatr Scand. Oct. 2006;114(4):257-64. X-4. [pmid: 16968363].
2650 Maimburg RD, Vaeth M. Do children born after assisted conception have less risk of developing infantile autism?. Hum Reprod. Jul. 2007;22(7):1841-3. X-4. [pmid: 17456530].
2651 Maitland CH, Tsakanikos E, Holt G, et al. Mental health service provision for adults with intellectual disability: sources of referrals, clinical characteristics and pathways to care. Prim Care Ment Health. 2006;4(2):99-106. X-4.
2652 Majewska MD, Urbanowicz E, Rok-Bujko P, et al. Age-dependent lower or higher levels of hair mercury in autistic children than in healthy controls. Acta Neurobiol Exp (Wars). 2010;70(2):196-208. X-1, X-3, X-4. [pmid: 20628443].
2653 Makela NL, Birch PH, Friedman JM, et al. Parental perceived value of a diagnosis for intellectual disability (ID): a qualitative comparison of families with and without a diagnosis for their child’s ID. Am J Med Genet A. Nov. 2009;149A(11):2393-402. X-4. [pmid: 19842198].
2654 Makkonen I, Riikonen R, Kuikka JT, et al. Brain derived neurotrophic factor and serotonin transporter binding as markers of clinical response to fluoxetine therapy in children with autism. Journal of Pediatric Neurology. 2011;9(1):1-8. X-3.
2655 Malandraki GA, Okalidou A. The application of PECS in a deaf child with autism: a case study. Focus Autism Dev Disabil. Spr. 2007;22(1):23-32. X-1, X-2, X-3, X-4.
2656 Male DB, Rayner M. Who goes to SLD schools in England? A follow-up study. Educ Child Psychol. 2009;26(4):19-30. X-1, X-3, X-4.
2657 Malhotra S, Chakrabarti S, Gupta N, et al. High treatment drop-out rate of children with pervasive developmental disorders. Hong Kong College of Psychiatrists. Mar. 2004;14(1):10-5. X-1, X-3, X-4.
2658 Malhotra S, Gupta N. Childhood Disintegrative Disorder. J Autism Dev Disord. Dec. 1999;29(6):491-98. X-1, X-2, X-3, X-4. [pmid: 10638461].
2659 Mallory BL, Erickson K. “Play and Imagination in Children with Autism,” by Pamela J. Wolfberg Book Review. Early Child Res Q. 2000;15(4):583-86. X-2, X-3, X-4.
2660 Malloy C, Yousef E. To test or not to test: parent information for discussions of food allergy and autism. Del Med J. Oct. 2009;81(10):357-9. X-2, X-4. [pmid: 19999849].
2661 Malone RP, Cater J, Sheikh RM, et al. Olanzapine versus haloperidol in children with autistic disorder: an open pilot study. J Am Acad Child Adolesc Psychiatry. Aug. 2001;40(8):887-94. X-1, X-2, X-3, X-4. [pmid: 11501687].
2662 Malone RP, Delaney MA, Hyman SB, et al. Ziprasidone in adolescents with autism: an open-label pilot study. J Child Adolesc Psychopharmacol. Dec. 2007;17(6):779-90. X-3. [pmid: 18315450].
2663 Malone RP, Ernst M, Godfrey KA, et al. Repeated episodes of neuroleptic-related dyskinesias in autistic children. Psychopharmacology Bulletin. 1991;27(2):113-7. X-4. [pmid: 1681562].
2664 Malone RP, Maislin G, Choudhury MS, et al. Risperidone treatment in children and adolescents with autism: short- and long-term safety and effectiveness. J Am Acad Child Adolesc Psychiatry. Feb. 2002;41(2):140-7. X-1, X-3. [pmid: 11837403].
2665 Mancil GR, Boman M. Functional communication training in the classroom: a guide for success. Prev School Failure. 2010;54(4):238-46. X-1.
2666 Mancil GR, Conroy MA, Haydon TF. Effects of a modified milieu therapy intervention on the social communicative behaviors of young children with autism spectrum disorders. J Autism Dev Disord. Jan. 2009;39(1):149-63. X-1, X-2, X-3, X-4. [pmid: 18612805].
2667 Mancil GR, Conroy MA, Nakao T, et al. Functional communication training in the natural environment: a pilot investigation with a young child with autism spectrum disorder. Educ Treat Children. Nov. 2006;29(4):615-33. X-1, X-2, X-3, X-4.
2668 Mancina C, Tankersley M, Kamps D, et al. Reduction of inappropriate vocalizations for a child with autism using a self-management treatment program. J Autism Dev Disord. Dec. 2000;30(6):599-606. X-1, X-2, X-3, X-4. [pmid: 11261471].
2669 Mandel DS, Walrath CM, Manteuffel B, et al. Characteristics of children with autistic spectrum disorders served in comprehensive community-based mental health settings. J Autism Dev Disord. Jun. 2005;35(3):313-21. X-4. [pmid: 16119472].
2670 Mandell DS. Psychiatric hospitalization among children with autism spectrum disorders. J Autism Dev Disord. Jul. 2008;38(6):1059-65. X-4. [pmid: 17975720].
2671 Mandell DS, Cao J, Ittenbach R, et al. Medicaid expenditures for children with autistic spectrum disorders: 1994 to 1999. J Autism Dev Disord. May. 2006;36(4):475-85. X-4. [pmid: 16586155].
2672 Mandell DS, Listerud J, Levy SE, et al. Race differences in the age at diagnosis among medicaid-eligible children with autism. J Am Acad Child Adolesc Psychiatry. Dec. 2002;41(12):1447-53. X-4. [pmid: 12447031].
2673 Mandell DS, Morales KH, Marcus SC, et al. Psychotropic medication use among Medicaid-enrolled children with autism spectrum disorders. Pediatrics. Mar. 2008;121(3):e441-8. X-4. [pmid: 18310165].
2674 Mandell DS, Morales KH, Xie M, et al. Age of diagnosis among Medicaid-enrolled children with autism, 2001–2004. Psychiatr Serv. Aug. 2010;61(8):822-9. X-1, X-3, X-4. [pmid: 20675842].
2675 Mandell DS, Morales KH, Xie M, et al. County-level variation in the prevalence of medicaid-enrolled children with autism spectrum disorders. J Autism Dev Disord. Oct. 2010;40(10):1241-6. X-1, X-3, X-4. [pmid: 20195736].
2676 Mandell DS, Novak M. The role of culture in families’ treatment decisions for children with autism spectrum disorders. Ment Retard Dev Disabil Res Rev. 2005;11(2):110-5. X-2. [pmid: 15977313].
2677 Mandell DS, Thompson WW, Weintraub ES, et al. Trends in diagnosis rates for autism and ADHD at hospital discharge in the context of other psychiatric diagnoses. Psychiatr Serv. Jan. 2005;56(1):56-62. X-4. [pmid: 15637193].
2678 Mandlawitz MR. The impact of the legal system on educational programming for young children with autism spectrum disorder. J Autism Dev Disord. Oct. 2002;32(5):495-508. X-1, X-2, X-3, X-4. [pmid: 12463522].
2679 Mandleco B, Dyches T, Olsen S, et al. Stress and coping responses: siblings of children with autism or down syndrome. Proceedings of the communicating nursing research conference and win assembly, “responding to societal imperatives through discovery and innovation”. april 10–12, 2003. scottsdale, arizona. Commun Nurs Res. 2003;36:235. X-1, X-2, X-3, X-4.
2680 Mandleco B, Olsen S, Dyches T, et al. Snapshots reflecting the lives of siblings of children with autism. Commun Nurs Res. 2005;38:222. X-4.
2681 Manente CJ, Maraventano JC, LaRue RH, et al. Effective behavioral intervention for adults on the autism spectrum: best practices in functional assessment and treatment development. Behav Anal Today. 2010;11(1):36-48. X-1, X-2, X-3.
2682 Manev R, Manev H. Aminoglycoside antibiotics and autism: a speculative hypothesis. BMC Psychiatry. 2001;1:5. X-2, X-4. [pmid: 11696245].
2683 Mangus B, Henderson H, French R. Implementation of a token economy by peer tutors to increase on-task physical activity time of autistic children. Percept Mot Skills. Aug. 1986;63(1):97-8. X-3. [pmid: 3748749].
2684 Manjaly ZM, Marshall JC, Stephan KE, et al. In search of the hidden: an fMRI study with implications for the study of patients with autism and with acquired brain injury. Neuroimage. Jul. 2003;19(3):674-83. X-4. [pmid: 12880798].
2685 Mann TA, Walker P. Autism and a deficit in broadening the spread of visual attention. J Child Psychol Psychiatry. Feb. 2003;44(2):274-84. X-4. [pmid: 12587863].
2686 Manor-Binyamini I. Mothers of Children with Developmental Disorders in the Bedouin Community in Israel: Family Functioning, Caregiver Burden, and Coping Abilities. J Autism Dev Disord. May. 2011;41(5):610-7. X-1, X-3, X-4. [pmid: 20694507].
2687 Marc V. Beyond the archaic maternal background. The Journal of Analytical Psychology. Apr. 1991;36(2):231-40. X-2, X-4.
2688 Marcason W. What is the current status of research concerning use of a gluten-free, casein-free diet for children diagnosed with autism?. J Am Diet Assoc. Mar. 2009;109(3):572. X-2. [pmid: 19248872].
2689 Marchant P, Hussain A, Hall K. Autistic spectrum disorders and asian children. Br J Educ Stud. Jun. 2006;54(2):230-44. X-4.
2690 Marchetti B, Scifo R, Batticane N, et al. Immunological significance of opioid peptide dysfunction in infantile autism. Brain Dysfunction. Nov–Dec. 1990;3(5–6):346-54. X-4.
2691 Marchetto MC, Carromeu C, Acab A, et al. A model for neural development and treatment of Rett syndrome using human induced pluripotent stem cells. Cell. Nov. 12. 2010;143(4):527-39. X-1, X-3, X-4. [pmid: 21074045].
2692 Marckel JM, Neef NA, Ferreri SJ. A preliminary analysis of teaching improvisation with the picture exchange communication system to children with autism. J Appl Behav Anal. Spring. 2006;39(1):109-15. X-1, X-2, X-3, X-4. [pmid: 16602390].
2693 Marcu I, Oppenheim D, Koren-Karie N, et al. Attachment and symbolic play in preschoolers with autism spectrum disorders. J Autism Dev Disord. Sep. 2009;39(9):1321-8. X-4. [pmid: 19421849].
2694 Marcus A, Sinnott B, Bradley S, et al. Treatment of idiopathic toe-walking in children with autism using GaitSpot Auditory Speakers and simplified habit reversal. Res Autism Spectr Disord. Apr–Jun. 2010;4(2):260-7. X-3.
2695 Marcus A, Wilder DA. A comparison of peer video modeling and self video modeling to teach textual responses in children with autism. J Appl Behav Anal. Summer. 2009;42(2):335-41. X-1, X-2, X-3, X-4. [pmid: 19949521].
2696 Marcus B, Steward DJ, Khan NR, et al. Outpatient transesophageal echocardiography with intravenous propofol anesthesia in children and adolescents. J Am Soc Echocardiogr. Mar–Apr. 1993;6(2):205-9. X-4. [pmid: 8481250].
2697 Marcus BA, Vollmer TR. Combining noncontingent reinforcement and differential reinforcement schedules as treatment for aberrant behavior. J Appl Behav Anal. Spring. 1996;29(1):43-51. X-1, X-2, X-3, X-4. [pmid: 8881343].
2698 Marcus RN, Owen R, Kamen L, et al. A placebo-controlled, fixed-dose study of aripiprazole in children and adolescents with irritability associated with autistic disorder. J Am Acad Child Adolesc Psychiatry. Nov. 2009;48(11):1110-9. X-1, X-3, X-4. [pmid: 19797985].
2699 Marcus RN, Owen R, Manos G, et al. Aripiprazole in the treatment of irritability in pediatric patients (aged 6–17 years) with autistic disorder: Results from a 52-week, open-label study. J Child Adolesc Psychopharmacol. Jun. 2011;21(3):229-36. X-1, X-3, X-4. [pmid: 21663425].
2700 Marcus RN, Owen R, Manos G, et al. Safety and tolerability of aripiprazole for irritability in pediatric patients with autistic disorder: a 52-week, open-label, multicenter study. J Clin Psychiatry. 2011. Jul. 26. X-1, X-3. [pmid: 21813076].
2701 Marcus SC, Durkin M. Stimulant adherence and academic performance in urban youth with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. May. 2011;50(5):480-9. X-1, X-3, X-4. [pmid: 21515197].
2702 Margolis LH, Meisels SJ. Barriers to the effectiveness of EPSDT for children with moderate and severe developmental disabilities. Am J Orthopsychiatry. Jul. 1987;57(3):424-30. X-1, X-3, X-4. [pmid: 2441606].
2703 Maria BL, Deidrick KM, Roach ES, et al. Tuberous sclerosis complex: pathogenesis, diagnosis, strategies, therapies, and future research directions. J Child Neurol. Sep. 2004;19(9):632-42. X-2. [pmid: 15563008].
2704 Mark TL. For what diagnoses are psychotropic medications being prescribed?: a nationally representative survey of physicians. CNS Drugs. Apr. 2010;24(4):319-26. X-1, X-2, X-3, X-4. [pmid: 20297856].
2705 Marker C, Weeks M, Kraegel I. Integrating faith and treatment for children with high functioning autism spectrum disorders. J Psychol Christ. Sum. 2007;26(2):112-21. X-2.
2706 Markle K, Clark CE 2nd. Addressing multiple systems’ failures. One agency’s approach for working with youths with autism involved in multiple service systems. Behav Healthc. Nov. 2007;27(11):36-7. X-2. [pmid: 18293791].
2707 Markowitz PI. Effect of fluoxetine on self-injurious behavior in the developmentally disabled: a preliminary study. J Clin Psychopharmacol. Feb. 1992;12(1):27-31. X-1, X-3, X-4. [pmid: 1552036].
2708 Marks SU. Can “special” programs for children with autism spectrum disorders be inclusive?. Res Pract Persons Severe Disabl. Win. 2007;32(4):265-8. X-2, X-4.
2709 Marks SU, Schrader C, Longaker T, et al. Portraits of three adolescent students with asperger’s syndrome: personal stories and how they can inform practice. J Assoc Pers Sev Handicaps. Spr. 2000;25(1):3-17. X-3, X-4.
2710 Marmon P. The map: an innocent interaction with far-reaching outcomes. School Nurse News. May. 2010;27(3):15-6. X-1, X-2, X-3, X-4. [pmid: 20476529].
2711 Maroni L. Say hello to the scream extractor: working with an autistic child with psychotic mechanisms. J Child Psychother. Aug. 2008;34(2):222-39. X-1, X-2, X-3, X-4.
2712 Marquenie K, Rodger S, Mangohig K, et al. Dinnertime and bedtime routines and rituals in families with a young child with an autism spectrum disorder. Aust Occup Ther J. 2011;58(3):145-54. X-1, X-3, X-4. [pmid: 21599679].
2713 Marr D, Mika H, Miraglia J, et al. The effect of sensory stories on targeted behaviors in preschool children with autism. Phys Occup Ther Pediatr. 2007;27(1):63-79. X-1, X-2, X-3, X-4. [pmid: 17298941].
2714 Marriage KJ, Gordon V, Brand L. A social skills group for boys with Asperger’s syndrome. Aust N Z J Psychiatry. Mar. 1995;29(1):58-62. X-1, X-2, X-3, X-4. [pmid: 7625976].
2715 Marrosu F, Marrosu G, Rachel MG, et al. Paradoxical reactions elicited by diazepam in children with classic autism. Funct Neurol. Jul–Sep. 1987;2(3):355-61. X-3. [pmid: 2826308].
2716 Marshall J, Sheller B, Mancl L. Caries-risk assessment and caries status of children with autism. Pediatr Dent. Jan–Feb. 2010;32(1):69-75. X-4. [pmid: 20298657].
2717 Marshall J, Sheller B, Mancl L, et al. Parental attitudes regarding behavior guidance of dental patients with autism. Pediatr Dent. Sep–Oct. 2008;30(5):400-7. X-1, X-4. [pmid: 18942599].
2718 Marshall J, Sheller B, Williams BJ, et al. Cooperation predictors for dental patients with autism. Pediatr Dent. Sep–Oct. 2007;29(5):369-76. X-4. [pmid: 18027770].
2719 Marshall JK, Mirenda P. Parent-professional collaboration for positive behavior support in the home. Focus Autism Dev Disabil. Win. 2002;17(4):216-28. X-2.
2720 Marteleto MR, Lima e Menezes CG, Tamanaha AC, et al. Administration of the autism behavior checklist: agreement between parents and professionals’ observations in two intervention contexts. Rev Bras Psiquiatr. Sep. 2008;30(3):203-8. X-4. [pmid: 18833419].
2721 Martell R. The enigma of autism. Nurs Stand. Jan. 5–11. 1994;8(15):20-1. X-2, X-4. [pmid: 8123505].
2722 Martens BK, Houk JL. The application of Herrnstein’s law of effect to disruptive and on-task behavior of a retarded adolescent girl. J Exp Anal Behav. Jan. 1989;51(1):17-27. X-3. [pmid: 2921585].
2723 Martin A, Koenig K, Anderson GM, et al. Low-dose fluvoxamine treatment of children and adolescents with pervasive developmental disorders: a prospective, open-label study. J Autism Dev Disord. Feb. 2003;33(1):77-85. X-3. [pmid: 12708582].
2724 Martin A, Koenig K, Scahill L, et al. Open-label quetiapine in the treatment of children and adolescents with autistic disorder. J Child Adolesc Psychopharmacol. 1999;9(2):99-107. X-2, X-3, X-4. [pmid: 10461820].
2725 Martin A, Scahill L, Anderson GM, et al. Weight and leptin changes among risperidone-treated youths with autism: 6-month prospective data. Am J Psychiatry. Jun. 2004;161(6):1125-7. X-1, X-3, X-4. [pmid: 15169706].
2726 Martin A, Scahill L, Klin A, et al. Higher-functioning pervasive developmental disorders: rates and patterns of psychotropic drug use. J Am Acad Child Adolesc Psychiatry. Jul. 1999;38(7):923-31. X-4. [pmid: 10405512].
2727 Martin CA, Drasgow E, Halle JW, et al. Teaching a child with autism and severe language delays to reject: direct and indirect effects of functional communication training. Educ Psychol. Apr–Jun. 2005;25(2–3):287-304. X-1, X-2, X-3, X-4.
2728 Martin F, Farnum J. Animal-assisted therapy for children with pervasive developmental disorders. West J Nurs Res. Oct. 2002;24(6):657-70. X-1, X-3. [pmid: 12365766].
2729 Martin N. Assessing portrait drawings created by children and adolescents with autism spectrum disorder. Art Ther. 2008;25(1):15-23. X-4.
2730 Martin N. Art Therapy and autism: overview and recommendations. Art Ther. 2009;26(4):187-90. X-1, X-2, X-3, X-4.
2731 Martin N. A preliminary study of some broad disability related themes within the Edinburgh festival fringe. Disabil Soc. 2010;25(5):539-49. X-1, X-2, X-3, X-4.
2732 Martin NT, Bibby P, Mudford OC, et al. Toward the use of a standardized assessment for young children with autism: current assessment practices in the UK. Autism. Sep. 2003;7(3):321-30. X-4. [pmid: 14516063].
2733 Martin SC, Wolters PL, Smith AC. Adaptive and maladaptive behavior in children with Smith-Magenis Syndrome. J Autism Dev Disord. May. 2006;36(4):541-52. X-4. [pmid: 16570214].
2734 Martineau J, Barthelemy C, Cheliakine C, et al. Brief report: an open middle-term study of combined vitamin B6-magnesium in a subgroup of autistic children selected on their sensitivity to this treatment. J Autism Dev Disord. Sep. 1988;18(3):435-47. X-1, X-3, X-4. [pmid: 3170459].
2735 Martineau J, Barthelemy C, Garreau B, et al. Vitamin B6, magnesium, and combined B6-Mg: therapeutic effects in childhood autism. Biol Psychiatry. May. 1985;20(5):467-78. X-1, X-3, X-4. [pmid: 3886023].
2736 Martineau J, Barthélémy C, Jouve J, et al. Monoamines (serotonin and catecholamines) and their derivatives in infantile autism: Age-related changes and drug effects. Dev Med Child Neurol. Jul. 1992;34(7):593-603. X-4. [pmid: 1380929].
2737 Martineau J, Barthelemy C, Lelord G. Long-term effects of combined vitamin B_6_-magnesium administration in an autistic child. Biological Psychiatry. May. 1986;21(5–6):511-8. X-1, X-3, X-4. [pmid: 3083877].
2738 Martineau J, Barthelemy C, Roux S, et al. Electrophysiological effects of fenfluramine or combined vitamin B6 and magnesium on children with autistic behaviour. Dev Med Child Neurol. Dec. 1989;31(6):721-7. X-3. [pmid: 2599266].
2739 Martineau J, Garreau B, Barthelemy C, et al. Effects of vitamin B6 on averaged evoked potentials in infantile autism. Biol Psychiatry. Jul. 1981;16(7):627-41. X-3. [pmid: 7272379].
2740 Martineau J, Garreau B, Roux S, et al. Auditory evoked responses and their modifications during conditioning paradigm in autistic children. J Autism Dev Disord. Dec. 1987;17(4):525-39. X-1, X-3, X-4. [pmid: 3680154].
2741 Martineau J, Roux S, Adrien JL, et al. Electrophysiological evidence of different abilities to form cross-modal associations in children with autistic behavior. Electroencephalogr Clin Neurophysiol. Jan. 1992;82(1):60-6. X-4. [pmid: 1370145].
2742 Martineau J, Roux S, Garreau B, et al. Unimodal and crossmodal reactivity in autism: presence of auditory evoked responses and effect of the repetition of auditory stimuli. Biol Psychiatry. Jun. 15. 1992;31(12):1190-203. X-4. [pmid: 1391280].
2743 Martineau J, Tanguay P, Garreau B, et al. Are there sex differences in averaged evoked responses produced by coupling sound and light in children and adults?. Int J Psychophysiol. Dec. 1984;2(3):177-83. X-4. [pmid: 6543360].
2744 Martinez CA. Adapted aquatics for children with autism. Teach Elem Phys Educ. Sep. 2006;17(5):34-6. X-2, X-4.
2745 Martins MP, Harris SL. Teaching children with autism to respond to joint attention initiations. Child Fam Behav Ther. 2006;28(1):51-68. X-1, X-2, X-3, X-4.
2746 Martos Perez J, Fortea Sevilla MS. Psychological assessment of adolescents and adults with autism. J Autism Dev Disord. Dec. 1993;23(4):653-64. X-3. [pmid: 8106305].
2747 Marui T, Funatogawa I, Koishi S, et al. The NADH-ubiquinone oxidoreductase 1 alpha subcomplex 5 (NDUFA5) gene variants are associated with autism. Acta Psychiatrica Scandinavica. Feb. 2011;123(2):118-24. X-4. [pmid: 20825370].
2748 Mascha K, Boucher J. Preliminary investigation of a qualitative method of examining siblings’ experiences of living with a child with ASD. Br J Dev Disabil. 2006;52(part 1(102)):19-28. X-3, X-4.
2749 Mashal N, Kasirer A. Thinking maps enhance metaphoric competence in children with autism and learning disabilities. Res Dev Disabil: A Multidisciplinary Journal. Nov–Dec. 2011;32(6):2045-54. X-4.
2750 Masi G, Cosenza A, Millepiedi S, et al. Aripiprazole monotherapy in children and young adolescents with pervasive developmental disorders: a retrospective study. CNS Drugs. 2009;23(6):511-21. X-1. [pmid: 19480469].
2751 Masi G, Cosenza A, Mucci M. Prolactin levels in young children with pervasive developmental disorders during risperidone treatment. J Child Adolesc Psychopharmacol. Winter. 2001;11(4):389-94. X-1, X-2, X-3, X-4. [pmid: 11838821].
2752 Masi G, Cosenza A, Mucci M, et al. Open trial of risperidone in 24 young children with pervasive developmental disorders. J Am Acad Child Adolesc Psychiatry. Oct. 2001;40(10):1206-14. X-1, X-2, X-3, X-4. [pmid: 11589534].
2753 Masi G, Cosenza A, Mucci M, et al. A 3-year naturalistic study of 53 preschool children with pervasive developmental disorders treated with risperidone. J Clin Psychiatry. Sep. 2003;64(9):1039-47. X-1, X-2, X-3, X-4. [pmid: 14628979].
2754 Masi G, Cosenza A, Mucci M, et al. Risperidone monotherapy in preschool children with pervasive developmental disorders. J Child Neurol. Jun. 2001;16(6):395-400. X-1, X-2, X-3, X-4. [pmid: 11417603].
2755 Mason MC. Head for bed. Nurs Stand. Jan 26-Feb 1. 2011;25(21):20. X-2. [pmid: 21329128].
2756 Mason SA, McGee GG, Farmer-Dougan V, et al. A practical strategy for ongoing reinforcer assessment. J Appl Behav Anal. Summer. 1989;22(2):171-9. X-1, X-3, X-4. [pmid: 2745238].
2757 Mason SA, Newsom CD. The application of sensory change to reduce stereotyped behavior. Res Dev Disabil. 1990;11(3):257-71. X-4. [pmid: 2399345].
2758 Massaro DW, Bosseler A. Read my lips: The importance of the face in a computer-animated tutor for vocabulary learning by children with autism. Autism. Sep. 2006;10(5):495-510. X-1, X-2, X-3, X-4. [pmid: 16940315].
2759 Massey NG, Wheeler JJ. Acquisition and generalization of activity schedules and their effects on task engagement in a young child with autism in an inclusive pre–school classroom. Educ Train Ment Retard Dev Disabil. Sep. 2000;35(3):326-35. X-1, X-3, X-4.
2760 Mastrangelo S. Harnessing the Power of Play: opportunities for children with autism spectrum disorders. Teach Except Child. Sep–Oct. 2009;42(1):34-44. X-2, X-4.
2761 Mathai J, Bourne A, Cranswick N. Lessons learnt in conducting a clinical drug trial in children with asperger syndrome. Australas Psychiatry. Jun. 2005;13(2):173-5. X-2, X-4. [pmid: 15948916].
2762 Mathews RR, Hall WD, Vos T, et al. What are the major drivers of prevalent disability burden in young Australians?. Med J Aust. Mar. 7. 2011;194(5):232-5. X-4. [pmid: 21381994].
2763 Mathewson KJ, Drmic IE, Jetha MK, et al. Behavioral and cardiac responses to emotional stroop in adults with autism spectrum disorders: influence of medication. Autism Res. Apr. 2011;4(2):98-108. X-4. [pmid: 21360828].
2764 Matson J. Aggression and tantrums in children with autism: a review of behavioral treatments and maintaining variables. J Ment Health Res Intellect Disabil. 2009;2(3):169-87. X-2.
2765 Matson JL. Current status of differential diagnosis for children with autism spectrum disorders. Res Dev Disabil: A Multidisciplinary Journal. Mar–Apr. 2007;28(2):109-18. X-2, X-4.
2766 Matson JL. Determining treatment outcome in early intervention programs for autism spectrum disorders: a critical analysis of measurement issues in learning based interventions. Res Dev Disabil: A Multidisciplinary Journal. Mar–Apr. 2007;28(2):207-18. X-2, X-4.
2767 Matson JL, Ancona MN, Wilkins J. Sleep disturbances in adults with autism spectrum disorders and severe intellectual impairments. J Ment Health Res Intellect Disabil. 2008;1(3):129-39. X-4.
2768 Matson JL, Baglio CS, Smiroldo BB, et al. Characteristics of autism as assessed by the Diagnostic Assessment for the Severely Handicapped-II (DASH-II). Res Dev Disabil. Mar–Apr. 1996;17(2):135-43. X-4. [pmid: 8778935].
2769 Matson JL, Boisjoli JA. The token economy for children with intellectual disability and/or autism: a review. Res Dev Disabil: A Multidisciplinary Journal. Mar–Apr. 2009;30(2):240-8. X-2, X-4.
2770 Matson JL, Boisjoli JA, Hess JA, et al. Factor structure and diagnostic fidelity of the Baby and Infant Screen for Children with aUtIsm Traits-Part 1 (BISCUIT-part 1). Dev Neurorehabil. 2010;13(2):72-9. X-1, X-2, X-3, X-4. [pmid: 20222767].
2771 Matson JL, Box ML, Francis KL. Treatment of elective mute behavior in two developmentally delayed children using modeling and contingency management. J Behav Ther Exp Psychiatry. Sep. 1992;23(3):221-9. X-1, X-2, X-3, X-4. [pmid: 1283169].
2772 Matson JL, Compton LS, Sevin JA. Comparison and item analysis of the MESSY for autistic and normal children. Res Dev Disabil. 1991;12(4):361-9. X-4. [pmid: 1792362].
2773 Matson JL, Dempsey T. The nature and treatment of compulsions, obsessions, and rituals in people with developmental disabilities. Res Dev Disabil: A Multidisciplinary Journal. May–Jun. 2009;30(3):603-11. X-2, X-4.
2774 Matson JL, Dempsey T, Fodstad JC. The effect of autism spectrum disorders on adaptive independent living skills in adults with severe intellectual disability. Res Dev Disabil. Nov–Dec. 2009;30(6):1203-11. X-1, X-4. [pmid: 19450950].
2775 Matson JL, Dempsey T, Wilkins J. Rett syndrome in adults with severe intellectual disability: exploration of behavioral characteristics. Eur Psychiatry. Sep. 2008;23(6):460-5. X-4. [pmid: 18207372].
2776 Matson JL, et al. Behavioral treatment of autistic persons: a review of research from 1980 to the present. Res Dev Disabil. Nov–Dec. 1996;17(6):433-65. X-1, X-2, X-3, X-4. [pmid: 8946569].
2777 Matson JL, Gardner WI, Coe DA, et al. A scale for evaluating emotional disorders in severely and profoundly mentally retarded persons. Development of the Diagnostic Assessment for the Severely Handicapped (DASH) scale. Br J Psychiatry. Sep. 1991;159:404-9. X-4. [pmid: 1958951].
2778 Matson JL, Lo Vullo SV. A review of behavioral treatments for self-injurious behaviors of persons with autism spectrum disorders. Behav Modif. 2008;32(1):61-76. X-2, X-4. [pmid: 18096972].
2779 Matson JL, Mahan S, Sipes M, et al. Effects of Symptoms of comorbid psychopathology on challenging behaviors among atypically developing infants and toddlers as assessed with the Baby and Infant Screen for Children with Autism Traits (BISCUIT). J Ment Health Res Intellect Disabil. 2010;3(3):164-76. X-1, X-2, X-3, X-4.
2780 Matson JL, Manikam R, Coe D, et al. Training social skills to severely mentally retarded multiply handicapped adolescents. Res Dev Disabil. 1988;9(2):195-208. X-3. [pmid: 2970102].
2781 Matson JL, Matson ML, Rivet TT. Social-skills treatments for children with autism spectrum disorders: an overview. Behav Modif. 2007;31(5):682-707. X-2, X-4. [pmid: 17699124].
2782 Matson JL, Rivet TT. Characteristics of challenging behaviours in adults with autistic disorder, PDD-NOS, and intellectual disability. J Intellect Dev Disabil. Dec. 2008;33(4):323-9. X-4. [pmid: 19039692].
2783 Matson JL, Sevin JA, Box ML, et al. An evaluation of two methods for increasing self-initiated verbalizations in autistic children. J Appl Behav Anal. Fal. 1993;26(3):389-98. X-1, X-2, X-3, X-4. [pmid: 8407687].
2784 Matson JL, Sevin JA, Fridley D, et al. Increasing spontaneous language in three autistic children. J Appl Behav Anal. Summer. 1990;23(2):227-33. X-1, X-2, X-3, X-4. [pmid: 2373659].
2785 Matson JL, Smiroldo BB, Hastings TL. Validity of the Autism/Pervasive Developmental Disorder subscale of the Diagnostic Assessment for the Severely Handicapped-II. J Autism Dev Disord. Feb. 1998;28(1):77-81. X-4. [pmid: 9546305].
2786 Matson JL, Taras ME, Sevin JA, et al. Teaching self-help skills to autistic and mentally retarded children. Res Dev Disabil. 1990;11(4):361-78. X-1, X-2, X-3, X-4. [pmid: 2270319].
2787 Matsuo M, Maeda T, Sasaki K, et al. Frequent association of autism spectrum disorder in patients with childhood onset epilepsy. Brain Dev. Oct. 2010;32(9):759-63. X-1, X-4. [pmid: 20542395].
2788 Matsushita H, Sonoyama S. Teaching ball-throwing skills to a boy with asperger’s disorder: A case study. Jpn J Spec Educ. Mar. 2010;47(6):495-508. X-2, X-3.
2789 Matthews S. Autistic children and their treatment. Health Visit. May. 1982;55(5):242-6. X-1, X-2, X-3, X-4. [pmid: 6918379].
2790 Maurer A. The shock rod controversy. J Clin Child Psychol. Win. 1983;12(3):272-8. X-1, X-2, X-3, X-4.
2791 Mavropoulou S. Developing pilot befriending schemes for people with autism spectrum disorders in a region of Greece: lessons from practice. Child Adolesc Ment Health. 2007;12(3):138-42. X-1, X-3, X-4.
2792 Mavropoulou S, Padeliadu S. Greek teachers’ perceptions of autism and implications for educational practice: A preliminary analysis. Autism. Jun. 2000;4(2):173-83. X-4.
2793 Max ML, Burke JC. Virtual reality for autism communication and education, with lessons for medical training simulators. Stud Health Technol Inform. 1997;39:46-53. X-1, X-3, X-4. [pmid: 10184722].
2794 Mayes SD, Calhoun SL, Murray MJ, et al. Comparison of scores on the checklist for autism spectrum disorder, childhood autism rating scale, and gilliam asperger’s disorder scale for children with low functioning autism, high functioning autism, asperger’s disorder, adhd, and typical development. J Autism Dev Disord. 2009;39(12):1682-93. X-4. [pmid: 19609662].
2795 Mays NM, Beal-Alvarez J, Jolivette K. Using movement-based sensory interventions to address self-stimulatory behaviors in students with autism. Teach Except Child. Jul–Aug. 2011;43(6):46-52. X-1, X-2, X-3, X-4.
2796 Mays RM, Gillon JE. Autism in young children: an update. J Pediatr Health Care. Jan–Feb. 1993;7(1):17-23. X-2, X-4. [pmid: 8421239].
2797 Mayton MR, Wheeler JJ, Menendez AL, et al. An analysis of evidence-based practices in the education and treatment of learners with autism spectrum disorders. Educ Train Autism Dev Disabil. Dec. 2010;45(4):539-51. X-1, X-2, X-3, X-4.
2798 Mazefsky CA, Goin-Kochel RP, Riley BP, et al. Genetic and environmental influences on symptom domains in twins and siblings with autism. Res Autism Spectr Disord. Apr–Jun. 2008;2(2):320-31. X-4. [pmid: 19718281].
2799 Mazefsky CA, Oswald DP. The discriminative ability and diagnostic utility of the ADOS-G, ADI-R, and GARS for children in a clinical setting. Autism. Nov. 2006;10(6):533-49. X-2, X-4. [pmid: 17088271].
2800 Mazefsky CA, Williams DL, Minshew NJ. Variability in adaptive behavior in autism: evidence for the importance of family history. J Abnorm Child Psychol. May. 2008;36(4):591-9. X-4. [pmid: 18188537].
2801 Mazurik-Charles R, Stefanou C. Using paraprofessionals to teach social skills to children with autism spectrum disorders in the general education classroom. J Instr Psychol. 2010;37(2):161-9. X-1, X-3, X-4.
2802 McArthur GM. Auditory processing disorders: can they be treated?. Curr Opin Neurol. Apr. 2009;22(2):137-43. X-2, X-4. [pmid: 19532037].
2803 McBride JA, Panksepp J. An examination of the phenomenology and the reliability of ratings of compulsive behavior in autism. J Autism Dev Disord. Aug. 1995;25(4):381-96. X-4. [pmid: 7592250].
2804 McBride PA, Anderson GM, Hertzig ME, et al. Serotonergic responsivity in male young adults with autistic disorder. Results of a pilot study. Arch Gen Psychiatry. Mar. 1989;46(3):213-21. X-3, X-4. [pmid: 2919950].
2805 McCabe H. The importance of parent-to-parent support among families of children with autism in the People’s Republic of China. Int J Disabil Dev Educ. Dec. 2008;55(4):303-14. X-1, X-3, X-4.
2806 McCabe H. Two decades of serving children with autism in the People’s Republic of China: achievements and challenges of a state-run mental health center. Disabil Soc. May. 2008;23(3):271-82. X-4.
2807 McCabe H. Employment experiences, perspectives, and wishes of mothers of children with autism in the People’s Republic of China. J Appl Res Intellect Disabil. Mar. 2010;23(2):122-31. X-1, X-4.
2808 McCabe H, Wu S. Helping each other, helping ourselves: a case of employment for an adult with autism in Nanjing, China. J Vocat Rehabil. 2009;30(1):57-66. X-3.
2809 McCarthy M, Hendren RL. Autism spectrum disorders have increased dramatically in prevalence in recent years. Preface Psychiatr Clin North Am. Mar. 2009;32(1):xiii-xv. X-2. [pmid: 19248912].
2810 McCarthy P. Childhood autism: 0–35 years. Ir Med J. Jul. 1985;78(7):182-5. X-1, X-2, X-3, X-4. [pmid: 4030294].
2811 McCathren RB. Teacher-implemented prelinguistic communication intervention. Focus Autism Dev Disabil. Spr. 2000;15(1):21-9. X-1, X-2, X-3, X-4.
2812 McClannahan LE, MacDuff GS, Krantz PJ. Behavior analysis and intervention for adults with autism. Behav Modif. Jan. 2002;26(1):9-26. X-1, X-2, X-3. [pmid: 11799656].
2813 McClannahan LE, McGee GG, MacDuff GS, et al. Assessing and improving child care: a personal appearance index for children with autism. J Appl Behav Anal. Winter. 1990;23(4):469-82. X-4. [pmid: 2074237].
2814 McClean B, Grey IM, McCracken M. An evaluation of positive behavioural support for people with very severe challenging behaviours in community-based settings. J Intellect Disabil. Sep. 2007;11(3):281-301. X-3. [pmid: 17846050].
2815 McCleery JP, Ceponiene R, Burner KM, et al. Neural correlates of verbal and nonverbal semantic integration in children with autism spectrum disorders. J Child Psychol Psychiatry. Mar. 2010;51(3):277-86. X-1, X-2, X-3, X-4. [pmid: 20025622].
2816 McClellan J, Sikich L, Findling RL, et al. Treatment of Early-Onset Schizophrenia Spectrum Disorders (TEOSS): rationale, design, and methods. J Am Acad Child Adolesc Psychiatry. Aug. 2007;46(8):969-78. X-1, X-3, X-4. [pmid: 17667476].
2817 McClure MK, Holtz-Yotz M. The effects of sensory stimulatory treatment on an autistic child. Am J Occup Ther. Dec. 1991;45(12):1138-42. X-3, X-4. [pmid: 1805627].
2818 McComas J, Hoch H, Paone D, et al. Escape behavior during academic tasks: A preliminary analysis of idiosyncratic establishing conditions. J Appl Behav Anal. Special Issue: Establishing operations in applied behavior analysis. Win. 2000;33(4):479-93. X-1, X-2, X-3, X-4. [pmid: 11214024].
2819 McComas JJ. Response Persistence: the effects of stimulus control on negatively reinforced problem behavior in a concurrent operant. Behav Anal. Fall. 2009;32(2):301-7. X-4. [pmid: 22478529].
2820 McComas JJ, Thompson A, Johnson L. The effects of presession attention on problem behavior maintained by different reinforcers. J Appl Behav Anal. Fall. 2003;36(3):297-307. X-1, X-2, X-3, X-4. [pmid: 14596571].
2821 McConachie H, Barry R, Spencer A, et al. Dasl(n)e: the challenge of developing a regional database for autism spectrum disorder. Arch Dis Child. Jan. 2009;94(1):38-41. X-4. [pmid: 18456689].
2822 McConachie H, Hoole S, Le Couteur AS. Improving mental health transitions for young people with autism spectrum disorder. Child Care Health Dev. Nov. 2011;37(6):764-6. X-1, X-2, X-3, X-4. [pmid: 22007975].
2823 McConachie H, Randle V, Hammal D, et al. A controlled trial of a training course for parents of children with suspected autism spectrum disorder. J Pediatr. Sep. 2005;147(3):335-40. X-1, X-2, X-3, X-4. [pmid: 16182672].
2824 McConachie H, Robinson G. What services do young children with autism spectrum disorder receive?. Child Care Health Dev. Sep. 2006;32(5):553-7. X-4. [pmid: 16919134].
2825 McConkey R, Bhlirgri S. Children with autism attending preschool facilities: the experiences and perceptions of staff. Early Child Dev Care. Aug. 2003;173(4):445-52. X-1, X-3, X-4.
2826 McConkey R, Truesdale-Kennedy M, Cassidy A. Mothers’ recollections of early features of autism spectrum disorders. Child Adolesc Ment Health. 2009;14(1):31-6. X-4.
2827 McConkey R, Truesdale-Kennedy M, Crawford H, et al. Preschoolers with autism spectrum disorders: evaluating the impact of a home-based intervention to promote their communication. Early Child Dev Care. Apr. 2010;180(3):299-315. X-1, X-2, X-3, X-4.
2828 McConnell SR. Interventions to facilitate social interaction for young children with autism: review of available research and recommendations for educational intervention and future research. J Autism Dev Disord. Oct. 2002;32(5):351-72. X-2, X-4. [pmid: 12463515].
2829 McCormick MC. The autism “epidemic”: impressions from the perspective of immunization safety review. Ambul Pediatr. May–Jun. 2003;3(3):119-20. X-2. [pmid: 12708887].
2830 McCracken JT, Aman MG, McDougle CJ, et al. Possible influence of variant of the P-glycoprotein gene (MDR1/ABCB1) on clinical response to guanfacine in children with pervasive developmental disorders and hyperactivity. J Child Adolesc Psychopharmacol. Feb. 2010;20(1):1-5. X-1, X-3, X-4. [pmid: 20166790].
2831 McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med. Aug. 1. 2002;347(5):314-21. X-1, X-3. [pmid: 12151468].
2832 McCrory E, Henry LA, Happe F. Eye-witness memory and suggestibility in children with Asperger syndrome. J Child Psychol Psychiatry. May. 2007;48(5):482-9. X-4. [pmid: 17501729].
2833 McDaniel KD. Pharmacologic treatment of psychiatric and neurodevelopmental disorders in children and adolescents (Part 2). Clin Pediatr (Phila). Mar. 1986;25(3):143-6. X-1, X-2, X-3, X-4. [pmid: 2868821].
2834 McDermott S, Moran R, Platt T, et al. Prevalence of epilepsy in adults with mental retardation and related disabilities in primary care. Am J Ment Retard. Jan. 2005;110(1):48-56. X-4. [pmid: 15568966].
2835 McDermott S, Zhou L, Mann J. Injury treatment among children with autism or pervasive developmental disorder. J Autism Dev Disord. Apr. 2008;38(4):626-33. X-4. [pmid: 17690968].
2836 McDonald S, Birnbrauer JS, Swerissen H. The effect of an integration program on teacher and student attitudes to mentally-handicapped children. Aust Psychol. Nov. 1987;22(3):313-22. X-1, X-3, X-4.
2837 McDonnell J, Thorson N, McQuivey C, et al. Academic engaged time of students with low-incidence disabilities in general education classes. Ment Retard. Feb. 1997;35(1):18-26. X-4. [pmid: 9046783].
2838 McDonnell MA, Hamrin V, Moffett J, et al. Timely diagnosis of comorbid pervasive developmental disorder and bipolar disorder. Minerva Pediatr. Feb. 2008;60(1):115-27. X-2, X-4. [pmid: 18277370].
2839 McDougall J, Servais M, Meyer K, et al. A preliminary evaluation of a school support program for children with autism spectrum disorders: educator and school level outcomes and program processes. Exceptionality Educ Int. 2009;19(1):32-50. X-1, X-2, X-3, X-4.
2840 McDougle CJ, Brodkin ES, Yeung PP, et al. Risperidone in adults with autism or pervasive developmental disorder. J Child Adolesc Psychopharmacol. Win. 1995;5(4):273-82. X-1, X-2, X-3, X-4.
2841 McDougle CJ, Holmes JP, Bronson MR, et al. Risperidone treatment of children and adolescents with pervasive developmental disorders: a prospective open-label study. J Am Acad Child Adolesc Psychiatry. May. 1997;36(5):685-93. X-1, X-2, X-3, X-4. [pmid: 9136504].
2842 McDougle CJ, Kem DL, Posey DJ. Case series: use of ziprasidone for maladaptive symptoms in youths with autism. J Am Acad Child Adolesc Psychiatry. Aug. 2002;41(8):921-7. X-3, X-4. [pmid: 12164181].
2843 McDougle CJ, Kresch LE, Goodman WK, et al. A case-controlled study of repetitive thoughts and behavior in adults with autistic disorder and obsessive-compulsive disorder. Am J Psychiatry. May. 1995;152(5):772-7. X-4. [pmid: 7726318].
2844 McDougle CJ, Kresch LE, Posey DJ. Repetitive thoughts and behavior in pervasive developmental disorders: treatment with serotonin reuptake inhibitors. J Autism Dev Disord. Oct. 2000;30(5):427-35. X-2. [pmid: 11098879].
2845 McDougle CJ, Naylor ST, Cohen DJ, et al. Effects of tryptophan depletion in drug-free adults with autistic disorder. Arch Gen Psychiatry. Nov. 1996;53(11):993-1000. X-4. [pmid: 8911222].
2846 McDougle CJ, Naylor ST, Goodman WK, et al. Acute tryptophan depletion in autistic disorder: a controlled case study. Biol Psychiatry. Apr. 1. 1993;33(7):547-50. X-3. [pmid: 8513041].
2847 McDougle CJ, Posey D. Genetics of childhood disorders: XLIV. autism, part 3: psychopharmacology of autism. J Am Acad Child Adolesc Psychiatry. Nov. 2002;41(11):1380-3. X-2. [pmid: 12410082].
2848 McDougle CJ, Price LH, Goodman WK. Fluvoxamine treatment of coincident autistic disorder and obsessive-compulsive disorder: A case report. J Autism Dev Disord. Dec. 1990;20(4):537-43. X-3. [pmid: 2126264].
2849 McDougle CJ, Price LH, Volkmar FR, et al. Clomipramine in autism: Preliminary evidence of efficacy. J Am Acad Child Adolesc Psychiatry. Jul. 1992;31(4):746-50. X-3. [pmid: 1644740].
2850 McDougle CJ, Scahill L, Aman MG, et al. Risperidone for the core symptom domains of autism: results from the study by the autism network of the research units on pediatric psychopharmacology. Am J Psychiatry. Jun. 2005;162(6):1142-8. X-1, X-3. [pmid: 15930063].
2851 McDuffie A, Yoder P. Types of parent verbal responsiveness that predict language in young children with autism spectrum disorder. J Speech Lang Hear Res. Aug. 2010;53(4):1026-39. X-1, X-3, X-4. [pmid: 20605942].
2852 McEachin JJ, Smith T, Lovaas OI. Long-term outcome for children with autism who received early intensive behavioral treatment. Am J Ment Retard. Jan. 1993;97(4):359-72. discussion 73–91. X-1, X-2, X-3, X-4. [pmid: 8427693].
2853 McEntee JE, Saunders RR. A response-restriction analysis of stereotypy in adolescents with mental retardation: implications for applied behavior analysis. J Appl Behav Anal. Fall. 1997;30(3):485-506. X-3, X-4. [pmid: 9316261].
2854 McEvoy MA, Brady MP. Contingent access to play materials as an academic motivator for autistic and behavior disordered children. Educ Treat Children. Feb. 1988;11(1):5-18. X-1, X-3, X-4.
2855 McEvoy MA, Nordquist VM, Twardosz S, et al. Promoting autistic children’s peer interaction in an integrated early childhood setting using affection activities. J Appl Behav Anal. Summer. 1988;21(2):193-200. X-3. [pmid: 3417581].
2856 McGarrell M, Healy O, Leader G, et al. Six reports of children with autism spectrum disorder following intensive behavioral intervention using the preschool inventory of repertoires for kindergarten. Res Autism Spectr Disord. Jul–Sep. 2009;3(3):767-82. X-1, X-2, X-3, X-4.
2857 McGee GG, Almeida MC, Sulzer-Azaroff B, et al. Promoting reciprocal interactions via peer incidental teaching. J Appl Behav Anal. Spring. 1992;25(1):117-26. X-1, X-2, X-3, X-4. [pmid: 1582961].
2858 McGee GG, et al. Free effects of integration on levels of autistic behavior. Topics Early Child Spec Educ. Spr. 1993;13(1):57-67. X-1, X-2, X-3, X-4.
2859 McGee GG, Feldman RS, Morrier MJ. Benchmarks of social treatment for children with autism. J Autism Dev Disord. Aug. 1997;27(4):353-64. X-1, X-3, X-4. [pmid: 9261663].
2860 McGee GG, Krantz PJ, Mason D, et al. A modified incidental-teaching procedure for autistic youth: acquisition and generalization of receptive object labels. J Appl Behav Anal. Fall. 1983;16(3):329-38. X-3. [pmid: 6643324].
2861 McGee GG, Krantz PJ, McClannahan LE. Conversational skills for autistic adolescents: teaching assertiveness in naturalistic game settings. J Autism Dev Disord. Sep. 1984;14(3):319-30. X-3. [pmid: 6480549].
2862 McGee GG, Krantz PJ, McClannahan LE. An extension of incidental teaching procedures to reading instruction for autistic children. J Appl Behav Anal. Summer. 1986;19(2):147-57. X-3. [pmid: 3733586].
2863 McGill P, Murphy G, Kelly-Pike A. Frequency of use and characteristics of people with intellectual disabilities subject to physical interventions. J Appl Res Intellect Disabil. Mar. 2009;22(2):152-8. X-4.
2864 McGovern CW, Sigman M. Continuity and change from early childhood to adolescence in autism. J Child Psychol Psychiatry. Apr. 2005;46(4):401-8. X-4. [pmid: 15819649].
2865 McGreevy D. Risks and benefits of the single versus the triple MMR vaccine: how can health professionals reassure parents?. J R Soc Promot Health. Mar. 2005;125(2):84-6. X-2, X-4. [pmid: 15819183].
2866 McGregor E, Campbell E. The attitudes of teachers in Scotland to the integration of children with autism into mainstream schools. Autism. Jun. 2001;5(2):189-207. X-4. [pmid: 11706866].
2867 McGuinness TM, Lewis S. Update on autism and vaccines. J Psychosoc Nurs Ment Health Serv. Jun. 2010;48(6):15-8. X-1, X-2, X-3, X-4. [pmid: 20506968].
2868 McGurk SR, Mueser KT, Feldman K, et al. Cognitive training for supported employment: 2–3 year outcomes of a randomized controlled trial. Am J Psychiatry. Mar. 2007;164(3):437-41. X-1, X-3, X-4. [pmid: 17329468].
2869 McGurk SR, Mueser KT, Pascaris A. Cognitive training and supported employment for persons with severe mental illness: one-year results from a randomized controlled trial. Schizophr Bull. Oct. 2005;31(4):898-909. X-1, X-3, X-4. [pmid: 16079391].
2870 McHale SM, Olley JG, Marcus LM, et al. Nonhandicapped peers as tutors for autistic children. Except Child. Nov. 1981;48(3):263-5. X-1, X-3, X-4. [pmid: 7297587].
2871 McHale SM, Simeonsson RJ, Marcus LM, et al. The social and symbolic quality of autistic children’s communication. J Autism Dev Disord. Sep. 1980;10(3):299-310. X-3. [pmid: 6085946].
2872 McIntyre LL, Blacher J, Baker BL. Behaviour/mental health problems in young adults with intellectual disability: the impact on families. J Intellect Disabil Res. Mar. 2002;46(Pt 3):239-49. X-4. [pmid: 11896809].
2873 McKee SA, Harris GT, Rice ME, et al. Effects of a Snoezelen room on the behavior of three autistic clients. Res Dev Disabil. May–Jun. 2007;28(3):304-16. X-1, X-2, X-3, X-4. [pmid: 16806812].
2874 McKeegan GF, Estill K, Campbell B. Elimination of rumination by controlled eating and differential reinforcement. J Behav Ther Exp Psychiatry. Jun. 1987;18(2):143-8. X-3. [pmid: 3611383].
2875 McKeegan GF, Estill K, Campbell BM. Brief report: Use of nonexclusionary timeout for the elimination of a stereotyped behavior. J Behav Ther Exp Psychiatry. Sep. 1984;15(3):261-4. X-3. [pmid: 6490938].
2876 McLaughlin MR. Speech and language delay in children. Am Fam Physician. May. 15. 2011;83(10):1183-8. X-1, X-2, X-3, X-4. [pmid: 21568252].
2877 McLellan A, Davies S, Heyman I, et al. Psychopathology in children with epilepsy before and after temporal lobe resection. Dev Med Child Neurol. Oct. 2005;47(10):666-72. X-1, X-2, X-3, X-4. [pmid: 16174309].
2878 McLennan JD, Huculak S, Sheehan D. Brief report: pilot investigation of service receipt by young children with autistic spectrum disorders. J Autism Dev Disord. Jul. 2008;38(6):1192-6. X-1, X-2, X-3, X-4. [pmid: 18324468].
2879 McLennan JD, Lord C, Schopler E. Sex differences in higher functioning people with autism. J Autism Dev Disord. Jun. 1993;23(2):217-27. X-4. [pmid: 8331044].
2880 McMahon CR, Malesa EE, Yoder PJ, et al. Parents of children with autism spectrum disorders have merited concerns about their later-born infants. Res Pract Persons Severe Disabl. Sum. 2007;32(2):154-60. X-4.
2881 McNally RJ, Calamari JE, Hansen PM, et al. Behavioral treatment of psychogenic polydipsia. J Behav Ther Exp Psychiatry. Mar. 1988;19(1):57-61. X-3. [pmid: 3392224].
2882 McNeilly LG, Sheppard JJ. Prologue: Managing dysphagia in the schools. Lang Speech Hear Serv Sch. Apr. 2008;39(2):158-9. X-2, X-4. [pmid: 18420518].
2883 McWilliam RA. What happened to service coordination?. J Early Interv. 2006;28(3):166-8. X-2, X-4.
2884 Meadan H, Ostrosky MM, Zaghlawan HY, et al. Promoting the social and communicative behavior of young children with autism spectrum disorders: a review of parent-implemented intervention studies. Topics Early Child Spec Educ. 2009;29(2):90-104. X-2, X-4.
2885 Meador SK, Derby KM, McLaughlin TF, et al. Using response latency within a preference assessment. Behav Anal Today. 2007;8(1):63-9. X-4.
2886 Meany-Daboul MG, Roscoe EM, Bourret JC, et al. A comparison of momentary time sampling and partial-interval recording for evaluating functional relations. J Appl Behav Anal. Fall. 2007;40(3):501-14. X-3, X-4. [pmid: 17970263].
2887 Medhurst B, Beresford J. “THOMAS” Training: an early years intervention for children with an autistic spectrum disorder (ASD). Educ Psychol Prac. Mar. 2007;23(1):1-17. EJ764161. X-1, X-3, X-4.
2888 Medhurst B, Clay D. The Thomas Outreach Project (TOP): an early years intervention for children with an autistic spectrum disorder (ASD). Educ Psychol Prac. Mar. 2008;24(1):69-78. X-1, X-2, X-3, X-4.
2889 Megson MN. Is autism a G-alpha protein defect reversible with natural vitamin A?. Med Hypotheses. Jun. 2000;54(6):979-83. X-4. [pmid: 10867750].
2890 Meguid NA, Atta HM, Gouda AS, et al. Role of polyunsaturated fatty acids in the management of Egyptian children with autism. Clin Biochem. Sep. 2008;41(13):1044-8. X-1, X-3, X-4. [pmid: 18582451].
2891 Meguid NA, Hashish AF, Anwar M, et al. Reduced serum levels of 25-hydroxy and 1,25-dihydroxy vitamin D in Egyptian children with autism. J Altern Complement Med. Jun. 2010;16(6):641-5. X-4. [pmid: 20569030].
2892 Mehlinger R, Scheftner WA, Poznanski E. Fluoxetine and autism. J Am Acad Child Adolesc Psychiatry. Nov. 1990;29(6):985. X-3, X-4. [pmid: 2273035].
2893 Mehl-Madrona L. Micronutrients and autism. 14th annual symposium on Complementary Health Care. 11th to 13th December 2007. University of Exeter, UK. Focus Altern Complement Ther. 2007;12:36. X-1, X-4.
2894 Mehl-Madrona L. Oxytocin and autism. 14th Annual Symposium on Complementary Health Care. 11th to 13th December 2007. University of Exeter, UK. Focus Altern Complement Ther. 2007;12:36-7. X-1, X-2, X-3, X-4.
2895 Mehl-Madrona L, Leung B, Kennedy C, et al. Micronutrients versus standard medication management in autism: a naturalistic case-control study. J Child Adolesc Psychopharmacol. Apr. 2010;20(2):95-103. X-1, X-3, X-4. [pmid: 20415604].
2896 Mehta UC, Patel I, Castello FV. EEG sedation for children with autism. J Dev Behav Pediatr. Apr. 2004;25(2):102-4. X-2. [pmid: 15083132].
2897 Meilleur AA, Fombonne E. Regression of language and non-language skills in pervasive developmental disorders. J Intellect Disabil Res. Feb. 2009;53(2):115-24. X-4. [pmid: 19054269].
2898 Meindl JN, Cannella-Malone HI. Initiating and responding to joint attention bids in children with autism: a review of the literature. Res Dev Disabil: A Multidisciplinary Journal. Sep–Oct. 2011;32(5):1441-54. X-1, X-2, X-3, X-4.
2899 Meiri G, Bichovsky Y, Belmaker RH. Omega 3 fatty acid treatment in autism. J Child Adolesc Psychopharmacol. Aug. 2009;19(4):449-51. X-1, X-2, X-3, X-4. [pmid: 19702497].
2900 Meiselas KD, Spencer EK, Oberfield R, et al. Differentiation of stereotypies from neuroleptic-related dyskinesias in autistic children. J Clin Psychopharmacol. Jun. 1989;9(3):207-9. X-1, X-3, X-4. [pmid: 2500463].
2901 Meissner HC, Strebel PM, Orenstein WA. Measles vaccines and the potential for worldwide eradication of measles. Pediatrics. Oct. 2004;114(4):1065-9. X-2, X-4. [pmid: 15466106].
2902 Meltzer LJ, Johnson C, Crosette J, et al. Prevalence of diagnosed sleep disorders in pediatric primary care practices. Pediatrics. Jun. 2010;125(6):e1410-8. X-4. [pmid: 20457689].
2903 Ménage P, Thibault G, Berthélémy C, et al. CD4 + CD45RA + T lymphocyte deficiency in autistic children: Effect of a pyridoxine-magnesium treatment. Brain Dysfunction. Sep–Dec. 1992;5(5–6):326-33. X-1, X-3, X-4.
2904 Menear KS, Smith S. Physical Education for Students with Autism: Teaching Tips and Strategies. Teach Except Child. May–Jun. 2008;40(5):32-7. X-2, X-4.
2905 Menear KS, Smith SC. Teaching physical education to students with autism spectrum disorders. Strategies. Jan–Feb. 2011;24(3):21-4. X-1, X-2, X-3, X-4.
2906 Menezes CG, Perissinoto J. Joint attention ability in children with autistic spectrum disorders. Pro Fono. Oct–Dec. 2008;20(4):273-9. X-1, X-3, X-4. [pmid: 19142472].
2907 Menyuk P. Language development in a social context. J Pediatr. Jul. 1986;109(1):217-24. X-1, X-2, X-3, X-4. [pmid: 2425068].
2908 Merlo LJ, Lehmkuhl HD, Geffken GR, et al. Decreased family accommodation associated with improved therapy outcome in pediatric obsessive-compulsive disorder. J Consult Clin Psychol. Apr. 2009;77(2):355-60. X-1, X-3, X-4. [pmid: 19309195].
2909 Mesibov GB. Social skills training with verbal autistic adolescents and adults: a program model. J Autism Dev Disord. Dec. 1984;14(4):395-404. X-3. [pmid: 6520094].
2910 Mesibov GB. Normalization and its relevance today. J Autism Dev Disord. Sep. 1990;20(3):379-90. X-2, X-4. [pmid: 1699925].
2911 Mesibov GB. Treatment outcome is encouraging. Am J Ment Retard. Jan. 1993;97(4):379-80. X-1, X-2, X-3, X-4.
2912 Mesibov GB. Commentary: facilitated communication: a warning for pediatric psychologists. J Pediatr Psychol. Feb. 1995;20(1):127-30. X-2, X-4. [pmid: 7891235].
2913 Mesibov GB. Preschool issues in autism: introduction. J Autism Dev Disord. Dec. 1997;27(6):637-40. X-1, X-2, X-3, X-4. [pmid: 9455725].
2914 Mesibov GB. Are children with autism better off in an autism classroom or a multidisability classroom?. J Autism Dev Disord. Oct. 1999;29(5):429. X-1, X-2, X-3, X-4. [pmid: 10587891].
2915 Mesibov GB, Schopler E, Caison W. The adolescent and adult psychoeducational profile: assessment of adolescents and adults with severe developmental handicaps. J Autism Dev Disord. Mar. 1989;19(1):33-40. X-4. [pmid: 2708302].
2916 Mesibov GB, Shea V. The TEACCH program in the era of evidence-based practice. J Autism Dev Disord. May. 2010;40(5):570-9. X-1, X-2, X-3, X-4. [pmid: 19937103].
2917 Messieha Z, Cruz-Gonzalez W, Hakim MI. Retrospective outcomes evaluation of 100 parenteral moderate and deep sedations conducted in a general practice dental residency. Anesth Prog. Winter. 2008;55(4):116-20. X-4. [pmid: 19108595].
2918 Messmer RL, Nader R, Craig KD. Brief report: judging pain intensity in children with autism undergoing venepuncture: the influence of facial activity. J Autism Dev Disord. Aug. 2008;38(7):1391-4. X-4. [pmid: 18161016].
2919 Mevorach C, Hodsoll J, Allen H, et al. Ignoring the elephant in the room: a neural circuit to downregulate salience. J Neurosci. Apr. 28. 2010;30(17):6072-9. X-1, X-3, X-4. [pmid: 20427665].
2920 Meyer JA, Hobson RP. Orientation in relation to self and other: the case of autism. Interact Stud. 2004;5(2):221-44. X-4.
2921 Meyer LH, Fox A, Schermer A, et al. The effects of teacher intrusion on social play interactions between children with autism and their nonhandicapped peers. J Autism Dev Disord. Sep. 1987;17(3):315-32. X-3. [pmid: 3654485].
2922 Miano S, Bruni O, Elia M, et al. Sleep in children with autistic spectrum disorder: a questionnaire and polysomnographic study. Sleep Med. Dec. 2007;9(1):64-70. X-4. [pmid: 17728182].
2923 Michaud F, Salter T, Duquette A, et al. Perspectives on mobile robots as tools for child development and pediatric rehabilitation. Assist Technol. Spring. 2007;19(1):21-36. X-2, X-4. [pmid: 17461288].
2924 Micheli E. A training group for parents of autistic children. Int J Ment Health. Fal. 1999;28(3):100-5. X-1.
2925 Mickel J, Griffin J. Inclusion and disability awareness training for educators in the kids like you, kids like me program. Young Children. Jul. 2007;62(4):42-5. X-2, X-4.
2926 Miguel CF, Clark K, Tereshko L, et al. The effects of response interruption and redirection and sertraline on vocal stereotypy. J Appl Behav Anal. Winter. 2009;42(4):883-8. X-1, X-3, X-4. [pmid: 20514198].
2927 Miguel CF, Yang HG, Finn HE, et al. Establishing derived textual control in activity schedules with children with autism. J Appl Behav Anal. Fall. 2009;42(3):703-9. X-1, X-2, X-3, X-4. [pmid: 20190932].
2928 Miilher LP, Fernandes FD. Pragmatic, lexical and grammatical abilities of autistic spectrum children. Pro Fono. Oct–Dec. 2009;21(4):309-14. X-1, X-3, X-4. [pmid: 20098949].
2929 Mikkelsen EJ. Efficacy of neuroleptic medication in pervasive developmental disorders of childhood. Schizophr Bull. 1982;8(2):320-32. X-1, X-2, X-3, X-4. [pmid: 6126001].
2930 Milbrath C, Siegel B. Perspective taking in the drawings of a talented autistic child. Vis Arts Res. Fall. 1996;22(44):56-75. X-1, X-3, X-4.
2931 Miles NI, Wilder DA. The effects of behavioral skills training on caregiver implementation of guided compliance. J Appl Behav Anal. Summer. 2009;42(2):405-10. X-3. [pmid: 19949532].
2932 Millar DC, Light JC, Schlosser RW. The impact of augmentative and alternative communication intervention on the speech production of individuals with developmental disabilities: a research review. J Speech Lang Hear Res. Apr. 2006;49(2):248-64. X-2. [pmid: 16671842].
2933 Miller AR, Zwaigenbaum L. New provincial initiatives for childhood disabilities: the imperative for research. CMAJ. Jun. 12. 2001;164(12):1704-5. X-2. [pmid: 11450214].
2934 Miller B. “a kaleidoscope of themes”: intensive psychotherapy with a girl on the autistic spectrum”. J Child Psychother. Dec. 2008;34(3):384-99. X-1, X-3, X-4.
2935 Miller E, Andrews N, Grant A, et al. No evidence of an association between MMR vaccine and gait disturbance. Arch Dis Child. Mar. 2005;90(3):292-6. X-4. [pmid: 15723921].
2936 Miller E, Batten B, Hampton L, et al. Tracking vaccine-safety inquiries to detect signals and monitor public concerns. Pediatrics. 2011:S87-91. X-1, X-3, X-4. [pmid: 21502241].
2937 Miller JM, Singer HS, Bridges DD, et al. Behavioral therapy for treatment of stereotypic movements in nonautistic children. J Child Neurol. Feb. 2006;21(2):119-25. X-4. [pmid: 16566875].
2938 Miller JS, Gabrielsen T, Villalobos M, et al. The each child study: systematic screening for autism spectrum disorders in a pediatric setting. Pediatrics. May. 2011;127(5):866-71. X-1, X-3, X-4. [pmid: 21482605].
2939 Miller M, Funayama ES. Life after high school for deaf youth with autism: challenges for students, parents, and professionals. Odyssey. Spr-Sum. 2008;9(1):32-7. X-1, X-2, X-3, X-4.
2940 Mills C, Wilson AD, Williams JHG, et al. Investigating visual attention in autism. Proceedings of SRR: abstracts from the Society for Research in Rehabilitation summer meeting held at Weetwood Hall. Leeds. 3 and 4 July 2007. Clin Rehabil. 2008;22(7):663. X-1, X-2, X-4.
2941 Mills PB, Footitt EJ, Mills KA, et al. Genotypic and phenotypic spectrum of pyridoxine-dependent epilepsy (ALDH7A1 deficiency). Brain. Jul. 2010;133(Pt 7):2148-59. X-1, X-3, X-4. [pmid: 20554659].
2942 Milne E, Scope A. Are children with autistic spectrum disorders susceptible to contour illusions?. Br J Dev Psychol. 2008;26(Part 1):91-102. X-3, X-4.
2943 Milo J-S, Mace FC, Nevin JA. The effects of constant versus varied reinforcers on preference and resistance to change. J Exp Anal Behav. May. 2010;93(3):385-94. X-3. [pmid: 21119852].
2944 Minagawa-Kawai Y, Naoi N, Kikuchi N, et al. Cerebral laterality for phonemic and prosodic cue decoding in children with autism. Neuroreport. Aug. 26. 2009;20(13):1219-24. X-4. [pmid: 19617855].
2945 Minderaa RB, Anderson GM, Volkmar FR, et al. Neurochemical study of dopamine functioning in autistic and normal subjects. J Am Acad Child Adolesc Psychiatry. Mar. 1989;28(2):190-4. X-4. [pmid: 2925571].
2946 Minderaa RB, Anderson GM, Volkmar FR, et al. Noradrenergic and adrenergic functioning in autism. Biol Psychiatry. Aug. 15. 1994;36(4):237-41. X-4. [pmid: 7986888].
2947 Minderaa RB, Anderson GM, Volkmar FR, et al. Whole blood serotonin and tryptophan in autism: temporal stability and the effects of medication. J Autism Dev Disord. Mar. 1989;19(1):129-36. X-3. [pmid: 2708296].
2948 Ming X, Brimacombe M, Wagner GC. Prevalence of motor impairment in autism spectrum disorders. Brain Dev. Oct. 2007;29(9):565-70. X-1, X-3, X-4. [pmid: 17467940].
2949 Ming X, Gordon E, Kang N, et al. Use of clonidine in children with autism spectrum disorders. Brain Dev. Aug. 2008;30(7):454-60. X-3. [pmid: 18280681].
2950 Minio-Paluello I, Baron-Cohen S, Avenanti A, et al. Absence of embodied empathy during pain observation in asperger syndrome. Biol Psychiatry. Jan. 1. 2009;65(1):55-62. X-4. [pmid: 18814863].
2951 Miniscalco C, Hagberg B, Kadesjo B, et al. Narrative skills, cognitive profiles and neuropsychiatric disorders in 7–8-year-old children with late developing language. Int J Lang Commun Disord. Nov. 2007;42(6):665-81. X-4. [pmid: 17852517].
2952 Minjarez MB, Williams SE, Mercier EM, et al. Pivotal response group treatment program for parents of children with autism. J Autism Dev Disord. Jan. 2011;41(1):92-101. X-1, X-3, X-4. [pmid: 20440638].
2953 Minnes P, Steiner K. Parent views on enhancing the quality of health care for their children with fragile X syndrome, autism or down syndrome. Child Care Health Dev. Mar. 2009;35(2):250-6. X-2. [pmid: 19228158].
2954 Minshew NJ, Goldstein G, Taylor HG, et al. Academic achievement in high functioning autistic individuals. J Clin Exp Neuropsychol. Apr. 1994;16(2):261-70. X-4. [pmid: 8021313].
2955 Miral S, Gencer O, Inal-Emiroglu FN, et al. Risperidone versus haloperidol in children and adolescents with AD : a randomized, controlled, double-blind trial. Eur Child Adolesc Psychiatry. Feb. 2008;17(1):1-8. X-1. [pmid: 18080171].
2956 Miranda-Linne F, Melin L. Acquisition, generalization, and spontaneous use of color adjectives: a comparison of incidental teaching and traditional discrete-trial procedures for children with autism. Res Dev Disabil. 1992;13(3):191-210. X-1, X-3, X-4. [pmid: 1626079].
2957 Mirenda P, Locke PA. A comparison of symbol transparency in nonspeaking persons with intellectual disabilities. J Speech Hear Disord. May. 1989;54(2):131-40. X-1, X-3, X-4. [pmid: 2709831].
2958 Mirenda PL, Donnellan AM, Yoder DE. Gaze behavior: a new look at an old problem. J Autism Dev Disord. Dec. 1983;13(4):397-409. X-1, X-2, X-3, X-4. [pmid: 6662843].
2959 Mishna F, Muskat B. Group therapy for boys with features of asperger syndrome and concurrent learning disabilities: Finding a peer group. J Child Adolesc Group Ther. Sep. 1998;8(3):97-114. X-1, X-3, X-4.
2960 Mitchel K, Regehr K, Reaume J, et al. Group social skills training for adolescents with asperger syndrome or high functioning autism. J Dev Disabil. 2010;16(2):52-63. X-3.
2961 Mitchell P, Parsons S, Leonard A. Using virtual environments for teaching social understanding to 6 adolescents with autistic spectrum disorders. J Autism Dev Disord. Mar. 2007;37(3):589-600. X-3. [pmid: 16900403].
2962 Mithaug DK, Mithaug DE. Effects of teacher-directed versus student-directed instruction on self-management of young children with disabilities. J Appl Behav Anal. Spring. 2003;36(1):133-6. X-1, X-3, X-4. [pmid: 12723878].
2963 CMM MJ, de Gelder B, van Engeland H, et al. Atypical processing of fearful face-voice pairs in pervasive developmental disorder: an ERP study. Clin Neurophysiol. Sep. 2008;119(9):2004-10. X-4. [pmid: 18571467].
2964 DE MK. Infantile autism: patients and their families. Curr Probl Pediatr. Feb. 1982;12(4):1-52. X-1, X-2, X-3, X-4. [pmid: 6176400].
2965 Moes DR, Frea WD. Using family context to inform intervention planning for the treatment of a child with autism. J Posit Behav Interv. Win. 2000;2(1):40-6. X-1, X-3, X-4.
2966 Moes DR, Frea WD. Contextualized behavioral support in early intervention for children with autism and their families. J Autism Dev Disord. Dec. 2002;32(6):519-33. X-1, X-3, X-4. [pmid: 12553589].
2967 Mogensen L. Hearing their views: engaging teenagers diagnosed with autism in qualitative research using a collaborative participatory approach... Occupational Therapy Australia. 24th national conference and exhibition. 29 June –1 July 2011. Aust Occup Ther J. 2011;58:36. X-1, X-2, X-3, X-4.
2968 Mohammad NS, Jain JMN, Chintakindi KP, et al. Aberrations in folate metabolic pathway and altered susceptibility to autism. Psychiatr Genet. Aug. 2009;19(4):171-6. X-4. [pmid: 19440165].
2969 Mohan D, Taylor R, Mackeith JA. Cyproterone acetate and striae. Int J Psychiatry Clin Pract. Jun. 1998;2(2):147-8. X-4.
2970 Mohr C, Sharpley CF. Elimination of self-injurious behaviour in an autistic child by use of overcorrection. Behav Change. 1985;2(2):143-7. X-1, X-3, X-4.
2971 Molinari JA. Vaccination: science versus perception. Dent Today. Dec. 84. 2010;29(12):6. X-1, X-2, X-3, X-4. [pmid: 21229925].
2972 Moller AR, Kern JK, Grannemann B. Are the non-classical auditory pathways involved in autism and PDD?. Neurol Res. Sep. 2005;27(6):625-9. X-4. [pmid: 16157013].
2973 Molloy CA, Manning-Courtney P, Swayne S, et al. Lack of benefit of intravenous synthetic human secretin in the treatment of autism. J Autism Dev Disord. Dec. 2002;32(6):545-51. X-1, X-3, X-4. [pmid: 12553591].
2974 Molloy CA, Murray DS, Kinsman A, et al. Differences in the clinical presentation of Trisomy 21 with and without autism. J Intellect Disabil Res. 2009;53(Part 2):143-51. X-4. [pmid: 19198037].
2975 Monji A, Maekawa T, Yanagimoto K, et al. Carbamazepine may trigger new-onset epileptic seizures in an individual with autism spectrum disorders: a case report. Eur Psychiatry. Aug. 2004;19(5):322-3. X-3. [pmid: 15276670].
2976 Monsen RB. Watching children. J Pediatr Nurs. Dec. 2008;23(6):469-70. X-2. [pmid: 19026915].
2977 Montes G, Halterman JS. White-black disparities in family-centered care among children with autism in the United States: evidence From the NS-CSHCN 2005–2006. Acad Pediatr. 2011;11(4):297-304. X-1, X-4. [pmid: 21622042].
2978 Montes G, Halterman JS, Magyar CI. Access to and satisfaction with school and community health services for US children with ASD. Pediatr. Dec. Suppl 4. 2009;124:S407-13. X-4. [pmid: 19948606].
2979 Montgomery J, Storey K, Post M, et al. The use of auditory prompting systems for increasing independent performance of students with autism in employment training. Int J Rehabil Res. Dec. 2011;34(4):330-5. X-3. [pmid: 21885987].
2980 Montgomery JM, Duncan CR, Francis GC. Test Review: Siegel, B. Pervasive Developmental Disorder Screening Test--II (PDDST-II). San Antonio, TX. Harcourt. J Psychoeduc Assess. 2007. 2004;25(3):299-306. X-2, X-4.
2981 Moomaw S, Davis JA. STEM Comes to Preschool. Young Children. 16–18. Sep. 2010;65(5):12-4. X-1, X-2, X-3, X-4.
2982 Moore JW, Fisher WW, Pennington A. Systematic application and removal of protective equipment in the assessment of multiple topographies of self-injury. J Appl Behav Anal. Spr. 2004;37(1):73-7. X-3. [pmid: 15154217].
2983 Moore M, Calvert S. Brief report: vocabulary acquisition for children with autism: teacher or computer instruction. J Autism Dev Disord. Aug. 2000;30(4):359-62. X-1, X-3, X-4. [pmid: 11039862].
2984 Moore SJ, Turnpenny P, Quinn A, et al. A clinical study of 57 children with fetal anticonvulsant syndromes. J Med Genet. Jul. 2000;37(7):489-97. X-4. [pmid: 10882750].
2985 Moore TR. A brief report on the effects of a self-management treatment package on stereotypic behavior. Res Autism Spectr Disord. Jul–Sep. 2009;3(3):695-701. X-3.
2986 Moore TR, Symons FJ. Adherence to behavioral and medical treatment recommendations by parents of children with autism spectrum disorders. J Autism Dev Disord. Aug. 2009;39(8):1173-84. X-4. [pmid: 19333747].
2987 Moore V, Goodson S. How well does early diagnosis of autism stand the test of time? Follow-up study of children assessed for autism at age 2 and development of an early diagnostic service. Autism. Mar. 2003;7(1):47-63. X-1, X-3, X-4. [pmid: 12638764].
2988 Moore V, Titcomb J, Cronk E, et al. Developing an autism assessment service I: Procedures, priorities, and pitfalls over the first 5 years. Child Psychol Psychiatry Rev. 1998;3(3):116-20. X-2, X-4.
2989 Moore V, Titcomb J, Johnson C, et al. Developing an autism assessment service II: Analysis of the first 81 cases seen. Child Psychol Psychiatry Rev. 1998;3(3):121-7. X-4.
2990 Moores DF. Issues in the modification of American sign language for instructional purposes. J Autism Dev Disord. Mar. 1981;11(1):153-62. X-1, X-2, X-3, X-4. [pmid: 6927696].
2991 Moores-Abdool W. Included students with autism and access to general curriculum: what is being provided?. Issues Teach Educ. Fall. 2010;19(2):153-69. X-1, X-2, X-3, X-4.
2992 Moors A, Fabrizio M. Using Tool Skill Rates to Predict Composite Skill Frequency Aims. J Precision Teach Celeration. Spr. 2002;18(1):28-9. X-3.
2993 Morag A, Pasmanik-Chor M, Oron-Karni V, et al. Genome-wide expression profiling of human lymphoblastoid cell lines identifies CHL1 as a putative SSRI antidepressant response biomarker. Pharmacogenomics. Feb. 2011;12(2):171-84. X-1, X-2, X-3, X-4. [pmid: 21332311].
2994 Morales AW. MEG reveals epileptic foci in brains of autistic children. Diagn Imaging (San Franc). Jan. Suppl. 1999:IR34. X-4. [pmid: 11692368].
2995 Moran DR, Whitman TL. Developing generalized teaching skills in mothers of autistic children. Child Fam Behav Ther. 1991;13(1):13-37. X-1, X-3, X-4.
2996 Moreland R. National vaccine injury compensation program: the potential impact of Cedillo for vaccine-related autism cases. J Leg Med. Jul–Sep. 2008;29(3):363-80. X-2, X-4. [pmid: 18726760].
2997 Moreno J, Aguilera A, David S. Do Spanish parents prefer special schools for their children with autism?. Educ Train Dev Disabil. Jun. 2008;43(2):162-73. X-1, X-3, X-4.
2998 Moreton J. MMR vaccination: protecting our children. J Fam Health Care. 2002;12(2):31. X-2, X-4. [pmid: 12415749].
2999 Moreton J. Who’s irresponsible?. Community Pract. May. 2009;82(5):14. X-1, X-2, X-3, X-4. [pmid: 19480113].
3000 Moretti P, Peters SU, Del Gaudio D, et al. Brief report: autistic symptoms, developmental regression, mental retardation, epilepsy, and dyskinesias in CNS folate deficiency. J Autism Dev Disord. Jul. 2008;38(6):1170-7. X-1, X-3, X-4. [pmid: 18027081].
3001 Moretti P, Sahoo T, Hyland K, et al. Cerebral folate deficiency with developmental delay, autism, and response to folinic acid. Neurology. Mar. 2005;64(6):1088-90. X-1, X-3, X-4. [pmid: 15781839].
3002 Morgan CN, Roy M, Chance P. Psychiatric comorbidity and medication use in autism: A community survey. Psychiatr Bull. Oct. 2003;27(10):378-81. X-4.
3003 Morgan SB. Helping parents understand the diagnosis of autism. J Dev Behav Pediatr. Apr. 1984;5(2):78-85. X-1, X-2, X-3, X-4. [pmid: 6715557].
3004 Mori K, Ujiie T, Smith A, et al. Parental stress associated with caring for children with asperger’s syndrome or autism. Pediatr Int. Jun. 2009;51(3):364-70. X-2, X-4. [pmid: 19419495].
3005 Mori S. The role of the self–object experience in the therapy of an autistic child: from lying flat to launching a ‘spaceship’. J Child Psychother. Aug. 2001;27(2):159-73. X-1, X-3, X-4.
3006 Morinushi T, Ueda Y, Tanaka C. Autistic children: experience and severity of dental caries between 1980 and 1995 in Kagoshima City, Japan. J Clin Pediatr Dent. Summer. 2001;25(4):323-8. X-4. [pmid: 11497015].
3007 Morowitz HJ. Autism and authority. Hosp Pract (Off Ed). Apr. 15. 1989;24(4):221-2. X-1, X-2, X-3, X-4. [pmid: 2494214].
3008 Morrier MJ, Hess KL, Heflin LJ. Ethnic disproportionality in students with autism spectrum disorders. Multicultural Educ. Fall. 2008;16(1):31-8. X-2, X-4.
3009 Morrier MJ, Hess KL, Heflin LJ. Teacher training for implementation of teaching strategies for students with autism spectrum disorders. Teach Educ Spec Educ. May. 2011;34(2):119-32. X-1, X-3, X-4.
3010 Morris CR, Agin MC. Syndrome of allergy, apraxia, and malabsorption: characterization of a neurodevelopmental phenotype that responds to omega 3 and vitamin E supplementation. Altern Ther Health Med. Jul–Aug. 2009;15(4):34-43. X-1, X-3. [pmid: 19623831].
3011 Morris RG, Rowe A, Fox N, et al. Spatial working memory in asperger’s syndrome and in patients with focal frontal and temporal lobe lesions. Brain Cogn. Oct. 1999;41(1):9-26. X-4. [pmid: 10536083].
3012 Morrison A, Bickerstaff D, Taylor BJ. Referrals to a learning disability social work team 1996 to 2005. Br J Learn Disabil. Sep. 2010;38(3):168-74. X-4.
3013 Morrison H, Roscoe EM, Atwell A. An evaluation of antecedent exercise on behavior maintained by automatic reinforcement using a three-component multiple schedule. J Appl Behav Anal. Fall. 2011;44(3):523-41. X-3s. [pmid: 21941383].
3014 Morrison RS, Sainato DM, Benchaaban D, et al. Increasing play skills of children with autism using activity schedules and correspondence training. J Early Interv. Win-Spr. 2002;25(1):58-72. X-1, X-3, X-4.
3015 Morse TE. Perspectives on addressing the literacy needs of low functioning individuals with autism. Int J Educ Reform. Fall. 2008;17(4):330-40. X-2, X-4.
3016 Morse TE. Comprehensive special education programming for students with autism spectrum disorder in the United States. Int J Educ Reform. Win. 2010;19(1):2-13. X-1, X-2, X-3, X-4.
3017 Morse TE, Schuster JW. Teaching elementary students with moderate intellectual disabilities how to shop for groceries. Except Child. Win. 2000;66(2):273-88. X-1, X-3, X-4.
3018 Morton DD. Deafness and Autism. Odyssey. Spr-Sum. 2008;9(1):4-5. X-1, X-2, X-3, X-4.
3019 Morton JF, Campbell JM. Information source affects peers’ initial attitudes toward autism. Res Dev Disabil. May–Jun. 2008;29(3):189-201. X-4. [pmid: 17391914].
3020 Morton M. Silenced in the court: meanings of research and difference in the US legal system. Disabil Soc. 2009;24(7):883-95. X-1, X-2, X-3, X-4.
3021 Moss HA, Brouwers P, Wolters PL, et al. The development of a Q-sort behavioral rating procedure for pediatric HIV patients. J Pediatr Psychol. Feb. 1994;19(1):27-46. X-4. [pmid: 8151493].
3022 Moss J, Magiati I, Charman T, et al. Stability of the autism diagnostic interview-revised from pre-school to elementary school age in children with autism spectrum disorders. J Autism Dev Disord. Jul. 2008;38(6):1081-91. X-4. [pmid: 18058215].
3023 Mostafa GA, El-Sherif DF, Hamza RT, et al. Hyperserotonemia in Egyptian autistic children: relation to allergic manifestations. J Pediatr Neurol. 2008;6(3):227-36. X-4.
3024 Mostert MP. Facilitated Communication since 1995: A Review of Published Studies. J Autism Dev Disord. Jun. 2001;31(3):287-313. X-2, X-4. [pmid: 11518483].
3025 Mostert MP. Facilitated communication and its legitimacy--twenty-first century developments. Exceptionality. 2010;18(1):31-41. X-1, X-2, X-3, X-4.
3026 Mothander PR, Moe RG. Self-reported depressive symptoms and parental stress in mothers and fathers who bring their infants to an infant mental health clinic. Nord J Psychiatry. Oct. 2010;64(5):310-6. X-1, X-3, X-4. [pmid: 20184497].
3027 Mouridsen SE, Rich B, Isager T. Validity of childhood disintegrative psychosis. General findings of a long-term follow-up study. Br J Psychiatry. Mar. 1998;172:263-7. X-4. [pmid: 9614477].
3028 Mouridsen SE, Rich B, Isager T. Epilepsy in disintegrative psychosis and infantile autism: a long-term validation study. Dev Med Child Neurol. Feb. 1999;41(2):110-4. X-4. [pmid: 10075096].
3029 Mouridsen SE, Rich B, Isager T. Psychiatric morbidity in disintegrative psychosis and infantile autism: a long-term follow-up study. Psychopathology. Jul–Aug. 1999;32(4):177-83. X-4. [pmid: 10364726].
3030 Mouridsen SE, Rich B, Isager T, et al. Psychiatric disorders in the parents of individuals with infantile autism: a case-control study. Psychopathology. 2007;40(3):166-71. X-4. [pmid: 17318009].
3031 Mousain-Bosc M, Roche M, Polge A, et al. Improvement of neurobehavioral disorders in children supplemented with magnesium-vitamin B6. II. Pervasive developmental disorder-autism. Magnes Res. Mar. 2006;19(1):53-62. X-1, X-3, X-4. [pmid: 16846101].
3032 Mraz KD, Dixon J, Dumont-Mathieu T, et al. Accelerated head and body growth in infants later diagnosed with autism spectrum disorders: A comparative study of optimal outcome children. J Child Neurol. Jul. 2009;24(7):833-45. X-4. [pmid: 19617459].
3033 Mrozek-Budzyn D, Kieltyka A, Majewska R. Lack of association between measles-mumps-rubella vaccination and autism in children: a case-control study. Pediatr Infect Dis J. May. 2010;29(5):397-400. X-1, X-2, X-3, X-4. [pmid: 19952979].
3034 Mruzek DW, Cohen C, Smith T. Contingency contracting with students with autism spectrum disorders in a public school setting. J Dev Phys Disabil. Apr. 2007;19(2):103-14. X-1, X-3, X-4.
3035 Msall ME, Avery RC, Tremont MR, et al. Functional disability and school activity limitations in 41,300 school-age children: relationship to medical impairments. Pediatrics. Mar. 2003;111(3):548-53. X-4. [pmid: 12612235].
3036 Msall ME, Phelps DL, Hardy RJ, et al. Educational and social competencies at 8 years in children with threshold retinopathy of prematurity in the CRYO-ROP multicenter study. Pediatrics. Apr. 2004;113(4):790-9. X-4. [pmid: 15060229].
3037 Muckian J. Influencing policy development: the whirling dervish of the autism in-home program. J Pediatr Nurs. Jun. 2007;22(3):223-30. X-2, X-4. [pmid: 17524966].
3038 Mudford OC, Cross BA, Breen S, et al. Auditory integration training for children with autism: no behavioral benefits detected. Am J Ment Retard. Mar. 2000;105(2):118-29. X-3. [pmid: 10755175].
3039 Mudford OC, Martin NT, Eikeseth S, et al. Parent-managed behavioral treatment for preschool children with autism: some characteristics of UK programs. Res Dev Disabil. May–Jun. 2001;22(3):173-82. X-1, X-3, X-4. [pmid: 11380057].
3040 Mukaddes NM, Abali O, Gurkan K. Short-term efficacy and safety of risperidone in young children with autistic disorder (AD). World J Biol Psychiatry. Oct. 2004;5(4):211-4. X-1, X-3, X-4. [pmid: 15543515].
3041 Mukaddes NM, Bilge S, Alyanak B, et al. Clinical characteristics and treatment responses in cases diagnosed as reactive attachment disorder. Child Psychiatry Hum Dev. Summer. 2000;30(4):273-87. X-4. [pmid: 10921209].
3042 Mukaddes NM, Kaynak FN, Kinali G, et al. Psychoeducational treatment of children with autism and reactive attachment disorder. Autism. Mar. 2004;8(1):101-9. X-1, X-3, X-4. [pmid: 15070550].
3043 Müller E, Schuler A, Burton BA, et al. Meeting the vocational support needs of individuals with asperger syndrome and other autism spectrum disabilities. J Vocat Rehabil. 2003;18(3):163-75. X-3, X-4.
3044 Muller E, Schuler A, Yates GB. Social challenges and supports from the perspective of individuals with asperger syndrome and other autism spectrum disabilities. Autism. Mar. 2008;12(2):173-90. X-3, X-4. [pmid: 18308766].
3045 Mullins JL, Christian L. The effects of progressive relaxation training on the disruptive behavior of a boy with autism. Res Dev Disabil. Nov–Dec. 2001;22(6):449-62. X-1, X-3, X-4. [pmid: 11768670].
3046 Mullins M, Rincover A. Comparing autistic and normal children along the dimensions of reinforcement maximization, stimulus sampling, and responsiveness to extinction. J Exp Child Psychol. Oct. 1985;40(2):350-74. X-3. [pmid: 4045384].
3047 Munasinghe SA, Oliff C, Finn J, et al. Digestive enzyme supplementation for autism spectrum disorders: a double-blind randomized controlled trial. J Autism Dev Disord. Sep. 2010;40(9):1131-8. X-1, X-4. [pmid: 20204691].
3048 Mundkur N. Developmental and behavioral pediatrics--the present and the future. Indian J Pediatr. Oct. 2005;72(10):853. X-2. [pmid: 16272657].
3049 Mundschenk NA, Sasso GM. Assessing sufficient social exemplars for students with autism. Behav Disord. Special Issue: Autism. Nov. 1995;21(1):62-78. X-1, X-3, X-4.
3050 Mundy P. Normal versus high-functioning status in children with autism. Am J Ment Retard. Jan. 1993;97(4):381-84. X-1, X-2, X-3, X-4.
3051 Mundy P, Crowson M. Joint attention and early social communication: implications for research on intervention with autism. J Autism Dev Disord. Dec. 1997;27(6):653-76. X-1, X-2, X-3, X-4. [pmid: 9455727].
3052 Munesue T, Ono Y, Mutoh K, et al. High prevalence of bipolar disorder comorbidity in adolescents and young adults with high-functioning autism spectrum disorder: a preliminary study of 44 outpatients. J Affect Disord. Dec. 2008;111(2–3):170-5. X-4. [pmid: 18378000].
3053 Munir S, Scholwinski E, Lasser J. The use of psychodrama techniques for students with asperger’s disorder. J Pychol Theol. 2006;4(2). X-1, X-2, X-3, X-4.
3054 Munson BL. Myths and facts...about autism. Nursing. Oct. 2004;34(10):75. X-2. [pmid: 15489628].
3055 Murdoch H. Stereotyped behaviors in deaf and hard of hearing children. Am Ann Deaf. Dec. 1996;141(5):379-86. X-4. [pmid: 9002324].
3056 Murdock LC, Hobbs JQ. Picture Me Playing: increasing pretend play dialogue of children with autism spectrum disorders. J Autism Dev Disord. Jul. 2011;41(7):870-8. X-1, X-3, X-4. [pmid: 20872061].
3057 Murdock LC, Hobbs JQ. Tell me what you did today: a visual cueing strategy for children with ASD. Focus Autism Dev Disabil. Sep. 2011;26(3):162-72. X-3, X-4.
3058 Murphy C, Barnes-Holmes D. Establishing five derived mands in three adolescent boys with autism. J Appl Behav Anal. Fall. 2010;43(3):537-41. X-3. [pmid: 21358916].
3059 Murphy D. Extreme violence in a man with an autistic spectrum disorder: assessment and treatment within high-security psychiatric care. J Forens Psychiatry Psychol. Jun. 2010;21(3):462-77. X-3.
3060 Murphy DGM, Beecham J, Craig M, et al. Autism in adults. New biologicial findings and their translational implications to the cost of clinical services. Brain Res. Mar. 2011;1380:22-33. X-4. [pmid: 20969835].
3061 Murphy DGM, Critchley HD, Schmitz N, et al. Asperger syndrome: a proton magnetic resonance spectroscopy study of brain. Arch Gen Psychiatry. Oct. 2002;59(10):885-92. X-4. [pmid: 12365875].
3062 Murphy G, Hall S, Oliver C, et al. Identification of early self-injurious behaviour in young children with intellectual disability. J Intellect Disabil Res. Jun. 1999;43(Pt 3):149-63. X-4. [pmid: 10392602].
3063 Murphy G, Powell S, Guzman AM, et al. Cognitive-behavioural treatment for men with intellectual disabilities and sexually abusive behaviour: a pilot study. J Intellect Disabil Res. Nov. 2007;51(Pt 11):902-12. X-3. [pmid: 17910542].
3064 Murphy JF. MMR and the measles crisis. Ir Med J. Mar–Apr. 2000;93(2):36. X-2, X-4. [pmid: 11037244].
3065 Murphy JV, Wheless JW, Schmoll CM. Left vagal nerve stimulation in six patients with hypothalamic hamartomas. Pediatr Neurol. Aug. 2000;23(2):167-8. X-1, X-3, X-4. [pmid: 11020644].
3066 Murray M, Baker PH, Murray-Slutsky C, et al. Strategies for supporting the sensory-based learner. Prev School Failure. Sum. 2009;53(4):245-51. X-2, X-4.
3067 Music G. Surfacing the depths: thoughts on imitation, resonance and growth. J Child Psychother. Apr. 2005;31(1):72-90. X-1, X-3, X-4.
3068 Muys V, Rodger S, Bundy AC. Assessment of playfulness in children with autistic disorder: a comparison of the Children’s Playfulness Scale and the Test of Playfulness. OTJR. 2006;26(4):159-70. X-1, X-3, X-4.
3069 Myers KM, Goulet M, Rusche J, et al. Partial reversal of phencyclidine-induced impairment of prepulse inhibition by secretin. Biol Psychiatry. Jul. 1. 2005;58(1):67-73. X-4. [pmid: 15992525].
3070 Myers SM. Management of autism spectrum disorders in primary care. Pediatr Ann. Jan. 2009;38(1):42-9. X-2. [pmid: 19213293].
3071 Myers SM, Johnson CP. Management of children with autism spectrum disorders. Pediatrics. Nov. 2007;120(5):1162-82. X-1, X-2, X-3, X-4. [pmid: 17967921].
3072 Myles BS. Behavioral forms of stress management for individuals with asperger syndrome. Child Adolesc Psychiatr Clin N Am. Jan. 2003;12(1):123-41. X-2, X-4. [pmid: 12512402].
3073 Myles BS, Ferguson H, Hagiwara T. Using a personal digital assistant to improve the recording of homework assignments by an adolescent with asperger syndrome. Focus Autism Dev Disabil. Sum. 2007;22(2):96-9. X-3, X-4.
3074 Myles BS, Simpson RL, Ormsbee CK, et al. Integrating preschool children with autism with their normally developing peers: Research findings and best practices recommendations. Focus on Autistic Behavior. Dec. 1993;8(5):1-18. X-1, X-3, X-4.
3075 Nader R, Oberlander TF, Chambers CT, et al. Expression of pain in children with autism. Clin J Pain. Mar–Apr. 2004;20(2):88-97. X-4. [pmid: 14770048].
3076 Naganuma GM, Billingsley FF. Effect of hand splints on stereotypic hand behavior of three girls with Rett syndrome. Phys Ther. May. 1988;68(5):664-71. X-1, X-3, X-4. [pmid: 3362979].
3077 Nagaraj R, Singhi P, Malhi P. Risperidone in children with autism: randomized, placebo-controlled, double-blind study. J Child Neurol. Jun. 2006;21(6):450-5. X-1, X-3, X-4. [pmid: 16948927].
3078 Nagarajan RP, Patzel KA, Martin M, et al. MECP2 promoter methylation and X chromosome inactivation in autism. Autism Res. Jun. 2008;1(3):169-78. X-1, X-3, X-4. [pmid: 19132145].
3079 Nahshoni E, Spitzer S, Berant M, et al. QT interval and dispersion in very young children treated with antipsychotic drugs: a retrospective chart review. J Child Adolesc Psychopharmacol. Apr. 2007;17(2):187-94. X-1, X-3, X-4. [pmid: 17489713].
3080 Najdowski AC, Chilingaryan V, Bergstrom R, et al. Comparison of data-collection methods in a behavioral intervention program for children with pervasive developmental disorders: a replication. J Appl Behav Anal. Winter. 2009;42(4):827-32. X-3. [pmid: 20514189].
3081 Najdowski AC, Wallace MD, Doney JK, et al. Parental assessment and treatment of food selectivity in natural settings. J Appl Behav Anal. Fall. 2003;36(3):383-6. X-1, X-3, X-4. [pmid: 14596582].
3082 Nalitz NG. Consultation and collaboration programs for individuals with autism. Clin Commun Disord. Winter. 1993;3(1):31-43. X-2. [pmid: 8485511].
3083 Namerow LB, Mangini LM. Targeting symptom domains: a strategy for pharmacotherapy in childhood pervasive developmental disorders. Conn Med. Oct. 2005;69(9):525-33. X-2, X-4. [pmid: 16270789].
3084 Namerow LB, Thomas P, Bostic JQ, et al. Use of citalopram in pervasive developmental disorders. J Dev Behav Pediatr. Apr. 2003;24(2):104-8. X-3. [pmid: 12692455].
3085 Naoi N, Tsuchiya R, Yamamoto J, et al. Functional training for initiating joint attention in children with autism. Res Dev Disabil. Nov–Dec. 2008;29(6):595-609. X-3, X-4. [pmid: 18065199].
3086 Naoi N, Yokoyama K, Yamamoto J-i. Matrix training for expressive and receptive two-word utterances in children with autism. Jpn J Spec Educ. Mar. 2006;43(6):505-18. X-3.
3087 Napolitano DA, Smith T, Zarcone JR, et al. Increasing response diversity in children with autism. J Appl Behav Anal. Sum. 2010;43(2):265-71. X-1, X-3. [pmid: 21119899].
3088 Narayan J, Chakravarti SN, David J, et al. Analysis of educational support systems for children with mental retardation and autism spectrum disorders. Int J Rehabil Res. Dec. 2005;28(4):365-8. X-1, X-2, X-3, X-4. [pmid: 16319564].
3089 Narayanan A, White CA, Saklayen S, et al. Effect of propranolol on functional connectivity in autism spectrum disorder--a pilot study. Brain Imaging Behav. Jun. 2010;4(2):189-97. X-3. [pmid: 20502989].
3090 Nataf R, Skorupka C, Amet L, et al. Porphyrinuria in childhood autistic disorder: implications for environmental toxicity. Toxicol Appl Pharmacol. Jul. 15. 2006;214(2):99-108. X-4. [pmid: 16782144].
3091 Nation K, Norbury CF. Why reading comprehension fails: insights from developmental disorders. Top Lang Disord. Jan–Mar. 2005;25(1):21. X-2, X-4.
3092 Natof TH, Romanczyk RG. Teaching students with ASD: does teacher enthusiasm make a difference?. Behav Int. Feb. 2009;24(1):55-72. X-3.
3093 Neef NA. Pyramidal parent training by peers. J Appl Behav Anal. Fall. 1995;28(3):333-7. X-3. [pmid: 7592149].
3094 Neef NA, Shafer MS, Egel AL, et al. The class specific effects of compliance training with “do” and “don’t” requests: analogue analysis and classroom application. J Appl Behav Anal. Spring. 1983;16(1):81-99. X-1, X-3, X-4. [pmid: 6187723].
3095 Neef NA, Walters J, Egel AL. Establishing generative yes/no responses in developmentally disabled children. J Appl Behav Anal. Winter. 1984;17(4):453-60. X-1, X-3, X-4. [pmid: 6526766].
3096 Neely-Barnes SL, Hall HR, Roberts RJ, et al. Parenting a child with an autism spectrum disorder: public perceptions and parental conceptualizations. J Fam Soc Work. 2011;14(3):208-25. X-4.
3097 Nefdt N, Koegel R, Singer G, et al. The use of a self-directed learning program to provide introductory training in pivotal response treatment to parents of children with autism. J Posit Behav Interv. Jan. 2010;12(1):23-32. X-1, X-3, X-4.
3098 Neidert PL, Iwata BA, Dozier CL. Treatment of multiply controlled problem behavior with procedural variations of differential reinforcement. Exceptionality. 2005;13(1):45-53. X-3.
3099 Neitzel J. Positive behavior supports for children and youth with autism spectrum disorders. Prev School Failure. 2010;54(4):247-55. X-1, X-2, X-3, X-4.
3100 Nelson C, Huefner DS. Young children with autism: judicial responses to the lovaas and discrete trial training debates. J Early Interv. Fall. 2003;26(1):1-19. X-1, X-2, X-3, X-4.
3101 Nelson C, McDonnell AP, Johnston SS, et al. Keys to play: A strategy to increase the social interactions of young children with autism and their typically developing peers. Educ Train Dev Disabil. Jun. 2007;42(2):165-81. X-1, X-3, X-4.
3102 Nelson D, Amplo K. Care of the autistic patient in the perioperative area. AORN J. Feb. 2009;89(2):391-2. 5. 7. X-2. [pmid: 19200470].
3103 Nelson EC, Pribor EF. A calendar savant with autism and Tourette syndrome: Response to treatment and thoughts on the interrelationships of these conditions. Ann Clin Psychiatry. Jun. 1993;5(2):135-40. X-4. [pmid: 8348206].
3104 Nepo KG. The use of technology to improve staff performance. Int J Behav Consult Ther. Aug. 2010;6(2):134-41. X-4.
3105 Nesbitt S. An evaluation of multi-agency service provision for children with autistic spectrum disorders. Br J Dev Disabil. Jan. 2000;46(90, Pt 1):43-50. X-4.
3106 Nesbitt S. Why and why not? Factors influencing employment for individuals with asperger syndrome. Autism. Dec. 2000;4(4):357-69. X-1, X-3, X-4.
3107 Network AaDDM. Prevalence of the Autism Spectrum Disorders (ASDs) in Multiple Areas of the United States, 2004 and 2006 Centers for Disease Control and Prevention. Atlanta. CDC. 2009. 2009 http://www.cdc.gov/ncbddd/autism/states/ADDMCommunityReport2009.pdf.
3108 Neufeld A, Fantuzzo JW. Contingent application of a protective device to treat the severe self-biting behavior of a disturbed autistic child. J Behav Ther Exp Psychiatry. Mar. 1984;15(1):79-83. X-1, X-3, X-4. [pmid: 6470161].
3109 Neufeld RE, Clark BG, Robertson CM, et al. Five-year neurocognitive and health outcomes after the neonatal arterial switch operation. J Thorac Cardiovasc Surg. Dec. 2008;136(6):1413-21. 21 e1. 21 e2. X-4. [pmid: 19114183].
3110 Neumann N, Dubischar-Krivec AM, Braun C, et al. The mind of the mnemonists: An MEG and neuropsychological study of autistic memory savants. Behavioural Brain Research. Dec. 2010;215(1):114-21. X-3, X-4. [pmid: 20637245].
3111 Neves SN, Reimao R. Sleep disturbances in 50 children with attention-deficit hyperactivity disorder. Arq Neuropsiquiatr. Jun. 2007;65(2A):228-33. X-4. [pmid: 17607419].
3112 Nevo Y, Shinnar S, Samuel E, et al. Unprovoked seizures and developmental disabilities: clinical characteristics of children referred to a child development center. Pediatr Neurol. Oct. 1995;13(3):235-41. X-4. [pmid: 8554661].
3113 Newman B, Buffington DM, O’Grady MA, et al. Self-management of schedule following in three teenagers with autism. Behav Disord. May. 1995;20(3):190-6. X-3.
3114 Newman B, Needelman M, Reinecke DR, et al. The effect of providing choices on skill acquisition and competing behavior of children with autism during discrete trial instruction. Behav Int. Jan–Mar. 2002;17(1):31-41. X-1, X-3, X-4.
3115 Newman B, Reinecke D, Ramos M. Is a reasonable attempt reasonable? Shaping versus reinforcing verbal attempts of preschoolers with autism. Anal Verbal Behav. 2009;25:67-72. X-1, X-3, X-4. [pmid: 22477429].
3116 Newman B, Reinecke DR, Meinberg DL. Self-management of varied responding in three students with autism. Behav Int. Apr–Jun. 2000;15(2):145-51. X-1, X-3, X-4.
3117 Newman B, Ten Eyck P. Self-management of initiations by students diagnosed with autism. Anal Verbal Behav. 2005;21:117-22. X-1, X-3, X-4. [pmid: 22477317].
3118 Newman B, Tuntigian L, Ryan CS, et al. Self-management of a DRO procedure by three students with autism. Behav Int. Jul. 1997;12(3):149-56. X-1, X-3, X-4.
3119 Newmeyer Amy J, Grether S, Aylward C, et al. Results of the sensory profile in children with suspected childhood apraxia of speech. Phys Occup Ther Pediatr. 2009;29(2):203-18. X-4. [pmid: 19401932].
3120 Newsome WS. Parental perceptions during periods of transition: implications for social workers serving families coping with autism. J Fam Soc Work. 2000;5(2):17-31. X-4.
3121 Neysmith-Roy JM. The Tomatis Method with severely autistic boys: individual case studies of behavioural changes. S Afr J Psychol. Mar. 2001;31(1):19-28. X-1, X-3, X-4.
3122 Nichols S, Blakeley-Smith A. “I’m not sure we’re ready for this -- “: working with families toward facilitating healthy sexuality for individuals with autism spectrum disorders. Soc Work Ment Health. Jan–Feb. 8. 2010;2010(1):72-91. X-3.
3123 Nicholson H, Kehle TJ, Bray MA, et al. The effects of antecedent physical activity on the academic engagement of children with autism spectrum disorder. Psychol Sch. Feb. 2011;48(2):198-213. X-1, X-3, X-4.
3124 Nickels K, Katusic SK, Colligan RC, et al. Stimulant medication treatment of target behaviors in children with autism: a population-based study. J Dev Behav Pediatr. Apr. 2008;29(2):75-81. X-1, X-3, X-4. [pmid: 18478626].
3125 Nicolson R, Awad G, Sloman L. An open trial of risperidone in young autistic children. J Am Acad Child Adolesc Psychiatry. Apr. 1998;37(4):372-6. X-1, X-3, X-4. [pmid: 9549957].
3126 Nicolson R, Castellanos FX. Commentary: considerations on the pharmacotherapy of attention deficits and hyperactivity in children with autism and other pervasive developmental disorders. J Autism Dev Disord. Oct. 2000;30(5):461-2. X-2, X-4. [pmid: 11098884].
3127 Nicolson R, Craven-Thuss B, Smith J. A prospective, open-label trial of galantamine in autistic disorder. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):621-9. X-1, X-3, X-4. [pmid: 17069550].
3128 Nicpon MF, Allmon A, Sieck B, et al. Empirical investigation of twice-exceptionality: where have we been and where are we going?. Gift Child Q. Jan. 2011;55(1):3-17. X-1, X-2, X-3, X-4.
3129 Niederhofer H. Arbohydrate-deficient transferrin does not seem to be associated with ADHD and autism. Psychiatria Danubina. 2009;21(4):517. X-4. [pmid: 19935486].
3130 Niederhofer H. First preliminary results of an observation of Panax ginseng treatment in patients with autistic disorder. J Diet Suppl. 2009;6(4):342-6. X-3. [pmid: 22435515].
3131 Niederhofer H. St John’s Wort treating patients with autistic disorder. Phytother Res. Nov. 2009;23(11):1521-3. X-3. [pmid: 19274686].
3132 Niederhofer H, Pittschieler K. A preliminary investigation of ADHD symptoms in persons with celiac disease. J Atten Disord. 2006;10(2):200-4. X-4. [pmid: 17085630].
3133 Niederhofer H, Staffen W, Mair A. Galantamine may be effective in treating autistic disorder. BMJ British Medical Journal. Dec. 2002;325(7377):1422-3. X-1, X-3, X-4.
3134 Niederhofer H, Staffen W, Mair A. Tianeptine: a novel strategy of psychopharmacological treatment of children with autistic disorder. Hum Psychopharmacol. Jul. 2003;18(5):389-93. X-1, X-3, X-4. [pmid: 12858327].
3135 Nielsen CMB. Towards applied integrationism--integrating autism in teaching and coaching sessions. Lang Sci. Jul. 2011;33(4):593-602. X-1, X-2, X-3, X-4.
3136 Nientimp EG, Cole CL. Teaching socially valid social interaction responses to students with severe disabilities in an integrated school setting. J Sch Psychol. Win. 1992;30(4):343-54. X-3.
3137 Nigam R, Schlosser RW, Lloyd LL. Concomitant use of the matrix strategy and the mand-model procedure in teaching graphic symbol combinations. AAC. 2006;22(3):160-77. X-3. [pmid: 17114161].
3138 Nigro-Bruzzi D, Sturmey P. The effects of behavioral skills training on mand training by staff and unprompted vocal mands by children. J Appl Behav Anal. Winter. 2010;43(4):757-61. X-1, X-3, X-4. [pmid: 21541162].
3139 Nikolopoulos TP, Archbold SM, Wever CC, et al. Speech production in deaf implanted children with additional disabilities and comparison with age-equivalent implanted children without such disorders. Int J Pediatr Otorhinolaryngol. Dec. 2008;72(12):1823-8. X-1, X-3, X-4. [pmid: 18922585].
3140 Nikopoulos CK, Canavan C, Nikopoulou-Smyrni P. Generalized effects of video modeling on establishing instructional stimulus control in children with autism: Results of a preliminary study. J Posit Behav Interv. Oct. 2009;11(4):198-207. X-3.
3141 Nikopoulos CK, Keenan M. Promoting social initiation children with autism using video modeling. Behav Int. Apr. 2003;18(2):87-108. X-1, X-3, X-4.
3142 Nikopoulos CK, Keenan M. Effects of video modeling on social initiations by children with autism. J Appl Behav Anal. Spr. 2004;37(1):93. X-3. [pmid: 15154221].
3143 Nikopoulos CK, Keenan M. Using video modeling to teach complex social sequences to children with autism. J Autism Dev Disord. Apr. 2007;37(4):678-93. X-1, X-3, X-4. [pmid: 16897375].
3144 Nilsson M. Table Hockey: attack or linking? Psychoanalytic psychotherapy with an autistic boy. J Child Psychother. Aug. 2009;35(2):131-41. X-1, X-3, X-4.
3145 Nind M, Powell S. Intensive interaction and autism: some theoretical concerns. Child Soc. Apr. 2000;14(2):98-109. X-1, X-2, X-3, X-4.
3146 Nissen B. Hypochondria: a tentative approach. Int J Psychoanal. Aug. 2000;81(Pt 4):651-66. X-4. [pmid: 11028232].
3147 Njardvik U, Matson JL, Cherry KE. A comparison of social skills in adults with autistic disorder, pervasive developmental disorder not otherwise specified, and mental retardation. J Autism Dev Disord. Aug. 1999;29(4):287-95. X-4. [pmid: 10478728].
3148 Nobile M, Perego P, Piccinini L, et al. Further evidence of complex motor dysfunction in drug naive children with autism using automatic motion analysis of gait. Autism. May. 2011;15(3):263-83. X-4. [pmid: 21478224].
3149 Noggle CA, Dean RS. Atypical and typical antipsychotics in the schools. Psychol Sch. Nov. 2009;46(9):869-84. X-1, X-2, X-3, X-4.
3150 Noland RM, Gabriels RL. Screening and identifying children with autism spectrum disorders in the public school system: the development of a model process. J Autism Dev Disord. Jun. 2004;34(3):265-77. X-3, X-4. [pmid: 15264495].
3151 Norbury CF, Bishop DVM. Narrative skills of children with communication impairments. Int J Lang Commun Disord. Jul. 2003;38(3):287-313. X-4. [pmid: 12851080].
3152 Norman J. Freedom to play, dream and think. The Scandinavian Psychoanalytic Review. 1999;22(2):172-88. X-4.
3153 Norris C, Dattilo J. Evaluating effects of a social story intervention on a young girl with autism. Focus Autism Dev Disabil. Fal. 1999;14(3):180-6. X-1, X-3, X-4.
3154 Novaes CM, Ponde MP, Freire AC. Control of psychomotor agitation and aggressive behavior in patients with autistic disorder: a retrospective chart review. Arq Neuropsiquiatr. Sep. 2008;66(3B):646-51. X-1. [pmid: 18949256].
3155 Novick B, Vaughan HG Jr, Kurtzberg D, et al. An electrophysiologic indication of auditory processing defects in autism. Psychiatry Res. Sep. 1980;3(1):107-14. X-1, X-3, X-4. [pmid: 6934552].
3156 Nuehring ML, Sitlington PL. Transition as a vehicle: moving from high school to an adult vocational service provider. J Disabil Pol Stud. Sum. 2003;14(1):23-35. X-3, X-4.
3157 Nunes D, Hanline MF. Enhancing the alternative and augmentative communication use of a child with autism through a parent-implemented naturalistic intervention. Int J Disabil Dev Educ. Jun. 2007;54(2):177-97. X-1, X-3.
3158 Nuzzolo-Gomez R, Leonard MA, Ortiz E, et al. Teaching children with autism to prefer books or toys over stereotypy or passivity. J Posit Behav Interv. Spr. 2002;4(2):80-7. X-1, X-3, X-4.
3159 Nwora AJ, Gee BM. A case study of a five-year-old child with pervasive developmental disorder-not otherwise specified using sound-based interventions. Occup Ther Int. Special Issue: Occupational therapy and complementary and alternative medicine. 2009;16(1):25-43. X-1, X-3, X-4. [pmid: 19222056].
3160 Nyden A, Myren KJ, Gillberg C. Long-term psychosocial and health economy consequences of ADHD, autism, and reading-writing disorder: a prospective service evaluation project. J Atten Disord. Sep. 2008;12(2):141-8. X-3. [pmid: 17968030].
3161 Nystul MS. Reaching in-reaching out: Counseling an autistic child. Am Ment Health Couns Assoc J. Jan. 1986;8(1):18-26. X-1, X-2, X-3, X-4.
3162 O’Connor AB, Healy O. Long-term post-intensive behavioral intervention outcomes for five children with autism spectrum disorder. Res Autism Spectr Disord. Oct–Dec. 2010;4(4):594-604. X-4.
3163 Oades RD, Stern LM, Walker MK, et al. Event-related potentials and monoamines in autistic children on a clinical trial of fenfluramine. Int J Psychophysiol. Apr. 1990;8(3):197-212. X-3, X-4. [pmid: 2187009].
3164 Oberleitner R. Talking to the autism community. [interviewed by Semahat S Demir]. IEEE Eng Med Biol Mag. Jan–Feb. 2005;24(1):14-5. 9. X-2. [pmid: 15709530].
3165 Oberleitner R, Laxminarayan S. Information technology and behavioral medicine: impact on autism treatment & research. Stud Health Technol Inform. 2004;103:215-22. X-2. [pmid: 15747924].
3166 Oberman LM, Horvath JC, Pascual-Leone A. TMS: using the theta-burst protocol to explore mechanism of plasticity in individuals with Fragile X syndrome and autism. J Vis Exp. 2010;(46). X-4. [pmid: 21248685].
3167 Oblak A, Gibbs TT, Blatt GJ. Decreased GABA_A_ receptors and benzodiazepine binding sites in the anterior cingulate cortex in autism. Autism Res. Aug. 2009;2(4):205-19. X-4. [pmid: 19650112].
3168 O’Brien J, Coker P, Lynn R, et al. The impact of occupational therapy on a child’s playfulness. Occup Ther Health Care. 2000;12(2/3):39-51. X-3.
3169 O’Brien K, Slaughter V, Peterson CC. Sibling influences on theory of mind development for children with ASD. J Child Psychol Psychiatry. Jun. 2011;52(6):713-9. X-1, X-3, X-4. [pmid: 21418062].
3170 Obrusnikova I, Dillon SR. Challenging situations when teaching children with autism spectrum disorders in general physical education. Adapt Phys Activ Q. Apr. 2011;28(2):113-31. X-1, X-3, X-4. [pmid: 21757784].
3171 Ochs E, Kremer-Sadlik T, Solomon O, et al. Inclusion as social practice: Views of children with autism. Soc Dev. 2001;10(3):399-419. X-1, X-3, X-4.
3172 O’Connor K, Hamm JP, Kirk IJ. The neurophysiological correlates of face processing in adults and children with asperger’s syndrome. Brain Cogn. Oct. 2005;59(1):82-95. X-1, X-3, X-4. [pmid: 16009478].
3173 O’Connor J, Barnes-Holmes Y, Barnes-Holmes D. Establishing contextual control over symmetry and asymmetry performances in typically developing children and children with autism. Psychol Rec. Spr. 2011;61(2):287-311. X-1, X-3, X-4.
3174 O’Dell L, Brownlow C. Media reports of links between MMR and autism: a discourse analysis. Br J Learn Disabil. 2005;33(4):194-9. X-1, X-2, X-3, X-4.
3175 Odom SL, Boyd BA, Hall LJ, et al. Evaluation of comprehensive treatment models for individuals with autism spectrum disorders. J Autism Dev Disord. Apr. 2010;40(4):425-36. X-1, X-3, X-4. [pmid: 19633939].
3176 Odom SL, Brown WH, Frey T, et al. Evidence-based practices for young children with autism: contributions for single-subject design research. Focus Autism Dev Disabil. Fall. 2003;18(3):166-75. X-2.
3177 Odom SL, Collet-Klingenberg L, Rogers SJ, et al. Evidence-based practices in interventions for children and youth with autism spectrum disorders. Prev School Failure. 2010;54(4):275-82. X-1, X-2, X-3, X-4.
3178 Odom SL, Strain PS. A comparison of peer-initiation and teacher-antecedent interventions for promoting reciprocal social interaction of autistic preschoolers. J Appl Behav Anal. Spr. 1986;19(1):59-71. X-1, X-3, X-4. [pmid: 3710949].
3179 Odom SL, Watts E. Reducing teacher prompts in peer-mediated interventions for young children with autism. J Spec Educ. Spr. 1991;25(1):26-43. X-1, X-3.
3180 Oeseburg B, Jansen DE, Dijkstra GJ, et al. Prevalence of chronic diseases in adolescents with intellectual disability. Res Dev Disabil. May–Jun. 2010;31(3):698-704. X-4. [pmid: 20188511].
3181 Ogawa T, Sugiyama A, Ishiwa S, et al. Ontogenic development of EEG-asymmetry in early infantile autism. Brain Dev. 1982;4(6):439-49. X-1, X-3, X-4. [pmid: 7168481].
3182 Ogletree BT, Crawford K. Contemplating the communicative value of objects: establishing iconic and indexical object experiences with individuals with severe intellectual disabilities. Focus Autism Dev Disabil. 2009;24(4):248-51. X-2, X-4.
3183 Ogletree BT, Fischer MA, Sprouse J. An innovative language treatment for a child with high-functioning autism. Focus Autistism Other Dev Disabil. Aug. 1995;10(3):1-10. X-1, X-3, X-4.
3184 Ogletree BT, Hamtil A, Solberg L, et al. Facilitated communication: Illustration of a naturalistic validation method. Focus Autistism Other Dev Disabil. Oct. 1993;8(4):1-10. X-1, X-3, X-4.
3185 Ogletree BT, Oren T. Application of ABA principles to general communication instruction. Focus Autism Other Dev Disabil. Sum. 2001;16(2):102-09. X-2, X-3.
3186 Ogletree BT, Oren T, Fischer MA. Examining effective intervention practices for communication impairment in autism spectrum disorder. Exceptionality. Nov. 2007;15(4):233-47. X-2.
3187 O’Hara J. Psychodynamic work and mental handicap: observations of an autistic child. Ment Handicap. Mar. 1993;21(1):32-4. X-1, X-3, X-4.
3188 O’Hare AE, Quew R, Aitken K. The identification of autism in children referred to a tertiary speech and language clinic and the implications for service delivery. Autism. Jun. 1998;2(2):171-80. X-1, X-3, X-4.
3189 O’Hearn K, Schroer E, Minshew N, et al. Lack of developmental improvement on a face memory task during adolescence in autism. Neuropsychologia. Nov. 2010;48(13):3955-60. X-4. [pmid: 20813119].
3190 Ohtake Y, Yanagihara M, Nakaya A, et al. Repair strategies used by elementary-age beginning communicators with autism: a preliminary descriptive study. Focus Autism Dev Disabil. Fall. 2005;20(3):158-68. X-4.
3191 Oi M. Interpersonal compensation for pragmatic impairments in Japanese children with asperger syndrome or high-functioning autism. J Multiling Commun Disord. 2005;3(3):203-10. X-1, X-3, X-4.
3192 Oi M, Tanaka S. When do Japanese children with autism spectrum disorder comprehend ambiguous language overliterally or overnonliterally?. Asia Pac JSpeech Lang Hear. 2011;14(1):1-12. X-1, X-3, X-4.
3193 Okada S, Ohtake Y, Yanagihara M. Improving the manners of a student with autism: the effects of manipulating perspective holders in social stories[tm]--a pilot study. Int J Disabil Dev Educ. Jun. 2010;57(2):207-19. X-1, X-3.
3194 Oke NJ, Schreibman L. Training social initiations to a high-functioning autistic child: assessment of collateral behavior change and generalization in a case study. J Autism Dev Disord. Dec. 1990;20(4):479-97. X-1, X-3, X-4. [pmid: 2279969].
3195 Olejnik L. Understanding autism. How to appropriately & safely approach, assess & manage autistic patients. JEMS. Jun. 2004;29(6):56-61. 4. X-2. [pmid: 15211315].
3196 Olesker W. Treatment of a boy with atypical ego development. Psychoanal Study Child. 1999;54:25-46. X-1, X-3, X-4. [pmid: 10748627].
3197 Olfson M, Blanco C, Liu L, et al. National trends in the outpatient treatment of children and adolescents with antipsychotic drugs. Arch Gen Psychiatry. Jun. 2006;63(6):679-85. X-2, X-4. [pmid: 16754841].
3198 Olfson M, Crystal S, Huang C, et al. Trends in antipsychotic drug use by very young, privately insured children. J Am Acad Child Adolesc Psychiatry. Jan. 2010;49(1):13-23. X-1, X-3, X-4. [pmid: 20215922].
3199 Olin AR, Reichle J, Johnson L, et al. Examining dynamic visual scene displays: implications for arranging and teaching symbol selection. Am J Speech Lang Pathol. Nov. 2010;19(4):284-97. X-1, X-3, X-4. [pmid: 20581110].
3200 Olive M. Assessment and intervention for young children with nonphysiological feeding concerns. Young Except Child. 2004;7(4):10-9. X-2.
3201 Olive ML, de la Cruz B, Davis TN, et al. The effects of enhanced milieu teaching and a voice output communication aid on the requesting of three children with autism. J Autism Dev Disord. Sep. 2007;37(8):1505-13. X-1, X-3, X-4. [pmid: 17066309].
3202 Olive ML, Lang RB, Davis TN. An analysis of the effects of functional communication and a Voice Output Communication Aid for a child with autism spectrum disorder. Res Autism Spectr Disord. Apr–Jun. 2008;2(2):223-36. X-1, X-3, X-4.
3203 Oliver L, Johnson A. Autism Disorders. NCSL legisbrief. Nov–Dec. 2004;12(46):1-2. X-2. [pmid: 15523767].
3204 Ollendick TH, Shapiro ES, Barrett RP. Effects of vicarious reinforcement in normal and severely disturbed children. J Consult Clin Psychol. Feb. 1982;50(1):63-70. X-1, X-3, X-4. [pmid: 7056921].
3205 Olley JG, Devellis RF, Devellis BM, et al. The autism attitude scale for teachers. Except Child. Feb. 1981;47(5):371-2. X-1, X-2, X-3, X-4. [pmid: 7202461].
3206 Olson LJ, Moulton HJ. Use of weighted vests in pediatric occupational therapy practice. Phys Occup Ther Pediatr. 2004;24(3):45-60. X-4. [pmid: 15257968].
3207 Olsson MB, Hwang CP. Depression in mothers and fathers of children with intellectual disability. J Intellect Disabil Res. 2001;45(part 6):535-43. X-4. [pmid: 11737541].
3208 Olsson MB, Hwang CP. Socioeconomic and psychological variables as risk and protective factors for parental well-being in families of children with intellectual disabilities. J Intellect Disabil Res. Dec. 2008;52(12):1102-13. X-4. [pmid: 18507702].
3209 Oneal BJ, Reeb RN, Korte JR, et al. Assessment of home-based behavior modification programs for autistic children: reliability and validity of the behavioral summarized evaluation. J Prev Interv Community. 2006;32(1–2):25-39. X-2. [pmid: 17000600].
3210 O’Neill RE, Sweetland-Baker M. Brief report: An assessment of stimulus generalization and contingency effects in functional communication training with two students with autism. J Autism Dev Disord. Apr. 2001;31(2):235-40. X-3. [pmid: 11450822].
3211 Ooi YP, Lam CM, Sung M, et al. Effects of cognitive-behavioural therapy on anxiety for children with high-functioning autistic spectrum disorders. Singapore Med J. Mar. 2008;49(3):215-20. X-1, X-3, X-4. [pmid: 18363003].
3212 Oosterling I, Visser J, Swinkels S, et al. Randomized controlled trial of the focus parent training for toddlers with autism: 1-year outcome. J Autism Dev Disord. Dec. 2010;40(12):1447-58. X-1, X-3, X-4. [pmid: 20440639].
3213 Opler LA, White L, Caton CL, et al. Gender differences in the relationship of homelessness to symptom severity, substance abuse, and neuroleptic noncompliance in schizophrenia. J Nerv Ment Dis. Jul. 2001;189(7):449-56. X-4. [pmid: 11504322].
3214 Oram Cardy JE, Ferrari P, Flagg EJ, et al. Prominence of M50 auditory evoked response over M100 in childhood and autism. Neuroreport. Aug. 26. 2004;15(12):1867-70. X-4. [pmid: 15305126].
3215 Oram Cardy JE, Flagg EJ, Roberts W, et al. Magnetoencephalography identifies rapid temporal processing deficit in autism and language impairment. Neuroreport. Mar. 15. 2005;16(4):329-32. X-4. [pmid: 15729132].
3216 Oram Cardy JE, Flagg EJ, Roberts W, et al. Auditory evoked fields predict language ability and impairment in children. Int J Psychophysiol. May. 2008;68(2):170-5. X-4. [pmid: 18304666].
3217 O’Reilly MF, Edrisinha C, Sigafoos J, et al. Isolating the evocative and abative effects of an establishing operation on challenging behavior. Behav Int. Jul. 2006;21(3):195-204. X-3.
3218 Orekhova EV, Stroganova TA, Prokofyev AO, et al. Sensory gating in young children with autism: relation to age, IQ, and EEG gamma oscillations. Neurosci Lett. Mar. 28. 2008;434(2):218-23. X-4. [pmid: 18313850].
3219 Oriel KN, George CL, Peckus R, et al. The effects of aerobic exercise on academic engagement in young children with autism spectrum disorder. Pediatr Phys Ther. Summer. 2011;23(2):187-93. X-1, X-3, X-4. [pmid: 21552085].
3220 O’Riordan M, Passetti F. Discrimination in autism within different sensory modalities. J Autism Dev Disord. Jul. 2006;36(5):665-75. X-4. [pmid: 16639532].
3221 Orme DM. A qualitative examination of mothers’ resolution or non-resolution of their children’s disability of down syndrome or autism using a cognitive intervention. Qual Rep. Sep. 2005;10(3):561-92. X-1, X-3, X-4.
3222 Ornitz EM, Lane SJ, Sugiyama T, et al. Startle modulation studies in autism. J Autism Dev Disord. Dec. 1993;23(4):619-37. X-4. [pmid: 8106303].
3223 Ortega Santamaria MA. Focus on research... occupational therapy intervention with autistic children: study of current practice in Colombia. Br J Occup Ther. 2001;64(5):222. X-1, X-2, X-3, X-4.
3224 Orvalho V, Miranda J, Sousa AA. Facial synthesys of 3D avatars for therapeutic applications. Annu Rev CyberTher Telemed. 2009;7:96-8. X-1, X-2, X-3, X-4.
3225 Osborne J. Art and the child with autism: therapy or education?. Early Child Dev Care. Aug. 2003;173(4):411-23. X-1, X-2, X-3, X-4.
3226 Osborne LA, McHugh L, Saunders J, et al. Parenting stress reduces the effectiveness of early teaching interventions for autistic spectrum disorders. J Autism Dev Disord. Jul. 2008;38(6):1092-103. X-1, X-3, X-4. [pmid: 18027079].
3227 Osborne LA, Reed P. School factors associated with mainstream progress in secondary education for included pupils with autism spectrum disorders. Res Autism Spectr Disord. Jul–Sep. 2011;5(3):1253-63. X-6.
3228 O’Shea TM, Allred EN, Dammann O, et al. The ELGAN study of the brain and related disorders in extremely low gestational age newborns. Early Hum Dev. Nov. 2009;85(11):719-25. X-4. [pmid: 19765918].
3229 Osler A, Osler C. Inclusion, exclusion and children’s rights: a case study of a student with asperger syndrome. Emot Behav Difficulties. Feb. 2002;7(1):35-54. X-3, X-4.
3230 Ospina MB, Krebs Seida J, Clark B, et al. Behavioural and developmental interventions for autism spectrum disorder: a clinical systematic review. PLoS One. 2008;3(11):e3755. X-1, X-2, X-3, X-4. [pmid: 19015734].
3231 Ostryn C, Wolfe PS. Teaching children with autism to ask “what’s that?” using picture communication with vocal results. Infants Young Child. Apr–Jun. 2011;24(2):174-92. X-1, X-3, X-4.
3232 Ostryn C, Wolfe PS, Rusch FR. A review and analysis of the picture exchange communication system (pecs) for individuals with autism spectrum disorders using a paradigm of communication competence. Res Pract Persons Severe Disabl. 2008;33(1–2):13-24. X-2.
3233 Oswald DP, Ollendick TH. Role taking and social competence in autism and mental retardation. J Autism Dev Disord. Mar. 1989;19(1):119-27. X-3, X-4. [pmid: 2708295].
3234 Oswald DP, Sonenklar NA. Medication use among children with autism spectrum disorders. J Child Adolesc Psychopharmacol. Jun. 2007;17(3):348-55. X-4. [pmid: 17630868].
3235 Ottenbacher KJ. Vestibular processing dysfunction in children with severe emotional and behavioral disorders: a review. Phys Occup Ther Pediatr. 1982;2:3-12. X-1, X-2, X-3, X-4.
3236 Ouellette-Kuntz H, Coo H, Lloyd JEV, et al. Trends in special education code assignment for autism: implications for prevalence estimates. J Autism Dev Disord. Nov. 2007;37(10):1941-8. X-4. [pmid: 17216561].
3237 Owen R, Sikich L, Marcus RN, et al. Aripiprazole in the treatment of irritability in children and adolescents with autistic disorder. Pediatrics. Dec. 2009;124(6):1533-40. X-1, X-3. [pmid: 19948625].
3238 Owen-DeSchryver JS, Carr EG, Cale SI, et al. Promoting social interactions between students with autism spectrum disorders and their peers in inclusive school settings. Focus Autism Dev Disabil. 2008;23(1):15-28. X-1, X-3.
3239 Owens G, Granader Y, Humphrey A, et al. Lego therapy and the social use of language programme: an evaluation of two social skills interventions for children with high functioning autism and asperger syndrome. J Autism Dev Disord. Nov. 2008;38(10):1944-57. X-1, X-3, X-4. [pmid: 18566882].
3240 Owens JA, Rosen CL, Mindell JA. Medication use in the treatment of pediatric insomnia: results of a survey of community-based pediatricians. Pediatr. May. 2003;111(5 Pt 1):e628-35. X-4. [pmid: 12728122].
3241 Owens SR. Injection of confidence. The recent controversy in the UK has led to falling MMR vaccination rates. EMBO Rep. May. 2002;3(5):406-9. X-2. [pmid: 11991943].
3242 Owley T, Brune CW, Salt J, et al. A pharmacogenetic study of escitalopram in autism spectrum disorders. Autism Res. Feb. 2010;3(1):1-7. X-1, X-3, X-4. [pmid: 20020537].
3243 Owley T, McMahon W, Cook EH, et al. Multisite, double-blind, placebo-controlled trial of porcine secretin in autism. J Am Acad Child Adolesc Psychiatry. Nov. 2001;40(11):1293-9. X-1, X-3, X-4. [pmid: 11699803].
3244 Owley T, Salt J, Guter S, et al. A prospective, open-label trial of memantine in the treatment of cognitive, behavioral, and memory dysfunction in pervasive developmental disorders. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):517-24. X-1, X-3, X-4. [pmid: 17069541].
3245 Owley T, Walton L, Salt J, et al. An open-label trial of escitalopram in pervasive developmental disorders. J Am Acad Child Adolesc Psychiatry. Apr. 2005;44(4):343-8. X-1, X-3, X-4. [pmid: 15782081].
3246 Ozbayrak KR. Sertraline in PDD. J Am Acad Child Adolesc Psychiatry. Jan. 1997;36(1):7-8. X-1, X-3, X-4. [pmid: 9000775].
3247 Ozdemir S. The effectiveness of social stories on decreasing disruptive behaviors of children with autism: three case studies. J Autism Dev Disord. Oct. 2008;38(9):1689-96. X-1, X-3, X-4. [pmid: 18373187].
3248 Ozonoff S, Cathcart K. Effectiveness of a home program intervention for young children with autism. J Autism Dev Disord. Feb. 1998;28(1):25-32. X-1, X-3, X-4. [pmid: 9546299].
3249 Ozonoff S, Miller JN. Teaching theory of mind: a new approach to social skills training for individuals with autism. J Autism Dev Disord. Aug. 1995;25(4):415-33. X-3. [pmid: 7592252].
3250 Paavonen EJ, Nieminen-von Wendt T, Vanhala R, et al. Effectiveness of melatonin in the treatment of sleep disturbances in children with asperger disorder. J Child Adolesc Psychopharmacol. Spring. 2003;13(1):83-95. X-1, X-3, X-4. [pmid: 12804129].
3251 Padhye U. Excess dietary iron is the root cause for increase in childhood autism and allergies. Med Hypotheses. Aug. 2003;61(2):220-2. X-2, X-4. [pmid: 12888307].
3252 Page J, Boucher J. Motor impairments in children with autistic disorder. Child Lang Teach Ther. 1998;14(3):233-59. X-4.
3253 Page T. Metabolic approaches to the treatment of autism spectrum disorders. J Autism Dev Disord. Oct. 2000;30(5):463-9. X-2. [pmid: 11098885].
3254 Page T, Moseley C. Metabolic treatment of hyperuricosuric autism. Prog in Neuropsychopharmacol Biol Psychiatry. Feb. 2002;26(2):397-400. X-1, X-2, X-3, X-4. [pmid: 11817520].
3255 Pajareya K, Nopmaneejumruslers K. A pilot randomized controlled trial of dir/floortime[tm] parent training intervention for pre-school children with autistic spectrum disorders. Autism. Sep. 2011;15(5):563-77. X-1, X-3, X-4. [pmid: 21690083].
3256 Pakenham KI, Sofronoff K, Samios C. Finding meaning in parenting a child with asperger syndrome: correlates of sense making and benefit finding. Res Dev Disabil. May–Jun. 2004;25(3):245-64. X-1, X-3, X-4. [pmid: 15134791].
3257 Palermo MT. Preventing filicide in families with autistic children. Int J Offender Ther Comp Criminol. Feb. 2003;47(1):47-57. X-2, X-4. [pmid: 12613431].
3258 Palkovitz RJ, Wiesenfeld AR. Differential autonomic responses of autistic and normal children. J Autism Dev Disord. Sep. 1980;10(3):347-60. X-3. [pmid: 6927661].
3259 Pallanti S, Lassi S, La Malfa G, et al. Short report: autistic gastrointestinal and eating symptoms treated with secretin: a subtype of autism. Clin Pract Epidemiol Ment Health. 2005;1(24). X-1, X-2, X-3, X-4.
3260 Palmen A, Didden R, Arts M. Improving question asking in high-functioning adolescents with autism spectrum disorders: effectiveness of small-group training. Autism. Jan. 2008;12(1):83-98. X-1, X-3, X-4. [pmid: 18178598].
3261 Palmen A, Didden R, Korzilius H. Effectiveness of behavioral skills training on staff performance in a job training setting for high-functioning adolescents with autism spectrum disorders. Res Autism Spectr Disord. Oct–Dec. 2010;4(4):731-40. X-1, X-3, X-4.
3262 Palmen A, Didden R, Korzilius H. An outpatient group training programme for improving leisure lifestyle in high-functioning young adults with ASD: A pilot study. Dev Neurorehabil. Oct. 2011;14(5):297-309. X-3. [pmid: 21870954].
3263 Palmer RF, Walker T, Mandell D, et al. Explaining low rates of autism among Hispanic schoolchildren in Texas. Am J Public Health. Feb. 2010;100(2):270-2. X-2, X-4. [pmid: 20019320].
3264 Pan C, Tsai C, Chu C. Fundamental movement skills in children diagnosed with autism spectrum disorders and attention deficit hyperactivity disorder. J Autism Dev Disord. 2009;39(12):1694-705. X-1, X-3, X-4. [pmid: 19588236].
3265 Pan CY. School time physical activity of students with and without autism spectrum disorders during pe and recess. Adapt Phys Activ Q. Oct. 2008;25(4):308-21. X-1, X-3. [pmid: 18955747].
3266 Pan CY. Effects of water exercise swimming program on aquatic skills and social behaviors in children with autism spectrum disorders. Autism. Jan. 2010;14(1):9-28. X-1, X-3, X-4. [pmid: 20124502].
3267 Pan C-Y, Frey GC. Physical activity patterns in youth with autism spectrum disorders. J Autism Dev Disord. Jul. 2006;36(5):597-606. X-4. [pmid: 16652237].
3268 Pan C-Y, Tsai C-L, Chu C-H, et al. Physical activity and self-determined motivation of adolescents with and without autism spectrum disorders in inclusive physical education. Res Autism Spectr Disord. Apr–Jun. 2011;5(2):733-41. X-4.
3269 Pandina GJ, Bossie CA, Youssef E, et al. Risperidone improves behavioral symptoms in children with autism in a randomized, double-blind, placebo-controlled trial. J Autism Dev Disord. Feb. 2007;37(2):367-73. X-1, X-3, X-4. [pmid: 17019624].
3270 Panerai S, Ferrante L, Zingale M. Benefits of the treatment and education of autistic and communication handicapped children (teacch) programme as compared with a non-specific approach. J Intellect Disabil Res. May. 2002;46(Pt 4):318-27. X-3. [pmid: 12000583].
3271 Panerai S, Zingale M, Trubia G, et al. Special education versus inclusive education: the role of the TEACCH program. J Autism Dev Disord. Jun. 2009;39(6):874-82. X-1, X-3, X-4. [pmid: 19205860].
3272 Pang KH, Croaker GD. Constipation in children with autism and autistic spectrum disorder. Pediatr Surg Int. Apr. 2011;27(4):353-8. X-3, X-4. [pmid: 20697898].
3273 Panksepp J, Lensing P. Brief report: a synopsis of an open-trial of naltrexone treatment of autism with four children. J Autism Dev Disord. Jun. 1991;21(2):243-9. X-1, X-3, X-4. [pmid: 1864831].
3274 Pansegrouw I, Alant E. Communication intervention in an adolescent with profound cognitive impairment and autistic features. S Afr J Commun Disord. 1996;43:63-75. X-3, X-4. [pmid: 9265844].
3275 Panyan MV. Computer technology for autistic students. J Autism Dev Disord. Dec. 1984;14(4):375-82. X-1, X-2, X-3, X-4. [pmid: 6549182].
3276 Papavasiliou AS, Nikaina I, Rizou J, et al. The effect of a psycho-educational program on CARS scores and short sensory profile in autistic children. Eur J Paediatr Neurol. Jul. 2011;15(4):338-44. X-1, X-3, X-4. [pmid: 21354837].
3277 Pardew EM, Bunse C. Enhancing interaction through positive touch. Young Except Child. 2005;8(2):21-9. X-1, X-2, X-3, X-4.
3278 Pareek M, Pattison HM. The two-dose measles, mumps, and rubella (MMR) immunisation schedule: factors affecting maternal intention to vaccinate. Br J Gen Pract. Dec. 2000;50(461):969-71. X-4. [pmid: 11224968].
3279 Parellada M, Boada L, Moreno C, et al. Specialty care programme for autism spectrum disorders in an urban population: a case-management model for health care delivery in an ASD population. Eur Psychiatry. 2011. Sep. 8. X-1, X-2, X-4. [pmid: 21907549].
3280 Pares N, Carreras A, Durany J, et al. Starting research in interaction design with visuals for low-functioning children in the autistic spectrum: a protocol. Cyberpsychol Behav. Apr. 2006;9(2):218-23. X-2. [pmid: 16640483].
3281 Pares N, Masri P, van Wolferen G, et al. Achieving dialogue with children with severe autism in an adaptive multisensory interaction: the “MEDIAte” project. IEEE Trans Vis Comput Graph. Nov–Dec. 2005;11(6):734-43. X-2. [pmid: 16270865].
3282 Paribello C, Tao L, Folino A, et al. Open-label add-on treatment trial of minocycline in fragile X syndrome. BMC Neurol. 2010;10:91. X-1, X-3, X-4. [pmid: 20937127].
3283 Park M, Chitiyo M. An examination of teacher attitudes towards children with autism. J Res Spec Educ Needs. Mar. 2011;11(1):70-8. X-1, X-3, X-4.
3284 Park YD. The effects of vagus nerve stimulation therapy on patients with intractable seizures and either Landau-Kleffner syndrome or autism. Epilepsy Behav. Jun. 2003;4(3):286-90. X-1. [pmid: 12791330].
3285 Parker D, Kamps D. Effects of task analysis and self-monitoring for children with autism in multiple social settings. Focus Autism Dev Disabil. Sep. 2011;26(3):131-42. X-1, X-3, X-4.
3286 Parkinson GM. Pragmatic difficulties in children with autism associated with childhood epilepsy. Pediatr Rehabil. Jul–Sep. 2006;9(3):229-46. X-4. [pmid: 17050401].
3287 Parmanto B, Saptono A, Pramana G, et al. VISYTER: versatile and integrated system for telerehabilitation. Telemed J E Health. Nov. 2010;16(9):939-44. X-1, X-3, X-4. [pmid: 21034239].
3288 Parr J. Autism. Clin Evid (Online). 2008. 2008. X-1, X-2, X-3, X-4. [pmid: 19450315].
3289 Parris A. Implementing interventions for an individual with complex needs through a co-ordinated approach. Adv Ment Health Intellect Disabil. Jun. 2010;4(2):33-7. X-3.
3290 Parry-Cruwys DE, Neal CM, Ahearn WH, et al. Resistance to disruption in a classroom setting. J Appl Behav Anal. Sum. 2011;44(2):363-7. X-3. [pmid: 21709794].
3291 Parsons S, Lewis A, Ellins J. The views and experiences of parents of children with autistic spectrum disorder about educational provision: Comparisons with parents of children with other disabilities from an online survey. Eur J Spec Needs Educ. Feb. 2009;24(1):37-58. X-4.
3292 Parsons S, Mitchell P, Leonard A. The use and understanding of virtual environments by adolescents with autistic spectrum disorders. J Autism Dev Disord. Aug. 2004;34(4):449-66. X-3. [pmid: 15449520].
3293 Parteli L. Aesthetic listening: contributions of dance/movement therapy to the psychic understanding of motor stereotypes and distortions in autism and psychosis in childhood and adolescence. Arts Psychother. Special Issue: European Consortium for Arts Therapy Education (ECArTE). 1995;22(3):241-7. -2.
3294 Pary RJ. Acute psychiatric hospital admissions of adults and elderly adults with mental retardation. Am J Ment Retard. Nov. 1993;98(3):434-6. X-4. [pmid: 8292320].
3295 Pasco G, Gordon RK, Howlin P, et al. The Classroom Observation Schedule to Measure Intentional Communication (COSMIC): an observational measure of the intentional communication of children with autism in an unstructured classroom setting. J Autism Dev Disord. Nov. 2008;38(10):1807-18. X-4. [pmid: 18401692].
3296 Pasco G, Tohill C. Predicting progress in Picture Exchange Communication System (PECS) use by children with autism. Int J Lang Commun Disord. Jan–Feb. 2011;46(1):120-5. [pmid: 20536353]. X-1, X-3, X-4.
3297 Patel K, Curtis LT. A comprehensive approach to treating autism and attention-deficit hyperactivity disorder: a prepilot study. J Altern Complement Med. Dec. 2007;13(10):1091-7. X-1, X-3, X-4. [pmid: 18166120].
3298 Patel MR, Carr JE, Dozier CL. On the role of stimulus preference assessment in the evaluation of contingent access to stimuli associated with stereotypy during behavioral acquisition. Behav Int. Nov. 1998;13(4):269-74. X-1, X-3, X-4.
3299 Patel MR, Piazza CC, Kelly ML, et al. Using a fading procedure to increase fluid consumption in a child with feeding problems. J Appl Behav Anal. Fal. 2001;34(3):357-60. X-1, X-3, X-4. [pmid: 11678534].
3300 Paterson CR, Arco L. Using video modeling for generalizing toy play in children with autism. Behav Modif. Sep. 2007;31(5):660-81. X-1, X-3, X-4. [pmid: 17699123].
3301 Paterson H, Peck K. Sensory processing ability and eating behaviour in children with autism. J of Hum Nutr Diet. 2011;24(3):301. X-1, X-3, X-4.
3302 Patil AA, Andrews R. Surgical treatment of autistic epileptiform regression. J Epilepsy. Nov–Dec. 1998;11(6):368-73. X-1, X-3, X-4.
3303 Patrick LS R. The effect of essential fatty acid supplementation on language development and learning skills in autism and asperger’s syndrome. Autism Asperger Digest. Jan–Feb. 2005:36-7. X-1, X-3, X-4.
3304 Patten E, Watson LR. Interventions targeting attention in young children with autism. Am J Speech Lang Pathol. Feb. 2011;20(1):60-9. X-1, X-2, X-3, X-4. [pmid: 20739632].
3305 Patterson A, Rafferty A. Making it to work: towards employment for the young adult with autism. Int J Lang Commun Disord. Suppl. 2001;36:475-80. X-1, X-2, X-3, X-4. [pmid: 11340835].
3306 Patterson SY, Smith V, Jelen M. Behavioural intervention practices for stereotypic and repetitive behaviour in individuals with autism spectrum disorder: a systematic review. Dev Med Child Neurol. Apr. 2010;52(4):318-27. X-2, X-4. [pmid: 20412248].
3307 Paul AS, Frea WD. The importance of understanding the goals of the family. J Posit Behav Interv. Win. 2002;4(1):61-3. X-1, X-3, X-4.
3308 Paul C, Williams KE, Riegel K, et al. Combining repeated taste exposure and escape prevention: An intervention for the treatment of extreme food selectivity. Appetite. Nov. 2007;49(3):708-11. X-3, X-4. [pmid: 17920728].
3309 Paul R. Parents ask: Am I risking autism if I vaccinate my children?. J Autism Dev Disord. Jun. 2009;39(6):962-3. X-4. [pmid: 19363650].
3310 Paul R, Chawarska K, Cicchetti D, et al. Language outcomes of toddlers with autism spectrum disorders: a two year follow-up. Autism Res. Apr. 2008;1(2):97-107. X-1, X-3, X-4. [pmid: 19360656].
3311 Paul R, Cohen DJ. Communication development and its disorders: a psycholinguistic perspective. Schizophr Bull. 1982;8(2):279-93. X-1, X-2, X-3, X-4. [pmid: 7112042].
3312 Paul R, Cohen DJ. Outcomes of severe disorders of language acquisition. J Autism Dev Disord. Dec. 1984;14(4):405-21. X-1, X-3, X-4. [pmid: 6084003].
3313 Paul R, Miles S, Cicchetti D, et al. Adaptive behavior in autism and Pervasive Developmental Disorder-Not Otherwise Specified: microanalysis of scores on the Vineland Adaptive Behavior Scales. J Autism Dev Disord. Apr. 2004;34(2):223-8. X-4. [pmid: 15162940].
3314 Paul R, Shriberg LD, McSweeny J, et al. Brief Report: relations between Prosodic Performance and Communication and Socialization Ratings in high functioning speakers with autism spectrum disorders. J Autism Dev Disord. Dec. 2005;35(6):861-9. X-4. [pmid: 16283080].
3315 Paylor R, Yuva-Paylor LA, Nelson DL, et al. Reversal of sensorimotor gating abnormalities in Fmr1 knockout mice carrying a human Fmr1 transgene. Behav Neurosci. Dec. 2008;122(6):1371-7. X-4. [pmid: 19045956].
3316 Peck CA. Increasing opportunities for social control by children with autism and severe handicaps: effects on student behavior and perceived classroom climate. J Assoc Pers Sev Handicaps. Win. 1985;10(4):183-93. X-3.
3317 Pedrosa E, Shah A, Tenore C, et al. beta-catenin promoter ChIP-chip reveals potential schizophrenia and bipolar disorder gene network. J Neurogenet. Dec. 2010;24(4):182-93. X-1, X-3, X-4. [pmid: 20615089].
3318 Peele PB, Lave JR, Kelleher KJ. Exclusions and limitations in children’s behavioral health care coverage. Psychiatr Serv. May. 2002;53(5):591-4. X-4. [pmid: 11986509].
3319 Pelios LV, MacDuff GS, Axelrod S. The effects of a treatment package in establishing independent academic work skills in children with autism. Educ Treat Children. Feb. 2003;26(1):1-21. X-1, X-3, X-4.
3320 Pelletier K, McNamara B, Braga-Kenyon P, et al. Effect of video self-monitoring on procedural integrity. Behav Int. Nov. 2010;25(4):261-74. X-1, X-3, X-4.
3321 Peng CZ, Hatlestad P, Klug MG, et al. Health care costs and utilization rates for children with pervasive developmental disorders in North Dakota from 1998 to 2004: impact on Medicaid. J Child Neurol. Feb. 2009;24(2):140-7. X-4. [pmid: 19182149].
3322 Pengelly S, Rogers P, Evans K. Space at home for families with a child with autistic spectrum disorder. Br J Occup Ther. 2009;72(9):378-83. X-3.
3323 Penn CL. Vaccine safety & immunization information. J Ark Med Soc. Jun. 2006;102(12):322-4. X-4. [pmid: 16776306].
3324 Pennington L, James P, McNally R, et al. Analysis of compositional data in communication disorders research. J Commun Disord. Jan–Feb. 2009;42(1):18-28. X-2, X-4. [pmid: 18723184].
3325 Penrod B, Wallace MD, Dyer EJ. Assessing potency of high- and low-preference reinforcers with respect to response rate and response patterns. J Appl Behav Anal. Summer. 2008;41(2):177-88. X-3, X-4. [pmid: 18595282].
3326 Penzner JB, Dudas M, Saito E, et al. Lack of effect of stimulant combination with second-generation antipsychotics on weight gain, metabolic changes, prolactin levels, and sedation in youth with clinically relevant aggression or oppositionality. J Child Adolesc Psychopharmacol. Oct. 2009;19(5):563-73. X-1. [pmid: 19877981].
3327 Pepperberg IM, Sherman D. Proposed use of two-part interactive modeling as a means to increase functional skills in children with a variety of disabilities. Teach Learn Med. Fall. 2000;12(4):213-20. X-1, X-3, X-4. [pmid: 11273372].
3328 Perel I. Deinstitutionalization at a large facility: a focus on treatment. Res Dev Disabil. 1992;13(1):81-6. X-2, X-4. [pmid: 1585024].
3329 Perez-Gonzalez LA, Williams G. Multicomponent procedure to teach conditional discriminations to children with autism. Am J Ment Retard. Jul. 2002;107(4):293-301. X-1, X-3, X-4. [pmid: 12069648].
3330 Pérez-González LA, Williams G. Comprehensive program for teaching skills to children with autism. Psychology in Spain. 2006;10:37-51. X-3.
3331 Perry A, Bryson S, Bebko J. Brief report: Degree of facilitator influence in facilitated communication as a function of facilitator characteristics, attitudes, and beliefs. J Autism Dev Disord. Feb. 1998;28(1):87-90. X-1, X-3, X-4. [pmid: 9546307].
3332 Perry A, Cummings A, Geier JD, et al. Effectiveness of intensive behavioral intervention in a large, community-based program. Res Autism Spectr Disord. Oct. 2008;2(4):621-42. X-1, X-3, X-4.
3333 Perry A, Factor DC. Psychometric validity and clinical usefulness of the Vineland Adaptive Behavior Scales and the AAMD Adaptive Behavior Scale for an autistic sample. J Autism Dev Disord. Mar. 1989;19(1):41-55. X-3, X-4. [pmid: 2708303].
3334 Perry A, Flanagan HE, Dunn Geier J, et al. Brief report: the Vineland Adaptive Behavior Scales in young children with autism spectrum disorders at different cognitive levels. J Autism Dev Disord. Jul. 2009;39(7):1066-78. X-4. [pmid: 19234777].
3335 Perry DW, Marston GM, Hinder SA, et al. The phenomenology of depressive illness in people with a learning disability and autism. Autism. Sep. 2001;5(3):265-75. X-2, X-4. [pmid: 11708586].
3336 Perry R, Campbell M, Adams P, et al. Long-term efficacy of haloperidol in autistic children: continuous versus discontinuous drug administration. J Am Acad Child Adolesc Psychiatry. Jan. 1989;28(1):87-92. X-1, X-3, X-4. [pmid: 2914841].
3337 Perry R, Campbell M, Green WH, et al. Neuroleptic-related dyskinesias in autistic children: a prospective study. Psychopharmacol Bull. 1985;21(1):140-3. X-1, X-3, X-4. [pmid: 3885290].
3338 Perry R, Cohen I, DeCarlo R. Case study: Deterioration, autism, and recovery in two siblings. J Am Acad Child Adolesc Psychiatry. Feb. 1995;34(2):232-7. X-1, X-3, X-4. [pmid: 7896656].
3339 Perry R, Nobler MS, Campbell M. Tourette-like symptoms associated with neuroleptic therapy in an autistic child. J Am Acad Child Adolesc Psychiatry. Jan. 1989;28(1):93-6. X-1, X-3, X-4. [pmid: 2914842].
3340 Perry R, Pataki C, Munoz-Silva DM, et al. Risperidone in children and adolescents with pervasive developmental disorder: pilot trial and follow-up. J Child Adolesc Psychopharmacol. 1997;7(3):167-79. X-1, X-3, X-4. [pmid: 9466234].
3341 Perry W, Minassian A, Lopez B, et al. Sensorimotor gating deficits in adults with autism. Biol Psychiatry. Feb. 15. 2007;61(4):482-6. X-4. [pmid: 16460695].
3342 Persson B. Brief report: A longitudinal study of quality of life and independence among adult men with autism. J Autism Dev Disord. Feb. 2000;30(1):61-6. X-3. [pmid: 10819121].
3343 Persson B, Nordstrom B, Petersson K, et al. Screening for infants with developmental deficits and/or autism: a Swedish pilot study. J Pediatr Nurs. Aug. 2006;21(4):313-24. X-4. [pmid: 16843217].
3344 Peterson CC. Theory-of-mind development in oral deaf children with cochlear implants or conventional hearing aids. J Child Psychol Psychiatry. Sep. 2004;45(6):1096-106. X-4. [pmid: 15257666].
3345 Peterson CC. Mind and body: concepts of human cognition, physiology and false belief in children with autism or typical development. J Autism Dev Disord. Aug. 2005;35(4):487-97. X-4. [pmid: 16134034].
3346 Peterson CC, Garnett M, Kelly A, et al. Everyday social and conversation applications of theory-of-mind understanding by children with autism-spectrum disorders or typical development. Eur Child Adolesc Psychiatry. Feb. 2009;18(2):105-15. X-1, X-3, X-4. [pmid: 18810310].
3347 Peterson CC, Siegal M. Deafness, conversation and theory of mind. J Child Psychol Psychiatry. Mar. 1995;36(3):459-74. X-4. [pmid: 7782409].
3348 Peterson CC, Siegal M. Domain specificity and everyday biological, physical, and psychological thinking in normal, autistic, and deaf children. New Dir Child Dev. Spring. 1997;(75):55-70. X-1, X-2, X-3, X-4. [pmid: 9306746].
3349 Peterson CC, Slaughter VP, Paynter J. Social maturity and theory of mind in typically developing children and those on the autism spectrum. J Child Psychol Psychiatry. Dec. 2007;48(12):1243-50. X-4. [pmid: 18093030].
3350 Peterson L, McLaughlin TF, Weber KP, et al. The effects of model, lead, and test technique with visual prompts paired with a fading procedure to teach “where” to a 13-year-old echolalic boy with autism. J Dev Phys Disabil. Feb. 2008;20(1):31-9. X-1, X-3, X-4.
3351 Peterson SMP, Caniglia C, Royster AJ. Application of choice-making intervention for a student with multiply maintained problem behavior. Focus Autism Dev Disabil. Win. 2001;16(4):240-6. X-1, X-2, X-3, X-4.
3352 Peters-Scheffer N, Didden R, Green VA, et al. The behavior flexibility rating scale-revised (BFRS-R): factor analysis, internal consistency, inter-rater and intra-rater reliability, and convergent validity. Res Dev Disabil. Sep–Oct. 2008;29(5):398-407. X-4. [pmid: 17826945].
3353 Peters-Scheffer N, Didden R, Mulders M, et al. Low intensity behavioral treatment supplementing preschool services for young children with autism spectrum disorders and severe to mild intellectual disability. Res Dev Disabil. Nov–Dec. 2010;31(6):1678-84. X-1, X-3, X-4. [pmid: 20627451].
3354 Petrovic M, Roberts R, Ramsay M. Second dose of measles, mumps, and rubella vaccine: questionnaire survey of health professionals. BMJ. Jan. 13. 2001;322(7278):82-5. X-4. [pmid: 11154622].
3355 Pfeiffer B, Kinnealey M, Reed C, et al. Sensory modulation and affective disorders in children and adolescents with Asperger’s disorder. Am J Occup Ther. May–Jun. 2005;59(3):335-45. X-1, X-3, X-4. [pmid: 15969281].
3356 Pfeiffer BA, Koenig K, Kinnealey M, et al. Effectiveness of sensory integration interventions in children with autism spectrum disorders: a pilot study. Am J Occup Ther. Jan–Feb. 2011;65(1):76-85. X-1, X-3, X-4. [pmid: 21309374].
3357 Pfeiffer SI, Nelson DD. The cutting edge in services for people with autism. J Autism Dev Disord. Mar. 1992;22(1):95-105. X-4. [pmid: 1592767].
3358 Phadraig BM. Towards inclusion: the development of provision for children with special educational needs in ireland from 1991 to 2004. Ir Educ Stud. Sep. 2007;26(3):289-300. X-2, X-4.
3359 Phancharoen S. Rett syndrome in Thai female girls: clinical studies. J Med Assoc Thai. Jun. Suppl 1. 2001;84:S57-60. X-4. [pmid: 11529381].
3360 Phelan MC. Deletion 22q13.3 syndrome. Orphanet J Rare Dis. 2008;3:14. X-1, X-2, X-3, X-4. [pmid: 18505557].
3361 Phelan S, Steinke L, Mandich A. Exploring a cognitive intervention for children with pervasive developmental disorder. Can J Occup Ther. Feb. 2009;76(1):23-8. X-1, X-3, X-4. [pmid: 19341019].
3362 Phetrasuwan S, Miles MS, Mesibov GB, et al. Defining autism spectrum disorders. J Spec Pediatr Nurs. Jul. 2009;14(3):206-9. X-2, X-4. [pmid: 19614831].
3363 Philippart M. Clinical recognition of Rett syndrome. Am J Med Genet Suppl. 1986;1:111-8. X-1, X-2, X-3, X-4. [pmid: 3087171].
3364 Philippe P, Scholl JM, Jacques J. Comorbidity in autism spectrum. Psychiatr Danub. Nov. Suppl 1. 2010;22:S158-60. X-4. [pmid: 21057429].
3365 Piazza CC, Fisher WW, Hagopian LP, et al. Using a choice assessment to predict reinforcer effectiveness. J Appl Behav Anal. Spring. 1996;29(1):1-9. X-1, X-2, X-3, X-4. [pmid: 8881340].
3366 Piazza CC, Fisher WW, Hanley GP, et al. Treatment of pica through multiple analyses of its reinforcing functions. J Appl Behav Anal. Sum. 1998;31(2):165-89. X-1, X-3, X-4. [pmid: 9652098].
3367 Piazza CC, Hagopian LP, Hughes CR, et al. Using chronotherapy to treat severe sleep problems: A case study. Am J Ment Retard. Jan. 1998;102(4):358-66. X-1, X-3, X-4. [pmid: 9475944].
3368 Piazza CC, Hanley GP, Fisher WW. Functional analysis and treatment of cigarette pica. J Appl Behav Anal. Win. 1996;29(4):437-50. X-1, X-3, X-4. [pmid: 8995829].
3369 Piazza CC, Moes DR, Fisher WW. Differential reinforcement of alternative behavior and demand fading in the treating fading in the treatment of escape-maintained destructive behavior. J Appl Behav Anal. Win. 1996;29(4):569-72. X-1, X-3, X-4. [pmid: 8995837].
3370 Piazza CC, Patel MR, Santana CM, et al. An evaluation of simultaneous and sequential presentation of preferred and nonpreferred food to treat food selectivity. J Appl Behav Anal. Fall. 2002;35(3):259-70. X-1, X-3, X-4. [pmid: 12365739].
3371 Pickering D, Morgan SB. Parental ratings of treatments of self-injurious behavior. J Autism Dev Disord. Sep. 1985;15(3):303-14. X-3. [pmid: 4030663].
3372 Pierce K, Schreibman L. Increasing complex social behaviors in children with autism: Effects of peer-implemented pivotal response training. J Appl Behav Anal. Fal. 1995;28(3):285-95. X-1, X-3, X-4. [pmid: 7592145].
3373 Pierce K, Schreibman L. Multiple peer use of pivotal response training to increase social behaviors of classmates with autism: results from trained and untrained peers. J Appl Behav Anal. Spring. 1997;30(1):157-60. X-1, X-3, X-4. [pmid: 9103991].
3374 Pierce K, Schreibman L. Using peer trainers to promote social behavior in autism: are they effective at enhancing multiple social modalities?. Focus Autism Dev Disabil. Win. 1997;12(4):207-18. X-1, X-3, X-4.
3375 Pierce KL, Schreibman L. Teaching daily living skills to children with autism in unsupervised settings through pictorial self-management. J Appl Behav Anal. Fall. 1994;27(3):471-81. X-1, X-3, X-4. [pmid: 7928790].
3376 Pierson MR, Glaeser BC. Using comic strip conversations to increase social satisfaction and decrease loneliness in students with autism spectrum disorder. Educ Train Dev Disabil. Dec. 2007;42(4):460-6. X-1, X-3, X-4.
3377 Piggott LR, Gdowski CL, Villanueva D, et al. Side effects of fenfluramine in autistic children. J Am Acad Child Psychiatry. Mar. 1986;25(2):287-9. X-3. [pmid: 3700920].
3378 Pilebro C, Backman B. Teaching oral hygiene to children with autism. Int J Paediatr Dent. Jan. 2005;15(1):1-9. X-1, X-3, X-4. [pmid: 15663439].
3379 Pilling N, McGill P, Cooper V. Characteristics and experiences of children and young people with severe intellectual disabilities and challenging behaviour attending 52-week residential special schools. J Intellect Disabil Res. Mar. 2007;51(Pt 3):184-96. X-4. [pmid: 17300414].
3380 Pine E, Luby J, Abbacchi A, et al. Quantitative assessment of autistic symptomatology in preschoolers. Autism. Jul. 2006;10(4):344-52. X-4. [pmid: 16908478].
3381 Pinto AF. Treating patients with autism. Emerg Med Serv. Jun. 78. 2001;30(6):83. X-2. [pmid: 11680228].
3382 Pinto-Martin JA, Young LM, Mandell DS, et al. Screening strategies for autism spectrum disorders in pediatric primary care. J Dev Behav Pediatr. Oct. 2008;29(5):345-50. X-4. [pmid: 18852608].
3383 Pioggia G, Igliozzi R, Ferro M, et al. An android for enhancing social skills and emotion recognition in people with autism. IEEE Trans Neural Syst Rehabil Eng. Dec. 2005;13(4):507-15. X-1, X-2, X-3, X-4. [pmid: 16425833].
3384 Pipkin CSP, Vollmer TR, Sloman KN. Effects of treatment integrity failures during differential reinforcement of alternative behavior: a translational model. J Appl Behav Anal. Spr. 2010;43(1):47-70. X-1, X-3, X-4. [pmid: 20808495].
3385 Piravej K, Tangtrongchitr P, Chandarasiri P, et al. Effects of Thai traditional massage on autistic children’s behavior. J Altern Complement Med. Dec. 2009;15(12):1355-61. X-1, X-3, X-4. [pmid: 20001837].
3386 Pisalchaiyong T, Trairatvorakul C, Jirakijja J, et al. Comparison of the effectiveness of oral diazepam and midazolam for the sedation of autistic patients during dental treatment. Pediatr Dent. May–Jun. 2005;27(3):198-206. X-1, X-3, X-4. [pmid: 16173223].
3387 Pitetti KH, Rendoff AD, Grover T, et al. The efficacy of a 9-month treadmill walking program on the exercise capacity and weight reduction for adolescents with severe autism. J Autism Dev Disord. Jul. 2007;37(6):997-1006. X-3. [pmid: 17151799].
3388 Pituch KA, Green VA, Didden R, et al. Parent reported treatment priorities for children with autism spectrum disorders. Res Autism Spectr Disord. Jan–Mar. 2011;5(1):135-43. X-4.
3389 Piven J, Harper J, Palmer P, et al. Course of behavioral change in autism: a retrospective study of high-IQ adolescents and adults. J Am Acad Child Adolesc Psychiatry. Apr. 1996;35(4):523-9. X-4. [pmid: 8919715].
3390 Pizzamiglio MR, Nasti M, Piccardi L, et al. Sensory-motor rehabilitation in rett syndrome: a case report. Focus Autism Dev Disabil. 2008;23(1):49-62. X-4.
3391 Plavnick JB, Ferreri SJ, Maupin AN. The effects of self-monitoring on the procedural integrity of a behavioral intervention for young children with developmental disabilities. J Appl Behav Anal. Sum. 2010;43(2):315-20. X-3. [pmid: 21119907].
3392 Plienis AJ, Robbins FR, Dunlap G. Parent adjustment and family stress as factors in behavioral parent training for young autistic children. J Dev Phys Disabil. Mar. 1988;1(1):31-52. X-3.
3393 Plioplys AV. Autism: electroencephalogram abnormalities and clinical improvement with valproic acid. Arch Pediatr Adolesc Med. Feb. 1994;148(2):220-2. X-1, X-3, X-4. [pmid: 8118547].
3394 Plioplys AV. Intravenous immunoglobulin treatment of children with autism. J Child Neurol. Feb. 1998;13(2):79-82. X-3. [pmid: 9512308].
3395 Ploog BO. Stimulus overselectivity four decades later: a review of the literature and its implications for current research in autism spectrum disorder. J Autism Dev Disord. Nov. 2010;40(11):1332-49. X-1, X-2, X-3, X-4. [pmid: 20238154].
3396 Polimeni MA, Richdale AL, Francis AJ. A survey of sleep problems in autism, asperger’s disorder and typically developing children. J Intellect Disabil Res. Apr. 2005;49(Pt 4):260-8. X-1, X-3. [pmid: 15816813].
3397 Polirstok SR, Dana L, Buono S, et al. Improving functional communication skills in adolescents and young adults with severe autism using gentle teaching and positive approaches. Top Lang Disord. 2003;23(2):146-53. X-3.
3398 Polirstok SR, Lesser DR. Useful online information, resources, and interventions for speech language pathologists and teachers of students with autistic spectrum disorders. Top Lang Disord. Apr–Jun. 2003;23(2):166-67. X-1, X-2, X-3, X-4.
3399 Politi P, Cena H, Comelli M, et al. Behavioral effects of omega-3 fatty acid supplementation in young adults with severe autism: an open label study. Arch Med Res. Oct. 2008;39(7):682-5. X-3. [pmid: 18760197].
3400 Politi P, Rocchetti M, Emanuele E, et al. Randomized placebo-controlled trials of omega-3 polyunsaturated fatty acids in psychiatric disorders: a review of current literature. Curr Drug Discov Technol. 2011. Aug. 15. X-1, X-2, X-3, X-4. [pmid: 21838664].
3401 Pollak M. Speech problems in children. Practitioner. May. 22. 1990;234(1489):542-5. 8. X-1, X-2, X-3, X-4. [pmid: 2392405].
3402 Pollard NL. Development of social interaction skills in preschool children with autism: a review of the literature. Child Fam Behav Ther. 1998;20(2):1-16. X-1, X-2, X-3, X-4.
3403 Pongpech S, Aurboonyawat T, Visudibhan A, et al. Endovascular management in children with vein of Galen aneurysmal malformation. Minim Invasive Neurosurg. Aug. 2010;53(4):169-74. X-1, X-3, X-4. [pmid: 21132608].
3404 Poon L, Partika N, Bolman W. New hope in the treatment of autism in Hawaii. Hawaii Med J. Jul. 1994;53(7):194-5. 9. X-3, X-4. [pmid: 7928306].
3405 Pope KK. The pervasive developmental disorder spectrum: a case illustration. Bull Menninger Clin. Win. 1993;57(1):100-17. X-4. [pmid: 8443614].
3406 Portoghese C, Buttiglione M, Pavone F, et al. The usefulness of the Revised Psychoeducational Profile for the assessment of preschool children with pervasive developmental disorders. Autism. Mar. 2009;13(2):179-91. X-1, X-3, X-4. [pmid: 19261687].
3407 Portway SM, Johnson B. Do you know I have asperger’s syndrome? Risks of a non-obvious disability. Health, Risk & Society. 2005;7(1):73-83. X-1, X-2, X-3, X-4.
3408 Posey DJ, Aman MG, McCracken JT, et al. Positive effects of methylphenidate on inattention and hyperactivity in pervasive developmental disorders: an analysis of secondary measures. Biol Psychiatry. Feb. 15. 2007;61(4):538-44. X-1, X-3. [pmid: 17276750].
3409 Posey DJ, Guenin KD, Kohn AE, et al. A naturalistic open-label study of mirtazapine in autistic and other pervasive developmental disorders. J Child Adolesc Psychopharmacol. Fall. 2001;11(3):267-77. X-1, X-3. [pmid: 11642476].
3410 Posey DJ, Kem DL, Swiezy NB, et al. A pilot study of D-cycloserine in subjects with autistic disorder. Am J Psychiatry. 2004;161(11):2115-7. X-2. [pmid: 15514414].
3411 Posey DJ, McDougle CJ. Treating autism spectrum disorders. Preface Child Adolesc Psychiatr Clin N Am. Oct. 2008;17(4):xv-xviii. X-2. [pmid: 18775365].
3412 Posey DJ, Puntney JI, Sasher TM, et al. Guanfacine treatment of hyperactivity and inattention in pervasive developmental disorders: a retrospective analysis of 80 cases. J Child Adolesc Psychopharmacol. Summer. 2004;14(2):233-41. X-1, X-3. [pmid: 15319020].
3413 Posey DJ, Walsh KH, Wilson GA, et al. Risperidone in the treatment of two very young children with autism. J Child Adolesc Psychopharmacol. Win. 1999;9(4):273-6. X-1, X-3, X-4. [pmid: 10630457].
3414 Posey DJ, Wiegand RE, Wilkerson J, et al. Open-label atomoxetine for attention-deficit/hyperactivity disorder symptoms associated with high-functioning pervasive developmental disorders. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):599-610. X-1, X-3, X-4. [pmid: 17069548].
3415 Posserud M, Lundervold AJ, Lie SA, et al. The prevalence of autism spectrum disorders: impact of diagnostic instrument and non-response bias. Soc Psychiatry Psychiatr Epidemiol. Mar. 2010;45(3):319-27. X-4. [pmid: 19551326].
3416 Posserud M-B, Lundervold AJ, Gillberg C. Validation of the autism spectrum screening questionnaire in a total population sample. J Autism Dev Disord. Jan. 2009;39(1):126-34. X-4. [pmid: 18592364].
3417 Potenza MN, Holmes JP, Kanes SJ, et al. Olanzapine treatment of children, adolescents, and adults with pervasive developmental disorders: an open-label pilot study. J Clin Psychopharmacol. Feb. 1999;19(1):37-44. X-1, X-3, X-4. [pmid: 9934941].
3418 Powell DE. Home-based intervention for preschoolers with emotional disturbances and autism. Prev School Failure. Sum. 1990;34(4):41-5. X-1, X-2, X-3, X-4.
3419 Powell KK, Van Naarden Braun K, Singh RH, et al. Long-term speech and language developmental issues among children with Duarte galactosemia. Genet Med. Dec. 2009;11(12):874-9. X-4. [pmid: 19904210].
3420 Powell SD, Jordan RR. Remediating the thinking of pupils with autism: principles into practice. J Autism Dev Disord. Sep. 1992;22(3):413-8. X-2. [pmid: 1400104].
3421 Power TJ, et al. Brief Report: response to methylphenidate in two children with william syndrome. J Autism Dev Disord. Feb. 1997;27(1):79-87. X-1, X-3, X-4. [pmid: 9018583].
3422 Powers AR 3rd, Hillock AR, Wallace MT. Perceptual training narrows the temporal window of multisensory binding. J Neurosci. Sep. 30. 2009;29(39):12265-74. X-4. [pmid: 19793985].
3423 Powers MD, Crowel RL. The educative effects of positive practice overcorrection: acquisition, generalization, and maintenance. School Psychology Review. 1985;14(3):360-72. X-1, X-3, X-4.
3424 Pozzi M. A three-year-old boy with ADHD and asperger’s syndrome treated with parent-child psychotherapy. Journal of the British Association of Psychotherapists (BAP). Jan. 2003;41(1):16-31. X-1, X-3, X-4.
3425 Pozzi ME. The use of observation in the psychoanalytic treatment of a 12-year-old boy with asperger’s syndrome. Int J Psychoanal. Oct. 2003;84(5):1333-49. X-1, X-3, X-4. [pmid: 14633433].
3426 Prado de Oliveria LE. Little Jeremy’s struggle with autism, schizophrenia and paranoia. International Forum of Psychoanalysis. Dec. 1999;8(3–4):172-88. X-1, X-2, X-3, X-4.
3427 Prasher VP, Clarke DJ. Case report: challenging behaviour in a young adult with down’s syndrome and autism. Br J Learn Disabil. 1996;24(4):167-9. X-1, X-3, X-4.
3428 Prather JH, Chovan WL. Normal peers’ reactions toward autistic children following a tutoring experience. Psychol Rep. Dec. 1984;55(3):887-92. X-1, X-3, X-4. [pmid: 6522555].
3429 Prats JM, Garaizar C, Rua MJ, et al. Infantile spasms treated with high doses of sodium valproate: initial response and follow-up. Dev Med Child Neurol. Jul. 1991;33(7):617-25. X-1, X-3, X-4. [pmid: 1879625].
3430 Preator KK, Jenson WR, Petersen PB, et al. Overcorrection and alternative response training in the reduction of an autistic child’s inappropriate touching. School Psychology Review. Win. 1984;13(1):107-10. X-1, X-3, X-4.
3431 Preece D. Consultation with children with autistic spectrum disorders about their experience of short-term residential care. Br J Learn Disabil. Sep. 2002;30(3):97-104. X-3.
3432 Preece D. Effective short breaks services for families with children with autism spectrum disorders: how one local authority in the United Kingdom is working to meet the challenge. Practice (09503153). 2009;21(3):159-74. X-1, X-2, X-3, X-4.
3433 Preece D, Jordan R. Short breaks services for children with autistic spectrum disorders: factors associated with service use and non-use. J Autism Dev Disord. Feb. 2007;37(2):374-85. X-4. [pmid: 16897379].
3434 Preece D, Jordan R. Social workers’ understanding of autistic spectrum disorders: an exploratory investigation. Br J Social Work. 2007;37(5):925-36. X-4.
3435 Preece D, Jordan R. Obtaining the views of children and young people with autism spectrum disorders about their experience of daily life and social care support. Br J Learn Disabil. Mar. 2010;38(1):10-20. X-3, X-4.
3436 Preece PM, Mott J. Multidisciplinary assessment at a child development centre: Do we conform to recommended standards?. Child: Care, Health and Development. Sep. 2006;32(5):559-63. X-4.
3437 Preissler MA. Associative learning of pictures and words by low-functioning children with autism. Autism. May. 2008;12(3):231-48. X-4. [pmid: 18445733].
3438 Prelock PA, Beatson J, Bitner B, et al. Interdisciplinary assessment of young children with autism spectrum disorder. Lang Speech Hear Serv Sch. Jul. 2003;34(3):194-202. X-2, X-4.
3439 Prelock PA, Calhoun J, Morris H, et al. Supporting parents to facilitate communication and joint attention in their young children with autism spectrum disorders: two pilot studies. Top Lang Disord. 2011;31(3):210-34. X-1, X-3, X-4.
3440 Price A. Neurotherapy and specialization. Am J Occup Ther. Dec. 1980;34(12):809-15. X-1, X-2, X-3, X-4. [pmid: 7282843].
3441 Prichard EA, Palucka A, Reid M, et al. Review of admissions of individuals with autism spectrum disorders to a specialized Dual Diagnosis program. J Dev Disabil. 2010;16(1):76-84. X-4.
3442 Pring L, Dewart H, Brockbank M. Social cognition in children with visual impairments. J Vis Impair Blind. 1998;92(11):754-68. X-1, X-3, X-4.
3443 Prior M. Childhood autism. Aust Paediatr J. Jun. 1987;23(3):147-9. X-1, X-2, X-3, X-4. [pmid: 3662977].
3444 Prior M, Cummins R. Questions about facilitated communication and autism. J Autism Dev Disord. Sep. 1992;22(3):331-7. discussion 7–8. X-1, X-2, X-3, X-4. [pmid: 1400102].
3445 Prizant BM. Speech-language pathologists and autistic children: what is our role?. ASHA. Jul. 1982;24(7):463-8. X-1, X-2, X-3, X-4. [pmid: 6760872].
3446 Prizant BM, Wetherby AM, Rubin E, et al. The SCERTS Model: a transactional, family-centered approach to enhancing communication and socioemotional abilities of children with autism spectrum disorder. Infants Young Child. Oct–Dec. 2003;16(4):296-316. X-1, X-2, X-3, X-4.
3447 Probst P, Jung F, Micheel J, et al. Tertiary-preventive interventions for autism spectrum disorders (ASD) in children and adults: An evaluative synthesis of two TEACCH based outcome studies. Life Span and Disability. 2010;13(2):129-67. X-3.
3448 Probst P, Leppert T. Brief report: outcomes of a teacher training program for autism spectrum disorders. J Autism Dev Disord. Oct. 2008;38(9):1791-6. X-1, X-3, X-4. [pmid: 18369717].
3449 Prothmann A, Albrecht K, Dietrich S, et al. Analysis of child-dog play behavior in child psychiatry. Anthrozoös. 2005;18(1):43-58. X-4.
3450 Provost B, Crowe TK, Acree K, et al. Sensory behaviors of preschool children with and without autism spectrum disorders. NZ J Occup Ther. 2009;56(2):9-17. X-1, X-3, X-4.
3451 Provost B, Heimerl S, Lopez BR. Levels of gross and fine motor development in young children with autism spectrum disorder. Phys Occup Ther Pediatr. 2007;27(3):21-36. X-4. [pmid: 17613454].
3452 Prupas A, Harvey WJ, Benjamin J. Early intervention aquatics: a program for children with autism and their families. J Phys Educ Recreat Dance. Feb. 2006;77(2):46-51. X-2, X-4.
3453 Puleo CM, Kendall PC. Anxiety disorders in typically developing youth: Autism spectrum symptoms as a predictor of cognitive-behavioral treatment. J Autism Dev Disord. Mar. 2011;41(3):275-86. X-1, X-3, X-4. [pmid: 20694508].
3454 Punt M, MDEJ, EDEG, et al. Minor neurological dysfunction in children with dyslexia. Dev Med Child Neurol. Dec. 2010;52(12):1127-32. X-1, X-3, X-4. [pmid: 20518800].
3455 Puri BK, Singh I. Normal phospholipid-related signal transduction in autism. Prog Neuropsychopharmacol Biol Psychiatry. Dec. 2002;26(7–8):1405-7. X-4. [pmid: 12502030].
3456 Puttahraksa P, Tilokskulchai F, Sitthimongkol Y, et al. Empowerment program on promoting perceived self-efficacy in caregivers of autistic children. Thai Journal of Nursing Research. 2006;10(3):180-90. X-1, X-3, X-4.
3457 Puzzo I, Cooper NR, Vetter P, et al. Reduced cortico-motor facilitation in a normal sample with high traits of autism. Neurosci Lett. Dec. 25. 2009;467(2):173-7. X-2, X-4. [pmid: 19833170].
3458 Quill K, Gurry S, Larkin A. Daily life therapy: a Japanese model for educating children with autism. J Autism Dev Disord. Dec. 1989;19(4):625-35. X-1, X-2, X-3, X-4. [pmid: 2606888].
3459 Quill KA. A model for integrating children with autism. Focus on Autistic Behavior. Oct. 1990;5(4):1-19. X-1, X-3, X-4.
3460 Quilty KM. Teaching paraprofessionals how to write and implement social stories for student with autism spectrum disorders. Remedial Spec Educ. May–Jun. 2007;28(3):182-9. X-3.
3461 Quintana H, Birmaher B, Stedge D, et al. Use of methylphenidate in the treatment of children with autistic disorder. Annual Progress in Child Psychiatry & Child Development. 1996:295-307. X-1, X-3, X-4.
3462 Quintana H, Birmaher B, Stedge D, et al. Use of methylphenidate in the treatment of children with autistic disorder. J Autism Dev Disord. Jun. 1995;25(3):283-94. X-1, X-3, X-4. [pmid: 7559293].
3463 Quintero N, McIntyre LL. Kindergarten transition preparation: a comparison of teacher and parent practices for children with autism and other developmental disabilities. Early Child Educ J. Mar. 2011;38(6):411-20. X-1, X-3, X-4.
3464 Quirantes D. Collaborative approach to autism: a parent’s perspective. J Spec Pediatr Nurs. Jul. 2009;14(3):203-5. X-2. [pmid: 19614830].
3465 Quirmbach LM, Lincoln AJ, Feinberg-Gizzo MJ, et al. Social stories: mechanisms of effectiveness in increasing game play skills in children diagnosed with autism spectrum disorder using a pretest posttest repeated measures randomized control group design. J Autism Dev Disord. Feb. 2009;39(2):299-321. X-1, X-3, X-4. [pmid: 18704672].
3466 Raab MM, Nordquist VM, Cunningham JL. Promoting peer regard of an autistic child in a mainstreamed preschool using pre-enrollment activities. Child Stud J. Special Issue: Cognitive and behavioral dysfunction in multiply handicapped children. 1986;16(4):265-84. X-1, X-3, X-4.
3467 Raglio A, Traficante D, Oasi O. A coding scheme for the evaluation of the relationship in music therapy sessions. Psychol Rep. Aug. 2006;99(1):85-90. X-4. [pmid: 17037452].
3468 Raheja S, Libretto SE, Singh I. Successful use of risperidone in an adult with the pervasive developmental disorder, asperger’s syndrome: A case report. Br J Dev Disabil. Jan. 2002;48(94,Pt1):61-6. X-1, X-3, X-4.
3469 Raiten DJ, Massaro T. Perspectives on the nutritional ecology of autistic children. J Autism Dev Disord. Jun. 1986;16(2):133-43. X-1, X-3, X-4. [pmid: 3722115].
3470 Raja M, Azzoni A, Giammarco V. Diabetes insipidus and polydipsia in a patient with asperger’s disorder and an empty sella: a case report. J Autism Dev Disord. Jun. 1998;28(3):235-39. X-1, X-3, X-4. [pmid: 9656135].
3471 Rajendran G, Mitchell P, Rickards H. How do individuals with asperger syndrome respond to nonliteral language and inappropriate requests in computer-mediated communication?. J Autism Dev Disord. Aug. 2005;35(4):429-43. X-4. [pmid: 16134029].
3472 Rakap S. Impacts of learning styles and computer skills on adult students’ learning online. TOJET. Apr. 2010;9(2):108-15. X-1, X-3, X-4.
3473 Ramachandran VS, Oberman LM. Broken mirrors: a theory of autism. Sci Am. Nov. 2006;295(5):62-9. X-2. [pmid: 17076085].
3474 Ramaekers VT, Blau N, Sequeira JM, et al. Folate receptor autoimmunity and cerebral folate deficiency in low-functioning autism with neurological deficits. Neuropediatrics. Dec. 2007;38(6):276-81. X-1, X-3, X-4. [pmid: 18461502].
3475 Ramdoss S, Lang R, Mulloy A, et al. Use of computer-based interventions to teach communication skills to children with autism spectrum disorders: a systematic review. J Behav Educ. Mar. 2011;20(1):55-76. X-1, X-2, X-3.
3476 Ramos AE, Shytle RD, Silver AA, et al. Ziprasidone-induced oculogyric crisis. J Am Acad Child Adolesc Psychiatry. Sep. 2003;42(9):1013-4. X-1, X-3, X-4. [pmid: 12964566].
3477 Randell T, Hall M, Bizo L, et al. DTkid: interactive simulation software for training tutors of children with autism. J Autism Dev Disord. Apr. 2007;37(4):637-47. X-4. [pmid: 17019627].
3478 Randi J, Newman T, Grigorenko EL. Teaching children with autism to read for meaning: challenges and possibilities. J Autism Dev Disord. Jul. 2010;40(7):890-902. X-2, X-4. [pmid: 20101452].
3479 Rankovic CM, Rabinowitz WM, Lof GL. Maximum output intensity of the Audiokinetron. Am J Speech Lang Pathology. 1996;5(2):68-72. X-1, X-3, X-4.
3480 Rao PA, Beidel DC. The impact of children with high-functioning autism on parental stress, sibling adjustment, and family functioning. Behav Modif. 2009;33(4):437-51. X-3, X-4. [pmid: 19436073].
3481 Rao PA, Beidel DC, Murray MJ. Social skills interventions for children with asperger’s syndrome or high-functioning autism: a review and recommendations. J Autism Dev Disord. Feb. 2008;38(2):353-61. X-2, X-4. [pmid: 17641962].
3482 Rao S, Salmon G. Autism spectrum disorders. Br J Hosp Med (Lond). Dec. 2010;71(12):699-703. X-1, X-2, X-3, X-4. [pmid: 21135768].
3483 Rapin I. Children with inadequate language development: management guidelines for otolaryngologists. Int J Pediatr Otorhinolaryngol. Dec. 1988;16(3):189-98. X-1, X-2, X-3, X-4. [pmid: 3235285].
3484 Raposa KA. Behavioral management for patients with intellectual and developmental disorders. Dent Clin North Am. Apr. 2009;53(2):359-73. xi. X-2. [pmid: 19269404].
3485 Rapp JT. Further evaluation of methods to identify matched stimulation. J Appl Behav Anal. Spring. 2007;40(1):73-88. X-3, X-4. [pmid: 17471794].
3486 Rapp JT, Dozier CL, Carr JE. Functional assessment and treatment of pica: A single-case experiment. Behav Int. Apr–Jun. 2001;16(2):111-25. X-1, X-3, X-4.
3487 Rapp JT, Dozier CL, Carr JE, et al. Functional analysis of hair manipulation: A replication and extension. Behav Int. Apr–Jun. 2000;15(2):121-33. X-1, X-3, X-4.
3488 Rapp JT, Vollmer Timothy R. Stereotypy II: a review of neurobiological interpretations and suggestions for an integration with behavioral methods. Res Dev Disabil: A Multidisciplinary Journal. Nov–Dec. 2005;26(6):548-64. X-2, X-4.
3489 Rapp JT, Vollmer TR, Hovanetz AN. Evaluation and Treatment of Swimming Pool Avoidance Exhibited by an Adolescent Girl With Autism. Behavior Therapy. Win. 2005;36(1):101-5. X-3.
3490 Rapp JT, Vollmer TR, St. Peter C, et al. Analysis of response allocation in individuals with multiple forms of stereotyped behavior. J Appl Behav Anal. Win. 2004;37(4):481-501. X-1, X-3, X-4. [pmid: 15669407].
3491 Rapport MD. Bridging theory and practice: conceptual understanding of treatments for children with attention deficit hyperactivity disorder (ADHD), obsessive-compulsive disorder (OCD), autism, and depression. J Clin Child Psychol. Mar. 2001;30(1):3-7. X-2, X-4. [pmid: 11294075].
3492 Rasalam AD, Hailey H, Williams JH, et al. Characteristics of fetal anticonvulsant syndrome associated autistic disorder. Dev Med Child Neurol. Aug. 2005;47(8):551-5. X-4. [pmid: 16108456].
3493 Rastam M, Bjure J, Vestergren E, et al. Regional cerebral blood flow in weight-restored anorexia nervosa: a preliminary study. Dev Med Child Neurol. Apr. 2001;43(4):239-42. X-4. [pmid: 11305400].
3494 Rastam M, Gillberg C, Wentz E. Outcome of teenage-onset anorexia nervosa in a Swedish community-based sample. Eur Child Adolesc Psychiatry. Suppl 1. 2003;12:I78-90. X-4. [pmid: 12567219].
3495 Rastegar M, Hotta A, Pasceri P, et al. MECP2 isoform-specific vectors with regulated expression for Rett syndrome gene therapy. PLoS One. 2009;4(8):e6810. X-2, X-4. [pmid: 19710912].
3496 Ratey JJ, Bemporad JR, Sorgi P, et al. Open trial effects of beta-blockers on speech and social behaviors in 8 autistic adults. J Autism Dev Disord. Sep. 1987;17(3):439-46. X-1, X-3. [pmid: 3654495].
3497 Ratliff-Schaub K, Carey T, Reeves GD, et al. Randomized controlled trial of transdermal secretin on behavior of children with autism. Autism. Jul. 2005;9(3):256-65. X-1, X-3, X-4. [pmid: 15937041].
3498 Rausch JL, Sirota EL, Londino DL, et al. Open-label risperidone for asperger’s disorder: negative symptom spectrum response. J Clin Psychiatry. Dec. 2005;66(12):1592-7. X-3. [pmid: 16401163].
3499 Ravizza SM, Ivry RB. Comparison of the basal ganglia and cerebellum in shifting attention. J Cogn Neurosci. Apr. 1. 2001;13(3):285-97. X-2. [pmid: 11371307].
3500 Ray F, Marks C, Bray-Garretson H. Challenges to treating adolescents with asperger’s syndrome who are sexually abusive. Sex Addict Compulsivity. Dec. 2004;11(4):265-85. X-2.
3501 Ray T, Tobias JD. Dexmedetomidine for sedation during electroencephalographic analysis in children with autism, pervasive developmental disorders, and seizure disorders. J Clin Anesth. Aug. 2008;20(5):364-8. X-4. [pmid: 18761245].
3502 Ray TC, King LJ, Grandin T. The effectiveness of self-initiated vestibular stimulation in producing speech sounds in an autistic child. Occupational Therapy Journal of Research. May–Jun. 1988;8(3):186-90. X-1, X-3, X-4.
3503 Rayner C. Teaching students with autism to tie a shoelace knot using video prompting and backward chaining. Dev Neurorehabil. 2011. Sep. 27. X-3. [pmid: 21950374].
3504 Ray-Subramanian CE, Huai N, Ellis Weismer S. Brief report: adaptive behavior and cognitive skills for toddlers on the autism spectrum. J Autism Dev Disord. May. 2011;41(5):679-84. X-1, X-3, X-4. [pmid: 20697794].
3505 Raz N, Pritchard WS, August GJ. Effects of fenfluramine on EEG and brainstem average evoked response in infantile autism. Preliminary investigation. Neuropsychobiology. 1987;18(2):105-9. X-1, X-3, X-4. [pmid: 2836758].
3506 Read N, Schofield A. Autism: are mental health services failing children and parents?. J Fam Health Care. 2010;20(4):120-4. X-1, X-2, X-3, X-4. [pmid: 21053660].
3507 Read SG, Rendall M. An open-label study of risperidone in the improvement of quality of life and treatment of symptoms of violent and self-injurious behaviour in adults with intellectual disability. J Appl Res Intellect Disabil. May. 2007;20(3):256-64. X-3, X-4.
3508 Reading S, Richie C. Documenting changes in communication behaviours using a structured observation system. Child Lang Teach Ther. 2007;23(2):181-200. X-4.
3509 Reagon KA, Higbee TS. Parent-implemented script fading to promote play-based verbal initiations in children with autism. J Appl Behav Anal. Fall. 2009;42(3):659-64. X-3. [pmid: 20190925].
3510 Reagon KA, Higbee TS, Endicott K. Teaching pretend play skills to a student with autism using video modeling with a sibling as model and play partner. Educ Treat Children. Aug. 2006;29(3):517-28. X-1, X-3.
3511 Realmuto GM, August GJ, Garfinkel BD. Clinical effect of buspirone in autistic children. Journal of Clinical Psychopharmacology. Apr. 1989;9(2):122-5. X-1, X-3, X-4. [pmid: 2723129].
3512 Realmuto GM, et al. Growth hormone response to L-Dopa and Clonidine in autistic children. J Autism Dev Disord. Dec. 1990;20(4):455-65. X-3, X-4. [pmid: 2279968].
3513 Realmuto GM, Ruble LA. Sexual behaviors in autism: problems of definition and management. J Autism Dev Disord. Apr. 1999;29(2):121-7. X-3. [pmid: 10382132].
3514 Reaven J, Hepburn S. Cognitive-behavioral treatment of obsessive-compulsive disorder in a child with Asperger syndrome: a case report. Autism. Jun. 2003;7(2):145-64. X-1, X-3, X-4. [pmid: 12846384].
3515 Reaven JA, Blakeley-Smith A, Nichols S, et al. Cognitive-behavioral group treatment for anxiety symptoms in children with high-functioning autism spectrum disorders: a pilot study. Focus Autism Dev Disabil. Mar. 2009;24(1):27-37. X-1, X-3.
3516 Redefer LA, Goodman JF. Brief report: pet-facilitated therapy with autistic children. J Autism Dev Disord. Sep. 1989;19(3):461-7. X-1, X-3, X-4. [pmid: 2793790].
3517 Redfearn J. Possible psychosomatic hazards to the therapist: patients as self-objects. J Anal Psychol. Apr. 2000;45(2):177-94. X-2, X-4. [pmid: 14533393].
3518 Redl F. Rethinking youthful defiance. Reclaiming Children and Youth. Spr. 2007;16(1):33-5. X-2.
3519 Redmond NB, et al. Using functional assessment to support a student with severe disabilities in the community. Teach Except Child. Spr. 1993;25(3):51-2. X-3, X-4.
3520 Reeb RN, Folger SF, Oneal BJ. Behavioral summarized evaluation: an assessment tool to enhance multidisciplinary and parent-professional collaborations in assessing symptoms of autism. Child Health Care. Oct. 2009;38(4):301-20. X-1, X-2, X-3, X-4.
3521 Reed CL, Beall PM, Stone VE, et al. Brief report: perception of body posture--what individuals with autism spectrum disorder might be missing. J Autism Dev Disord. Sep. 2007;37(8):1576-84. X-4. [pmid: 17029019].
3522 Reed CN, Dunbar SB, Bundy AC. The effects of an inclusive preschool experience on the playfulness of children with and without autism. Phys Occup Ther Pediatr. 2000;19(3/4):73-89. X-1, X-3, X-4.
3523 Reed DD, Luiselli JK, Morizio LC, et al. Sequential modification and the identification of instructional components occasioning self-injurious behavior. Child Fam Behav Ther. 2010;32(1):1-16. X-1, X-3.
3524 Reed HE, McGrew SG, Artibee K, et al. Parent-based sleep education workshops in autism. J Child Neurol. Aug. 2009;24(8):936-45. X-1, X-3, X-4. [pmid: 19491110].
3525 Reed P, Broomfield L, McHugh L, et al. Extinction of over-selected stimuli causes emergence of under-selected cues in higher-functioning children with autistic spectrum disorders. J Autism Dev Disord. Feb. 2009;39(2):290-8. X-1, X-3, X-4. [pmid: 18787937].
3526 Reed P, Osborne LA, Corness M. Brief report: relative effectiveness of different home-based behavioral approaches to early teaching intervention. J Autism Dev Disord. Oct. 2007;37(9):1815-21. X-1, X-3, X-4. [pmid: 17180714].
3527 Reed P, Osborne LA, Corness M. The real-world effectiveness of early teaching interventions for children with autism spectrum disorder. Except Child. Sum. 2007;73(4):417-33. X-1, X-4.
3528 Reed P, Osborne LA, Corness M. Effectiveness of special nursery provision for children with autism spectrum disorders. Autism. Jan. 2010;14(1):67-82. X-1, X-3, X-4. [pmid: 20124504].
3529 Reese RM, Richman DM, Zarcone J, et al. Individualizing functional assessments for children with autism: the contribution of perseverative behavior and sensory disturbances to disruptive behavior. Focus Autism Dev Disabil. Sum. 2003;18(2):89-94. X-4.
3530 Reese RM, Sherman JA, Sheldon JB. Reducing disruptive behavior of a group-home resident with autism and mental retardation. J Autism Dev Disord. Apr. 1998;28(2):159-65. X-3. [pmid: 9586778].
3531 Reeve SA, Reeve KF, Townsend DB, et al. Establishing a generalized repertoire of helping behavior in children with autism. J Appl Behav Anal. Spring. 2007;40(1):123-36. X-1, X-3, X-4. [pmid: 17471797].
3532 Reeves C. Children, words and symptomatic acts. J Child Psychother. Aug. 1996;22(2):279-98. X-4.
3533 Regal RA, Rooney JR, Wandas T. Facilitated communication: an experimental evaluation. J Autism Dev Disord. Jun. 1994;24(3):345-55. X-3. [pmid: 8050987].
3534 Regehr K, Feldman M. Parent-selected interventions for infants at-risk for autism spectrum disorders and their affected siblings. Behav Int. Nov. 2009;24(4):237-48. X-4.
3535 Rehfeldt RA, Chambers MR. Functional analysis and treatment of verbal perseverations displayed by an adult with autism. J Appl Behav Anal. Summer. 2003;36(2):259-61. X-3, X-4. [pmid: 12858991].
3536 Rehfeldt RA, Kinney EM, Root S, et al. Creating activity schedules using Microsoft Powerpoint. J Appl Behav Anal. Spring. 2004;37(1):115-28. X-2. [pmid: 15154226].
3537 Rehfeldt RA, Latimore D, Stromer R. Observational learning and the formation of classes of reading skills by individuals with autism and other developmental disabilities. Res Dev Disabil. Sep–Oct. 2003;24(5):333-58. X-1, X-3, X-4. [pmid: 12951131].
3538 Reichelt KL, Knivsberg AM. The possibility and probability of a gut-to-brain connection in autism. Ann Clin Psychiatry. Nov. 2009;21(4):205-11. X-4. [pmid: 19917211].
3539 Reichelt KL, Knivsberg A-M, Lind G, et al. Probable etiology and possible treatment of childhood autism. Brain Dysfunct. Nov–Dec. 1991;4(6):308-19. X-1, X-3.
3540 Reichle J, Johnson L, Monn E, et al. Task engagement and escape maintained challenging behavior: differential effects of general and explicit cues when implementing a signaled delay in the delivery of reinforcement. J Autism Dev Disord. Jun. 2010;40(6):709-20. X-1, X-3, X-4. [pmid: 20162345].
3541 Reichle J, McComas J, Dahl N, et al. Teaching an individual with severe intellectual delay to request assistance conditionally. Educ Psychol. Apr–Jun. 2005;25(2–3):275-86. X-3.
3542 Reichow B, Barton EE, Good L, et al. Brief report: effects of pressure vest usage on engagement and problem behaviors of a young child with developmental delays. J Autism Dev Disord. Aug. 2009;39(8):1218-21. X-1, X-3, X-4. [pmid: 19291378].
3543 Reichow B, Barton EE, Sewell JN, et al. Effects of weighted vests on the engagement of children with developmental delays and autism. Focus Autism Dev Disabil. 2010;25(1):3-11. X-1, X-3, X-4.
3544 Reichow B, Sabornie EJ. Brief Report: increasing verbal greeting initiations for a student with autism via a social story[tm] intervention. J Autism Dev Disord. Dec. 2009;39(12):1740-3. X-1, X-3, X-4. [pmid: 19593645].
3545 Reichow B, Salamack S, Paul R, et al. Pragmatic assessment in autism spectrum disorders: a comparison of a standard measure with parent report. Commun Disord Q. 2008;29(3):169-76. X-4. [pmid: 20948979].
3546 Reichow B, Volkmar FR. Social skills interventions for individuals with autism: evaluation for evidence-based practices within a best evidence synthesis framework. J Autism Dev Disord. Feb. 2010;40(2):149-66. X-2, X-4. [pmid: 19655240].
3547 Reichow B, Volkmar FR, Cicchetti DV. Development of the evaluative method for evaluating and determining evidence-based practices in autism. J Autism Dev Disord. Aug. 2008;38(7):1311-9. X-2, X-4. [pmid: 18095149].
3548 Reichow B, Wolery M. Comprehensive synthesis of early intensive behavioral interventions for young children with autism based on the UCLA young autism project model. J Autism Dev Disord. Jan. 2009;39(1):23-41. X-2. [pmid: 18535894].
3549 Reid DH, Parsons MB, Lattimore LP. Designing and evaluating assessment-based interventions to reduce stereotypy among adults with autism in a community job. Behav Anal Pract. 2010;3(2):27-36. X-3. [pmid: 22532891].
3550 Reid DH, Parsons MB, Lattimore LP, et al. Improving staff performance through clinician application of outcome management. Res Dev Disabil. Mar–Apr. 2005;26(2):101-16. X-4. [pmid: 15590242].
3551 Reiman M, Albers L. International adoption: A four-year-old child with unusual behaviors adopted at six months of age: website discussion. J Dev Behav Pediatr. Feb. 2003;24(1):67. X-2, X-4.
3552 Reinecke DR, et al. Teaching deception skills in a game-play context to three adolescents with autism. J Autism Dev Disord. Apr. 1997;27(2):127-37. X-1, X-3, X-4. [pmid: 9105964].
3553 Reinhold JA, Molloy CA, Manning-Courtney P. Electroencephalogram abnormalities in children with autism spectrum disorders. J Neurosci Nurs. Jun. 2005;37(3):136-8. X-4. [pmid: 16001817].
3554 Reinke T. States increasingly mandate special autism services. Insurers are being handed some treatment responsibility for this complex disorder, but some say that it is an educational, not medical, task. Manag Care. Aug. 2008;17(8):35-6. 9. X-2. [pmid: 18777788].
3555 Reiss AL, Egel AL, Feinstein C, et al. Effects of fenfluramine on social behavior in autistic children. J Autism Dev Disord. Dec. 1988;18(4):617-25. X-3. [pmid: 3215887].
3556 Reiter S, Vitani T. Inclusion of pupils with autism: the effect of an intervention program on the regular pupils’ burnout, attitudes and quality of mediation. Autism. 2007;11(4):321-33. X-1, X-3, X-4. [pmid: 17656397].
3557 Rembrand R. Sound of a hug. Stud Health Technol Inform. 2009;149:357-67. X-2, X-4. [pmid: 19745494].
3558 Remington B, Clarke S. Acquisition of expressive signing by autistic children: an evaluation of the relative effects of simultaneous communication and sign-alone training. J Appl Behav Anal. Fall. 1983;16(3):315-27. X-3, X-4. [pmid: 6643323].
3559 Remington B, Hastings RP, Kovshoff H, et al. Early intensive behavioral intervention: outcomes for children with autism and their parents after two years. Am J Ment Retard. Nov. 2007;112(6):418-38. X-1, X-3, X-4. [pmid: 17963434].
3560 Renna R. Autism spectrum disorders learning to listen as we shape behaviors blending choice theory with applied behavioral analysis. Int J Reality Ther. Spr. 2004;23(2):17-22. X-1, X-2, X-3, X-4.
3561 Renshaw TL, Kuriakose S. Pivotal Response Treatment for Children with Autism: Core Principles and Applications for School Psychologists. Journal of Applied School Psychology. 2011;27(2):181-200. X-1, X-2, X-3, X-4.
3562 Renty J, Roeyers H. Students with Autism Spectrum Disorder in Special and General Education Schools in Flanders. Br J Dev Disabil. 2005;51(100,Pt1):27-39. X-1, X-3, X-4.
3563 Renty J, Roeyers H. Satisfaction with formal support and education for children with autism spectrum disorder: the voices of the parents. Child Care Health Dev. May. 2006;32(3):371-85. X-1. [pmid: 16634981].
3564 Resch RC, Grand S, May M. Eye, hand, and the mother: the mother’s role in the neuromaturation and development of an autistic child. Bull Menninger Clin. Jul. 1988;52(4):304-20. X-1, X-3, X- 4. [pmid: 3401627].
3565 Reynhout G, Carter M. Social Story[Trademark sign] efficacy with a child with autism spectrum disorder and moderate intellectual disability. Focus Autism Dev Disabil. Fall. 2007;22(3):173-82. X-1, X-3, X-4.
3566 Reynhout G, Carter M. The use of social stories by teachers and their perceived efficacy. Res Autism Spectr Disord. Jan. 2009;3(1):232-51. X-1, X-3, X-4.
3567 Reynolds S, Bendixen RM, Lawrence T, et al. A pilot study examining activity participation, sensory responsiveness, and competence in children with high functioning autism spectrum disorder. J Autism Dev Disord. Nov. 2011;41(11):1496-506. X-1, X-3, X-4. [pmid: 21221753].
3568 Rezaei V, Mohammadi MR, Ghanizadeh A, et al. Double-blind, placebo-controlled trial of risperidone plus topiramate in children with autistic disorder. Prog Neuropsychopharmacol Biol Psychiatry. Oct. 1. 2010;34(7):1269-72. X-1, X-3, X-4. [pmid: 20637249].
3569 Rhine D, Tarbox J. Chewing gum as a treatment for rumination in a child with autism. J Appl Behav Anal. Summer. 2009;42(2):381-5. X-1, X-3, X-4. [pmid: 19949528].
3570 Rhoades RA, Scarpa A, Salley B. The importance of physician knowledge of autism spectrum disorder: results of a parent survey. BMC Pediatr. 2007;7:37. X-1, X-3, X-4. [pmid: 18021459].
3571 Rhode M. Autistic breathing. J Child Psychother. Special Issue: Autism. Apr. 1994;20(1):25-41. X-3.
3572 Rhode M. Links between Henri Rey’s thinking and psychoanalytic work with autistic children. Psychoanalytic Psychotherapy. 1995;9(2):149-55. X-2, X-4.
3573 Rhode M. Some aspects of dependence on the therapist’s mental functioning. Journal of Melanie Klein & Object Relations. Jun. 1998;16(2):233-43. X-4.
3574 Rhode M. Different responses to trauma in two children with autistic spectrum disorder: the mouth as crossroads for the sense of self. J Child Psychother. Apr. 2004;30(1):3-20. X-1, X-3, X-4.
3575 Riby D, Hancock PJB. Looking at movies and cartoons: eye-tracking evidence from Williams syndrome and autism. J Intellect Disabil Res. 2009;53(Part 2):169-81. X-4. [pmid: 19192099].
3576 Riby DM, Doherty-Sneddon G, Bruce V. Exploring face perception in disorders of development: evidence from Williams syndrome and autism. J Neuropsychol. Mar. 2008;2(Pt 1):47-64. X-4. [pmid: 19334304].
3577 Ricciardi JN, Luiselli JK. Behavioral intervention to eliminate socially mediated urinary incontinence in a child with autism. Child Fam Behav Ther. 2003;25(4):53-63. X-1, X-3, X-4.
3578 Ricciardi JN, Luiselli JK, Camare M. Shaping approach responses as intervention for specific phobia in a child with autism. J Appl Behav Anal. Win. 2006;39(4):445-8. X-1, X-3, X-4. [pmid: 17236342].
3579 Ricciardi JN, Luiselli JK, Terrill S, et al. Alternative response training with contingent practice as intervention for pica in a school setting. Behav Int. Jul. 2003;18(3):219-26. X-1, X-3, X-4.
3580 Rice MA, Haas RH. The nutritional aspects of Rett syndrome. J Child Neurol. Suppl. 1988;3:S35-42. X-1, X-2, X-3, X-4. [pmid: 3198901].
3581 Richdale AL. Sleep problems in autism: prevalence, cause, and intervention. Dev Med Child Neurol. Jan. 1999;41(1):60-6. X-1, X-2, X-3, X-4. [pmid: 10068053].
3582 Richer J. Avoidance behavior, attachment and motivational conflict. Early Child Dev Care. 1993;96:7-18. X-1, X-2, X-3, X-4.
3583 Richman DM, Reese RM, Daniels D. Use of evidence-based practice as a method for evaluating the effects of secretin on a child with autism. Focus Autism Dev Disabil. Win. 1999;14(4):204-11. X-1, X-3, X-4.
3584 Richman DM, Wacker DP, Asmus JM, et al. Functional analysis and extinction of different behavior problems exhibited by the same individual. J Appl Behav Anal. Fal. 1998;31(3):475-8. X-3. [pmid: 9757585].
3585 Rickards AL, Walstab JE, Wright-Rossi RA, et al. A randomized, controlled trial of a home-based intervention program for children with autism and developmental delay. J Dev Behav Pediatr. Aug. 2007;28(4):308-16. X-1, X-3, X-4. [pmid: 17700083].
3586 Rickards AL, Walstab JE, Wright-Rossi RA, et al. One-year follow-up of the outcome of a randomized controlled trial of a home-based intervention programme for children with autism and developmental delay and their families. Child Care Health Dev. Sep. 2009;35(5):593-602. X-1, X-3, X-4. [pmid: 19508318].
3587 Ridge K, Guerin S. Irish clinicians’ views of interventions for children with autistic spectrum disorders. Autism. Mar. 2011;15(2):239-52. X-1, X-3, X-4. [pmid: 21325370].
3588 Ridley J, Hunter S. The development of supported employment in Scotland. J Vocat Rehabil. Special Issue: Spinal Cord Injury and Vocational Rehabilitation. 2006;25(1):57-68. X-2, X-4.
3589 Riedlinger JE. The scheduling of MDMA: a pharmacist’s perspective. J Psychoactive Drugs. Jul–Sep. 1985;17(3):167-71. X-1, X-2, X-3, X-4. [pmid: 2865343].
3590 Rijk C, Hoksbergen R, ter Laak J. Parents’ and mental health workers’ perceptions of the therapeutic needs and experiences of services for Dutch children adopted from Romania. Adopt Fostering. 2007;31(3):58-70. X-3, X-4.
3591 Rimland B. Controversies in the treatment of autistic children: vitamin and drug therapy. J Child Neurol. 1988;3:68-72. X-1, X-2, X-3, X-4.
3592 Rimland B. Comments on “secretin and autism: a two-part clinical investigation” by M. G. Chez et al. J Autism Dev Disord. Apr. 2000;30(2):95. X-1, X-2, X-3, X-4. [pmid: 10832773].
3593 Rimland B, Baker SM. Brief report: alternative approaches to the development of effective treatments for autism. J Autism Dev Disord. Apr. 1996;26(2):237-41. X-1, X-2, X-3, X-4. [pmid: 8744492].
3594 Rimland B, Edelson SM. Brief report: a pilot study of auditory integration training in autism. J Autism Dev Disord. Feb. 1995;25(1):61-70. X-1, X-3, X-4. [pmid: 7608035].
3595 Rimmer JH, Yamaki K, Lowry BM, et al. Obesity and obesity-related secondary conditions in adolescents with intellectual/developmental disabilities. J Intellect Disabil Res. Sep. 2010;54(9):787-94. X-4. [pmid: 20630017].
3596 Rincover A, Newsom CD. The relative motivational properties of sensory and edible reinforcers in teaching autistic children. J Appl Behav Anal. Fal. 1985;18(3):237-48. X-1, X-3, X-4. [pmid: 4044457].
3597 Ring HA, Baron-Cohen S, Wheelwright S, et al. Cerebral correlates of preserved cognitive skills in autism: a functional MRI study of Embedded Figures Task performance. Brain: J Neurol. Jul. 1999;122(7):1305-15. X-4.
3598 Ring RH, Schechter LE, Leonard SK, et al. Receptor and behavioral pharmacology of WAY-267464, a non-peptide oxytocin receptor agonist. Neuropharmacol. Jan. 2010;58(1):69-77. X-2, X-4. [pmid: 19615387].
3599 Ringdahl JE, Call NA, Christensen T, et al. Brief report: signals enhance the suppressive effects of noncontingent reinforcement. J Autism Dev Disord. Mar. 2010;40(3):378-82. X-2. [pmid: 19777331].
3600 Ringdahl JE, Kitsukawa K, Andelman MS, et al. Differential reinforcement with and without instructional fading. J Appl Behav Anal. Fal. 2002;35(3):291-4. X-1, X-3, X-4. [pmid: 12365743].
3601 Risley TR. Family preservation for children with autism. J Early Interv. Win. 1997;21(1):15-6. X-2, X-3.
3602 Rispoli M, O’Reilly M, Lang R, et al. Effects of motivating operations on problem and academic behavior in classrooms. J Appl Behav Anal. Spr. 2011;44(1):187-92. X-3. [pmid: 21541143].
3603 Ritvo ER, Freeman BJ. A medical model of autism: etiology, pathology and treatment. Pediatr Ann. Apr. 1984;13(4):298-305. X-1, X-2, X-3, X-4. [pmid: 6610163].
3604 Ritvo ER, Freeman BJ, Geller E, et al. Effects of fenfluramine on 14 outpatients with the syndrome of autism. J Am Acad Child Psychiatry. Nov. 1983;22(6):549-58. X-3. [pmid: 6655169].
3605 Ritvo ER, Freeman BJ, Yuwiler A, et al. Fenfluramine treatment of autism: UCLA collaborative study of 81 patients at nine medical centers. Psychopharmacol Bull. 1986;22(1):133-40. X-1, X-3. [pmid: 3726059].
3606 Ritvo ER, Freeman BJ, Yuwiler A, et al. Study of fenfluramine in outpatients with the syndrome of autism. J Pediatr. Nov. 1984;105(5):823-8. X-3. [pmid: 6502317].
3607 Ritvo ER, Neathery SK. Parental reports on favorable responses to fenfluramine treatment in autism. Brain Dysfunction. Nov–Dec. 1990;3(5–6):308-14. X-1.
3608 Ritvo ER RR, Yuwiler A, Brothers A, Freeman BJ, Plotkin S. Elevated daytime melatonin concentrations in autism: a pilot study. Eur Child Adolesc Psychiatry. 1993;2(2):75-8. X-3, X-4.
3609 Riva D, Giorgi C. The cerebellum contributes to higher functions during development: evidence from a series of children surgically treated for posterior fossa tumours. Brain. May. 2000;123(Pt 5):1051-61. X-4. [pmid: 10775549].
3610 Riviere V, Becquet M, Peltret E, et al. Increasing compliance with medical examination requests directed to children with autism: Effects of a high-probability request procedure. J Appl Behav Anal. 2011;44(1):193-7. X-1, X-3, X-4. [pmid: 21541109].
3611 Riviere V, Becquet M, Peltret E, et al. Increasing compliance with medical examination requests directed to children with autism: effects of a high-probability request procedure. J Appl Behav Anal. Spring. 2011;44(1):193-7. X-1, X-3, X-4. [pmid: 21541109].
3612 Robb AS. Managing irritability and aggression in autism spectrum disorders in children and adolescents. Dev Disabil Res Rev. 2010;16(3):258-64. X-1, X-2, X-3. [pmid: 20981764].
3613 Robb AS, Andersson C, Bellocchio EE, et al. Safety and tolerability of aripiprazole in the treatment of irritability associated with autistic disorder in pediatric subjects 6–17 years old):results from a pooled analysis of 2 studies. Prim Care Companion CNS Disord. 2011;13(1). X-1. [pmid: 21731831].
3614 Robbins FR, Dunlap G. Effects of task difficulty on parent teaching skills and behavior problems of young children with autism. Am J Ment Retard. May. 1992;96(6):631-43. X-1, X-3, X-4. [pmid: 1344940].
3615 Robbins FR, Dunlap G, Plienis AJ. Family characteristics, family training, and the progress of young children with autism. J Early Interv. Spr. 1991;15(2):173-84. X-1, X-3, X-4.
3616 Roberts D, Pickering N. Parent training programme for autism spectrum disorders: an evaluation. Community Pract. Oct. 2010;83(10):27-30. IX-1, X-3, X-4. [pmid: 21049753].
3617 Roberts EM, English PB, Grether JK, et al. Maternal residence near agricultural pesticide applications and autism spectrum disorders among children in the California Central Valley. Environ Health Perspect. Oct. 2007;115(10):1482-9. X-1, X-3, X-4. [pmid: 17938740].
3618 Roberts JE, Mankowski JB, Sideris J, et al. Trajectories and predictors of the development of very young boys with fragile X syndrome. J Pediatr Psychol. Sep. 2009;34(8):827-36. X-4. [pmid: 19074489].
3619 Roberts JMA, Keane E, Clark TR. Making inclusion work: autism spectrum Australia satellite class project. Teach Except Child. Nov–Dec. 2008;41(2):22-7. X-2.
3620 Roberts KD. Topic areas to consider when planning transition from high school to postsecondary education for students with autism spectrum disorders. Focus Autism Dev Disabil. Sep. 2010;25(3):158-62. X-1, X-2, X-3.
3621 Roberts RN. Wow! Models of service coordination do make a difference. J Early Interv. 2006;28(3):169-71. X-2, X-4.
3622 Roberts TP, Khan SY, Rey M, et al. MEG detection of delayed auditory evoked responses in autism spectrum disorders: towards an imaging biomarker for autism. Autism Res. Feb. 2010;3(1):8-18. X-1, X-3, X-4. [pmid: 20063319].
3623 Roberts W, Weaver L, Brian J, et al. Repeated doses of porcine secretin in the treatment of autism: a randomized, placebo-controlled trial. Pediatrics. May. 2001;107(5):E71. X-1, X-3, X-4. [pmid: 11331721].
3624 Roberts-Gwinn MM, Luiten L, Derby KM, et al. Identification of competing reinforcers for behavior maintained by automatic reinforcement. J Posit Behav Interv. Spr. 2001;3(2):83-7. X-1, X-3, X-4.
3625 Robertson J, Emerson E, Gregory N, et al. Social networks of people with mental retardation in residential settings. Ment Retard. Jun. 2001;39(3):201-14. X-4. [pmid: 11419999].
3626 Robertson K, Chamberlain B, Kasari C. General education teachers’ relationships with included students with autism. J Autism Dev Disord. Apr. 2003;33(2):123-30. X-1, X-3, X-4. [pmid: 12757351].
3627 Robins B, Dickerson P, Stribling P, et al. Robot-mediated joint attention in children with autism: a case study in robot-human interaction. Interaction Studies: Social Behaviour and Communication in Biological and Artificial Systems. 2004;5(2):161-98. X-1, X-3, X-4.
3628 Robins DL. Screening for autism spectrum disorders in primary care settings. Autism. Special Issue: Early detection. Sep. 2008;12(5):537-56. X-4. [pmid: 18805946].
3629 Robins DL, Fein D, Barton ML, et al. The modified checklist for autism in toddlers: an initial study investigating the early detection of autism and pervasive developmental disorders. J Autism Dev Disord. Apr. 2001;31(2):131-44. X-1, X-2, X-3, X-4. [pmid: 11450812].
3630 Robins DL, Fein D, Barton ML, et al. Reply to charman et al.’s commentary on the modified checklist for autism in toddlers. J Autism Dev Disord. Apr. 2001;31(2):149-51. X-1, X-2, X-3, X-4.
3631 Robinson S, Magill-Evans J. Young children with autism spectrum disorder: sensory processing and daily life skills. Occupational Therapy Now. 2009;11(5):11-3. X-1, X-3, X-4.
3632 Robinson TW. Homeopathic Secretin in autism: a clinical pilot study. Br Homeopath J. Apr. 2001;90(2):86-91. X-1, X-3, X-4. [pmid: 11341462].
3633 Rocha ML, Schreibman L, Stahmer AC. Effectiveness of training parents to teach joint attention in children with autism. J Early Interv. 2007;29(2):154-73. X-1, X-3, X-4.
3634 Rocque B. Mediating self-hood: exploring the construction and maintenance of identity by mothers of children labeled with autism spectrum disorder. Disabil Soc. 2010;25(4):485-97. X-4.
3635 Rodger S, Ashburner J, Cartmill L, et al. Helping children with autism spectrum disorders and their families: are we losing our occupation-centred focus?. Aust Occup Ther J. Aug. 2010;57(4):276-80. X-1, X-2, X-3, X-4. [pmid: 20854603].
3636 Rodger S, Braithwaite M, Keen D. Early intervention for children with autism: parental priorities. Aust J Early Child. Sep. 2004;29(3):34-41. X-1, X-3, X-4.
3637 Rodger S, Ireland S, Vun M. Can cognitive orientation to daily occupational performance (co-op) help children with asperger’s syndrome to master social and organisational goals?. Br J Occup Ther. 2008;71(1):23-32. X-1, X-3, X-4.
3638 Rodger S, Keen D, Braithwaite M, et al. Mothers’ satisfaction with a home based early intervention programme for children with ASD. J Appl Res Intellect Disabil. Mar. 2008;21(2):174-82. X-1, X-3, X-4.
3639 Rodger S, Pham C, Mitchell S. Cognitive strategy use by children with asperger’s syndrome during intervention for motor-based goals. Aust Occup Ther J. Apr. 2009;56(2):103-11. X-1, X-3, X-4. [pmid: 20854499].
3640 Rodger S, Vishram A. Mastering social and organization goals: strategy use by two children with asperger syndrome during cognitive orientation to daily occupational performance. Phys Occup Ther Pediatr. Nov. 2010;30(4):264-76. X-1, X-3. [pmid: 20822395].
3641 Rodrigue JR, Morgan SB, Geffken GR. A comparative evaluation of adaptive behavior in children and adolescents with autism, Down syndrome, and normal development. J Autism Dev Disord. Jun. 1991;21(2):187-96. X-1, X-3, X-4. [pmid: 1830878].
3642 Roeyers H. The influence of nonhandicapped peers on the social interactions of children with a pervasive development disorder. J Autism Dev Disord. Jun. 1996;26(3):303-20. X-1, X-3, X-4. [pmid: 8792262].
3643 Rogan P, Banks B, Howard M. Workplace supports in practice: as little as possible, as much as necessary. Focus Autism Dev Disabil. Spr. 2000;15(1):2-11. X-1, X-3, X-4.
3644 Rogers EJ. Has enhanced folate status during pregnancy altered natural selection and possibly autism prevalence? A closer look at a possible link. Med Hypotheses. Sep. 2008;71(3):406-10. X-2, X-4. [pmid: 18514430].
3645 Rogers EL. Functional behavioral assessment and children with autism: working as a team. Focus Autism Dev Disabil. Win. 2001;16(4):228-31. X-1, X-2, X-3, X-4.
3646 Rogers MF, Myles BS. Using social stories and comic strip conversations to interpret social situations for an adolescent with asperger syndrome. Interv School Clinic. May. 2001;36(5):310-13. X-3.
3647 Rogers SJ. Brief report: early intervention in autism. J Autism Dev Disord. Apr. 1996;26(2):243-46. X-1, X-2, X-3, X-4. [pmid: 8744493].
3648 Rogers SJ. Empirically supported comprehensive treatments for young children with autism. J Clin Child Psychol. Special Issue: Empirically supported psychosocial interventions for children. Jun. 1998;27(2):168-79. X-2, X-4. [pmid: 9648034].
3649 Rogers SJ. Intervention for young children with autism: from research to practice. Infants Young Child. Oct. 1999;12(2):1-16. X-1, X-2, X-3, X-4.
3650 Rogers SJ. Interventions that facilitate socialization in children with autism. J Autism Dev Disord. Oct. 2000;30(5):399-409. X-2. [pmid: 11098875].
3651 Rogers SJ, DiLalla DL. A comparative study of the effects of a developmentally based instructional model on young children with autism and young children with other disorders of behavior and development. Topics Early Child Spec Educ. Sum. 1991;11(2):29-47. X-1, X-3, X-4.
3652 Rogers SJ, Hayden D, Hepburn S, et al. Teaching young nonverbal children with autism useful speech: a pilot study of the Denver Model and PROMPT interventions. J Autism Dev Disord. Nov. 2006;36(8):1007-24. X-1, X-3, X-4. [pmid: 16845576].
3653 Rogers SJ, Lewis H. An effective day treatment model for young children with pervasive developmental disorders. J Am Acad Child Adolesc Psychiatry. Mar. 1989;28(2):207-14. X-1, X-3, X-4. [pmid: 2466824].
3654 Rogers SJ, Vismara LA. Evidence-based comprehensive treatments for early autism. J Clin Child Adolesc Psychol. Jan. 2008;37(1):8-38. X-2, X-4. [pmid: 18444052].
3655 Rogers-Adkinson DL, Ochoa TA, Delgado B. Developing cross-cultural competence: serving families of children with significant developmental needs. Focus Autism Dev Disabil. Spr. 2003;18(1):4-8. X-1, X-2, X-3, X-4.
3656 Rojahn J, Matson JL, Naglieri JA, et al. Relationships between psychiatric conditions and behavior problems among adults with mental retardation. Am J Ment Retard. Jan. 2004;109(1):21-33. X-4. [pmid: 14651452].
3657 Rojahn J, McGonigle JJ, Curcio C, et al. Suppression of pica by water mist and aromatic ammonia: a comparative analysis. Behav Modif. Jan. 1987;11(1):65-74. X-3. [pmid: 3508376].
3658 Rojahn J, Wilkins J, Matson JL, et al. A comparison of adults with intellectual disabilities with and without ASD on parallel measures of challenging behaviour: the Behavior Problems Inventory-01 (BPI-01) and Autism Spectrum Disorders-Behavior Problems for Intellectually Disabled Adults (ASD-BPA). J Appl Res Intellect Disabil. Mar. 2010;23(2):179-85. X-4.
3659 Rollins PR. Early pragmatic accomplishments and vocabulary development in preschool children with autism. Am J of Speech Lang Pathol. 1999;8(2):181-90. X-1, X-3, X-4.
3660 Rollins PR, Wambacq I, Dowell D, et al. An intervention technique for children with autistic spectrum disorder: joint attentional routines. J Commun Disord. Mar–Apr. 1998;31(2):181-93. X-1, X-2, X-3, X-4. [pmid: 9549673].
3661 Roll-Pettersson L, Ala’i-Rosales S. Using blended and guided technologies in a university course for scientist-practitioners: teaching applied behaviour analysis to autism professionals. J Intellect Disabil. Jun. 2009;13(2):113-42. X-4. [pmid: 19628533].
3662 Romanczyk RG. Micro-computers and behavior therapy: a powerful alliance. the Behavior Therapist. Apr. 1984;7(4):59-64. X-1, X-3, X-4.
3663 Ronder RW, Kastner T, Parker SJ, et al. Serving people with developmental disabilities in Medicaid managed care. Manag Care Q. Spring. 1999;7(2):23-30. X-2, X-4. [pmid: 10537636].
3664 Ropar D, Mitchell P, Ackroyd K. Do children with autism find it difficult to offer alternative interpretations to ambiguous figures?. Br J Dev Psychol. 2003;21(Part 3):387-95. X-4.
3665 Roscoe EM, Rooker GW, Pence ST, et al. Assessing the utility of a demand assessment for functional analysis. J Appl Behav Anal. Winter. 2009;42(4):819-25. X-3, X-4. [pmid: 20514188].
3666 Rose M, Torgerson NG. A behavioral approach to vision and autism. J Optom Vis Dev. Win. 1994;25(4):269-75.
3667 Rose R, Anketell C. The benefits of social skills groups for young people with autism spectrum disorder: a pilot study. Child Care Prac. Apr. 2009;15(2):127-44. X-1, X-3.
3668 Rose S, Massey P. Adventurous outdoor activities: an investigation into the benefits of adventure for seven people with severe learning difficulties. Ment Handicap Res. 1993;6(4):287-302. X-3.
3669 Rosen CE. Treatment foster home care for autistic children. Child Youth Serv. 1989;12(1–2):121-32. X-1, X-2, X-3, X-4.
3670 Rosenberg RE, Mandell DS, Farmer JE, et al. Psychotropic medication use among children with autism spectrum disorders enrolled in a national registry, 2007–2008. J Autism Dev Disord. Mar. 2010;40(3):342-51. X-1, X-3, X-4. [pmid: 19806445].
3671 Rosenthal-Malek A, Mitchell S. Brief report: the effects of exercise on the self-stimulatory behaviors and positive responding of adolescents with autism. J Autism Dev Disord. Apr. 1997;27(2):193-202. X-3. [pmid: 9105970].
3672 Rosenwasser B, Axelrod S. The contribution of applied behavior analysis to the education of people with autism. Behav Modif. Oct. 2001;25(5):671-7. X-2. [pmid: 11642227].
3673 Rosenwasser B, Axelrod S. More contributions of applied behavior analysis to education of people with autism. Behav Modif. Jan. 2002;26(1):3-8. X-2. [pmid: 11799653].
3674 Roser K, Mishne J. Beginning treatment of an autistic child from an intersubjective perspective. Psychoanal Rev. Jun. 1996;83(3):343-62. X-4. [pmid: 8853207].
3675 Rosinski D. The miraculous and the mundane. Focus Autism Dev Disabil. Spr. 2001;16(1):12-6. X-1, X-2, X-3, X-4.
3676 Ross DE, Greer RD. Generalized imitation and the mand: inducing first instances of speech in young children with autism. Res Dev Disabil. Jan–Feb. 2003;24(1):58-74. X-1, X-3, X-4. [pmid: 12553968].
3677 Ross DL, Klykylo WM, Hitzemann R. Reduction of elevated CSF beta-endorphin by fenfluramine in infantile autism. Pediatr Neurol. Mar–Apr. 1987;3(2):83-6. X-3. [pmid: 2977280].
3678 Rossetti ZS, Goessling DP. Paraeducators’ roles in facilitating friendships between secondary students with and without autism spectrum disorders or developmental disabilities. Teach Except Child. Jul–Aug. 2010;42(6):64-70. X-1, X-2, X-3, X-4.
3679 Rossi EL, Rossi KL. The neuroscience of observing consciousness & mirror neurons in therapeutic hypnosis. Am J Clin Hypn. Apr. 2006;48(4):263-78. X-2, X-4. [pmid: 16696558].
3680 Rossi PG, Posar A, Parmeggiani A, et al. Niaprazine in the treatment of autistic disorder. J Child Neurol. Aug. 1999;14(8):547-50. X-1, X-3, X-4. [pmid: 10456769].
3681 Rossignol DA. Hyperbaric oxygen therapy might improve certain pathophysiological findings in autism. Med Hypotheses. 2007;68(6):1208-27. X-2, X-4. [pmid: 17141962].
3682 Rossignol DA, Frye RE. Melatonin in autism spectrum disorders: a systematic review and meta-analysis. Dev Med Child Neurol. Sep. 2011;53(9):783-92. X-1, X-2, X-3, X-4. [pmid: 21518346].
3683 Rossignol DA, Rossignol LW, James SJ, et al. The effects of hyperbaric oxygen therapy on oxidative stress, inflammation, and symptoms in children with autism: an open-label pilot study. BMC Pediatr. 2007;7:36. X-3. [pmid: 18005455].
3684 Rossignol DA, Rossignol LW, Smith S, et al. Hyperbaric treatment for children with autism: a multicenter, randomized, double-blind, controlled trial. BMC Pediatr. 2009;9:21. X-1, X-3, X-4. [pmid: 19284641].
3685 Ross-Swain D. The effects of auditory stimulation on auditory processing disorder: a summary of the findings. Int J Listening. 2007;21(2):140-55. X-1, X-3, X-4.
3686 Roth MP, Williams KE, Paul CM. Treating food and liquid refusal in an adolescent with asperger’s disorder. Clin Case Stud. Aug. 2010;9(4):260-72. X-1, X-3, X-4.
3687 Rotheram-Fuller E, Kasari C, Chamberlain B, et al. Social involvement of children with autism spectrum disorders in elementary school classrooms. J Child Psychol Psychiatry. Nov. 2010;51(11):1227-34. X-1, X-3, X-4. [pmid: 20673234].
3688 Rotheram-Fuller E, MacMullen L. Cognitive-behavioral therapy for children with autism spectrum disorders. Psychol Sch. Mar. 2011;48(3):263-71. X-1, X-2, X-3, X-4.
3689 Rothman SM. Health advocacy organizations and evidence-based medicine. JAMA. Jun. 22. 2011;305(24):2569-70. X-1, X-2, X-3, X-4. [pmid: 21693747].
3690 Rotholz DA, Luce SC. Alternative reinforcement strategies for the reduction of self-stimulatory behavior in autistic youth. Educ Treat Children. Fal. 1983;6(4):363-77. X-1, X-3, X-4.
3691 Rotman A. Blood platelets in psychopharmacological research. Prog Neuropsychopharmacol Biol Psychiatry. 1983;7(2–3):135-51. X-1, X-2, X-3, X-4. [pmid: 6310688].
3692 Rotman A, Caplan R, Szekely GA. Platelet uptake of serotonin in psychotic children. Psychopharmacol (Berl). 1980;67(3):245-8. X-1, X-2, X-3, X-4. [pmid: 6770403].
3693 Rousseau MK, Krantz PJ, Poulson CL, et al. Sentence combining as a technique for increasing adjective use in writing by students with autism. Res Dev Disabil. Jan–Feb. 1994;15(1):19-37. X-3. [pmid: 8190970].
3694 Rowland GH. Polydipsia in adults with learning disabilities: prevalence, presentation and aetiology. Br J Dev Disabil. 1999;45(Part 1(88)):52-62. X-4.
3695 Rowles BM, Findling RL. Review of pharmacotherapy options for the treatment of attention-deficit/hyperactivity disorder (adhd) and adhd-like symptoms in children and adolescents with developmental disorders. Dev Disabil Res Rev. 2010;16(3):273-82. X-1, X-2, X-3. [pmid: 20981766].
3696 Roy H, Gillett T. E-mail: a new technique for forming a therapeutic alliance with high-risk young people failing to engage with mental health services? A case study. Clin Child Psychol Psychiatry. Jan. 2008;13(1):95-103. X-3. [pmid: 18411868].
3697 Roy M, Dillo W, Bessling S, et al. Effective methylphenidate treatment of an adult aspergers syndrome and a comorbid adhd: a clinical investigation with fMRI. J Atten Disord. 2009;12(4):381-5. X-3. [pmid: 19095892].
3698 Rozelle D. “Wheel inside, a real moveable color”, an autistic boy’s search for self through the use of symbolic imagery. Pratt Institute Creative Arts Ther Rev. 1982;3:1-10. X-1, X-3, X-4.
3699 Ruberman L. Psychotherapy of children with pervasive developmental disorders. Am J Psychother. 2002;56(2):262-74. X-2. [pmid: 12125303].
3700 Rubin DM, Feudtner C, Localio R, et al. State variation in psychotropic medication use by foster care children with autism spectrum disorder. Pediatr. Aug. 2009;124(2):e305-12. X-1, X-3, X-4. [pmid: 19620187].
3701 Ruble L, McDuffie A, King AS, et al. Caregiver responsiveness and social interaction behaviors of young children with autism. Topics Early Child Spec Educ. Nov. 2008;28(3):158-70. X-1, X-3, X-4.
3702 Ruble L, Willis H, Crabtree VM. Social skills group therapy for autism spectrum disorders. Clin Case Stud. Aug. 2008;7(4):287-300. X-1, X-3, X-4.
3703 Ruble LA, Dalrymple NJ. COMPASS: a parent-teacher collaborative model for students with autism. Focus Autism Dev Disabil. Sum. 2002;17(2):76-83. X-1, X-2, X-3, X-4.
3704 Ruble LA, Dalrymple NJ, McGrew JH. The effects of consultation on individualized education program outcomes for young children with autism: the collaborative model for promoting competence and success. J Early Interv. Sep. 2010;32(4):286-301. X-1, X-3, X-4. [pmid: 21691449].
3705 Ruble LA, Heflinger CA, Renfrew JW, et al. Access and service use by children with autism spectrum disorders in Medicaid managed care. J Autism Dev Disord. Feb. 2005;35(1):3-13. X-4. [pmid: 15796117].
3706 Ruble LA, McGrew J, Dalrymple N, et al. Examining the quality of IEPS for young children with autism. J Autism Dev Disord. Dec. 2010;40(12):1459-70. X-1, X-3, X-4. [pmid: 20373007].
3707 Ruble LA, Robson DM. Individual and environmental determinants of engagement in autism. J Autism Dev Disord. Sep. 2007;37(8):1457-68. X-4. [pmid: 17151800].
3708 Ruble LA, Usher EL, McGrew JH. Preliminary investigation of the sources of self-efficacy among teachers of students with autism. Focus Autism Dev Disabil. Jun. 2011;26(2):67-74. X-1, X-3, X-4.
3709 Ruedrich SL, Wilkinson L. Atypical unipolar depression in mentally retarded patients: Amoxapine treatment. J Nerv Ment Dis. Mar. 1992;180(3):206-7. X-3. [pmid: 1588341].
3710 Ruef MB, Turnbull AP. Stakeholder opinions on accessible informational products helpful in building positive, practical solutions to behavioral challenges of individuals with mental retardation and/or autism. Educ Train Ment Retard Dev Disabil. Dec. 2001;36(4):441-56. X-1, X-3, X-4.
3711 Rugino TA, Janvier YM. Aripiprazole in children and adolescents: clinical experience. J Child Neurol. Jul. 2005;20(7):603-10. X-3. [pmid: 16159529].
3712 Rugino TA, Samsock TC. Levetiracetam in autistic children: an open-label study. J Dev Behav Pediatr. Aug. 2002;23(4):225-30. X-1, X-3, X-4. [pmid: 12177568].
3713 Runco MA, Schreibman L. Parental judgments of behavior therapy efficacy with autistic children: a social validation. J Autism Dev Disord. Sep. 1983;13(3):237-48. X-1, X-3, X-4. [pmid: 6643371].
3714 Runco MA, Schreibman L. Socially validating behavioral objectives in the treatment of autistic children. J Autism Dev Disord. Mar. 1987;17(1):141-7. X-1, X-3, X-4. [pmid: 3571138].
3715 Runco MA, Schreibman L. Children’s judgments of autism and social validation of behavior therapy efficacy. Behav Ther. Fal. 1988;19(4):565-76. X-1, X-3, X-4.
3716 Russell G, Ford T, Steer C, et al. Identification of children with the same level of impairment as children on the autistic spectrum, and analysis of their service use. J Child Psychol Psychiatry. Jun. 2010;51(6):643-51. X-1, X-3, X-4. [pmid: 20345841].
3717 Russell G, Kelly S. Looking beyond risk: A study of lay epidemiology of childhood disorders. Health Risk Soc. 2011;13(2):129-45. X-1, X-3, X-4.
3718 Russell RL, Bryant FB, Estrada AU. Confirmatory P-technique analyses of therapist discourse: high-versus low-quality child therapy sessions. J Consult Clin Psychol. Dec. 1996;64(6):1366-76. X-4. [pmid: 8991323].
3719 Russo N, Foxe JJ, Brandwein AB, et al. Multisensory processing in children with autism: high-density electrical mapping of auditory-somatosensory integration. Autism Res. Oct. 2010;3(5):253-67. X-3, X-4. [pmid: 20730775].
3720 Russo N, Larson C, Kraus N. Audio-vocal system regulation in children with autism spectrum disorders. Exp Brain Res. Jun. 2008;188(1):111-24. X-1, X-3, X-4. [pmid: 18347784].
3721 Russo N, Nicol T, Trommer B, et al. Brainstem transcription of speech is disrupted in children with autism spectrum disorders. Dev Sci. Jul. 2009;12(4):557-67. X-2, X-4. [pmid: 19635083].
3722 Russo NM, Hornickel J, Nicol T, et al. Biological changes in auditory function following training in children with autism spectrum disorders. Behav Brain Funct. 2010;6:60. X-3. [pmid: 20950487].
3723 Russo NM, Skoe E, Trommer B, et al. Deficient brainstem encoding of pitch in children with autism spectrum disorders. Clin Neurophysiol. Aug. 2008;119(8):1720-31. X-4. [pmid: 18558508].
3724 Rust J, Smith A. How should the effectiveness of social stories to modify the behaviour of children on the autistic spectrum be tested?. Autism. 2006;10(2):125-38. X-2, X-4. [pmid: 16613863].
3725 Rutherford MD, Young GS, Hepburn S, et al. A longitudinal study of pretend play in autism. J Autism Dev Disord. Jul. 2007;37(6):1024-39. X-4. [pmid: 17146707].
3726 Rutter M. Autism research: prospects and priorities. J Autism Dev Disord. Apr. 1996;26(2):257-75. X-1, X-2, X-3, X-4. [pmid: 8744496].
3727 Rutter M, Kreppner J, Croft C, et al. Early adolescent outcomes of institutionally deprived and non-deprived adoptees. III. Quasi-autism. J Child Psychol Psychiatry. Dec. 2007;48(12):1200-7. X-4. [pmid: 18093025].
3728 Rutter M, Sonuga-Barke EJ, Castle J. Investigating the impact of early institutional deprivation on development: background and research strategy of the English and Romanian Adoptees (ERA) Study. Monogr Soc Res Child Dev. Apr. 2010;75(1):1-20. X-1, X-2, X-3, X-4. [pmid: 20500631].
3729 Rydell PJ, Mirenda P. Effects of high and low constraint utterances on the production of immediate and delayed echolalia in young children with autism. J Autism Dev Disord. Dec. 1994;24(6):719-35. X-4. [pmid: 7844096].
3730 Ryden E, Johansson C, Blennow K, et al. Lower CSF HVA and 5-HIAA in bipolar disorder type 1 with a history of childhood ADHD. J Neural Transm. Dec. 2009;116(12):1667-74. X-4. [pmid: 19756368].
3731 Sabbagh MA, Taylor M. Neural correlates of theory-of-mind reasoning: an event-related potential study. Psychol Sci. Jan. 2000;11(1):46-50. X-4. [pmid: 11228842].
3732 Sabo RM. Autism consumer health web sites: are readability levels too high?. J Consum Health Internet. 2008;12(4):337-48. X-1, X-3, X-4.
3733 Senechal C, Fontaine C, Larivee S, et al. Insertion professionnelle des adultes québécois ayant un trouble autistique ou un syndrome d’Asperger. Sante Mentale au Quebec. 2011;36(1):181-99. X-1, X-2, X-3, X-4, X-5. [pmid: 21983910].
3734 Saegusa T. The providence of nature: teaching autistic children. Educ Forum. Win. 1991;55(2):139-53. X-1, X-3, X-4.
3735 Saemundsen E, Juliusson H, Hjaltested S, et al. Prevalence of autism in an urban population of adults with severe intellectual disabilities--a preliminary study. J Intellect Disabil Res. Aug. 2010;54(8):727-35. X-4. [pmid: 20633201].
3736 Saffari M. A loving challenge. Rehab Manag. Nov. 18. 2006;19(9):20. X-2. [pmid: 17131802].
3737 Safran SP. Asperger syndrome: the emerging challenge to special education. Except Child. Win. 2001;67(2):151-60. X-1, X-2, X-3, X-4.
3738 Safran SP. Why youngsters with autistic spectrum disorders remain underrepresented in special education. Remedial Spec Educ. 2008;29(2):90-5. X-4.
3739 Safran SP, Safran JS, Ellis K. Intervention ABCs for children with asperger syndrome. Top Lang Disord. Apr–Jun. 2003;23(2):154-65. X-1, X-2, X-3, X-4.
3740 Sahley TL, Panksepp J. Brain opioids and autism: an updated analysis of possible linkages. J Autism Dev Disord. Jun. 1987;17(2):201-16. X-1, X-2, X-3, X-4. [pmid: 3038836].
3741 Sainato DM, Goldstein H, Strain PS. Effects of self-evaluation on preschool children’s use of social interaction strategies with their classmates with autism. J Appl Behav Anal. Spring. 1992;25(1):127-41. X-1, X-3, X-4. [pmid: 1582962].
3742 Sainato DM, Strain PS, Lefebvre D, et al. Facilitating transition times with handicapped preschool children: a comparison between peer-mediated and antecedent prompt procedures. J Appl Behav Anal. Fall. 1987;20(3):285-91. X-1, X-3, X-4. [pmid: 3667478].
3743 Sainato DM, Strain PS, Lefebvre D, et al. Effects of self-evaluation on the independent work skills of preschool children with disabilities. Except Child. Apr. 1990;56(6):540-9. X-1, X-3, X-4. [pmid: 2332024].
3744 Salamanca AA. Psychotherapy treatment program in a group of adults with high-functioning autism spectrum disorder. Actas Esp Psiquiatr. Mar. 2010;38(2):94-100. X-5. [pmid: 20976638].
3745 Saldana D, Alvarez RM, Lobaton S, et al. Objective and subjective quality of life in adults with autism spectrum disorders in southern Spain. Autism. May. 2009;13(3):303-16. X-4. [pmid: 19369390].
3746 Salem S, Fazzio D, Arnal L, et al. A self-instructional package for teaching university students to conduct discrete-trials teaching with children with autism. J Dev Disabil. 2009;15(1):21-9. X-1, X-3, X-4.
3747 Sallows G. Educational interventions for children with autism in the UK. Early Child Dev Care. Aug. 2000;163:25-47. X-1, X-2, X-3, X-4.
3748 Sallows GO, Graupner TD. Intensive behavioral treatment for children with autism: four-year outcome and predictors. Am J Ment Retard. Nov. 2005;110(6):417-38. X-1, X-3, X-4. [pmid: 16212446].
3749 Salmon G, Cleave H, Samuel C. Development of multi-agency referral pathways for attention-deficit hyperactivity disorder, developmental coordination disorder and autistic spectrum disorders: reflections on the process and suggestions for new ways of working. Clin Child Psychol Psychiatry. Jan. 2006;11(1):63-81. X-2, X-4. [pmid: 17087487].
3750 Saloviita T. Dry bed training method in the elimination of bed-wetting in two adults with autism and severe mental retardation. Cogn Behav Ther. 2002;31(3):135-40. X-1, X-3, X-4.
3751 Salt J, Sellars V, Shemilt J, et al. The Scottish Centre for autism preschool treatment programme. I: a developmental approach to early intervention. Autism. Dec. 2001;5(4):362-73. X-2. [pmid: 11777254].
3752 Salt J, Shemilt J, Sellars V, et al. The Scottish Centre for Autism preschool treatment programme. Autism. Mar. 2002;6(1):33-46. X-1, X-3, X-4. [pmid: 11918108].
3753 Salt J, Shemilt J, Sellars V, et al. The Scottish Centre for autism preschool treatment programme. II: the results of a controlled treatment outcome study. Autism. Mar. 2002;6(1):33-46. X-1, X-3, X-4. [pmid: 11918108].
3754 Sams MJ, Fortney EV, Willenbring S. Occupational therapy incorporating animals for children with autism: A pilot investigation. Am J Occup Ther. May–Jun. 2006;60(3):268-74. X-1, X-3, X-4. [pmid: 16776394].
3755 Samson F, Hyde KL, Bertone A, et al. Atypical processing of auditory temporal complexity in autistics. Neuropsychologia. Feb. 2011;49(3):546-55. X-4. [pmid: 21192958].
3756 Samyn V, Roeyers H, Bijttebier P. Effortful control in typically developing boys and in boys with ADHD or autism spectrum disorder. Res Dev Disabil. Mar–Apr. 2011;32(2):483-90. X-4. [pmid: 21255973].
3757 Sanchez LE, Adams PB, Uysal S, et al. A comparison of live and videotape ratings: clomipramine and haloperidol in autism. Psychopharmacol Bull. 1995;31(2):371-8. X-1, X-3, X-4. [pmid: 7491394].
3758 Sanchez LE, Campbell M, Small AM, et al. A pilot study of clomipramine in young autistic children. J Am Acad Child Adolesc Psychiatry. Apr. 1996;35(4):537-44. X-1, X-3, X-4. [pmid: 8919717].
3759 Sanchez-Valle E, Posada M, Villaverde-Hueso A, et al. Estimating the burden of disease for autism spectrum disorders in Spain in 2003. J Autism Dev Disord. Feb. 2008;38(2):288-96. X-4. [pmid: 17546489].
3760 Sander JL, Morgan SB. Family stress and adjustment as perceived by parents of children with autism or down syndrome: implications for intervention. Child Fam Behav Ther. 1997;19(4):15-32. X-4.
3761 Sandford JJ, Gralton E, Donovan WM. Can deception ever be justified on therapeutic grounds? An ethical case report. Psychiatric Bulletin. Jun. 2001;25(6):206-8. X-2, X-4.
3762 Sandler A. Placebo effects in developmental disabilities: implications for research and practice. Ment Retard Dev Disabil Res Rev. 2005;11(2):164-70. X-2, X-4. [pmid: 15977316].
3763 Sandler AD, Bodfish JW. Placebo effects in autism: lessons from secretin. J Dev Behav Pediatr. Oct. 2000;21(5):347-50. X-2. [pmid: 11064962].
3764 Sandler AD, Sutton KA, DeWeese J, et al. Lack of benefit of a single dose of synthetic human secretin in the treatment of autism and pervasive developmental disorder. N Engl J Med. Dec. 9. 1999;341(24):1801-6. X-1, X-3. [pmid: 10588965].
3765 Sandler RH, Finegold SM, Bolte ER, et al. Short-term benefit from oral vancomycin treatment of regressive-onset autism. J Child Neurol. Jul. 2000;15(7):429-35. X-1, X-3, X-4. [pmid: 10921511].
3766 Sandman CA. Beta-endorphin disregulation in autistic and self-injurious behavior: a neurodevelopmental hypothesis. Synapse. 1988;2(3):193-9. X-1, X-3, X-4. [pmid: 2463689].
3767 Sandman CA, Hetrick W, Talyor D, et al. Uncoupling of proopiomelanocortin (POMC) fragments is related to self-injury. Peptides. Jun. 2000;21(6):785-91. X-4. [pmid: 10958998].
3768 Sandman CA, Touchette P, Marion S, et al. Disregulation of proopiomelanocortin and contagious maladaptive behavior. Regul Pept. Oct. 15. 2002;108(2–3):179-85. X-1, X-3, X-4. [pmid: 12220743].
3769 Sandt D. Social stories for students with autism in physical education. J Phys Educ Recreat Dance. Aug. 2008;79(6):42-5. X-2, X-4.
3770 Sandt DDR, Frey GC. Comparison of physical activity levels between children with and without autistic spectrum disorders. Adapt Phys Activ Q. 2005;22(2):146-59. X-1, X-3, X-4.
3771 Sansa G, Carlson C, Doyle W, et al. Medically refractory epilepsy in autism. Epilepsia. Jun. 2011;52(6):1071-5. X-4. [pmid: 21671922].
3772 Sansosti FJ. Teaching social skills to children with autism spectrum disorders using tiers of support: a guide for school-based professionals. Psychol Sch. Mar. 2010;47(3):257-81. X-2.
3773 Sansosti FJ, Powell-Smith KA. Using social stories to improve the social behavior of children with asperger syndrome. J Posit Behav Interv. 2006;8(1):43-57. X-3.
3774 Sansosti FJ, Powell-Smith KA. Using computer-presented social stories and video models to increase the social communication skills of children with high-functioning autism spectrum disorders. J Posit Behav Interv. 2008;10(3):162-78. X-3.
3775 Santarcangelo S, Dyer K. Prosodic aspects of motherese: effects on gaze and responsiveness in developmentally disabled children. J Exp Child Psychol. Dec. 1988;46(3):406-18. X-3. [pmid: 3216186].
3776 Santarcangelo S, Dyer K, Luce SC. Generalized reduction of disruptive behavior in unsupervised settings through specific toy training. J Assoc Pers Sev Handicaps. Spr. 1987;12(1):38-44. X-3.
3777 Santosh PJ, Baird G. Pharmacotherapy of target symptoms in autistic spectrum disorders. Indian J Pediatr. May. 2001;68(5):427-31. X-2. [pmid: 11407159].
3778 Santosh PJ, Baird G, Pityaratstian N, et al. Impact of comorbid autism spectrum disorders on stimulant response in children with attention deficit hyperactivity disorder: a retrospective and prospective effectiveness study. Child Care Health Dev. Sep. 2006;32(5):575-83. X-1, X-3, X-4. [pmid: 16919137].
3779 Santosh PJ, Mijovic A. Does pervasive developmental disorder protect children and adolescents against drug and alcohol use?. Eur Child Adoles Psychiatry. Jun. 2006;15(4):183-8. X-4.
3780 Sarokoff RA, Sturmey P. The effects of behavioral skills training on staff implementation of discrete-trial teaching. J Appl Behav Anal. Winter. 2004;37(4):535-8. X-4. [pmid: 15669415].
3781 Sarokoff RA, Sturmey P. The effects of instructions, rehearsal, modeling, and feedback on acquisition and generalization of staff use of discrete trial teaching and student correct responses. Res Autism Spectr Disord. Jan–Mar. 2008;2(1):125-36. X-1, X-3, X-4.
3782 Sarokoff RA, Taylor BA, Poulson CL. Teaching children with autism to engage in conversational exchanges: script fading with embedded textual stimuli. J Appl Behav Anal. Spr. 2001;34(1):81-4. X-1, X-3, X-4. [pmid: 11317993].
3783 Sartawi AM. Educational and behavioural characteristics of autistic children in the United Arab Emirates. Int J Rehabil Res. Dec. 1999;22(4):337-9. X-4. [pmid: 10669987].
3784 Sasso GM, Mitchell VM, Struthers EM. Peer tutoring versus structured interaction activities: Effects on the frequency and topography of peer initiations. Behav Disord. Aug. 1986;11(4):249-59. X-1, X-3, X-4.
3785 Sasso GM, Reimers TM, Cooper LJ, et al. Use of descriptive and experimental analyses to identify the functional properties of aberrant behavior in school settings. J Appl Behav Anal. Winter. 1992;25(4):809-21. X-4. [pmid: 1478904].
3786 Satiansukpong N, Pongsaksri M, Sung-U S, et al. Thai elephant-assisted therapy program: the feasibility in assisting an individual with autism. WFOT Bulletin. 2008;58:17-26. X-7.
3787 Sawada M, Negoro H, Iida J, et al. Pervasive developmental disorder with attention deficit hyperactivity disorder-like symptoms and mismatch negativity. Psychiatry Clin Neurosci. Aug. 2008;62(4):479-81. X-4. [pmid: 18778448].
3788 Sawyer LM, Luiselli JK, Ricciardi JN, et al. Teaching a child with autism to share among peers in an integrated preschool classroom: acquisition, maintenance, and social validation. Educ Treat Children. Feb. 2005;28(1):1-10. X-1, X-3, X-4.
3789 Sawyer MG, Bittman M, La Greca AM, et al. Time demands of caring for children with autism: what are the implications for maternal mental health?. J Autism Dev Disord. May. 2010;40(5):620-8. X-1, X-4. [pmid: 19949845].
3790 Saxena S, Chawla PL. Childhood psychoses: a brief review. Indian J Pediatr. Mar–Apr. 1984;51(409):217-23. X-1, X-2, X-3, X-4. [pmid: 6209218].
3791 Sayers N, Oliver C, Ruddick L, et al. Stereotyped behaviour in children with autism and intellectual disability: an examination of the executive dysfunction hypothesis. J Intellect Disabil Res. Jul. 2011;55(7):699-709. X-3, X-4. [pmid: 21199048].
3792 Scahill L. How do I decide whether or not to use medication for my child with autism? Should I try behavior therapy first?. J Autism Dev Disord. Jul. 2008;38(6):1197-8. X-2. [pmid: 18463973].
3793 Scahill L, Aman MG, McDougle CJ, et al. Trial design challenges when combining medication and parent training in children with pervasive developmental disorders. J Autism Dev Disord. May. 2009;39(5):720-9. X-2. [pmid: 19096921].
3794 Scahill L, Aman MG, McDougle CJ, et al. A prospective open trial of guanfacine in children with pervasive developmental disorders. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):589-98. X-1, X-3. [pmid: 17069547].
3795 Scahill L, Jekel JF, Schilling LS. Screening child psychiatric inpatients for communication disorders: a pilot study. Arch Psychiatr Nurs. Feb. 1991;5(1):31-7. X-1, X-3, X-4. [pmid: 2039279].
3796 Scahill L, Koenig K, Carroll DH, et al. Risperidone approved for the treatment of serious behavioral problems in children with autism. J Child Adolesc Psychiatr Nurs. Aug. 2007;20(3):188-90. X-2. [pmid: 17688557].
3797 Scahill L, McCracken J, McDougle CJ, et al. Methodological issues in designing a multisite trial of risperidone in children and adolescents with autism. J Child Adolesc Psychopharmacol. Winter. 2001;11(4):377-88. X-2. [pmid: 11838820].
3798 Scahill L, McDougle CJ, Williams SK, et al. Children’s Yale-Brown Obsessive Compulsive Scale modified for pervasive developmental disorders. J Am Acad Child Adolesc Psychiatry. Sep. 2006;45(9):1114-23. X-4. [pmid: 16926619].
3799 Scanlon K. Art therapy with autistic children. Pratt Institute Creative Arts Ther Rev. 1993;14:34-43. X-1, X-3, X-4.
3800 Scarpa A, Reyes NM. Improving emotion regulation with CBT in young children with high functioning autism spectrum disorders: a pilot study. Behav Cogn Psychother. Jul. 2011;39(4):495-500. X-1, X-3, X-4. [pmid: 21457605].
3801 Scattone D. Social skills interventions for children with autism. Psychol Sch. Sep. 2007;44(7):717-26. X-2, X-4.
3802 Scattone D. Enhancing the conversation skills of a boy with asperger’s disorder through social stories and video modeling. J Autism Dev Disord. Feb. 2008;38(2):395-400. X-1, X-3, X-4. [pmid: 17546490].
3803 Scattone D, Tingstrom DH, Wilczynski SM. Increasing appropriate social interactions of children with autism spectrum disorders using social stories. Focus Autism Dev Disabil. Win. 2006;21(4):211-22. X-1, X-3, X-4.
3804 Scattone D, Wilczynski SM, Edwards RP, et al. Decreasing disruptive behaviors of children with autism using social stories. J Autism Dev Disord. Dec. 2002;32(6):535-43. X-1, X-3, X-4. [pmid: 12553590].
3805 Schaefer GB, Lutz RE. Diagnostic yield in the clinical genetic evaluation of autism spectrum disorders. Genet Med. Sep. 2006;8(9):549-56. X-4. [pmid: 16980810].
3806 Schall C. A Consumer’s Guide to Monitoring Psychotropic Medication for Individuals with Autism Spectrum Disorders. Focus Autism Dev Disabil. Win. 2002;17(4):229-35. X-1, X-3, X-4.
3807 Schall C, McDonough J. Autism spectrum disorderes in adolescense and early adulthood: characteristics and issues. Journal of Vocational Rehabilitation. 2010. 2010;32:81-8. X-1, X-2, X-3, X-4.
3808 Schaller J, Yang NK. Competitive employment for people with autism: correlates of successful closure in competitive and supported employment. Rehabil Couns Bull. Fal. 2005;49(1):4-16. X-4.
3809 Schatz J, Hamdan-Allen G. Effects of age and IQ on adaptive behavior domains for children with autism. J Autism Dev Disord. Feb. 1995;25(1):51-60. X-4. [pmid: 7608034].
3810 Schechtman MA. Scientifically unsupported therapies in the treatment of young children with autism spectrum disorders. Pediatr Ann. Aug. 2007;36(8):497-8. 500. 2. 4. 5. X-2, X-4. [pmid: 17849608].
3811 Scheeren AM, Begeer S, Banerjee R, et al. Can you tell me something about yourself?: self-presentation in children and adolescents with high functioning autism spectrum disorder in hypothetical and real life situations. Autism. Sep. 2010;14(5):457-73. X-4. [pmid: 20841344].
3812 Schepis MM, Reid DH, Fitzgerald JR, et al. A program for increasing manual signing by autistic and profoundly retarded youth within the daily environment. J Appl Behav Anal. Fall. 1982;15(3):363-79. X-3. [pmid: 7142061].
3813 Scherer NJ, Olswang LB. Using structured discourse as a language intervention technique with autistic children. J Speech Hear Disord. Aug. 1989;54(3):383-94. X-1, X-3, X-4. [pmid: 2755101].
3814 Schertz H, Robb M. Interventions for toddlers with autism: building on the parent-child relationship to promote joint attention. Young Except Child. 2006;9(3):20-7. X-1, X-2, X-3, X-4.
3815 Schertz HH, Baker C, Hurwitz S, et al. Principles of early intervention reflected in toddler res autism spectr disord. Topics Early Child Spec Educ. May. 2011;31(1):4-21. X-1, X-2, X-3, X-4.
3816 Schertz HH, Odom SL. Joint attention and early intervention with autism: a conceptual framework and promising approaches. J Early Interv. Fall. 2004;27(1):42-54. X-2, X-4.
3817 Schertz HH, Odom SL. Promoting joint attention in toddlers with autism: a parent-mediated developmental model. J Autism Dev Disord. Sep. 2007;37(8):1562-75. X-1, X-3, X-4. [pmid: 17096190].
3818 Scheuermann B, Webber J, Boutot EA, et al. Problems with personnel preparation in autism spectrum disorders. Focus Autism Dev Disabil. Fall. 2003;18(3):197-206. X-1, X-2, X-3, X-4.
3819 Schieve LA, Blumberg SJ, Rice C, et al. The relationship between autism and parenting stress. Pediatr. Feb. Suppl 1. 2007;119:S114-21. X-1, X-3, X-4. [pmid: 17272578].
3820 Schiff A, Tarbox J, Lanagan T, et al. Establishing compliance with liquid medication administration in a child with autism. J Appl Behav Anal. 2011;44(2):381-5. X-2, X-4. [pmid: 21709797].
3821 Schilling DL, Schwartz IS. Alternative seating for young children with autism spectrum disorder: effects on classroom behavior. J Autism Dev Disord. 2004;34(4):423-32. X-1, X-3, X-4. [pmid: 15449517].
3822 Schindler HR, Horner RH. Generalized reduction of problem behavior of young children with autism: building trans-situational interventions. Am J Ment Retard. Jan. 2005;110(1):36-47. X-1, X-3, X-4. [pmid: 15568965].
3823 Schleien SJ, et al. Effects of social play activities on the play behavior of children with autism. J Leisure Res. 1990;22(4):317-28. X-1, X-3, X-4.
3824 Schleien SJ, Mustonen T, Rynders JE. Participation of children with autism and nondisabled peers in a cooperatively structured community art program. J Autism Dev Disord. Aug. 1995;25(4):397-413. X-1, X-3, X-4. [pmid: 7592251].
3825 Schleismann KD, Gillis JM. The treatment of social phobia in a young boy with asperger’s disorder. Cogn Behav Pract. Nov. 2011;18(4):515-29. X-1, X-3, X-4.
3826 Schlosser RW, Blischak DM. Effects of speech and print feedback on spelling by children with autism. J Speech Lang Hear Res. Aug. 2004;47(4):848-62. X-1, X-3, X-4. [pmid: 15324290].
3827 Schmidt GL, Rey MM, Oram Cardy JE, et al. Absence of M100 source asymmetry in autism associated with language functioning. Neuroreport. Jul. 15. 2009;20(11):1037-41. X-4. [pmid: 19491710].
3828 Schmidt H, Kern W, Giese R, et al. Intranasal insulin to improve developmental delay in children with 22q13 deletion syndrome: an exploratory clinical trial. J Med Genet. Apr. 2009;46(4):217-22. X-4. [pmid: 18948358].
3829 Schmidt JG, Dombvoy ML, Watkins K. Treatment of viral encephalitis organic personality disorder and autistic features with propranolol: a case report. J Neurol Rehabil. 1995;9(1):41-5. X-4.
3830 Schmit J, Alper S, Raschke D, et al. Effects of using a photographic cueing package during routine school transitions with a child who has autism. Ment Retard. Apr. 2000;38(2):131-7. X-1, X-3, X-4. [pmid: 10804703].
3831 Schmitt L, Heiss CJ, Campbell EE. A comparison of nutrient intake and eating behaviors of boys with and without autism. Topics in Clinical Nutrition. Jan–Mar. 23. 2008;2008(1):23-31. X-1, X-3, X-4.
3832 Schneider A, Hagerman RJ, Hessl D. Fragile X syndrome--from genes to cognition. Dev Disabil Res Rev. 2009;15(4):333-42. X-1, X-2, X-3, X-4. [pmid: 20014363].
3833 Schneider CK, Melmed RD, Barstow LE, et al. Oral human immunoglobulin for children with autism and gastrointestinal dysfunction: a prospective, open-label study. J Autism Dev Disord. Nov. 2006;36(8):1053-64. X-1, X-3, X-4. [pmid: 16845577].
3834 Schneider HD, Hopp JP. The use of the Bilingual Aphasia Test for assessment and transcranial direct current stimulation to modulate language acquisition in minimally verbal children with autism. Clin Linguist Phon. Jun. 2011;25(6–7):640-54. X-3. [pmid: 21631313].
3835 Schneider N, Goldstein H. Using social stories and visual schedules to improve socially appropriate behaviors in children with autism. J Posit Behav Interv. Jul. 2010;12(3):149-60. X-1, X-3, X-4.
3836 Schneiter R, Devine MA. Reduction of self-injurious behaviors of an individual with autism: use of a leisure communication book. Ther Recreation J. 3rd Qtr. 2001;35(3):207-19. X-3.
3837 Schopler E. Evolution in understanding and treatment of autism. Triangle. 1982;21(2–3):51-7. X-1. [pmid: 7164155].
3838 Schopler E. Treatment abuse and its reduction. J Autism Dev Disord. Jun. 1986;16(2):99-104. X-1, X-2, X-3, X-4. [pmid: 3722122].
3839 Schopler E. Specific and nonspecific factors in the effectiveness of a treatment system. Am Psychol. Apr. 1987;42(4):376-83. X-1, X-2, X-3, X-4. [pmid: 3605819].
3840 Schopler E. Collaboration between research professional and consumer. J Autism Dev Disord. Apr. 1996;26(2):277-80. X-1, X-3, X-4. [pmid: 8744497].
3841 Schopler E, Dalldorf J. Autism: definition, diagnosis, and management. Hosp Pract. Jun. 1980;15(6):64-73. X-1, X-2, X-3, X-4. [pmid: 7399485].
3842 Schopler E, Hennike JM. Past and present trends in residential treatment. J Autism Dev Disord. Sep. 1990;20(3):291-8. X-2, X-4. [pmid: 1699923].
3843 Schopler E, Mesibov G, Baker A. Evaluation of treatment for autistic children and their parents. J Am Acad Child Psychiatry. May. 1982;21(3):262-7. X-1, X-2, X-3, X-4. [pmid: 7096846].
3844 Schopler E, Olley JG. Public school programing for autistic children. Except Child. Mar. 1980;46(6):461-3. X-1, X-2, X-3, X-4. [pmid: 7363914].
3845 Schrandt JA, Townsend DB, Poulson CL. Teaching empathy skills to children with autism. J Appl Behav Anal. Spr. 2009;42(1):17-32. X-1, X-3, X-4. [pmid: 19721727].
3846 Schreck KA. It can be done: An example of a behavioral individualized education program (IEP) for a child with autism. Behav Int. Oct–Dec. 2000;15(4):279-300. X-1, X-3, X-4.
3847 Schreck KA, Mazur A. Behavior analyst use of and beliefs in treatments for people with autism. Behav Int. Jul. 2008;23(3):201-12. X-4.
3848 Schreck KA, Mulick JA. Parental report of sleep problems in children with autism. J Autism Dev Disord. Apr. 2000;30(2):127-35. X-1, X-3, X-4. [pmid: 10832777].
3849 Schreck KA, Mulick JA, Smith AF. Sleep problems as possible predictors of intensified symptoms of autism. Res Dev Disabil. Jan–Feb. 2004;25(1):57-66. X-4. [pmid: 14733976].
3850 Schreck KA, Williams K. Food preferences and factors influencing food selectivity for children with autism spectrum disorders. Res Dev Disabil: A Multidisciplinary Journal. Jul–Aug. 2006;27(4):353-63. X-4.
3851 Schreck KA, Williams K, Smith AF. A comparison of eating behaviors between children with and without autism. J Autism Dev Disord. Aug. 2004;34(4):433-8. X-4. [pmid: 15449518].
3852 Schreibman L. Brief Report: the case for social and behavioral intervention research. J Autism Dev Disord. Apr. 1996;26(2):247-50. X-1, X-2, X-3, X-4. [pmid: 8744494].
3853 Schreibman L. Intensive behavioral/psychoeducational treatments for autism: research needs and future directions. J Autism Dev Disord. Oct. 2000;30(5):373-8. X-2, X-4. [pmid: 11098871].
3854 Schreibman L, Charlop MH, Koegel RL. Teaching autistic children to use extra-stimulus prompts. J Exp Child Psychol. Jun. 1982;33(3):475-91. X-1, X-3. [pmid: 7097156].
3855 Schreibman L, O’Neill RE, Koegel RL. Behavioral training for siblings of autistic children. J Appl Behav Anal. Summer. 1983;16(2):129-38. X-3. [pmid: 6885667].
3856 Schreibman L, Stahmer AC, Barlett VC, et al. Brief report: toward refinement of a predictive behavioral profile for treatment outcome in children with autism. Res Autism Spectr Disord. Jan. 2009;3(1):163-72. X-1, X-2, X-3, X-4. [pmid: 20046210].
3857 Schreibman L, Whalen C, Stahmer AC. The use of video priming to reduce disruptive transition behavior in children with autism. J Posit Behav Interv. Win. 2000;2(1):3-11. X-1, X-3, X-4.
3858 Schroeder CS, Schroeder SR. The future of children is now. J Autism Dev Disord. Sep. 1990;20(3):367-78. X-2, X-4. [pmid: 1699924].
3859 Schroeder SR, et al. Brief report: reliability and validity of instruments for assessing psychotropic medication effects on self-injurious behavior in mental retardation. J Autism Dev Disord. Feb. 1997;27(1):89-102. X-1, X-3, X-4. [pmid: 9018584].
3860 Schroeder SR, LeBlanc JM, Mayo L. Brief report: a life-span perspective on the development of individuals with autism. J Autism Dev Disord. Apr. 1996;26(2):251-5. X-1, X-2, X-3, X-4. [pmid: 8744495].
3861 Schroeder SR, Mulick JA, Rojahn J. The definition, taxonomy, epidemiology, and ecology of self-injurious behavior. J Autism Dev Disord. Dec. 1980;10(4):417-32. X-1, X-2, X-3, X-4. [pmid: 6985454].
3862 Schubert A. “I want to talk like everyone”: on the use of multiple means of communication. Ment Retard. Oct. 1997;35(5):347-54. X-4. [pmid: 9339063].
3863 Schultz ST. Can autism be triggered by acetaminophen activation of the endocannabinoid system?. Acta Neurobiol Exp (Wars). 2010;70(2):227-31. X-4. [pmid: 20628445].
3864 Schultz ST, Klonoff-Cohen HS, Wingard DL, et al. Acetaminophen (paracetamol) use, measles-mumps-rubella vaccination, and autistic disorder: the results of a parent survey. Autism. 2008;12(3):293-307. X-4. [pmid: 18445737].
3865 Schultz TR, Schmidt CT, Stichter JP. A review of parent education programs for parents of children with autism spectrum disorders. Focus Autism Dev Disabil. Jun. 2011;26(2):96-104. X-1, X-2, X-3, X-4.
3866 Schumacher BI, Rapp JT. Evaluation of the immediate and subsequent effects of response interruption and redirection on vocal stereotypy. J Appl Behav Anal. Fall. 2011;44(3):681-5. X-3. [pmid: 21941405].
3867 Schumacher K. Informed consent: should it be extended to vaccinations?. Thomas Jefferson Law Rev. Fall. 1999;22(1):89-119. X-1, X-2, X-3, X-4. [pmid: 15732182].
3868 Schuntermann P. Pervasive developmental disorder and parental adaptation: previewing and reviewing atypical development with parents in child psychiatric consultation. Harv Rev Psychiatry. Jan–Feb. 2002;10(1):16-27. X-1, X-3, X-4. [pmid: 11751642].
3869 Schwarte AR. Fragile X syndrome. Sch Psychol Q. Jun. 2008;23(2):290-300. X-2, X-4.
3870 Schwartz CB, Henderson HA, Inge AP, et al. Temperament as a predictor of symptomotology and adaptive functioning in adolescents with high-functioning autism. J Autism Dev Disord. Jun. 2009;39(6):842-55. X-1, X-3, X-4. [pmid: 19165586].
3871 Schwartz H, Drager KD. Training and knowledge in autism among speech-language pathologists: a survey. Lang Speech Hear Serv Sch. Jan. 2008;39(1):66-77. X-4. [pmid: 18162649].
3872 Schwartz IS, Anderson SR, Halle JW. Training teachers to use naturalistic time delay: effects on teacher behavior and on the language use of students. J Assoc Pers Sev Handicaps. Spr. 1989;14(1):48-57. X-1, X-3, X-4.
3873 Schwartz IS, Boulware G-L, McBride BJ, et al. Functional assessment strategies for young children with autism. Focus Autism Dev Disabil. Win. 2001;16(4):222-27. 31. X-1, X-3, X-4.
3874 Schwartz IS, Sandall SR. Is autism the disability that breaks part c? A commentary on “infants and toddlers with autism spectrum disorder: early identification and early intervention,” by Boyd, Odom, Humphreys, and Sam. J Early Interv. 2010;32(2):105-9. X-2, X-4.
3875 Schwartz IS, Sandall SR, Garfinkle AN, et al. Outcomes for children with autism: three case studies. Topics Early Child Spec Educ. Fal. 1998;18(3):132-43. X-1, X-3, X-4.
3876 Schwartz IS, Sandall SR, McBride BJ, et al. Project DATA (developmentally appropriate treatment for autism): an inclusive school-based approach to educating young children with autism. Topics Early Child Spec Educ. Sep. 2004;24(3):156-68. X-1, X-4.
3877 Schwichtenberg A, Poehlmann J. Applied behaviour analysis: does intervention intensity relate to family stressors and maternal well-being?. J Intellect Disabil Res. Aug. 2007;51(Pt 8):598-605. X-1, X-3, X-4. [pmid: 17598873].
3878 Scifo R, Batticane N, Quattropani MC, et al. A double-blind trial with naltrexone in autism. Brain Dysfunction. Nov–Dec. 1991;4(6):301-7. X-1, X-3.
3879 Scifo R, Cioni M, Nicolosi A, et al. Opioid-immune interactions in autism: behavioural and immunological assessment during a double-blind treatment with naltrexone. Ann Ist Super Sanita. 1996;32(3):351-9. X-3. [pmid: 9028057].
3880 Scolnick B. Effects of electroencephalogram biofeedback with Asperger’s syndrome. Int J Rehabil Res. Jun. 2005;28(2):159-63. X-3. [pmid: 15900187].
3881 Scott DW, Eames P. Use of sulpiride in a case of atypical autism. J Autism Dev Disord. Mar. 1988;18(1):144-6. X-3. [pmid: 3372456].
3882 Scott FJ, Baron-Cohen S, Bolton P, et al. The CAST (Childhood Asperger Syndrome Test): preliminary development of a UK screen for mainstream primary-school-age children. Autism. Mar. 2002;6(1):9-31. X-4. [pmid: 11918111].
3883 Scott MA, Fletcher JM, Brookshire BL, et al. Memory functions in children with early hydrocephalus. Neuropsychol. Oct. 1998;12(4):578-89. X-4. [pmid: 9805328].
3884 Scragg P, Shah A. Prevalence of asperger's syndrome in a secure hospital. Br J Psychiatry. Nov. 1994;165(5):679-82. X-4. [pmid: 7794327].
3885 Seabert H, Eastwood EC, Harris A. A multiprofessional children's feeding clinic. J Fam Health Care. 2005;15(3):72-4. X-2, X-4. [pmid: 16094900].
3886 Seal BC, Bonvillian JD. Sign language and motor functioning in students with autistic disorder. J Autism Dev Disord. Aug. 1997;27(4):437-66. X-4. [pmid: 9261668].
3887 Searles HF. Separation and loss in psychoanalytic therapy with borderline patients: further remarks. Am J Psychoanal. Spring. 1985;45(1):9-34. X-1, X-2, X-3, X-4. [pmid: 3993826].
3888 Sebestik J, Garralda ME. Survey of difficult to contain and treat children and adolescents. Arch Dis Child. Jul. 1996;75(1):78-81. X-1, X-3, X-4. [pmid: 8813878].
3889 Secan KE, Egel AL, Tilley CS. Acquisition, generalization, and maintenance of question-answering skills in autistic children. J Appl Behav Anal. Summer. 1989;22(2):181-96. X-1, X-3, X-4. [pmid: 2745239].
3890 Seery ME, Kretschmer RR Jr, Elgas PM. I have something to show you: a qualitative study of the interactions of mothers and their young sons diagnosed with autism. Infant-Toddler Interv. 1998;8(1):67-84. X-1, X-3, X-4.
3891 Seida JK, Ospina MB, Karkhaneh M, et al. Systematic reviews of psychosocial interventions for autism: an umbrella review. Dev Med Child Neurol. Feb. 2009;51(2):95-104. X-1, X-2, X-3, X-4. [pmid: 19191842].
3892 Seiverling L, Hendy HM, Williams K. The screening tool of feeding problems applied to children (step-child): psychometric characteristics and associations with child and parent variables. Res Dev Disabil. May–Jun. 2011;32(3):1122-9. X-1, X-3, X-4. [pmid: 21316919].
3893 Seiverling L, Pantelides M, Ruiz HH, et al. The effect of behavioral skills training with general-case training on staff chaining of child vocalizations within natural language paradigm. Behav Int. Feb. 2010;25(1):53-75. X-1, X-3, X-4.
3894 Seiverling LJ, Hendy HM, Williams KE. Child and parent variables associated with texture problems in children’s feeding. J Dev Phys Disabil. Aug. 2011;23(4):303-11. X-1, X-3, X-4.
3895 Selassie GR-H, Viggedal G, Olsson I, et al. Speech, language, and cognition in preschool children with epilepsy. Dev Med Child Neurol. Jun. 2008;50(6):432-8. X-4. [pmid: 18422681].
3896 Self T, Scudder RR, Weheba G, et al. A virtual approach to teaching safety skills to children with autism spectrum disorder. Top Lang Disord. 2007;27(3):242. X-3.
3897 Self TL, Coufal K, Parham DF. Allied healthcare providers' role in screening for autism spectrum disorder. Journal of Allied Health. Fal. 2010;39(3, Pt1):165-74. X-4. [pmid: 21174021].
3898 Self TL, Hale LS, Crumrine D. Pharmacotherapy and children with autism spectrum disorder: a tutorial for speech-language pathologists. Lang Speech Hear Serv Sch. Jul. 2010;41(3):367-75. X-1, X-2, X-3, X-4. [pmid: 20543026].
3899 Seltzer MM, Greenberg JS, Floyd F, et al. Life course impacts of parenting a child with a disability. Am J Ment Retard. 2001;106(3):265-86. X-1, X-3, X-4. [pmid: 11389667].
3900 Seltzer MM, Krauss MW, Shattuck PT, et al. The symptoms of autism spectrum disorders in adolescence and adulthood. J Autism Dev Disord. Dec. 2003;33(6):565-81. X-4. [pmid: 14714927].
3901 Seltzer MM, Shattuck P, Abbeduto L, et al. Trajectory of development in adolescents and adults with autism. Ment Retard Dev Disabil Res Rev. 2004;10(4):234-47. X-4. [pmid: 15666341].
3902 Sen E, Yurtsever S. Difficulties experienced by families with disabled children. J Spec Pediatr Nurs. Oct. 2007;12(4):238-52. X-4. [pmid: 17956372].
3903 Senel HG. Parents' views and experiences about complementary and alternative medicine treatments for their children with autistic spectrum disorder. J Autism Dev Disord. Apr. 2010;40(4):494-503. X-1, X-3. [pmid: 19904598].
3904 Sergeant L, Dewsbury G, Johnstone S. Supporting people with complex behavioural difficulties and autistic spectrum disorder in a community setting: an inclusive approach. Housing, Care & Support. 2007;10(1):23-30. X-1, X-2, X-3, X-4.
3905 Serra M, Minderaa RB, van Geert PL, et al. Social-cognitive abilities in children with lesser variants of autism: skill deficits or failure to apply skills?. Eur Child Adolesc Psychiatry. Dec. 1999;8(4):301-11. X-4. [pmid: 10654124].
3906 Serra M, Minderaa RB, van Geert PL, et al. Emotional role-taking abilities of children with a pervasive developmental disorder not otherwise specified. J Child Psychol Psychiatry. Mar. 1995;36(3):475-90. X-4. [pmid: 7782410].
3907 Serrano AC. Haloperidol -- its use in children. J Clin Psychiatry. Apr. 1981;42(4):154-6. X-1, X-2, X-3, X-4. [pmid: 6937455].
3908 Sersen EA, Heaney G, Clausen J, et al. Brainstem auditory-evoked responses with and without sedation in autism and Down's syndrome. Biol Psychiatry. Apr. 1990;27(8):834-40. X-4. [pmid: 2139583].
3909 Servais V. Some comments on context embodiment in zootherapy: The case of the Autidolfin project. Anthrozoös. 1999;12(1):5-15. X-3, X-4.
3910 Seth SB. Autism: The impact on caregivers. Journal of Psychosocial Research. Jan–Jun. 2011;6(1):149-56. X-4.
3911 Seung H, Rogalski Y, Shankar M, et al. The gluten- and casein-free diet and autism: communication outcomes from a preliminary double-blind clinical trial. J Med Speech Lang Pathol. Dec. 2007;15(4):337-45. X-1, X-3.
3912 Seung HK, Ashwell S, Elder JH, et al. Verbal communication outcomes in children with autism after in-home father training. J Intellect Disabil Res. Feb. 2006;50(Pt 2):139-50. X-1, X-3, X-4. [pmid: 16403202].
3913 Sevy S, Nathanson K, Visweswaraiah H, et al. The relationship between insight and symptoms in schizophrenia. Compr Psychiatry. Jan–Feb. 2004;45(1):16-9. X-4. [pmid: 14671732].
3914 Sgro MD, Barozzino T, Mirghani HM, et al. Pregnancy outcome post renal transplantation. Teratology. Jan. 2002;65(1):5-9. X-2, X-4. [pmid: 11835226].
3915 Shabani DB, Fisher WW. Stimulus fading and differential reinforcement for the treatment of needle phobia in a youth with autism. J Appl Behav Anal. Win. 2006;39(4):449-52. X-1, X-3, X-4. [pmid: 17236343].
3916 Shabani DB, Katz RC, Wilder DA, et al. Increasing social initiations in children with autism: effects of a tactile prompt. J Appl Behav Anal. Spring. 2002;35(1):79-83. X-1, X-3, X-4. [pmid: 11936550].
3917 Shabani DB, Wilder DA, Flood WA. Reducing stereotypic behavior through discrimination training, differential reinforcement of other behavior, and self monitoring. Behav Int. Oct–Dec. 2001;16(4):279-86. X-1, X-3, X-4.
3918 Shabry F, Wolk JA. Granulocytopenia in children after phenothiazine therapy. Am J Psychiatry. Mar. 1980;137(3):374-5. X-1, X-3, X-4. [pmid: 6101935].
3919 Shafer MS, Egel AL, Neef NA. Training mildly handicapped peers to facilitate changes in the social interaction skills of autistic children. J Appl Behav Anal. Winter. 1984;17(4):461-76. X-1, X-3, X-4. [pmid: 6526767].
3920 Shah A, Parikh D, Jawaheer G, et al. Persistent rectal prolapse in children: sclerotherapy and surgical management. Pediatr Surg Int. Apr. 2005;21(4):270-3. X-4. [pmid: 15761711].
3921 Shaked M, Bilu Y. Grappling with affliction: Autism in the Jewish ultraorthodox community in Israel. Cult Med Psychiatry. Mar. 2006;30(1):1-27. X-2, X-4. [pmid: 16783528].
3922 Shannon M, Graef JW. Lead intoxication in children with pervasive developmental disorders. J Toxicol Clin Toxicol. 1996;34(2):177-81. X-4. [pmid: 8618251].
3923 Shapira J, Mann J, Tamari I, et al. Oral health status and dental needs of an autistic population of children and young adults. Spec Care Dentist. Mar–Apr. 1989;9(2):38-41. X-4. [pmid: 2533709].
3924 Shapiro T, Frosch E, Arnold S. Communicative interaction between mothers and their autistic children: application of a new instrument and changes after treatment. J Am Acad Child Adolesc Psychiatry. Jul. 1987;26(4):485-90. X-1, X-3, X-4. [pmid: 3654498].
3925 Sharp WG, Jaquess DL, Morton JF, et al. A retrospective chart review of dietary diversity and feeding behavior of children with autism spectrum disorder before and after admission to a day-treatment program. Focus Autism Dev Disabil. Mar. 2011;26(1):37-48. X-1, X-3, X-4.
3926 Sharpley CF, Bitsika V, Efremidis B. Influence of gender, parental health, and perceived expertise of assistance upon stress, anxiety, and depression among parents of children with autism. J Intellect Dev Disabil. 1997;22(1):19-28. X-4.
3927 Shattuck PT, Grosse S, Parish S, et al. Utilization of a Medicaid-funded intervention for children with autism. Psychiatr Serv. Apr. 2009;60(4):549-52. X-4. [pmid: 19339334].
3928 Shattuck PT, Seltzer MM, Greenberg JS, et al. Change in autism symptoms and maladaptive behaviors in adolescents and adults with an autism spectrum disorder. J Autism Dev Disord. Oct. 2007;37(9):1735-47. X-4. [pmid: 17146700].
3929 Shattuck PT, Wagner M, Narendorf S, et al. Post-high school service use among young adults with an autism spectrum disorder. Arch Pediatr Adolesc Med. Feb. 2011;165(2):141-6. X-4. [pmid: 21300654].
3930 Shavelle RM, Strauss D. Comparative mortality of persons with autism in California, 1980–1996. J Insur Med. 1998;30(4):220-5. X-4. [pmid: 10537926].
3931 Shaw P, Rapoport JL. Decision making about children with psychotic symptoms: using the best evidence in choosing a treatment. J Am Acad Child Adolesc Psychiatry. Nov. 2006;45(11):1381. X-1, X-3, X-4. [pmid: 17075361].
3932 Shaw W. Increased urinary excretion of a 3-(3-hydroxyphenyl)-3-hydroxypropionic acid (HPHPA), an abnormal phenylalanine metabolite of Clostridia spp. in the gastrointestinal tract, in urine samples from patients with autism and schizophrenia. Nutr Neurosci. Jun. 2010;13(3):135-43. X-3, X-4. [pmid: 20423563].
3933 Shea S, Turgay A, Carroll A, et al. Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. Pediatr. Nov. 2004;114(5):e634-41. X-1, X-3, X-4. [pmid: 15492353].
3934 Shea V. A perspective on the research literature related to early intensive behavioral intervention (Lovaas) for young children with autism. Autism. Dec. 2004;8(4):349-67. X-2, X-4. [pmid: 15556956].
3935 Shea V. A perspective on the research literature related to early intensive behavioral intervention (Lovaas) for young children with autism. Commun Disord Q. Win. 2005;26(2):102-11. X-2, X-4.
3936 Sheinkopf SJ, Siegel B. Home-based behavioral treatment of young children with autism. J Autism Dev Disord. Feb. 1998;28(1):15-23. X-1, X-3, X-4. [pmid: 9546298].
3937 Sheitman BB, Knable MB, Jarskog LF, et al. Secretin for refractory schizophrenia. Schizophr Res. Feb. 1. 2004;66(2–3):177-81. X-1, X-3, X-4. [pmid: 15061251].
3938 Shek DT, Tsang SK, Lam LL, et al. Psychometric properties of the Chinese version of the Psycho-educational Profile-Revised (CPEP-R). J Autism Dev Disord. Feb. 2005;35(1):37-44. X-2, X-4. [pmid: 15796120].
3939 Sheldrick RC, Perrin EC. Medical home services for children with behavioral health conditions. J Dev Behav Pediatr. Feb–Mar. 2010;31(2):92-9. X-1, X-3, X-4. [pmid: 20110825].
3940 Sheng L, Ding X, Ferguson M, et al. Prenatal polycyclic aromatic hydrocarbon exposure leads to behavioral deficits and downregulation of receptor tyrosine kinase, MET. Toxicol Sci. Dec. 2010;118(2):625-34. X-1, X-3, X-4. [pmid: 20889680].
3941 Sheppard S. Autism outreach services—influencing inclusive practice?. Educ Child Psychol. 2000;17(4):17-28. X-1, X-3, X-4.
3942 Sherer M, Pierce KL, Paredes S, et al. Enhancing conversation skills in children with autism via video technology. Which is better, "self" or "other" as a model?. Behav Modif. Jan. 2001;25(1):140-58. X-1, X-3, X-4. [pmid: 11151482].
3943 Sherer MR, Schreibman L. Individual behavioral profiles and predictors of treatment effectiveness for children with autism. J Consult Clin Psychol. Jun. 2005;73(3):525-38. X-1, X-3, X-4. [pmid: 15982150].
3944 Sherman BR. Predictors of the decision to place developmentally disabled family members in residential care. Am J Ment Retard. Jan. 1988;92(4):344-51. X-4. [pmid: 3342136].
3945 Sherman J, Barker P, Lorimer P, et al. Treatment of autistic children: relative effectiveness of residential, out-patient and home-based interventions. Child Psychiatry Hum Dev. Winter. 1988;19(2):109-25. X-1, X-3, X-4. [pmid: 3229155].
3946 Sherman J, Factor DC, Swinson R, et al. The effects of fenfluramine (hydrochloride) on the behaviors of fifteen autistic children. J Autism Dev Disord. Dec. 1989;19(4):533-43. X-3. [pmid: 2606883].
3947 Sherratt D. Developing pretend play in children with autism: a case study. Autism. Jun. 2002;6(2):169-79. X-1, X-3, X-4. [pmid: 12083283].
3948 Sheth RD, Goulden KJ, Ronen GM. Aggression in children treated with clobazam for epilepsy. Clin Neuropharmacol. Aug. 1994;17(4):332-7. X-1, X-3, X-4. [pmid: 9316680].
3949 Shevell M, Majnemer A, Platt RW, et al. Developmental and functional outcomes in children with global developmental delay or developmental language impairment. Dev Med Child Neurol. Oct. 2005;47(10):678-83. X-4. [pmid: 16174311].
3950 Shields J. The NAS EarlyBird Programme: autism-specific early intervention for parents. Prof Care Mother Child. 2000;10(2):53-4. X-2. [pmid: 11040767].
3951 Shields J. The NAS EarlyBird Programme: partnership with parents in early intervention. Autism. Mar. 2001;5(1):49-56. X-2. [pmid: 11708389].
3952 Shields-Wolfe J, Gallagher PA. Functional utilization of splinter skills for the employment of a young adult with autism. Focus on Autistic Behavior. Oct. 1992;7(4):1-16. X-3.
3953 Shih A, Rosanoff M, Wallace S, et al. Autism speaks global autism public health initiative: bridging gaps in autism awareness, research, and services around the world. Beijing Da Xue Xue Bao. Aug. 18. 2009;41(4):389-91. X-1, X-2, X-3, X-4. [pmid: 19845067].
3954 Shillingsburg MA, Valentino AL. Teaching a child with autism to mand for information using “how”. Anal Verbal Behav. 2011;27:179-84. X-3. [pmid: 22532762].
3955 Shillingsburg MA, Valentino AL, Bowen CN, et al. Teaching children with autism to request information. Res Autism Spectr Disord. Jan–Mar. 2011;5(1):670-9. X-3.
3956 Shimoji T, Shimabukuro S, Sugama S, et al. Mild trigonocephaly with clinical symptoms: analysis of surgical results in 65 patients. Childs Nerv Syst. May. 2002;18(5):215-24. X-1, X-2, X-3, X-4. [pmid: 12042920].
3957 Shimoji T, Tomiyama N. Mild trigonocephaly and intracranial pressure: report of 56 patients. Childs Nerv Syst. Oct. 2004;20(10):749-56. X-4. [pmid: 15185114].
3958 Shine R, Perry A. The relationship between parental stress and intervention outcome of children with autism. J Dev Disabil. 2010;16(2):64-6. X-1, X-3, X-4.
3959 Shirataki S, Hanada M, Kuromaru S, et al. Long-term follow-up study of 13 autistic children. Folia Psychiatr Neurol Jpn. 1984;38(1):25-31. X-3. [pmid: 6537390].
3960 Shireman TI, Reichard A, Nazir N, et al. Quality of diabetes care for adults with developmental disabilities. Disabil Health J. Jul. 2010;3(3):179-85. X-1, X-3, X-4. [pmid: 21122783].
3961 Shireman TI, Reichard A, Rigler SK. Psychotropic medication use among Kansas Medicaid youths with disabilities. J Child Adolesc Psychopharmacol. Feb. 2005;15(1):107-15. X-4. [pmid: 15741792].
3962 Shogren KA, Lang R, Machalicek W, et al. Self-versus teacher management of behavior for elementary school students with asperger syndrome: Impact on classroom behavior. J Posit Behav Interv. Apr. 2011;13(2):87-96. X-1, X-3, X-4.
3963 Shook GL, Ala'i-Rosales S, Glenn SS. Training and certifying behavior analysts. Behav Modif. Jan. 2002;26(1):27-48. X-2, X-4. [pmid: 11799652].
3964 Short AB. Short-term treatment outcome using parents as co-therapists for their own autistic children. J Child Psychol Psychiatry. Jul. 1984;25(3):443-58. X-3. [pmid: 6746793].
3965 Shtayermman O. Suicidal ideation and comorbid disorders in adolescents and young adults diagnosed with asperger's syndrome: a population at risk. J Hum Behav Soc Environ. 2008;18(3):301-28. X-4.
3966 Shtayermman O. An exploratory study of the stigma associated with a diagnosis of asperger's syndrome: the mental health impact on the adolescents and young adults diagnosed with a disability with a social nature. J Hum Behav Soc Environ. 2009;19(3):298-313. X-3, X-4.
3967 Shu BC, Lung FW. The effect of support group on the mental health and quality of life for mothers with autistic children. J Intellect Disabil Res. Jan. 2005;49(Pt 1):47-53. X-4. [pmid: 15634311].
3968 Shukla-Mehta S, Miller T, Callahan KJ. Evaluating the effectiveness of video instruction on social and communication skills training for children with autism spectrum disorders: a review of the literature. Focus Autism Dev Disabil. 2010;25(1):23-36. X-2, X-4.
3969 Shute N. Desperate for an autism cure. Sci Am. Oct. 2010;303(4):80-5. X-1. [pmid: 20923134].
3970 Shuttleworth J. The suffering of asperger children and the challenge they present to psychoanalytic thinking. J Child Psychother. Aug. 1999;25(2):239-65. X-1, X-3, X-4.
3971 Shyu Y-IL, Tsai J-L, Tsai WC. Explaining and selecting treatments for autism: parental explanatory models in Taiwan. J Autism Dev Disord. Nov. 2010;40(11):1323-31. X-3. [pmid: 20224997].
3972 Siaperas P, Beadle-Brown J. A case study of the use of a structured teaching approach in adults with autism in a residential home in Greece. Autism. Jul. 2006;10(4):330-43. X-3. [pmid: 16908477].
3973 Siaperas P, Higgins S, Proios P. Challenging behaviours on people with autism: a case study on the effect of a residential training programme based on structured teaching and TEACCH method. Psychiatriki. Oct–Dec. 2007;18(4):343-50. X-3. [pmid: 22466678].
3974 Sidener TM, Carr JE, Firth AM. Superimposition and withholding of edible consequences as treatment for automatically reinforced stereotypy. J Appl Behav Anal. Spring. 2005;38(1):121-4. X-1, X-3, X-4. [pmid: 15898482].
3975 Sidener TM, Shabani DB, Carr JE, et al. An evaluation of strategies to maintain mands at practical levels. Res Dev Disabil. Nov–Dec. 2006;27(6):632-44. X-1, X-3, X-4. [pmid: 16298103].
3976 Sidoli M. The little puppet: working with autistic defences in mother-infant psychotherapy. J Anal Psychol. Apr. 2000;45(2):159-75. X-4. [pmid: 14533392].
3977 Siegel B. Autistic learning disabilities and individualizing treatment for autistic spectrum disorders. Infants Young Child. Oct. 1999;12(2):27-36. X-1, X-2, X-3, X-4.
3978 Sigafoos J, Drasgow E, Halle JW, et al. Teaching VOCA use as a communicative repair strategy. J Autism Dev Disord. Aug. 2004;34(4):411-22. X-3. [pmid: 15449516].
3979 Sigafoos J, Kerr M, Roberts D, et al. Increasing opportunities for requesting in classrooms serving children with developmental disabilities. J Autism Dev Disord. Oct. 1994;24(5):631-45. X-1, X-3, X-4. [pmid: 7814311].
3980 Sigafoos J, Meikle B. Functional communication training for the treatment of multiply determined challenging behavior in two boys with autism. Behav Modif. Jan. 1996;20(1):60-84. X-1, X-3, X-4. [pmid: 8561770].
3981 Sigafoos J, O'Reilly M, Ma CH, et al. Effects of embedded instruction versus discrete-trial training on self-injury, correct responding, and mood in a child with autism. J Intellect Dev Disabil. Dec. 2006;31(4):196-203. X-1, X-3, X-4. [pmid: 17178531].
3982 Sigafoos J, O'Reilly M, Seely-York S, et al. Teaching students with developmental disabilities to locate their AAC device. Res Dev Disabil. Jul–Aug. 2004;25(4):371-83. X-3. [pmid: 15193671].
3983 Sigafoos J, Pittendreigh N, Pennell D. Parent and teacher ratings of challenging behaviour in young children with developmental disabilities. Br J Learn Disabil. 1997;25(1):13-7. X-1, X-3, X-4.
3984 Sigafoos J, Roberts D, Kerr M, et al. Opportunities for communication in classrooms serving children with developmental disabilities. J Autism Dev Disord. Jun. 1994;24(3):259-79. X-1, X-3, X-4. [pmid: 8050981].
3985 Sigafoos J, Roberts-Pennell D, Graves D. Longitudinal assessment of play and adaptive behavior in young children with developmental disabilities. Res Dev Disabil. Mar–Apr. 1999;20(2):147-61. X-4. [pmid: 10198944].
3986 Sigafoos J, Saggers E. A discrete-trial approach to the functional analysis of aggressive behaviour in two boys with autism. Aust NZ J Dev Disabil. 1995;20(4):287-97. X-1, X-3, X-4.
3987 Sigman M, McGovern CW. Improvement in cognitive and language skills from preschool to adolescence in autism. J Autism Dev Disord. Feb. 2005;35(1):15-23. X-4. [pmid: 15796118].
3988 Sigman M, Ruskin E, Arbeile S, et al. Continuity and change in the social competence of children with autism, down syndrome, and developmental delays. Monogr Soc Res Child Dev. 1999;64(1):1-114. X-4. [pmid: 10412222].
3989 Sik Lanyi C, Laky V, Tilinger A, et al. Developing multimedia software and virtual reality worlds and their use in rehabilitation and psychology. Stud Health Technol Inform. 2004;105:273-84. X-2, X-4. [pmid: 15718616].
3990 Siller M, Sigman M. Modeling longitudinal change in the language abilities of children with autism: parent behaviors and child characteristics as predictors of change. Dev Psychol. Nov. 2008;44(6):1691-704. X-1, X-3, X-4. [pmid: 18999331].
3991 Silliman ER, Diehl SF, Bahr RH, et al. Clinical forum A new look at performance on theory-of-mind tasks by adolescents with autism spectrum disorder. Lang Speech Hear Serv Sch. 2003;34(3):236. X-3.
3992 Silva LM, Ayres R, Schalock M. Outcomes of a pilot training program in a qigong massage intervention for young children with autism. Am J Occup Ther. Sep–Oct. 2008;62(5):538-46. X-1, X-3, X-4. [pmid: 18826014].
3993 Silva LM, Cignolini A. A medical qigong methodology for early intervention in autism spectrum disorder: a case series. Am J Chin Med. 2005;33(2):315-27. X-1, X-3, X-4. [pmid: 15974490].
3994 Silva LM, Cignolini A, Warren R, et al. Improvement in sensory impairment and social interaction in young children with autism following treatment with an original Qigong massage methodology. Am J Chin Med. 2007;35(3):393-406. X-1, X-3, X-4. [pmid: 17597498].
3995 Silva LM, Schalock M, Ayres R, et al. Qigong massage treatment for sensory and self-regulation problems in young children with autism: a randomized controlled trial. Am J Occup Ther. Jul–Aug. 2009;63(4):423-32. X-1, X-3, X-4. [pmid: 19708471].
3996 Silva RR, Malone RP, Anderson LT, et al. Haloperidol withdrawal and weight changes in autistic children. Psychopharmacol Bull. 1993;29(2):287-91. X-4. [pmid: 8290679].
3997 Silveira R, Jainer AK, Bates G. Fluoxetine treatment of selective mutism in pervasive developmental disorder. Int J Psychiatry Clin Pract. Sep. 2004;8(3):179-80. X-1, X-3, X-4.
3998 Silver AA. Children with autistic behavior in a self-contained unit in the public schools. J Dev Behav Pediatr. Apr. 1986;7(2):84-92. X-4. [pmid: 2422217].
3999 Silver H, Goodman C, Knoll G, et al. Brief emotion training improves recognition of facial emotions in chronic schizophrenia. A pilot study. Psychiatry Res. Sep. 30. 2004;128(2):147-54. X-4. [pmid: 15488957].
4000 Silverman RD. Litigation, regulation, and education--protecting the public's health through childhood immunization. N Engl J Med. Jun. 11. 2009;360(24):2500-1. X-2. [pmid: 19516031].
4001 Simon EW, et al. A case study: follow-up assessment of facilitated communication. J Autism Dev Disord. Feb. 1996;26(1):9-18. X-3, X-4. [pmid: 8819768].
4002 Simonson LR, Simonson SM, Volkmar FR. Benhaven's residential program. J Autism Dev Disord. Sep. 1990;20(3):323-37. X-2, X-4. [pmid: 2228915].
4003 Simpson A, Langone J, Ayres KM. Embedded video and computer based instruction to improve social skills for students with autism. Educ Train Dev Disabil. 2004;39(3):240-52. X-3.
4004 Simpson CG, Gaus MD, Biggs MJG, et al. Physical education and implications for students with asperger's syndrome. Teach Except Child. Jul–Aug. 2010;42(6):48-56. X-3.
4005 Simpson K, Keen D. Music interventions for children with autism: narrative review of the literature. J Autism Dev Disord. Nov. 2011;41(11):1507-14. X-1, X-2, X-3, X-4. [pmid: 21203898].
4006 Simpson R. Tips for practitioners: reinforcement of social story compliance. Focus on Autistic Behavior. Aug. 1993;8(3):15-6. X-1, X-2, X-3, X-4.
4007 Simpson RL. Children and youth with autism in an age of reform: a perspective on current issues. Behav Disord. Nov. 1995;21(1):7-20. X-1, X-2, X-3, X-4.
4008 Simpson RL. ABA and students with autism spectrum disorders: issues and considerations for effective practice. Focus Autism Dev Disabil. Sum. 2001;16(2):68-71. X-1, X-2, X-3, X-4.
4009 Simpson RL. Finding effective intervention and personnel preparation practices for students with autism spectrum disorders. Except Child. Win. 2004;70(2):135-44. X-2.
4010 Simpson RL, de Boer-Ott SR, Smith-Myles B. Inclusion of learners with autism spectrum disorders in general education settings. Top Lang Disord. Apr–Jun. 2003;23(2):116-33. X-1, X-2, X-3, X-4.
4011 Simpson RL, Griswold DE, Myles BS. Educators' assessment accommodation preferences for students with autism. Focus Autism Dev Disabil. Win. 1999;14(4):212-19. 30. X-1, X-2, X-3, X-4.
4012 Simpson RL, McKee M, Teeter D, et al. Evidence-based methods for children and youth with autism spectrum disorders: stakeholder issues and perspectives. Exceptionality. Nov. 2007;15(4):203-17. X-2, X-4.
4013 Singh I. Prolonged oculogyric crisis on addition of nifedipine to neuroleptic medication regime. British Journal of Psychiatry. Jan. 1987;150:127-8. X-3. [pmid: 3651662].
4014 Singh J, Illes J, Lazzeroni L, et al. Trends in US autism research funding. J Autism Dev Disord. May. 2009;39(5):788-95. X-2, X-4. [pmid: 19148735].
4015 Singh NN, Lancioni GE, Manikam R, et al. A mindfulness-based strategy for self-management of aggressive behavior in adolescents with autism. Res Autism Spectr Disord. Jul–Sep. 2011;5(3):1153-8. X-3.
4016 Singh NN, Lancioni GE, Winton AS, et al. Mindful parenting decreases aggression and increases social behavior in children with developmental disabilities. Behav Modif. Nov. 2007;31(6):749-71. X-4. [pmid: 17932234].
4017 Singh NN, Lancioni GE, Winton ASW, et al. Mindful parenting decreases aggression, noncompliance, and self-injury in children with autism. J Emot Behav Disord. Fall. 2006;14(3):169-77. X-4.
4018 Singh VK, Jensen RL. Elevated levels of measles antibodies in children with autism. Pediatr Neurol. Apr. 2003;28(4):292-4. X-4. [pmid: 12849883].
4019 Siu AM, Lai CY, Chiu AS, et al. Development and validation of a fine-motor assessment tool for use with young children in a Chinese population. Res Dev Disabil. Jan–Feb. 2011;32(1):107-14. X-1, X-3, X-4. [pmid: 20956068].
4020 Sjogreen L, Andersson-Norinder J, Jacobsson C. Development of speech, feeding, eating, and facial expression in Mobius sequence. Int J Pediatr Otorhinolaryngol. Sep. 28. 2001;60(3):197-204. X-4. [pmid: 11551610].
4021 Skaines N, Rodger S, Bundy A. Playfulness in children with autistic disorder and their typically developing peers. Br J Occup Ther. 2006;69(11):505-12. X-1, X-3, X-4.
4022 Skokut M, Robinson S, Openden D, et al. Promoting the social and cognitive competence of children with autism: interventions at school. Calif School Psychol. 2008;13:93-108. X-2.
4023 Sloan JL, Marcus L. Some findings on the use of the adaptive behavior scale with autistic children. J Autism Dev Disord. Jun. 1981;11(2):191-9. X-1, X-3, X-4. [pmid: 6927704].
4024 Smith A, McCann R, McKinlay I. Second dose of MMR vaccine: health professionals' level of confidence in the vaccine and attitudes towards the second dose. Commun Dis Public Health. Dec. 2001;4(4):273-7. X-4. [pmid: 12109394].
4025 Smith A, Yarwood J, Salisbury DM. Tracking mothers' attitudes to MMR immunisation 1996–2006. Vaccine. May. 16. 2007;25(20):3996-4002. X-4. [pmid: 17395344].
4026 Smith B, Chung MC, Vostanis P. The path to care in autism: is it better now?. J Autism Dev Disord. Oct. 1994;24(5):551-63. X-4. [pmid: 7814305].
4027 Smith C. Using social stories to enhance behaviour in children with autistic spectrum difficulties. Educ Psychol Prac. Dec. 2001;17(4):337-45. X-3, X-4.
4028 Smith C, Felce D, Jones E, et al. Responsiveness to staff support: evaluating the impact of individual characteristics on the effectiveness of active support training using a conditional probability approach. J Intellect Disabil Res. Nov. 2002;46(Pt 8):594-604. X-1, X-3, X-4. [pmid: 12427166].
4029 Smith C, Goddard S, Fluck M. A scheme to promote social attention and functional language in young children with communication difficulties and autistic spectrum disorder. Educ Psychol Prac. Dec. 2004;20(4):319-33. X-1, X-3, X-4.
4030 Smith DE, McConnell JV, Walter TL, et al. Effect of using an auditory trainer on the attentional, language, and social behaviors of autistic children. J Autism Dev Disord. Sep. 1985;15(3):285-302. X-3. [pmid: 4030662].
4031 Smith DL, Gillon GT. Autistic spectrum disorder: caseload characteristics, and interventions implemented by speech-language therapists. Kairaranga. 2004;5(2):46-54. X-1, X-3, X-4.
4032 Smith EG, Bennetto L. Audiovisual speech integration and lipreading in autism. J Child Psychol Psychiatry. Aug. 2007;48(8):813-21. X-4. [pmid: 17683453].
4033 Smith IM, Koegel RL, Koegel LK, et al. Effectiveness of a novel community-based early intervention model for children with autistic spectrum disorder. Am J Intellect Dev Disabil. Nov. 2010;115(6):504-23. X-1, X-3, X-4. [pmid: 20946003].
4034 Smith JJ. How to fix an az-burger. Reclaiming Child Youth. 2010;19(1):7-11. X-1, X-2, X-3, X-4.
4035 Smith KRM, Matson JL. Behavior Problems: differences among intellectually disabled adults with co-morbid autism spectrum disorders and epilepsy. Res Dev Disabil: A Multidisciplinary Journal. Sep–Oct. 2010;31(5):1062-9. X-4.
4036 Smith L. Ethical principles in practice: evidence from participatory action research. Kairaranga. 2008;9(spec iss):16-21. X-1, X-2, X-3, X-4.
4037 Smith MD. Use of similar sensory stimuli in the community-based treatment of self-stimulatory behavior in an adult disabled by autism. J Behav Ther Exp Psychiatry. Jun. 1986;17(2):121-5. X-3. [pmid: 3722396].
4038 Smith MD, Belcher R. Teaching life skills to adults disabled by autism. J Autism Dev Disord. Jun. 1985;15(2):163-75. X-3. [pmid: 3997743].
4039 Smith MD, Belcher RG. Brief report: facilitated communication with adults with autism. J Autism Dev Disord. Mar. 1993;23(1):175-83. X-3. [pmid: 8463197].
4040 Smith MD, Coleman D. Managing the behavior of adults with autism in the job setting. J Autism Dev Disord. Jun. 1986;16(2):145-54. X-3. [pmid: 3722116].
4041 Smith MD, Haas PJ, Belcher RG. Facilitated communication: the effects of facilitator knowledge and level of assistance on output. J Autism Dev Disord. Jun. 1994;24(3):357-67. X-3. [pmid: 8050988].
4042 Smith MJ, Ellenberg SS, Bell LM, et al. Media coverage of the measles-mumps-rubella vaccine and autism controversy and its relationship to MMR immunization rates in the United States. Pediatrics. Apr. 2008;121(4):e836-43. X-2, X-4. [pmid: 18381512].
4043 Smith MJ, Woods CR, Marshall GS. Parental vaccine concerns in Kentucky. J Ky Med Assoc. Sep. 2009;107(9):342-9. X-4. [pmid: 19813430].
4044 Smith MR, Lerman DC. A preliminary comparison of guided compliance and high-probability instructional sequences as treatment for noncompliance in children with developmental disabilities. Res Dev Disabil. May–Jun. 1999;20(3):183-95. X-1, X-3, X-4. [pmid: 10372411].
4045 Smith SA, Press B, Koenig KP, et al. Effects of sensory integration intervention on self-stimulating and self-injurious behaviors. Am J Occup Ther. Jul–Aug. 2005;59(4):418-25. X-3. [pmid: 16124208].
4046 Smith SG, Gupta KK, Smith SH. Effects of naltrexone on self-injury, stereotypy, and social behavior of adults with developmental disabilities. J Dev Phys Disabil. Special Issue: Pharmacotherapy III. Jun. 1995;7(2):137-46. X-3.
4047 Smith T. Improving memory to promote maintenance of treatment gains in children with autism. Psychol Rec. Fal. 1994;44(4):459-73. X-1, X-3, X-4.
4048 Smith T. Discrete trial training in the treatment of autism. Focus Autism Dev Disabil. Sum. 2001;16(2):86-92. X-2.
4049 Smith T, Antolovich M. Parental perceptions of supplemental interventions received by young children with autism in intensive behavior analytic treatment. Behav Int. Apr–Jun. 2000;15(2):83-97. X-2, X-4.
4050 Smith T, Buch GA, Gamby TE. Parent-directed, intensive early intervention for children with pervasive developmental disorder. Res Dev Disabil. Jul–Aug. 2000;21(4):297-309. X-1, X-3, X-4. [pmid: 10983784].
4051 Smith T, Eikeseth S, Klevstrand M, et al. Intensive behavioral treatment for preschoolers with severe mental retardation and pervasive developmental disorder. Am J Ment Retard. Nov. 1997;102(3):238-49. X-1, X-3, X-4. [pmid: 9394133].
4052 Smith T, et al. Comments on replication and evaluation of outcome. Am J Ment Retard. Jan. 1993;97(4):385-91. X-1, X-2, X-3, X-4.
4053 Smith T, Groen AD, Wynn JW. Randomized trial of intensive early intervention for children with pervasive developmental disorder. Am J Ment Retard. Jul. 2000;105(4):269-85. X-1, X-3, X-4. [pmid: 10934569].
4054 Smith T, Lovaas OI. Intensive and early behavioral intervention with autism: the UCLA young autism project. Infants Young Child. Jan. 1998;10(3):67-78. X-1, X-3, X-4.
4055 Smith T, Lovass OI. The UCLA young autism project: a reply to Gresham and Macmillan. Behav Disord. Aug. 1997;22(4):202-18. X-1, X-2, X-3, X-4.
4056 Smith T, Mruzek DW, Wheat LA, et al. Error correction in discrimination training for children with autism. Behav Int. Nov. 2006;21(4):245-63. X-1, X-3, X-4.
4057 Smith T, Scahill L, Dawson G, et al. Designing research studies on psychosocial interventions in autism. J Autism Dev Disord. Feb. 2007;37(2):354-66. X-2, X-4. [pmid: 16897380].
4058 Smukler D. Unauthorized minds: how "theory of mind" theory misrepresents autism. Ment Retard. Feb. 2005;43(1):11-24. X-2, X-4. [pmid: 15628930].
4059 Smyth C, Slevin E. Experiences of family life with an autism assistance dog. Learn Disabil Pract. 2010;13(4):12-7. X-3.
4060 Smyth P, Hardy N. Evan's frequency of hand-biting during a six- hour school day. J Precision Teach Celeration. Fal. 2002;18(2):67-8. X-1, X-3, X-4.
4061 Snead RW, Boon F, Presberg J. Paroxetine for self-injurious behavior. J Am Acad Child Adolesc Psychiatry. Jul–Aug. 1994;33(6):909-10. X-3. [pmid: 8083152].
4062 Snell ME. Using dynamic assessment with learners who communicate nonsymbolically. AAC. 2002;18(3):163-76. X-1, X-2, X-3, X-4.
4063 Snyder A, Bahramali H, Hawker T, et al. Savant-like numerosity skills revealed in normal people by magnetic pulses. Perception. 2006;35(6):837-45. X-4. [pmid: 16836048].
4064 Snyder A, Bossomaier T, Mitchell DJ. Concept formation: 'object' attributes dynamically inhibited from conscious awareness. J Integr Neurosci. Mar. 2004;3(1):31-46. X-2, X-4. [pmid: 15139077].
4065 Soares DA, Vannest KJ, Harrison J. Computer aided self-monitoring to increase academic production and reduce self-injurious behavior in a child with autism. Behav Int. Jul. 2009;24(3):171-83. X-3.
4066 Sobel DM, Capps LM, Gopnik A. Ambiguous figure perception and theory of mind understanding in children with autistic spectrum disorders. Br J Dev Psychol. 2005;23(Part 2):159-74. X-4.
4067 Soden SE, Lowry JA, Garrison CB, et al. 24-hour provoked urine excretion test for heavy metals in children with autism and typically developing controls, a pilot study. Clin Toxicol (Phila). Jun–Aug. 2007;45(5):476-81. X-4. [pmid: 17503250].
4068 Soenksen D, Alper S. Teaching a young child to appropriately gain attention of peers using a social story intervention. Focus Autism Dev Disabil. Spr. 2006;21(1):36-44. X-1, X-3, X-4.
4069 Sofronoff K, Attwood T, Hinton S. A randomised controlled trial of a CBT intervention for anxiety in children with Asperger syndrome. J Child Psychol Psychiatry. Nov. 2005;46(11):1152-60. X-1, X-3, X-4. [pmid: 16238662].
4070 Sofronoff K, Attwood T, Hinton S, et al. A randomized controlled trial of a cognitive behavioural intervention for anger management in children diagnosed with asperger syndrome. J Autism Dev Disord. Aug. 2007;37(7):1203-14. X-1. [pmid: 17082978].
4071 Sofronoff K, Farbotko M. The effectiveness of parent management training to increase self-efficacy in parents of children with asperger syndrome. Autism. Sep. 2002;6(3):271-86. X-1, X-3, X-4. [pmid: 12212918].
4072 Sofronoff K, Leslie A, Brown W. Parent management training and asperger syndrome: a randomized controlled trial to evaluate a parent based intervention. Autism. Sep. 2004;8(3):301-17. X-1, X-3, X-4. [pmid: 15358872].
4073 Soke GN, Philofsky A, Diguiseppi C, et al. Longitudinal changes in scores on the Autism Diagnostic Interview—Revised (ADI-R) in pre-school children with autism. Autism. 2011;15(5):545-62. X-1, X-3, X-4. [pmid: 21586639].
4074 Sokhadze E, Baruth J, El-Baz A, et al. Impaired error monitoring and correction function in autism. J Neurother. 2010;14(2):79-95. X-3. [pmid: 20523752].
4075 Sokhadze E, Baruth J, Tasman A, et al. Low-frequency repetitive transcranial magnetic stimulation (rTMS) affects event-related potential measures of novelty processing in autism. Appl Psychophysiol Biofeedback. Jun. 2010;35(2):147-61. X-3, X-4. [pmid: 19941058].
4076 Sokhadze EM, El-Baz A, Baruth J, et al. Effects of low frequency repetitive transcranial magnetic stimulation (rTMS) on gamma frequency oscillations and event-related potentials during processing of illusory figures in autism. J Autism Dev Disord. Apr. 2009;39(4):619-34. X-3. [pmid: 19030976].
4077 Sokol DK, Dunn DW, Edwards-Brown M, et al. Hydrogen proton magnetic resonance spectroscopy in autism: Preliminary evidence of elevated choline/creatine ratio. J Child Neurol. Apr. 2002;17(4):245-9. X-4. [pmid: 12088077].
4078 Sokolski KN, Chicz-Demet A, Demet EM. Case Report. Selective serotonin reuptake inhibitor-related extrapyramidal symptoms in autistic children: a case series. J Child Adolesc Psychopharmacol. Spr. 2004;14(1):143-7. X-4. [pmid: 15142402].
4079 Solomon M, Goodlin-Jones BL, Anders TF. A social adjustment enhancement intervention for high functioning autism, Asperger's syndrome, and pervasive developmental disorder NOS. J Autism Dev Disord. Dec. 2004;34(6):649-68. X-1, X-3, X-4. [pmid: 15679185].
4080 Solomon M, Ono M, Timmer S, et al. The effectiveness of parent-child interaction therapy for families of children on the autism spectrum. J Autism Dev Disord. Oct. 2008;38(9):1767-76. X-1, X-3, X-4. [pmid: 18401693].
4081 Solomon R, Necheles J, Ferch C, et al. Pilot study of a parent training program for young children with autism: The PLAY project home consultation program. Autism. 2007;11(3):205-24. X-1, X-3, X-4. [pmid: 17478575].
4082 Son SH, Sigafoos J, O'Reilly M, et al. Comparing two types of augmentative and alternative communication systems for children with autism. Pediatr Rehabil. Oct–Dec. 2006;9(4):389-95. X-1, X-3, X-4. [pmid: 17111565].
4083 Soorya L, Kiarashi J, Hollander E. Psychopharmacologic interventions for repetitive behaviors in autism spectrum disorders. Child Adolesc Psychiatr Clin N Am. Oct. 2008;17(4):753-71. viii. X-2, X-4. [pmid: 18775368].
4084 Soper HV, Elliott RO Jr, Rejzer AA, et al. Effects of fenfluramine on neuropsychological and communicative functioning in treatment-refractory schizophrenic patients. J Clin Psychopharmacol. Jun. 1990;10(3):168-75. X-4. [pmid: 2198295].
4085 Soshensky R. Developing a guitar-based approach in Nordoff-Robbins music therapy. Music Ther Perspect. 2005;23(2):111-7. X-2, X-4.
4086 Sourander A, Ellila H, Valimaki M, et al. Use of holding, restraints, seclusion and time-out in child and adolescent psychiatric in-patient treatment. Eur Child Adolesc Psychiatry. Aug. 2002;11(4):162-7. X-4. [pmid: 12444425].
4087 Sourander A, Helenius H, Piha J. Outcome of short-term child psychiatric hospitalization: teacher evaluation at 5-month and 12-month follow-up. Eur Child Adolesc Psychiatry. Dec. 1996;5(4):204-11. X-1, X-3, X-4. [pmid: 8989559].
4088 Soutor TA, Houlihan D, Young A. An examination of response covariation on the behavioral treatment of identical twin boys with multiple behavioral disorders. Behav Int. Jul. 1994;9(3):141-55. X-1, X-3, X-4.
4089 Sovner R. The use of valproate in the treatment of mentally retarded persons with typical and atypical bipolar disorders. Journal of Clinical Psychiatry. Special Issue: Emerging perspectives on valproate in affective disorders. Mar. 1989;50(Suppl):40-3. X-3. [pmid: 2494159].
4090 Sowden H, Perkins M, Clegg J. The co-development of speech and gesture in children with autism. Clin Linguist Phon. Oct–Nov. 2008;22(10–11):804-13. X-1, X-3, X-4. [pmid: 18608250].
4091 Sowden H, Perkins M, Clegg J. Context and communication strategies in naturalistic behavioural intervention: a framework for understanding how practitioners facilitate communication in children with ASD. Child Lang Teach Ther. Feb. 2011;27(1):21-38. X-1, X-3, X-4.
4092 Spanarello S, Beoni AM, Mina G, et al. Analysis of differential clinical profiles of different antipsychotic molecules in the first psychotic episode: a retrospective study. Encephale. Nov–Dec. 2005;31(6 Pt 1):692-7. X-2. [pmid: 16462688].
4093 Spann SJ, Kohler FW, Soenksen D. Examining parents' involvement in and perceptions of special education services: an interview with families in a parent support group. Focus Autism Dev Disabil. Win. 2003;18(4):228-37. X-1, X-4.
4094 Sparkes E, Tanner P, Bouthillier M, et al. Developing expert practice. Adventures in research: the early steps: examining the Wilbarger protocol for children with autism. Occup Ther Now. 2002;4(3):7-8. X-1, X-2, X-3, X-4.
4095 Sparrow SS, Rescorla LA, Provence S, et al. Follow-up of "atypical" children--a brief report. J Am Acad Child Psychiatry. Mar. 1986;25(2):181-5. X-1, X-3, X-4. [pmid: 3700905].
4096 Spector JE. Sight word instruction for students with autism: an evaluation of the evidence base. J Autism Dev Disord. Oct. 2011;41(10):1411-22. X-1, X-2, X-3. [pmid: 21184159].
4097 Speers T, Lewis J. Journalists and jabs: media coverage of the MMR vaccine. Commun Med. 2004;1(2):171-81. X-4. [pmid: 16808699].
4098 Speirs S, Yelland G, Rinehart N, et al. Lexical processing in individuals with high-functioning autism and Asperger’s disorder. Autism. 2011;15(3):307-25. X-1, X-3, X-4. [pmid: 21363869].
4099 Spence SJ, Tasker RC, Pomeroy SL. Recent advances in autism spectrum disorders. Curr Opin Pediatr. Dec. 2011;23(6):607-8. X-1, X-2, X-3, X-4. [pmid: 21970831].
4100 Spencer EK, Alpert M, Pouget ER. Scales for the assessment of neuroleptic response in schizophrenic children: specific measures derived from the CPRS. Psychopharmacol Bull. 1994;30(2):199-202. X-4. [pmid: 7831455].
4101 Spencer KC, Turkett A, Vaughan R, et al. School-based practice patterns: a survey of occupational therapists in Colorado. Am J Occup Ther. Jan–Feb. 2006;60(1):81-91. X-4. [pmid: 16541987].
4102 Spencer TD, Petersen DB, Gillam SL. Picture Exchange Communication System (PECS) or sign language: an evidence-based decision-making example. Teach Except Child. Nov–Dec. 2008;41(2):40-7. X-2.
4103 Spencer VG, Simpson CG, Lynch SA. Using social stories to increase positive behaviors for children with autism spectrum disorders. Interv School Clinic. 2008;44(1):58-61. X-2.
4104 Spensley S. Cognitive deficit, mindlessness and psychotic depression: observations of a "born loser.". J Child Psychother. 1985;11(1):33-50. X-1, X-3, X-4.
4105 Spensley S. Mentally ill or mentally handicapped? A longitudinal study of severe learning disorder. Psychoanal Psychother. 1985;1(3):55-70. X-3.
4106 Spero MH. The emancipation of time from autistic encapsulation: a study in the use of countertransference. Am J Psychoanal. Jun. 1998;58(2):187-209. X-1, X-2, X-3, X-4. [pmid: 9648643].
4107 Sperry L, Neitzel J, Engelhardt-Wells K. Peer-mediated instruction and intervention strategies for students with autism spectrum disorders. Prev School Failure. 2010;54(4):256-64. X-1, X-2, X-3.
4108 Sponheim E, Oftedal G, Helverschou SB. Multiple doses of secretin in the treatment of autism: a controlled study. Acta Paediatr. 2002;91(5):540-5. X-1, X-3, X-4. [pmid: 12113323].
4109 Sprafkin J, Volpe RJ, Gadow KD, et al. A DSM-IV-referenced screening instrument for preschool children: the Early Childhood Inventory-4. J Am Acad Child Adolesc Psychiatry. May. 2002;41(5):604-12. X-4. [pmid: 12014793].
4110 Sprague JR, Horner RH. Covariation within functional response classes: implications for treatment of severe problem behavior. J Appl Behav Anal. Fal. 1992;25(3):735-45. X-1, X-3, X-4. [pmid: 1429324].
4111 Sprong M, Becker HE, Schothorst PF, et al. Pathways to psychosis: a comparison of the pervasive developmental disorder subtype multiple complex developmental disorder and the "at risk mental state". Schizophr Res. Feb. 2008;99(1–3):38-47. X-4. [pmid: 18055179].
4112 Srinath S, Chowdhury J, Bhide AV, et al. Descriptive study of infantile autism. NIMHANS. Jan. 1989;7(1):77-81. X-3.
4113 St John R. Transference and countertransference contributions toward understanding the phenomenon of institutionalization of schizophrenic patients. J Am Acad Psychoanal. Spring. 2001;29(1):17-32. X-2. [pmid: 11490675].
4114 St Pourcain B, Wang K, Glessner JT, et al. Association between a high-risk autism locus on 5p14 and social communication spectrum phenotypes in the general population. Am J Psychiatry. Nov. 2010;167(11):1364-72. X-1, X-3, X-4. [pmid: 20634369].
4115 St. Clair MC, Durkin K, Conti-Ramsden G, et al. Growth of reading skills in children with a history of specific language impairment: the role of autistic symptomatology and language-related abilities. Br J Dev Psychol. 2010;28(Part 1):109-31. X-4. [pmid: 20306628].
4116 Stahmer AC. Teaching symbolic play skills to children with autism using pivotal response training. J Autism Dev Disord. Apr. 1995;25(2):123-41. X-1, X-3, X-4. [pmid: 7559281].
4117 Stahmer AC. The basic structure of community early intervention programs for children with autism: provider descriptions. J Autism Dev Disord. Aug. 2007;37(7):1344-54. X-4. [pmid: 17086438].
4118 Stahmer AC, Aarons GA. Attitudes toward adoption of evidence-based practices: a comparison of autism early intervention providers and children’s mental health providers. Psychological Services. Aug. 2009;6(3):223-34. X-1, X-3, X-4. [pmid: 21796262].
4119 Stahmer AC, Akshoomoff N, Cunningham AB. Inclusion for toddlers with autism spectrum disorders: the first ten years of a community program. Autism. Sep. 2011;15(5):625-41. X-1, X-3, X-4. [pmid: 21486899].
4120 Stahmer AC, Carter C, Baker M, et al. Parent perspectives on their toddlers' development: comparison of regular and inclusion childcare. Early Child Dev Care. Oct. 2003;173(5):477-88. X-1, X-3, X-4.
4121 Stahmer AC, Collings NM, Palinkas LA. Early intervention practices for children with autism: descriptions from community providers. Focus Autism Dev Disabil. Sum. 2005;20(2):66-79. X-4.
4122 Stahmer AC, Gist K. The effects of an accelerated parent education program on technique mastery and child outcome. J Posit Behav Interv. Spr. 2001;3(2):75-82. X-1, X-3, X-4.
4123 Stahmer AC, Ingersoll B. Inclusive programming for toddlers with autism spectrum disorders: outcomes from the children's toddler school. J Posit Behav Interv. 2004;6(2):67-82. X-1, X-3, X-4.
4124 Stahmer AC, Ingersoll B, Koegel RL. Inclusive programming for toddlers autism spectrum disorders: outcomes from the Children's Toddler School. J Posit Behav Interv. Spr. 2004;6(2):67-82. X-1, X-3, X-4.
4125 Stahmer AC, Schreibman L. Teaching children with autism appropriate play in unsupervised environments using a self-management treatment package. J Appl Behav Anal. Summer. 1992;25(2):447-59. X-1, X-3, X-4. [pmid: 1634432].
4126 Stahmer AC, Suhrheinrich J, Reed S, et al. Pivotal response teaching in the classroom setting. Prev School Failure. 2010;54(4):265-74. X-1, X-2, X-3.
4127 Staines R. School nurses can help identify children with undiagnosed autism. Paediatr Nurs. Mar. 2010;22(2):7. X-2, X-4. [pmid: 20373658].
4128 Standen PJ, Brown DJ. Virtual reality in the rehabilitation of people with intellectual disabilities: review. CyberPsychol Behav. Special Issue: Use of Virtual Environments in Training and Rehabilitation: International Perspectives. Jun. 2005;8(3):272-82. X-2, X-4. [pmid: 15971976].
4129 Starkova L, Wiedermann J. Our experience with incisive neuroleptic drugs in child psychiatry. Acta Univ Palacki Olomuc Fac Med. 1991;131:213-7. X-1, X-2, X-3, X-4. [pmid: 1687949].
4130 Starr EM, Foy JB, Cramer KM. Parental perceptions of the education of children with pervasive developmental disorders. Educ Train Ment Retard Dev Disabil. Mar. 2001;36(1):55-68. X-4.
4131 Stavrakaki C, Antochi R, Emery PC. Olanzapine in the treatment of pervasive developmental disorders: a case series analysis. J Psychiatry Neurosci. Jan. 2004;29(1):57-60. X-3, X-2. [pmid: 14719051].
4132 Stavrou E, French JL. The K-ABC and cognitive processing styles in autistic children. J Sch Psychol. Fall. 1992;30(3):259-67. X-4.
4133 Steege MW, Mace FC, Perry L, et al. Applied behavior analysis: beyond discrete trial teaching. Psychol Sch. Jan. 2007;44(1):91-9. X-2.
4134 Stefanatou A. Use of drawings in children with pervasive developmental disorder during hospitalization: a developmental perspective. J Child Health Care. Dec. 2008;12(4):268-83. X-1, X-3, X-4. [pmid: 19052186].
4135 Stehr-Green P, Tull P, Stellfeld M, et al. Autism and thimerosal-containing vaccines: lack of consistent evidence for an association. Am J Prev Med. Aug. 2003;25(2):101-6. X-4. [pmid: 12880876].
4136 Stein D, Ring A, Shulman C, et al. Brief report: children with autism as they grow up--description of adult inpatients with severe autism. J Autism Dev Disord. Jun. 2001;31(3):355-60. X-2. [pmid: 11518489].
4137 Stein MT, Faber S, Berger SP, et al. International adoption: a four-year-old child with unusual behaviors adopted at six months of age. J Dev Behav Pediatr. Oct. 2004;25(5 Suppl):S26-32. X-2. [pmid: 15502529].
4138 Stein SJ, McNairn C. The changing nature of diagnosis in an inpatient service over 20 years. J Abnorm Child Psychol. Sep. 1983;11(3):443-61. X-4. [pmid: 6643862].
4139 Steiner AM. A strength-based approach to parent education for children with autism. J Posit Behav Interv. Jul. 2011;13(3):178-90. X-1, X-3, X-4.
4140 Steingard R, Biederman J. Lithium responsive manic-like symptoms in two individuals with autism and mental retardation. J Am Acad Child Adolesc Psychiatry. Nov. 1987;26(6):932-5. X-3. [pmid: 2892825].
4141 Steingard RJ, Zimnitzky B, DeMaso DR, et al. Sertraline treatment of transition-associated anxiety and agitation in children with autistic disorder. J Child Adolesc Psychopharmacol. Spring. 1997;7(1):9-15. X-1, X-3, X-4. [pmid: 9192538].
4142 Stel M, van den Heuvel C, Smeets RC. Facial feedback mechanisms in autistic spectrum disorders. J Autism Dev Disord. Aug. 2008;38(7):1250-8. X-4. [pmid: 18293075].
4143 Stengel BE. Developmental group therapy with autistic and other severely psychosocially handicapped adolescents. Int J Group Psychother. Jul. 1987;37(3):417-31. X-3. [pmid: 3667016].
4144 Stephens CE. Spontaneous imitation by children with autism during a repetitive musical play routine. Autism. Nov. 2008;12(6):645-71. X-1, X-3, X-4. [pmid: 19005033].
4145 Stephenson J, Carter M. The use of weighted vests with children with autism spectrum disorders and other disabilities. J Autism Dev Disord. Jan. 2009;39(1):105-14. X-2. [pmid: 18592366].
4146 Stephenson MB. Famotidine (Pepcid) and autistic spectrum disorders: a reason for optimism, or for heartburn?. Sci Rev Ment Health Prac. Fal-Win. 2002;1(2):184-8. X-2, X-4.
4147 Sterling-Turner HE, Jordan SS. Interventions addressing transition difficulties for individuals with autism. Psychol Sch. Sep. 2007;44(7):681-90. X-2, X-4.
4148 Stern LM, Walker MK, Sawyer MG, et al. A controlled crossover trial of fenfluramine in autism. J Child Psychol Psychiatry. May. 1990;31(4):569-85. X-1, X-3, X-4. [pmid: 2195054].
4149 Stevens S, Gruzelier J. Electrodermal activity to auditory stimuli in autistic, retarded, and normal children. J Autism Dev Disord. Sep. 1984;14(3):245-60. X-1, X-3, X-4. [pmid: 6480545].
4150 Stevenson CL, Krantz PJ, McClannahan LE. Social interaction skills for children with autism: a script-fading procedure for nonreaders. Behav Int. Jan–Mar. 2000;15(1):1-20. X-1, X-3, X-4.
4151 Stevenson RA, VanDerKlok RM, Pisoni DB, et al. Discrete neural substrates underlie complementary audiovisual speech integration processes. Neuroimage. Apr. 1. 2011;55(3):1339-45. X-1, X-3, X-4. [pmid: 21195198].
4152 Steward R On the record: Robyn Steward. Interview by Alita Howe Ment Health Today. 2010 Dec–2011 Jan:38 X-1, X-2, X-3, X-4 21235057
4153 Stewart AM. When vaccine injury claims go to court. N Engl J Med. Jun. 11. 2009;360(24):2498-500. X-2. [pmid: 19516030].
4154 Stichter JP, Herzog MJ, Visovsky K, et al. Social competence intervention for youth with asperger syndrome and high-functioning autism: an initial investigation. J Autism Dev Disord. Sep. 2010;40(9):1067-79. X-1, X-4. [pmid: 20162344].
4155 Stichter JP, Randolph J, Gage N, et al. A review of recommended social competency programs for students with autism spectrum disorders. Exceptionality. Nov. 2007;15(4):219-32. X-2.
4156 Stichter JP, Randolph JK, Kay D, et al. The use of structural analysis to develop antecedent-based interventions for students with autism. J Autism Dev Disord. Jun. 2009;39(6):883-96. X-2. [pmid: 19191017].
4157 Stigler KA, Diener JT, Kohn AE, Erickson CA, Posey DJ, McDougle CJ. A prospective, open-label study of aripiprazole in youth with pervasive developmental disorder not otherwise specified and asperger’s disorder. J Child Adolesc Psychopharmacol. 2009;19(3):265-74. X-6. [pmid: 19519261].
4158 Stigler KA, Desmond LA, Posey DJ, et al. A naturalistic retrospective analysis of psychostimulants in pervasive developmental disorders. J Child Adolesc Psychopharmacol. Spring. 2004;14(1):49-56. X-1, X-3, X-4. [pmid: 15142391].
4159 Stigler KA, Diener JT, Kohn AE, et al. Aripiprazole in pervasive developmental disorder not otherwise specified and Asperger's disorder: a 14-week, prospective, open-label study. J Child Adolesc Psychopharmacol. Jun. 2009;19(3):265-74. X-1, X-3, X-4. [pmid: 19519261].
4160 Stigler KA, Posey DJ, McDougle CJ. Aripiprazole for maladaptive behavior in pervasive developmental disorders. J Child Adolesc Psychopharmacol. Fal. 2004;14(3):455-63. X-3. [pmid: 15650503].
4161 Stiver RL, Dobbins JP. Treatment of atypical anorexia nervosa in the public school: an autistic girl. J Autism Dev Disord. Mar. 1980;10(1):67-73. X-3. [pmid: 6927680].
4162 Stoddart KP. Adolescents with asperger syndrome: Three case studies of individual and family therapy. Autism. Sep. 1999;3(3):255-71. X-3.
4163 Stoelb M, Yarnal R, Miles J, et al. Predicting responsiveness to treatment of children with autism: a retrospective study of the importance of physical dysmorphology. Focus Autism Dev Disabil. Sum. 2004;19(2):66-77. X-3, X-4.
4164 Stone VE, Baron-Cohen S, Knight RT. Frontal lobe contributions to theory of mind. J Cogn Neurosci. Sep. 1998;10(5):640-56. X-4. [pmid: 9802997].
4165 Stone WL, Caro-Martinez LM. Naturalistic observations of spontaneous communication in autistic children. J Autism Dev Disord. Dec. 1990;20(4):437-53. X-4. [pmid: 2279967].
4166 Stone WL, Ousley OY, Yoder PJ, et al. Nonverbal communication in two- and three-year-old children with autism. J Autism Dev Disord. Dec. 1997;27(6):677-96. X-1, X-3, X-4. [pmid: 9455728].
4167 Stone WL, Rosenbaum JL. A comparison of teacher and parent views of autism. J Autism Dev Disord. Sep. 1988;18(3):403-14. X-1, X-3, X-4. [pmid: 3170456].
4168 Stone WL, Yoder PJ. Predicting spoken language level in children with autism spectrum disorders. Autism. Dec. 2001;5(4):341-61. X-1, X-3, X-4. [pmid: 11777253].
4169 Strain PS. Identification of social skill curriculum targets for severely handicapped children in mainstream preschools. Appl Res Ment Retard. 1983;4(4):369-82. X-1, X-3, X-4. [pmid: 6670873].
4170 Strain PS. Empirically based social skill intervention: a case for quality-of-life improvement. Behav Disord. Nov. 2001;27(1):30-6. X-1, X-2, X-3, X-4.
4171 Strain PS, Bovey EH. Randomized, controlled trial of the leap model of early intervention for young children with autism spectrum disorders. Topics Early Child Spec Educ. Nov. 2011;31(3):133-54. X-1, X-3, X-4.
4172 Strain PS, Danko CD. Caregivers' encouragement of positive interaction between preschoolers with autism and their siblings. J Emot Behav Disord. Jan. 1995;3(1):2-12. X-1, X-3, X-4.
4173 Strain PS, et al. Teaching preschoolers with autism to self-monitor their social interactions: an analysis of results in home and school settings. J Emot Behav Disord. Apr. 1994;2(2):78-88. X-1, X-3, X-4.
4174 Strain PS, et al. Activity engagement and social interaction development in young children with autism: an examination of "free" intervention effects. J EmotB ehav Disord. Apr. 1995;3(2):108-23. X-1, X-3, X-4.
4175 Strain PS, Hoyson M. The need for longitudinal, intensive social skill intervention: LEAP follow-up outcomes for children with autism. Topics Early Child Spec Educ. Special issue: early childhood special education in a new century: voices from the past, visions for our future part 2. Sum. 2000;20(2):116-22. X-1, X-3, X-4.
4176 Strain PS, Kohler F. Peer-mediated social intervention for young children with autism. Semin Speech Lang. 1998;19(4):391-404. quiz −5; 24. X-2. [pmid: 9857394].
4177 Strambi M, Longini M, Hayek J, et al. Magnesium profile in autism. Biol Trace Elem Res. Feb. 2006;109(2):97-104. X-4. [pmid: 16443999].
4178 Strata F, Stoianov IP, de Villers-Sidani E, et al. Perinatal asphyxia affects rat auditory processing: implications for auditory perceptual impairments in neurodevelopmental disorders. PLoS One. 2010;5(12):e15326. X-1, X-3, X-4. [pmid: 21203459].
4179 Strauss DJ, Day SM, Shavelle RM, et al. Remote symptomatic epilepsy: does seizure severity increase mortality?. Neurology. Feb. 11. 2003;60(3):395-9. X-4. [pmid: 12578917].
4180 Strauss WL, Unis AS, Cowan C, et al. Fluorine magnetic resonance spectroscopy measurement of brain fluvoxamine and fluoxetine in pediatric patients treated for pervasive developmental disorders. Am J Psychiatry. May. 2002;159(5):755-60. X-1, X-3, X-4. [pmid: 11986128].
4181 Strayhorn JM. The vitamin and mineral mystery. J Am Acad Child Adolesc Psychiatry. Nov–Dec. 1994;33(9):1346-7. X-1, X-3, X-4. [pmid: 7995802].
4182 Strayhorn JM, Rapp N, Donina W, et al. Randomized trial of methylphenidate for an autistic child. Journal of the American Academy of Child & Adolescent Psychiatry. Mar. 1988;27(2):244-7. X-1, X-3, X-4. [pmid: 3360731].
4183 Stribling P, Rae J, Dickerson P. Using conversation analysis to explore the recurrence of a topic in the talk of a boy with an autism spectrum disorder. Clin Linguist Phon. Aug. 2009;23(8):555-82. X-4. [pmid: 19669991].
4184 Stringer MD. Informed consent and choice in cholecystectomy. Pediatr Surg Int. Oct. 2004;20(10):741-3. X-4. [pmid: 15490193].
4185 Stromer R, Mackay HA, Remington B. Naming, the formation of stimulus classes, and applied behavior analysis. J Appl Behav Anal. Fall. 1996;29(3):409-31. X-1, X-4. [pmid: 8810064].
4186 Strunk JA. School nurses' knowledge of autism spectrum disorders. J Sch Nurs. Dec. 2009;25(6):445-52. X-4. [pmid: 19776227].
4187 Stuart SK, Flis LD, Rinaldi C. Connecting with families: parents speak up about preschool services for their children with autism spectrum disorders. Teach Except Child. Sep–Oct. 2006;39(1):46-51. X-1, X-3, X-4.
4188 Stubbs EG, Budden SS, Burger DR, et al. Transfer factor immunotherapy of an autistic child with congenital cytomegalovirus. J Autism Dev Disord. Dec. 1980;10(4):451-8. X-3. [pmid: 6100889].
4189 Stubbs EG, Budden SS, Jackson RH, et al. Effects of fenfluramine on eight outpatients with the syndrome of autism. Dev Med Child Neurol. Apr. 1986;28(2):229-35. X-3. [pmid: 3709993].
4190 Stuhec V, Gisel EG. Compliance with administration procedures of tests for children with pervasive developmental disorders: does it exist?. Can J Occup Ther. Feb. 2003;70(1):33-41. X-4. [pmid: 12619397].
4191 Su H, Dickstein-Fischer L, Harrington K, et al. Cable-driven elastic parallel humanoid head with face tracking for autism spectrum disorder interventions. Conf Proc IEEE Eng Med Biol Soc. 2010;2010:467-70. X-1, X-2, X-3, X-4. [pmid: 21095653].
4192 Suarez SC. Show me again what i can do: documentation and self-determination for students with social challenges. Theory Into Practice. 2010;49(1):21-8. X-1, X-2, X-3, X-4.
4193 Suda M, Takei Y, Aoyama Y, et al. Autistic traits and brain activation during face-to-face conversations in typically developed adults. PLoS ONE. 2011;6(5). X-1, X-3, X-4.
4194 Suedfeld P, Schwartz G. Restricted environmental stimulation therapy (REST) as a treatment for autistic children. J Dev Behav Pediatr. Sep. 1983;4(3):196-201. X-1, X-3, X-4. [pmid: 6630534].
4195 Sugai G, White WJ. Effects of using object self-stimulation as a reinforcer on the prevocational work rates of an autistic child. J Autism Dev Disord. Dec. 1986;16(4):459-71. X-3. [pmid: 3804959].
4196 Sugarman SD. Cases in vaccine court--legal battles over vaccines and autism. N Engl J Med. Sep. 27. 2007;357(13):1275-7. X-2. [pmid: 17898095].
4197 Sugie Y, Sugie H, Fukuda T, et al. Clinical efficacy of fluvoxamine and functional polymorphism in a serotonin transporter gene on childhood autism. J Autism Dev Disord. Jun. 2005;35(3):377-85. X-3. [pmid: 16119478].
4198 Suda M, Takei Y, Aoyama Y, et al. Autistic traits and brain activation during face-to-face conversations in typically developed adults. PLoS ONE. 2011;6(5). X-1, X-3, X-4.
4199 Sukhodolsky DG, Scahill L, Gadow KD, et al. Parent-rated anxiety symptoms in children with pervasive developmental disorders: frequency and association with core autism symptoms and cognitive functioning. J Abnorm Child Psychol. Jan. 2008;36(1):117-28. X-4. [pmid: 17674186].
4200 Sullivan M, Finelli J, Marvin A, et al. Response to joint attention in toddlers at risk for autism spectrum disorder: a prospective study. J Autism Dev Disord. Jan. 2007;37(1):37-48. X-1, X-3, X-4. [pmid: 17216332].
4201 Sullivan MW, et al. Fostering environmental control in a young child with rett syndrome: a case study. J Autism Dev Disord. Apr. 1995;25(2):215-21. X-1, X-3, X-4. [pmid: 7559287].
4202 Sullivan RC. What does deinstitutionalization mean for our children?. J Autism Dev Disord. Sep. 1981;11(3):347-56. X-1, X-2, X-3, X-4. [pmid: 7052811].
4203 Sulzbacher S, Mas J, Larson EH, et al. Pediatric telehealth consultation to rural schools and clinics in the Pacific Northwest. J Spec Educ Technology. Win. 2004;19(1):35-42. X-4.
4204 Sulzer-Azaroff B, Fleming R, Tupa M, et al. Choosing objectives for a distance learning behavioral intervention in autism curriculum. Focus Autism Dev Disabil. 2008;23(1):29-36. X-4.
4205 Sumiyoshi C, Kawakubo Y, Suga M, et al. Impaired ability to organize information in individuals with autism spectrum disorders and their siblings. Neurosci Res. Mar. 2011;69(3):252-7. X-4. [pmid: 21129422].
4206 Summers J, Szatmari P. Using discrete trial instruction to teach children with angelman syndrome. Focus Autism Dev Disabil. Dec. 2009;24(4):216-26. X-4.
4207 Summers JA, Houlding CM, Reitzel J-AM. Behavior management services for children with autism/pdd: program description and patterns of referral. Focus Autism Dev Disabil. Sum. 2004;19(2):95-101. X-2.
4208 Sung M, Ooi YP, Goh TJ, et al. Effects of cognitive-behavioral therapy on anxiety in children with autism spectrum disorders: a randomized controlled trial. Child Psychiatry Hum Dev. 2011. Jun. 10. X-1. [pmid: 21660428].
4209 Sutera S, Pandey J, Esser EL, et al. Predictors of optimal outcome in toddlers diagnosed with autism spectrum disorders. J Autism Dev Disord. Jan. 2007;37(1):98-107. X-1, X-3, X-4. [pmid: 17206522].
4210 Sutherland S, Stroot SA. Brad's story: exploration of an inclusive adventure education experience. Ther Recreation J. 2009;43(3):27-39. X-3.
4211 Sutton SK, Burnette CP, Mundy PC, et al. Resting cortical brain activity and social behavior in higher functioning children with autism. J Child Psychol Psychiatry. Feb. 2005;46(2):211-22. X-4. [pmid: 15679529].
4212 Suwa S, Naruse H, Ohura T, et al. Influence of pimozide on hypothalamo-pituitary function in children with behavioral disorders. Psychoneuroendocrinology. 1984;9(1):37-44. X-4. [pmid: 6429690].
4213 Suzuki M. Mental development and autistic behavior in children with pervasive developmental disorders. Res Autism Spectr Disord. Oct–Dec. 2011;5(4):1517-25. X-1, X-3, X-4.
4214 Sverd J, Dubey DR, Schweitzer R, et al. Pervasive developmental disorders among children and adolescents attending psychiatric day treatment. Psychiatr Serv. Nov. 2003;54(11):1519-25. X-1, X-3, X-4. [pmid: 14600312].
4215 Swaggart B, Gagnon E, Bock SJ, et al. Using social stories to teach social and behavioral skills to children with autism. Focus Autism Other Dev Disabil. Apr. 1995;10(1):1-16. X-1, X-3, X-4.
4216 Swaim KF, Morgan SB. Children's attitudes and behavioral intentions toward a peer with autistic behaviors: does a brief educational intervention have an effect?. J Autism Dev Disord. Apr. 2001;31(2):195-205. X-4. [pmid: 11450818].
4217 Swartzwelder HS, Holahan W, Myers RD. Antagonism by d-amphetamine of trimethyltin-induced hyperactivity evidence toward an animal model of hyperkinetic behavior. Neuropharmacology. Sep. 1983;22(9):1049-54. X-1, X-3, X-4. [pmid: 6685232].
4218 Sweeney HM, LeBlanc JM. Effects of task size on work-related and aberrant behaviors of youths with autism and mental retardation. Res Dev Disabil. Mar–Apr. 1995;16(2):97-115. X-3. [pmid: 7792411].
4219 Sweet M. Helping children with sensory processing disorders: the role of occupational therapy. Odyssey. Spr-Sum. 2010;11(1):20-2. X-1, X-2, X-3, X-4.
4220 Swettenham J. Can children with autism be taught to understand false belief using computers?. J Child Psychol Psychiatry. Feb. 1996;37(2):157-65. X-1, X-3, X-4. [pmid: 8682895].
4221 Swiezy NB, Summers J. Parents' perceptions of the use of medication with children who are autistic. J Dev Phys Disabil. Dec. 1996;8(4):407-13. X-4.
4222 Sy JR, Borrero JC, Borrero CSW. Characterizing response-reinforcer relations in the natural environment: exploratory matching analyses. Psychol Rec. Fall. 2010;60(4):609-26. X-3.
4223 Symes MD, Remington B, Brown T, et al. Early intensive behavioral intervention for children with autism: therapists' perspectives on achieving procedural fidelity. Res Dev Disabil. Jan–Feb. 2006;27(1):30-42. X-4. [pmid: 15935615].
4224 Symes W, Humphrey N. Peer-group indicators of social inclusion among pupils with autistic spectrum disorders (ASD) in mainstream secondary schools: a comparative study. Sch Psychol Int. Oct. 2010;31(5):478-94. X-4.
4225 Symon JB. Expanding interventions for children with autism: parents as trainers. J Posit Behav Interv. 2005;7(3):159-73. X-1, X-3, X-4.
4226 Symons F, Davis M. Instructional conditions and stereotyped behavior: the function of prompts. J Behav Ther Exp Psychiatry. Dec. 1994;25(4):317-24. X-1, X-3, X-4. [pmid: 7706509].
4227 Symons FJ, Clark RD, Roberts JP, et al. Classroom behavior of elementary school-age boys with fragile X syndrome. J Spec Educ. Win. 2001;34(4):194-202. X-1, X-3, X-4.
4228 Symons FJ, Fox ND, Thompson T. Functional communication training and naltrexone treatment of self-injurious behaviour: An experimental case report. J Appl Res Intellect Disabil. 1998;11(3):273-92. X-1, X-3, X-4.
4229 Symons FJ, Hoch J, Dahl NA, et al. Sequential and matching analyses of self-injurious behavior a case of overmatching in the natural environment. J Appl Behav Anal. Summer. 2003;36(2):267-70. X-4. [pmid: 12858993].
4230 Symons FJ, Thompson A, Rodriguez MC. Self-injurious behavior and the efficacy of naltrexone treatment: a quantitative synthesis. Ment Retard Dev Disabil Res Rev. 2004;10(3):193-200. X-2. [pmid: 15611982].
4231 Szabo CP, Aber D. Asperger's syndrome: a valid DSM IV diagnostic entitity? A case report. S Af J Child Adolesc Psychiatry. 1992;4(1):3-7. X-4.
4232 Szabo CP, Bracken C. Imipramine and asperger's. J Am Acad Child Adolesc Psychiatry. Mar–Apr. 1994;33(3):431-2. X-1, X-3, X-4. [pmid: 8169195].
4233 Szapacs C. Applied behavior analysis. Teach Elem Phys Educ. Nov. 2006;17(6):12-5. X-2, X-4.
4234 Szatmari P, Archer L, Fisman S, et al. Parent and teacher agreement in the assessment of pervasive developmental disorders. J Autism Dev Disord. Dec. 1994;24(6):703-17. X-4. [pmid: 7844095].
4235 Szatmari P, Archer L, Fisman S, et al. Asperger's syndrome and autism: differences in behavior, cognition, and adaptive functioning. J Am Acad Child Adolesc Psychiatry. Dec. 1995;34(12):1662-71. X-1, X-3, X-4. [pmid: 8543538].
4236 Szatmari P, Bartolucci G, Bremner R, et al. A follow-up study of high-functioning autistic children. J Autism Dev Disord. Jun. 1989;19(2):213-25. X-3. [pmid: 2745389].
4237 Szatmari P, Streiner DL. The effect of selection criteria on outcome studies of children with pervasive developmental disorders (PDD). Eur Child Adolesc Psychiatry. Dec. 1996;5(4):179-84. X-4. [pmid: 8989556].
4238 Szekely GA, Caplan R, Rotman A. Platelet dopamine uptake in autistic and other psychotic children. Inhibition by imipramine. Prog Neuropsychopharmacol. 1980;4(2):215-8. X-1, X-3, X-4. [pmid: 7403355].
4239 Szempruch J, Jacobson JW. Evaluating facilitated communications of people with developmental disabilities. Res Dev Disabil. Jul–Aug. 1993;14(4):253-64. X-1, X-3, X-4. [pmid: 8210603].
4240 Szigethy E, Wiznitzer M, Branicky LA, et al. Risperidone-induced hepatotoxicity in children and adolescents? A chart review study. J Child Adolesc Psychopharmacol. 1999;9(2):93-8. X-1, X-3, X-4. [pmid: 10461819].
4241 Szymanski C, Brice PJ. When autism and deafness coexist in children: what we know now. Odyssey. Spr-Sum. 2008;9(1):10-5. X-1, X-2, X-3, X-4.
4242 Tada M, Kato M. Acquisition of mands through a behavior chain interruption strategy: task preference and occurrence of verbal requests by a child with autistic spectrum disorders. Jpn J Spec Educ. Mar. 2005;42(6):513-24. X-3.
4243 Taft RJ, Mason LH. Examining effects of writing interventions: highlighting results for students with primary disabilities other than learning disabilities. Remedial Spec Educ. Sep–Oct. 2011;32(5):359-70. X-1, X-2, X-3, X-4.
4244 Tager-Flusberg H. Brief report: current theory and research on language and communication in autism. J Autism Dev Disord. Apr. 1996;26(2):169-72. X-1, X-2, X-3, X-4. [pmid: 8744479].
4245 Tager-Flusberg H, Calkins S. Does imitation facilitate the acquisition of grammar? Evidence from a study of autistic, down's syndrome and normal children. J Child Lang. Oct. 1990;17(3):591-606. X-1, X-3, X-4. [pmid: 2148571].
4246 Tager-Flusberg H, Rogers S, Cooper J, et al. Defining spoken language benchmarks and selecting measures of expressive language development for young children with autism spectrum disorders. J Speech Lang Hear Res. Jun. 2009;52(3):643-52. X-2, X-4. [pmid: 19380608].
4247 Taira M, Takase M, Sasaki H. Sleep disorder in children with autism. Psychiatry Clin Neurosci. Apr. 1998;52(2):182-3. X-4. [pmid: 9628139].
4248 Takahashi H, Arai S, Tanaka-Taya K, et al. Autism and infection/immunization episodes in Japan. Jpn J Infect Dis. Apr. 2001;54(2):78-9. X-2. [pmid: 11427748].
4249 Takahashi H, Suzumura S, Shirakizawa F, et al. An epidemiological study on Japanese autism concerning routine childhood immunization history. Jpn J Infect Dis. Jun. 2003;56(3):114-7. X-4. [pmid: 12944678].
4250 Takase M, Taira M, Sasaki H. Sleep-wake rhythm of autistic children. Psychiatry Clin Neurosci. Apr. 1998;52(2):181-2. X-4. [pmid: 9628138].
4251 Takeuchi K, Kubota H, Yamamoto J-i. Intensive supervision for families conducting home-based behavioral treatment for children with autism in Malaysia. Jpn J Spec Educ. Mar. 2002;39(6):155-64. X-1, X-3, X-4.
4252 Tallal P, Merzenich M, Miller S, et al. Language learning impairment: integrating research and remediation. Scand J Psychol. Sep. 1998;39(3):197-9. X-1, X-2, X-3, X-4. [pmid: 9800537].
4253 Tamanaha AC, Perissinoto J. Comparison of the evolutional process of children with autism spectrum disorders in different language therapeutic interventions. J Soc Bras Fonoaudiol. Mar. 2011;23(1):8-12. X-3. [pmid: 21552726].
4254 Tamanaha AC, Perissinoto J, Chiari BM. Development of autistic children based on maternal responses to the Autism Behavior Checklist. Pro Fono. 2008;20(3):165-70. X-3. [pmid: 18852963].
4255 Tanaka JW, Wolf JM, Klaiman C, et al. Using computerized games to teach face recognition skills to children with autism spectrum disorder: the "let's face it!" program. J Child Psychol Psychiatry. Aug. 2010;51(8):944-52. X-1, X-3. [pmid: 20646129].
4256 Tang JC, Kennedy CH, Koppekin A, et al. Functional analysis of stereotypical ear covering in a child with autism. J Appl Behav Anal. Spring. 2002;35(1):95-8. X-3, X-4. [pmid: 11936553].
4257 Tansy M. Test Reviews. Euler BL, editor. “emotional disturbance decision tree” Lutz, fl: psychological assessment resources. J Psychoeduc Assess. 2009. 2007;27(1):68-78. X-2, X-4.
4258 Taras ME, Matson JL, Leary C. Training social interpersonal skills in two autistic children. J Behav Ther Exp Psychiatry. Dec. 1988;19(4):275-80. X-1, X-3, X-4. [pmid: 3235695].
4259 Tarbox J, Madrid W, Aguilar B, et al. Use of chaining to increase complexity of echoics in children with autism. J Appl Behav Anal. Winter. 2009;42(4):901-6. X-3. [pmid: 20514201].
4260 Tarbox J, Schiff A, Najdowski AC. Parent-implemented procedural modification of escape extinction in the treatment of food selectivity in a young child with autism. Educ Treat Children. May. 2010;33(2):223-34. X-3.
4261 Tarbox J, Wallace MD, Tarbox RSF. Successful generalized parent training and failed schedule thinning of response blocking for automatically maintained object mouthing. Behav Int. Jul–Sep. 2002;17(3):169-78. X-1, X-3, X-4.
4262 Tarbox RS, Wallace MD, Williams L. Assessment and treatment of elopement: a replication and extension. J Appl Behav Anal. Summer. 2003;36(2):239-44. X-2. [pmid: 12858987].
4263 Tardif C, Laine F, Rodriguez M, et al. Slowing down presentation of facial movements and vocal sounds enhances facial expression recognition and induces facial-vocal imitation in children with autism. J Autism Dev Disord. Sep. 2007;37(8):1469-84. X-3. [pmid: 17029018].
4264 Tartaglia N, Davis S, Hench A, et al. A new look at XXYY syndrome: medical and psychological features. Am J Med Genet A. Jun. 15. 2008;146A(12):1509-22. X-4. [pmid: 18481271].
4265 Taubman M, Brierley S, Wishner J, et al. The effectiveness of a group discrete trial instructional approach for preschoolers with developmental disabilities. Res Dev Disabil. May–Jun. 2001;22(3):205-19. X-1, X-3, X-4. [pmid: 11380059].
4266 Taylor B, Lingam R, Simmons A, et al. Autism and MMR vaccination in North London; no causal relationship. Mol Psychiatry. Suppl 2. 2002;7:S7-8. X-2. [pmid: 12142932].
4267 Taylor B, Miller E, Lingam R, et al. Measles, mumps, and rubella vaccination and bowel problems or developmental regression in children with autism: population study. BMJ. Feb. 16. 2002;324(7334):393-6. X-4. [pmid: 11850369].
4268 Taylor BA, Harris SL. Teaching children with autism to seek information: acquisition of novel information and generalization of responding. J Appl Behav Anal. Spring. 1995;28(1):3-14. X-3. [pmid: 7706148].
4269 Taylor BA, Hoch H. Teaching children with autism to respond to and initiate bids for joint attention. J Appl Behav Anal. Fall. 2008;41(3):377-91. X-3. [pmid: 18816976].
4270 Taylor BA, Hoch H, Potter B, et al. Manipulating establishing operations to promote initiations toward peers in children with autism. Res Dev Disabil. Jul–Aug. 2005;26(4):385-92. X-3. [pmid: 15766630].
4271 Taylor DC, Neville BG, Cross JH. Autistic spectrum disorders in childhood epilepsy surgery candidates. Eur Child Adolesc Psychiatry. Sep. 1999;8(3):189-92. X-4. [pmid: 10550700].
4272 Taylor DV, Hetrick WP, Neri CL, et al. Effect of naltrexone upon self-injurious behavior, learning and activity: A case study. Pharmacol Biochem Behav. Sep. 1991;40(1):79-82. X-3. [pmid: 1780350].
4273 Taylor E, Dopfner M, Sergeant J, et al. European clinical guidelines for hyperkinetic disorder -- first upgrade. Eur Child Adolesc Psychiatry. Suppl 1. 2004;13:I7-30. X-2, X-4. [pmid: 15322953].
4274 Taylor I, O'Reilly M, Lancioni G. An evaluation of an ongoing consultation model to train teachers to treat challenging behaviour. Int J Disabil Dev Educ. 1996;43(3):203-18. X-1, X-3, X-4.
4275 Taylor JC, Carr EG. Severe problem behaviors related to social interaction. 1: Attention seeking and social avoidance. Behav Modif. Jul. 1992;16(3):305-35. X-4. [pmid: 1385701].
4276 Taylor JC, Carr EG. Severe problem behaviors related to social interaction. 2: A systems analysis. Behav Modif. Jul. 1992;16(3):336-71. X-4. [pmid: 1385702].
4277 Taylor JC, Ekdahl MM, Romanczyk RG, et al. Escape behavior in task situations: task versus social antecedents. J Autism Dev Disord. Jun. 1994;24(3):331-44. X-4. [pmid: 8050986].
4278 Taylor JL, Seltzer MM. Changes in the Autism Behavioral Phenotype During the Transition to Adulthood. J Autism Dev Disord. 2010. Apr. 2. X-4. [pmid: 20361245].
4279 Taylor JL, Seltzer MM. Employment and post-secondary educational activities for young adults with autism spectrum disorders during the transition to adulthood. J Autism Dev Disord. May. 2011;41(5):566-74. X-4. [pmid: 20640591].
4280 Taylor L, Oliver C, Murphy G. The chronicity of self-injurious behaviour: a long-term follow-up of a total population study. J Appl Res Intellect Disabil. Mar. 2011;24(2):105-17. X-1, X-3, X-4.
4281 Taylor N, Isaac C, Milne E. A comparison of the development of audiovisual integration in children with autism spectrum disorders and typically developing children. J Autism Dev Disord. Nov. 2010;40(11):1403-11. X-4. [pmid: 20354776].
4282 Taylor R, Lane A, Olds T, et al. Implications of the activity participation levels of children with asperger syndrome for occupational therapy... Occupational Therapy Australia. 24th National Conference and Exhibition. 29 June –1 July 2011. Aust Occup Ther J. 2011;58:93-4. X-1, X-2, X-3, X-4.
4283 Taylor S, Cipani E, Clardy A. A stimulus control technique for improving the efficacy of an established toilet training program. J Behav Ther Exp Psychiatry. Jun. 1994;25(2):155-60. X-1, X-3, X-4. [pmid: 7983227].
4284 Tecchio F, Benassi F, Zappasodi F, et al. Auditory sensory processing in autism: a magnetoencephalographic study. Biol Psychiatry. Sep. 15. 2003;54(6):647-54. X-4. [pmid: 13129660].
4285 Teffs EE, Whitbread KM. Level of preparation of general education teachers to include students with autism spectrum disorders. Curr Issues Educ. 2009;12(10). X-2, X-4.
4286 Teising M. Permeability and demarcation in the psychoanalytic process. Functions of the contact-barrier. Int J Psychoanal. Dec. 2005;86(Pt 6):1627-44. X-2. [pmid: 16318941].
4287 Tekin-Iftar E, Birkan B. Small group instruction for students with autism: general case training and observational learning. J Spec Educ. 2010;44(1):50-63. X-3.
4288 Terai K, Munesue T, Hiratani M. Excessive water drinking behavior in autism. Brain Dev. Mar. 1999;21(2):103-6. X-4. [pmid: 10206527].
4289 Terry M. Telemedicine and autism: researchers and clinicians are just starting to consider telemedicine applications for the diagnosis and treatment of autism. Telemed J E Health. Jun. 2009;15(5):416-9. X-2, X-4. [pmid: 19548820].
4290 Tesink CM, Buitelaar JK, Petersson KM, et al. Neural correlates of pragmatic language comprehension in autism spectrum disorders. Brain. Jul. 2009;132(Pt 7):1941-52. X-4. [pmid: 19423680].
4291 Tews L. Early intervention for children with autism: methodologies critique. Dev Disabil Bull. 2007;35(1–2):148-68. X-2.
4292 Thakkar KN, Polli FE, Joseph RM, et al. Response monitoring, repetitive behaviour and anterior cingulate abnormalities in autism spectrum disorders (ASD). Brain. Sep. 2008;131(Pt 9):2464-78. X-3, X-4. [pmid: 18550622].
4293 Thalayasingam S, Alexander RT, Singh I. The use of clozapine in adults with intellectual disability. J Intellect Disabil Res. Sep. 2004;48(Pt 6):572-9. X-4. [pmid: 15312058].
4294 Tharpe AM. Auditory integration training: the magical mystery cure. Lang Speech Hear Serv Sch. Oct. 1999;30(4):378-82. X-1, X-2, X-3, X-4.
4295 Tharpe AM, Fino-Szumski MS, Bess FH. Survey of hearing aid fitting practices for children with multiple impairments. Am J Audiol. Jun. 2001;10(1):32-40. X-2, X-4. [pmid: 11501895].
4296 Theodorou F, Nind M. Inclusion in play: A case study of a child with autism in an inclusive nursery. J Res Spec Educ Needs. Jun. 2010;10(2):99-106. X-1, X-3, X-4.
4297 Thiemann KS, Goldstein H. Social stories, written text cues, and video feedback: effects on social communication of children with autism. J Appl Behav Anal. Winter. 2001;34(4):425-46. X-3. [pmid: 11800183].
4298 Thiemann KS, Goldstein H. Effects of peer training and written text cueing on social communication of school-age children with pervasive developmental disorder. J Speech Lang Hear Res. Feb. 2004;47(1):126-44. X-3. [pmid: 15072534].
4299 Thiessen C, Fazzio D, Arnal L, et al. Evaluation of a self-instructional manual for conducting discrete-trials teaching with children with autism. Behav Modif. May. 2009;33(3):360-73. X-4. [pmid: 19139527].
4300 Thoma CA, Held MF, Saddler S. Transition assessment practices in nevada and arizona: are they tied to best practices?. Focus Autism Other Dev Disabil. Win. 2002;17(4):242-50. X-1, X-3, X-4.
4301 Thomas BR, Lafasakis M, Sturmey P. The effects of prompting, fading, and differential reinforcement on vocal mands in non-verbal preschool children with autism spectrum disorders. Behav Int. Apr. 2010;25(2):157-68. X-3.
4302 Thomas KC, Ellis AR, McLaurin C, et al. Access to care for autism-related services. J Autism Dev Disord. Nov. 2007;37(10):1902-12. X-4. [pmid: 17372817].
4303 Thomas KC, Morrissey JP, McLaurin C. Use of autism-related services by families and children. J Autism Dev Disord. May. 2007;37(5):818-29. X-4. [pmid: 17146709].
4304 Thomas KC, Parish SL, Rose RA, et al. Access to care for children with autism in the context of state Medicaid reimbursement. Matern Child Health J. 2011. Aug. 11. X-4. [pmid: 21833759].
4305 Thomas M, Hunt A, Hurley M, et al. Time-use diaries are acceptable to parents with a disabled preschool child and are helpful in understanding families’ daily lives. Child Care Health Dev. Mar. 2011;37(2):168-74. X-1, X-3, X-4. [pmid: 20854450].
4306 Thomas N, Smith C. Developing play skills in children with autistic spectrum disorders. Educ Psychol Prac. Sep. 2004;20(3):195-206. X-3.
4307 Thomas RH, Foley KA, Mepham JR, et al. Altered brain phospholipid and acylcarnitine profiles in propionic acid infused rodents: further development of a potential model of autism spectrum disorders. J Neurochem. Apr. 2010;113(2):515-29. X-2, X-4. [pmid: 20405543].
4308 Thomeer ML, Rodgers JD, Lopata C, et al. Open-trial pilot of "mind reading" and in vivo rehearsal for children with HFASD. Focus Autism Dev Disabil. Sep. 2011;26(3):153-61. X-1, X-2, X-3, X-4,.
4309 Thompson AR, Beail N. The treatment of auto-erotic asphyxiation in a man with severe intellectual disabilities: The effectiveness of a behavioural and educational programme. J Appl Res Intellect Disabil. 2002;15(1):36-47. X-3.
4310 Thompson D, Emira M. ‘They say every child matters, but they don‘t’: an investigation into parental and carer perceptions of access to leisure facilities and respite care for children and young people with autistic spectrum disorder (ASD) or attention deficit, hyperactivity disorder (ADHD). Disabil Soc. Jan. 2011;26(1):65-78. X-1, X-2, X-3, X-4.
4311 Thompson DF, Thompson GD. Naltrexone in the management of seizures associated with Rett syndrome. Drug Intell Clin Pharm. Nov. 1987;21(11):874. X-1, X-3, X-4. [pmid: 3678057].
4312 Thompson L, Thompson M, Reid A. Neurofeedback outcomes in clients with asperger's syndrome. Appl Psychophysiol Biofeedback. Mar. 2010;35(1):63-81. X-1, X-2, X-3, X-4. [pmid: 19908142].
4313 Thompson MJ, McLaughlin TF, Derby KM. The use of differential reinforcement to decrease the inappropriate verbalizations of a nine-year-old girl with autism. Rev Electron Investig Psicoeduc Psigopedag. 2011;9(1):183-96. X-1, X-2, X-3, X-4.
4314 Thompson RH, Fisher WW, Contrucci SA. Evaluating the reinforcing effects of choice in comparison to reinforcement rate. Res Dev Disabil. Mar–Apr. 1998;19(2):181-87. X-1, X-3, X-4. [pmid: 9547528].
4315 Thompson RH, Fisher WW, Piazza CC, et al. The evaluation and treatment of aggression maintained by attention and automatic reinforcement. J Appl Behav Anal. Spr. 1998;31(1):103-16. X-1, X-3, X-4. [pmid: 9532754].
4316 Thompson SA. Proposed differentiated service model for community-based consultation organizations and the need for an inter-ministerial integrated service plan for persons with autism in B.C. Int J Spec Educ. 1992;16(2):139-53. X-1, X-2, X-3, X-4.
4317 Thompson WW, Price C, Goodson B, et al. Early thimerosal exposure and neuropsychological outcomes at 7 to 10 years. N Engl J Med. Sep. 27. 2007;357(13):1281-92. X-2, X-4. [pmid: 17898097].
4318 Thorne A. Are you ready to give care to a child with autism?. Nursing. May. 2007;37(5):59-61. X-2. [pmid: 17468640].
4319 Thorp DM, Stahmer AC, Schreibman L. Effects of sociodramatic play training on children with autism. J Autism Dev Disord. Jun. 1995;25(3):265-82. X-1, X-3, X-4. [pmid: 7559292].
4320 Thunberg G, Ahlsen E, Sandberg AD. Children with autistic spectrum disorders and speech-generating devices: communication in different activities at home. Clin Linguist Phon. Jun. 2007;21(6):457-79. X-3. [pmid: 17516231].
4321 Thuresson K, Färnstrand M. A follow-up of medical treatment of persons with psychiatric health problems and mental retardation. Nord J Psychiatry. 1999;53(2):127-30. X-1.
4322 Tiegerman E, Primavera L. Object manipulation: an interactional strategy with autistic children. J Autism Dev Disord. Dec. 1981;11(4):427-38. X-3. [pmid: 7052817].
4323 Tiegerman E, Primavera LH. Imitating the autistic child: facilitating communicative gaze behavior. J Autism Dev Disord. Mar. 1984;14(1):27-38. X-1, X-3, X-4. [pmid: 6706896].
4324 Tierney E, Aman M, Stout D, et al. Parent satisfaction in a multi-site acute trial of risperidone in children with autism: a social validity study. Psychopharmacology (Berl). Mar. 2007;191(1):149-57. X-1, X-3. [pmid: 17123125].
4325 Tiger JH, Bouxsein KJ, Fisher WW. Treating excessively slow responding of a young man with asperger syndrome using differential reinforcement of short response latencies. J Appl Behav Anal. Fal. 2007;40(3):559-63. X-3. [pmid: 17970270].
4326 Tiger JH, Fisher WW, Bouxsein KJ. Therapist- and self-monitored DRO contingencies as a treatment for the self-injurious skin picking of a young man with asperger syndrome. J Appl Behav Anal. Summer. 2009;42(2):315-9. X-3. [pmid: 19949518].
4327 Tiger JH, Hanley GP, Heal NA. The effectiveness of and preschoolers' preferences for variations of multiple-schedule arrangements. J Appl Behav Anal. Winter. 2006;39(4):475-88. X-1, X-3, X-4. [pmid: 17236348].
4328 Tiger JH, Toussaint KA, Roath CT. An evaluation of the value of choice-making opportunities in single-operant arrangements: simple fixed- and progressive-ratio schedules. J Appl Behav Anal. Fall. 2010;43(3):519-24. X-3. [pmid: 21358913].
4329 Tilsen J, Russell S, Nylund D. Nimble and courageous acts: how Michael became the boss of himself. J Systemic Ther. Sum. 2005;24(2):29-42. X-3.
4330 Tincani M. Comparing the picture exchange communication system and sign language training for children with autism. Focus Autism Dev Disabil. Fal. 2004;19(3):152-63. X-1, X-3, X-4.
4331 Tincani M, Crozier S, Alazetta L. The picture exchange communication system: effects on manding and speech development for school-aged children with autism. Educ Train Dev Disabil. Jun. 2006;41(2):177-84. X-3.
4332 Tincani M, Travers J, Boutot A. Race, culture, and autism spectrum disorder: understanding the role of diversity in successful educational interventions. Res Pract Persons Severe Disabl. 2009;34(3–4):81-90. X-1, X-3, X-2, X-4.
4333 Tissot C. Decisions after diagnosis: a practical path for parents of children with autism. Early Child Dev Care. Oct. 1999;157:85-96. X-1, X-2, X-3, X-4.
4334 Tissot C. Establishing a sexual identity: case studies of learners with autism and learning difficulties. Autism. 2009;13(6):551-66. X-3. [pmid: 19933763].
4335 Tissot C. Working together? Parent and local authority views on the process of obtaining appropriate educational provision for children with autism spectrum disorders. Educ Res. Mar. 2011;53(1):1-15. X-4.
4336 Tissot C, Evans R. Visual teaching strategies for children with autism. Early Child Dev Care. Aug. 2003;173(4):425-33. X-1, X-2, X-3, X-4.
4337 Tissot C, Evans R. Securing provision for children with autistic spectrum disorders: the views of parents. Research article. Perspect Educ. Mar. 2006;24(1):73-86. X-4.
4338 Tjus T, Heimann M, Nelson KE. Gains in literacy through the use of a specially developed multimedia computer strategy. Autism. Jun. 1998;2(2):139-56. X-1, X-3, X-4.
4339 Tjus T, Heimann M, Nelson KE. Interaction patterns between children and their teachers when using a specific multimedia and communication strategy: observations from children with autism and mixed intellectual disabilities. Autism. Jun. 2001;5(2):175-87. X-1, X-3, X-4. [pmid: 11706865].
4340 Tobias A. Supporting students with autistic spectrum disorder (ASD) at secondary school: a parent and student perspective. Educ Psychol Prac. Jun. 2009;25(2):151-65. X-4.
4341 Tobing LE, Glenwick DS. Relation of the childhood autism rating scale-parent version to diagnosis, stress, and age. Res Dev Disabil. May–Jun. 2002;23(3):211-23. X-4. [pmid: 12102589].
4342 Tobing LE, Glenwick DS. Predictors and moderators of psychological distress in mothers of children with pervasive development disorders. J Fam Soc Work. 2006;10(4):1-22. X-4.
4343 Toda Y, Mori K, Hashimoto T, et al. Administration of secretin for autism alters dopamine metabolism in the central nervous system. Brain Dev. Mar. 2006;28(2):99-103. X-1, X-3, X-4. [pmid: 16168596].
4344 Todd RD. Fluoxetine in autism. Am J Psychiatry. Aug. 1991;148(8):1089. X-3. [pmid: 1853966].
4345 Todd S, Bromley J, Ioannou K, et al. Using group-based parent training interventions with parents of children with disabilities: a description of process, content and outcomes in clinical practice. Child Adolesc Ment Health. 2010;15(3):171-5. X-1, X-4.
4346 Todd T, Reid G. Increasing physical activity in individuals with autism. Focus Autism Dev Disabil. Fall. 2006;21(3):167-76. X-1, X-3, X-4.
4347 Todd T, Reid G, Butler-Kisber L. Cycling for students with ASD: self-regulation promotes sustained physical activity. Adapt Phys Activ Q. Jul. 2010;27(3):226-41. X-3. [pmid: 20571157].
4348 Tolbert L, et al. Lack of response in an autistic population to a low dose clinical trial of pyridoxine plus magnesium. J Autism Dev Disord. Mar. 1993;23(1):193-99. X-3. [pmid: 8463199].
4349 Tolbert L, Haigler T, Waits MM, et al. Brief report: lack of response in an autistic population to a low dose clinical trial of pyridoxine plus magnesium. J Autism Dev Disord. Mar. 1993;23(1):193-9. X-6. [pmid: 8463199].
4350 Tomanik S, Harris GE, Hawkins J. The relationship between behaviours exhibited by children with autism and maternal stress. J Intellect Dev Disabil. 2004;29(1):16-26. X-1, X-3, X-4.
4351 Tomchek LB, Gordon R, Arnold M, et al. Teaching preschool children with autism and their normally developing peers: Meeting the challenges of integrated education. Focus Autistism Other Dev Disabil. Jun. 1992;7(2):1-17. X-1, X-3, X-4.
4352 Tomporowski PD. Training an autistic client: The effect of brief restraint on disruptive behavior. J Behav Ther Exp Psychiatry. Jun. 1983;14(2):169-73. X-3. [pmid: 6619299].
4353 Tonge B, Brereton A, Kiomall M, et al. Effects on parental mental health of an education and skills training program for parents of young children with autism: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. May. 2006;45(5):561-9. X-1, X-3, X-4. [pmid: 16670650].
4354 Tonge BJ. Autism. Aust Fam Physician. Mar. 1989;18(3):247-9. X-1, X-2, X-3, X-4. [pmid: 2735859].
4355 Torii M, Shimoyama I, Sugita K. Phonemic and semantic working memory in information processing in children with high function pervasive developmental disorders. Int Med J. 2010;17(1):35-9. X-3.
4356 Torisky DM, Torisky CV, Kaplan S, et al. The NAC pilot project: A model for nutrition screening and intervention for developmentally disabled children with behavior disorders. J Orthomolecular Med. 1993;8(1):25-42. X-1, X-3.
4357 Torrance J. Autism, aggression, and developing a therapeutic contract. Am J Dance Ther. Fal. 2003;25(2):97-109. X-2.
4358 Toth A. Bridge of signs: can sign language empower non-deaf children to triumph over their communication disabilities?. Am Ann Deaf. 2009;154(2):85-95. X-1, X-3, X-4. [pmid: 19839103].
4359 Towbin KE. Strategies for pharmacologic treatment of high functioning autism and asperger syndrome. Child Adolesc Psychiatr Clin N Am. Jan. 2003;12(1):23-45. X-2. [pmid: 12512397].
4360 Towle PO, Visintainer PF, O'Sullivan C, et al. Detecting autism spectrum disorder from early intervention charts: methodology and preliminary findings. J Autism Dev Disord. Mar. 2009;39(3):444-52. X-4. [pmid: 18791816].
4361 Townson L, Macauley S, Harkness E, et al. Research project on advocacy and autism. Disabil Soc. 2007;22(5):523-36. X-1, X-2, X-3, X-4.
4362 Toya K. The Dohsa method: a japanese therapy for autistic children. Emot Behav Difficulties. May. 2003;8(2):152-63. X-2.
4363 Trajkovski V, Petlichkovski A, Efinska-Mladenovska O, et al. Higher plasma concentration of food-specific antibodies in persons with autistic disorder in comparison to their siblings. Focus Autism Dev Disabil. 2008;23(3):176-85. X-4.
4364 Travis J, Geiger M. The effectiveness of the picture exchange communication system (pecs) for children with autism spectrum disorder (ASD): a South African pilot study. Child Lang Teach Ther. 2010;26(1):39-59. X-1, X-3, X-4.
4365 Trembath D, Balandin S, Togher L, et al. Peer-mediated teaching and augmentative and alternative communication for preschool-aged children with autism. J Intellect Dev Disabil. Jun. 2009;34(2):173-86. X-1, X-3, X-4. [pmid: 19404838].
4366 Trepagnier C. Families with autism. Infants Young Child. Oct. 1999;12(2):37-47. X-1, X-2, X-3, X-4.
4367 Trepagnier CY, Olsen DE, Boteler L, et al. Virtual conversation partner for adults with autism. Cyberpsychol Behav Soc Netw. Jan–Feb. 2011;14(1–2):21-7. X-1, X-3, X-4. [pmid: 21329439].
4368 Trepagnier CY, Sebrechts MM, Finkelmeyer A, et al. Simulating social interaction to address deficits of autistic spectrum disorder in children. Cyberpsychol Behav. Apr. 2006;9(2):213-7. X-2. [pmid: 16640482].
4369 Trillingsgaard A, Sørensen EU. School integration of high-functioning children with autism: a qualitative clinical interview study. Eur Child Adoles Psychiatry. Jul. 1994;3(3):187-96. X-3, X-4.
4370 Troost PW, Althaus M, Lahuis BE, et al. Neuropsychological effects of risperidone in children with pervasive developmental disorders: a blinded discontinuation study. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):561-73. X-1, X-3, X-4. [pmid: 17069545].
4371 Troost PW, Lahuis BE, Hermans MH, et al. Prolactin release in children treated with risperidone: impact and role of CYP2D6 metabolism. J Clin Psychopharmacol. Feb. 2007;27(1):52-7. X-1, X-3. [pmid: 17224713].
4372 Troost PW, Lahuis BE, Steenhuis MP, et al. Long-term effects of risperidone in children with autism spectrum disorders: a placebo discontinuation study. J Am Acad Child Adolesc Psychiatry. Nov. 2005;44(11):1137-44. X-1, X-3, X-4. [pmid: 16239862].
4373 Troost PW, Steenhuis MP, Tuynman-Qua HG, et al. Atomoxetine for attention-deficit/hyperactivity disorder symptoms in children with pervasive developmental disorders: a pilot study. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):611-9. X-3. [pmid: 17069549].
4374 Trosclair-Lasserre NM, Lerman DC, Call NA, et al. Reinforcement magnitude: an evaluation of preference and reinforcer efficacy. J Appl Behav Anal. Summer. 2008;41(2):203-20. X-3. [pmid: 18595284].
4375 Troster H. Prevalence and functions of stereotyped behaviors in nonhandicapped children in residential care. J Abnorm Child Psychol. Feb. 1994;22(1):79-97. X-4. [pmid: 8163776].
4376 Trottier N, Kamp L, Mirenda P. Effects of peer-mediated instruction to teach use of speech-generating devices to students with autism in social game routines. Augment Altern Commun. Mar. 2011;27(1):26-39. X-3. [pmid: 21284561].
4377 Trudgeon C, Carr D. The impacts of home-based early behavioural intervention programmes on families of children with autism. J Appl Res Intellect Disabil. Jul. 2007;20(4):285-96. X-3.
4378 Tsai L. Children with autism spectrum disorder: medicine today and in the new millennium. Focus Autism Dev Disabil. Fall. 2000;15(3):138-45. X-1, X-2, X-3, X-4.
4379 Tsai LY. Brief Report: comorbid psychiatric disorders of autistic disorder. J Autism Dev Disord. Apr. 1996;26(2):159-63. X-1, X-2, X-3, X-4. [pmid: 8744477].
4380 Tsai LY. Asperger syndrome and medication treatment. Focus Autism Dev Disabil. Fall. 2007;22(3):138-48. X-2.
4381 Tsai SJ. TrkB partial agonists: potential treatment strategy for epilepsy, mania, and autism. Med Hypotheses. 2006;66(1):173-5. X-2, X-4. [pmid: 16023301].
4382 Tsai WC, Tsai JL, Lotus Shyu YI. Integrating the nurturer-trainer roles: Parental and behavior/symptom management processes for mothers of children with autism. Soc Sci Med. Dec. 2008;67(11):1798-806. X-1, X-3, X-4. [pmid: 18783863].
4383 Tsakanikos E, Costello H, Holt G, et al. Psychopathology in adults with autism and intellectual disability. J Autism Dev Disord. Nov. 2006;36(8):1123-9. X-1, X-3, X-4. [pmid: 16855878].
4384 Tsakanikos E, Costello H, Holt G, et al. Behaviour management problems as predictors of psychotropic medication and use of psychiatric services in adults with autism. J Autism Dev Disord. Jul. 2007;37(6):1080-5. X-1, X-3, X-4. [pmid: 17053989].
4385 Tsakanikos E, McCarthy J, Kravariti E, et al. The role of ethnicity in clinical psychopathology and care pathways of adults with intellectual disabilities. Res Dev Disabil. Mar–Apr. 2010;31(2):410-5. X-1, X-3, X-4. [pmid: 19932597].
4386 Tsakanikos E, Sturmey P, Costello H, et al. Referral trends in mental health services for adults with intellectual disability and autism spectrum disorders. Autism. Jan. 2007;11(1):9-17. X-2. [pmid: 17175570].
4387 Tsang SK, Shek DT, Lam LL, et al. Brief report: application of the TEACCH program on Chinese pre-school children with autism--Does culture make a difference?. J Autism Dev Disord. Feb. 2007;37(2):390-6. X-1, X-3, X-4. [pmid: 16906461].
4388 Tsao L-L, Odom SL. Sibling-mediated social interaction intervention for young children with autism. Topics Early Child Spec Educ. Sum. 2006;26(2):106-23. X-1, X-3, X-4.
4389 Tsatsanis KD. Outcome research in asperger syndrome and autism. Child Adolesc Psychiatr Clin N Am. Jan. 2003;12(1):47-63. vi. X-2. [pmid: 12512398].
4390 Tsatsanis KD, Foley C, Donehower C. Contemporary outcome research and programming guidelines for asperger syndrome and high-functioning autism. Top Lang Disord. Oct–Dec. 2004;24(4):249. X-2, X-4.
4391 Tsiantis J, Macri I, Maratos O. Schizophrenia in children: a review of European research. Schizophr Bull. 1986;12(1):101-19. X-1, X-2, X-3, X-4. [pmid: 3961423].
4392 Tuchman R. Treatment of seizure disorders and EEG abnormalities in children with autism spectrum disorders. J Autism Dev Disord. Oct. 2000;30(5):485-9. X-2, X-4. [pmid: 11098889].
4393 Tuite DR, Luiten JW. 16PF research into addiction: meta-analysis and extension. Int J Addict. Mar. 1986;21(3):287-323. X-1, X-2, X-3, X-4. [pmid: 3721637].
4394 Turnbull A, Edmonson H, Griggs P, et al. A blueprint for schoolwide positive behavior support: Implementation of three components. Except Child. Spr. 2002;68(3):377-402. X-4.
4395 Turnbull A, Zuna N, Hong JY, et al. Knowledge-to-action guides: preparing families to be partners in making educational decisions. Teach Except Child. Jan–Feb. 2010;42(3):42-53. X-2, X-4.
4396 Turnbull HR 3rd, Wilcox BL, Stowe MJ. A brief overview of special education law with focus on autism. J Autism Dev Disord. Oct. 2002;32(5):479-93. X-2, X-4. [pmid: 12463521].
4397 Turner LM, Stone WL. Variability in outcome for children with an ASD diagnosis at age 2. J Child Psychol Psychiatry. Aug. 2007;48(8):793-802. X-1, X-3, X-4. [pmid: 17683451].
4398 Turner LM, Stone WL, Pozdol SL, et al. Follow-up of children with autism spectrum disorders from age 2 to age 9. Autism. May. 2006;10(3):243-65. X-1, X-3, X-4. [pmid: 16682397].
4399 Turner-Brown LM, Perry TD, Dichter GS, et al. Brief report: feasibility of social cognition and interaction training for adults with high functioning autism. J Autism Dev Disord. Oct. 2008;38(9):1777-84. X-3. [pmid: 18246419].
4400 Tustin F. Thoughts on autism with special reference to a paper by Melanie Klein. J Child Psychother. 1983;9(2):119-31. X-1, X-2, X-3, X-4.
4401 Tustin F. Autistic shapes. Int J Psychoanal. 1984;11(3):279-90. X-1, X-2, X-3, X-4.
4402 Tustin RD. The effects of advance notice of activity transitions on stereotypic behavior. J Appl Behav Anal. Spr. 1995;28(1):91-2. X-4. [pmid: 16795856].
4403 Tuttle LC. Experiential family therapy: An innovative approach to the resolution of family conflict in genetic counseling. Journal of Genetic Counseling. Apr. 1998;7(2):167-86. X-4.
4404 Twachtman-Reilly J, Amaral SC, Zebrowski PP. Addressing feeding disorders in children on the autism spectrum in school-based settings: physiological and behavioral issues. Lang Speech Hear Serv Sch. Apr. 2008;39(2):261-72. X-2. [pmid: 18420528].
4405 Twoy R, Connolly PM, Novak JM. Coping strategies used by parents of children with autism. J Am Acad Nurse Pract. May. 2007;19(5):251-60. X-1, X-3, X-4. [pmid: 17489958].
4406 Twyman JS, The Fred S. Keller School. J Appl Behav Anal. Win. 1998;31(4):695-701. X-1, X-2, X-3, X-4.
4407 Tyler CV, Schramm SC, Karafa M, et al. Chronic disease risks in young adults with autism spectrum disorder: Forewarned is forearmed. Am J Intellect Dev Disabil. Sep. 2011;116(5):371-80. X-4. [pmid: 21905805].
4408 Tyminski R. Long-term group psychotherapy for children with pervasive developmental disorders: evidence for group development. Int J Group Psychother. Apr. 2005;55(2):189-210. X-1, X-3, X-4. [pmid: 15899759].
4409 Tyminski RF, Moore PJ. The impact of group psychotherapy on social development in children with pervasive developmental disorders. Int J Group Psychother. Jul. 2008;58(3):363-79. X-1. [pmid: 18573027].
4410 Uchiyama T, Kurosawa M, Inaba Y. MMR-vaccine and regression in autism spectrum disorders: negative results presented from Japan. J Autism Dev Disord. Feb. 2007;37(2):210-7. X-4. [pmid: 16865547].
4411 Uehara I. An attempt at multiple counseling approaches to a client with autistic disabilities. Jpn J Counsel Sci. Oct. 1999;32(3):301-10. X-3.
4412 Ulke-Kurkcuoglu B, Kircaali-Iftar G. A comparison of the effects of providing activity and material choice to children with autism spectrum disorders. J Appl Behav Anal. Winter. 2010;43(4):717-21. X-3. [pmid: 21541155].
4413 Umeda C, Deitz J. Effects of therapy cushions on classroom behaviors of children with autism spectrum disorder. Am J Occup Ther. Mar–Apr. 2011;65(2):152-9. X-1, X-3, X-4. [pmid: 21476362].
4414 Unis AS, Munson JA, Rogers SJ, et al. A randomized, double-blind, placebo-controlled trial of porcine versus synthetic secretin for reducing symptoms of autism. J Am Acad Child Adolesc Psychiatry. Nov. 2002;41(11):1315-21. X-1, X-3, X-4. [pmid: 12410073].
4415 Unwin GL, Deb S. Use of medication for the management of behavior problems among adults with intellectual disabilities: a clinicians’ consensus survey. Am J Ment Retard. Jan. 2008;113(1):19-31. X-1, X-3, X-4. [pmid: 18173296].
4416 Urban E. The primary self and related concepts in Jung, Klein, and Isaacs. J Anal Psychol. Oct. 1992;37(4):411-32. X-2, X-4. [pmid: 1429214].
4417 Uvebrant P, Bauziene R. Intractable epilepsy in children. The efficacy of lamotrigine treatment, including non-seizure-related benefits. Neuropediatrics. Dec. 1994;25(6):284-9. X-1, X-3, X-4. [pmid: 7770124].
4418 Vacca JJ. Incorporating Interests and Structure to Improve Participation of a Child with Autism in a Standardized Assessment: A Case Study Analysis. Focus Autism Dev Disabil. Spr. 2007;22(1):51-9. X-2, X-4.
4419 Vaccarino FM, Urban AE, Stevens HE, et al. Annual research review: the promise of stem cell research for neuropsychiatric disorders. J Child Psychol Psychiatry. Apr. 2011;52(4):504-16. X-1, X-2, X-3, X-4. [pmid: 21204834].
4420 Vakalopoulos C. Unilateral neglect: a theory of proprioceptive space of a stimulus as determined by the cerebellar component of motor efference copy (and is autism a special case of neglect). Med Hypotheses. 2007;68(3):574-600. X-1, X-2, X-3, X-4. [pmid: 17070652].
4421 Valcante G. Educational implications of current research on the syndrome of autism. Behav Disord. Feb. 1986;11(2):131-39. X-1, X-2, X-3, X-4.
4422 Valdimarsdottir H, Halldorsdottir LY, Sigurdardottir ZG. Increasing the variety of foods consumed by a picky eater: generalization of effects across caregivers and settings. J Appl Behav Anal. Spr. 2010;43(1):101-5. X-1, X-3, X-4. [pmid: 20808499].
4423 Valdovinos MG, Nelson SM, Kuhle JL, et al. Using analogue functional analysis to measure variations in problem behavior rate and function after psychotropic medication changes: A clinical demonstration. J Ment Health Res Intellect Disabil. Oct. 2009;2(4):279-93. X-4.
4424 Valentine K. A consideration of medicalisation: choice, engagement and other responsibilities of parents of children with autism spectrum disorder. Soc Sci Med. Sep. 2010;71(5):950-7. X-1, X-3, X-4. [pmid: 20619521].
4425 Valicenti-McDermott MR, Demb H. Clinical effects and adverse reactions of off-label use of aripiprazole in children and adolescents with developmental disabilities. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):549-60. X-1, X-3. [pmid: 17069544].
4426 Van Acker R. Rett Syndrome: a review of current knowledge. J Autism Dev Disord. Dec. 1991;21(4):381-406. X-1, X-2, X-3, X-4. [pmid: 1778956].
4427 Van Adel JM, Geier JD, Perry A, et al. Credible knowledge: a pilot evaluation of a modified GRADE method using parent-implemented interventions for children with autism. BMC Health Serv Res. 2011;11:60. X-1, X-2, X-3, X-4. [pmid: 21426564].
4428 Van Berckelaer-Onnes IA. Promoting early play. Autism. Dec. 2003;7(4):415-23. X-2. [pmid: 14678680].
4429 van Berckelaer-Onnes IA, van Loon J, Peelen A. Challenging behaviour: a challenge to change. Autism. Sep. 2002;6(3):259-70. X-3. [pmid: 12212917].
4430 Van Bourgondien ME, Elgar S. The relationship between existing residential services and the needs of autistic adults. J Autism Dev Disord. Sep. 1990;20(3):299-308. X-1, X-2, X-3, X-4. [pmid: 2228913].
4431 Van Bourgondien ME, Reichle NC, Campbell DG, et al. The Environmental Rating Scale (ERS): a measure of the quality of the residential environment for adults with autism. Res Dev Disabil. Sep–Oct. 1998;19(5):381-94. X-4. [pmid: 9770251].
4432 Van Bourgondien ME, Reichle NC, Palmer A. Sexual behavior in adults with autism. J Autism Dev Disord. Apr. 1997;27(2):113-25. X-4. [pmid: 9105963].
4433 Van Bourgondien ME, Schopler E. Critical issues in the residential care of people with autism. J Autism Dev Disord. Sep. 1990;20(3):391-99. X-1, X-2, X-3, X-4. [pmid: 2228918].
4434 Van Brunt DL, Johnston JA, Ye W, et al. Predictors of selecting atomoxetine therapy for children with attention-deficit-hyperactivity disorder. Pharmacotherapy. Nov. 2005;25(11):1541-9. X-4. [pmid: 16232017].
4435 Van Camp CM, Vollmer TR, Daniel D. A systematic evaluation of stimulus preference, response effort, and stimulus control in the treatment of automatically reinforced self-injury. Behav Ther. Sum. 2001;32(3):603-13. X-3.
4436 van den Hazel P, Zuurbier M, Babisch W, et al. Today’s epidemics in children: possible relations to environmental pollution and suggested preventive measures. Acta Paediatr Suppl. Oct. 2006;95(453):18-25. X-2, X-4. [pmid: 17000565].
4437 van den Hazel T, Didden R, Korzilius H. Effects of personality disorder and other variables on professionals’ evaluation of treatment features in individuals with mild intellectual disabilities and severe behavior problems. Res Dev Disabil. May–Jun. 2009;30(3):547-57. X-4. [pmid: 18829254].
4438 van der Walt JH, Moran C. An audit of perioperative management of autistic children. Paediatr Anaesth. Jul. 2001;11(4):401-8. X-4. [pmid: 11442855].
4439 Van Dyke EM. Autistic disorder: early interventions can improve outcomes. JAAPA. Jul. 2009;22(7):18-9. X-2, X-4. [pmid: 19697566].
4440 van Engeland H. The electrodermal orienting response to auditive stimuli in autistic children, normal children, mentally retarded children, and child psychiatric patients. J Autism Dev Disord. Sep. 1984;14(3):261-79. X-1, X-3, X-4. [pmid: 6237097].
4441 van Engeland H, Roelofs JW, Verbaten MN, et al. Abnormal electrodermal reactivity to novel visual stimuli in autistic children. Psychiatry Res. Jul. 1991;38(1):27-38. X-4. [pmid: 1946832].
4442 Van Houten R, Rolider A. Recreating the scene: an effective way to provide delayed punishment for inappropriate motor behavior. J Appl Behav Anal. Summer. 1988;21(2):187-92. X-1, X-3, X-4. [pmid: 2458333].
4443 Van Laarhoven T, Kraus E, Karpman K, et al. A comparison of picture and video prompts to teach daily living skills to individuals with autism. Focus Autism Dev Disabil. Dec. 2010;25(4):195-208. X-3.
4444 Van Rie GL, Heflin LJ. The effect of sensory activities on correct responding for children with autism spectrum disorders. Res Autism Spectr Disord. Jul–Sep. 2009;3(3):783-96. X-3.
4445 van Roekel E, Scholte RHJ, Didden R. Bullying among adolescents with autism spectrum disorders: prevalence and perception. J Autism Dev Disord. Jan. 2010;40(1):63-73. X-4. [pmid: 19669402].
4446 Van Santen JP, Prud’hommeaux ET, Black LM, et al. Computational prosodic markers for autism. Autism. May. 2010;14(3):215-36. X-1, X-3, X-4. [pmid: 20591942].
4447 Van Soest M. Autism as a result of a dysfunctional hierarchy of the senses: treatment of autism by Van Soest therapy. J Autism Dev Disord. Dec. 1991;21(4):559-61. X-2, X-4. [pmid: 1778969].
4448 VanMeter L, Fein D, Morris R, et al. Delay versus deviance in autistic social behavior. J Autism Dev Disord. Oct. 1997;27(5):557-69. X-4. [pmid: 9403372].
4449 Vanvuchelen M, Vochten C. How much change is true change? The smallest detectable difference of the Preschool Imitation and Praxis Scale (PIPS) in preschoolers with intellectual disabilities of heterogeneous aetiology. Res Dev Disabil. Jan–Feb. 2011;32(1):180-7. X-1, X-2, X-3, X-4. [pmid: 20952157].
4450 Varley C, Kolff C, Trupin E, et al. Hemodialysis as a treatment for infantile autism. J Autism Dev Disord. Dec. 1980;10(4):399-404. X-3. [pmid: 6927743].
4451 Varley CK, Holm VA. A two-year follow-up of autistic children treated with fenfluramine. J Am Acad Child Adolesc Psychiatry. Jan. 1990;29(1):137-40. X-3. [pmid: 2295567].
4452 Vaughn BJ, Wilson D, Dunlap G. Family-centered intervention to resolve problem behaviors in a fast-food restaurant. J Posit Behav Interv. Win. 2002;4(1):38-45. X-1, X-3, X-4.
4453 Vazquez CA. Brief report: a multitask controlled evaluation of facilitated communication. J Autism Dev Disord. Jun. 1994;24(3):369-79. X-1, X-3, X-4. [pmid: 8050989].
4454 Vedora J, Meunier L, Mackay H. Teaching intraverbal behavior to children with autism: a comparison of textual and echoic prompts. Anal Verbal Behav. 2009;25:79-86. X-3. [pmid: 22477431].
4455 Venkatesan S. Activity log of preschool children with developmental disabilities and autism spectrum disorders. Asia Pac Disabil Rehab J. 2005;16(1):68-76. X-1, X-3, X-4.
4456 Venker CE, McDuffie AS, Ellis Weismer S, et al. Increasing verbal responsiveness in parents of children with autism: a pilot study. Autism. 2011. Aug. 16. X-1, X-3, X-4. [pmid: 21846665].
4457 Venn ML, Wolery M, Greco M. Effects of every-day and every-other-day instruction. Focus Autism Dev Disabil. Spr. 1996;11(1):15-28. X-1, X-3, X-4.
4458 Verbaten MN, Kemner C, Buitelaar JK, et al. Effects of ORG-2766 on brain event-related potentials of autistic children. Psychiatry Res. Jun. 26. 1996;63(1):33-45. X-1, X-3, X-4. [pmid: 8832772].
4459 Vered Y, Golubchik P, Mozes T, et al. The platelet-poor plasma 5-HT response to carbohydrate rich meal administration in adult autistic patients compared with normal controls. Human Psychopharmacology: Clinical and Experimental. Jul. 2003;18(5):395-9. X-4. [pmid: 12858328].
4460 Verheij F, Van Doorn EC. Autism and mental retardation: the planning of a therapeutic environment. Int J Rehabil Res. 1990;13(2):127-36. X-2, X-4. [pmid: 2269556].
4461 Vernon M, Rhodes A. Deafness and autistic spectrum disorders. Am Ann Deaf. Spr. 2009;154(1):5-14. X-1, X-2, X-3, X-4. [pmid: 19569300].
4462 Vessey JA. Care of the hospitalized child with a cognitive developmental delay. Holist Nurs Pract. Feb. 1988;2(2):48-54. X-1, X-3, X-4. [pmid: 2447107].
4463 Viau R, Arsenault-Lapierre G, Fecteau S, et al. Effect of service dogs on salivary cortisol secretion in autistic children. Psychoneuroendocrinology. Sep. 2010;35(8):1187-93. X-1, X-4. [pmid: 20189722].
4464 Victor H, Little SG, Akin-Little A. Increasing social engaged time in children with autism spectrum disorders using video self-modeling. Journal of Evidence Based Practices for Schools. 2011;12(1):105-24. X-3.
4465 Vig S, Jedrysek E. Adaptive behavior of young urban children with developmental disabilities. Ment Retard. Apr. 1995;33(2):90-8. X-4. [pmid: 7760730].
4466 Villa S, Micheli E, Villa L, et al. Further empirical data on the psychoeducational profile-revised (PEP-R): reliability and validation with the Vineland adaptive behavior scales. J Autism Dev Disord. Mar. 2010;40(3):334-41. X-4. [pmid: 19777332].
4467 Vismara LA, Colombi C, Rogers SJ. Can one hour per week of therapy lead to lasting changes in young children with autism?. Autism. Jan. 2009;13(1):93-115. X-1, X-3, X-4. [pmid: 19176579].
4468 Vismara LA, Lyons GL. Using perseverative interests to elicit joint attention behaviors in young children with autism: theoretical and clinical implications for understanding motivation. J Posit Behav Interv. 2007;9(4):214-28. X-1, X-2, X-3, X-4.
4469 Vismara LA, Rogers SJ. The early start denver model: a case study of an innovative practice. J Early Interv. 2008;31(1):91-108. X-1, X-3, X-4.
4470 Vismara LA, Young GS, Stahmer AC, et al. Dissemination of evidence-based practice: can we train therapists from a distance?. J Autism Dev Disord. Dec. 2009;39(12):1636-51. X-1, X-3, X-4. [pmid: 19582564].
4471 Visser M, Singer E, van Geert PLC, et al. What makes children behave aggressively? The inner logic of dutch children in special education. Eur J Spec Needs Educ. Feb. 2009;24(1):1-20. X-4.
4472 Vitiello B. An update on publicly funded multisite trials in pediatric psychopharmacology. Child Adolesc Psychiatr Clin N Am. Jan. 2006;15(1):1-12. X-2. [pmid: 16321723].
4473 Vitiello B. Recent NIMH clinical trials and implications for practice. J Am Acad Child Adolesc Psychiatry. Dec. 2008;47(12):1369-74. X-2. [pmid: 19034188].
4474 Vitiello B, Aman MG, Scahill L, et al. Research knowledge among parents of children participating in a randomized clinical trial. J Am Acad Child Adolesc Psychiatry. Feb. 2005;44(2):145-9. X-4. [pmid: 15689727].
4475 Vitiello B, Davies M, Arnold LE, et al. Assessment of the integrity of study blindness in a pediatric clinical trial of risperidone. J Clin Psychopharmacol. Dec. 2005;25(6):565-9. X-1, X-3, X-4. [pmid: 16282839].
4476 Vladescu JC, Kodak T. A review of recent studies on differential reinforcement during skill acquisition in early intervention. J Appl Behav Anal. Sum. 2010;43(2):351-5. X-1, X-2, X-3, X-4. [pmid: 21119913].
4477 Vlamings PH, Jonkman LM, Hoeksma MR, et al. Reduced error monitoring in children with autism spectrum disorder: an ERP study. Eur J Neurosci. Jul. 2008;28(2):399-406. X-4. [pmid: 18702711].
4478 Volden J. Features leading to judgements of inappropriacy in the language of speakers with autism: a preliminary study. J Speech Lang Pathol Aud. 2002;26(3):138-46. X-4.
4479 Volden J, Lord C. Neologisms and idiosyncratic language in autistic speakers. J Autism Dev Disord. Jun. 1991;21(2):109-30. X-4. [pmid: 1864825].
4480 Volden J, Magill-Evans J, Goulden K, et al. Varying language register according to listener needs in speakers with autism spectrum disorder. J Autism Dev Disord. Jul. 2007;37(6):1139-54. X-4. [pmid: 17160460].
4481 Volden J, Phillips L. Measuring pragmatic language in speakers with autism spectrum disorders: comparing the children’s communication checklist--2 and the test of pragmatic language. Am J Speech Lang Pathol. Aug. 2010;19(3):204-12. X-3, X-4. [pmid: 20220047].
4482 Volden J, Sorenson A. Bossy and nice requests: varying language register in speakers with autism spectrum disorder (ASD). J Commun Disord. Jan–Feb. 2009;42(1):58-73. X-4. [pmid: 18930471].
4483 Volker MA, Lopata C. Autism: a review of biological bases, assessment, and intervention. Sch Psychol Q. Jun. 2008;23(2):258-70. X-2, X-4.
4484 Volkert VM, Lerman DC, Call NA, et al. An evaluation of resurgence during treatment with functional communication training. J Appl Behav Anal. Spr. 2009;42(1):145-60. X-3. [pmid: 19721735].
4485 Volkert VM, Lerman DC, Trosclair N, et al. An exploratory analysis of task-interspersal procedures while teaching object labels to children with autism. J Appl Behav Anal. Fall. 2008;41(3):335-50. X-1, X-3, X-4. [pmid: 18816973].
4486 Volkert VM, Lerman DC, Vorndran C. The effects of reinforcement magnitude on functional analysis outcomes. J Appl Behav Anal. Summer. 2005;38(2):147-62. X-4. [pmid: 16033163].
4487 Volkert VM, Vaz PCM. Recent studies on feeding problems in children with autism. J Appl Behav Anal. Spr. 2010;43(1):155-9. X-2, X-4. [pmid: 20808508].
4488 Volkert VM, Vaz PCM, Piazza CC, et al. Using a flipped spoon to decrease packing in children with feeding disorders. J Appl Behav Anal. Fall. 2011;44(3):617-21. X-3. [pmid: 21941393].
4489 Volkmar F. Recently diagnosed with autism, autism or not. J Autism Dev Disord. Jun. 1998;28(3):269-70. X-1, X-2, X-3, X-4. [pmid: 9656140].
4490 Volkmar F. What is a “placebo controlled” study?. J Autism Dev Disord. Apr. 2001;31(2):251-2. X-2. [pmid: 11450827].
4491 Volkmar F. Predicting outcome in autism. J Autism Dev Disord. Feb. 2002;32(1):63-4. X-2. [pmid: 11916336].
4492 Volkmar F. Ask the editor. J Autism Dev Disord. Apr. 2006;36(3):437-8. X-2. [pmid: 16586156].
4493 Volkmar FR, Cohen DJ. Current concepts: infantile autism and the pervasive developmental disorders. J Dev Behav Pediatr. Oct. 1986;7(5):324-9. X-1, X-2, X-3, X-4. [pmid: 3771807].
4494 Volkmar FR, Hoder EL, Cohen DJ. Compliance, ‘negativism’, and the effects of treatment structure in autism: a naturalistic, behavioral study. J Child Psychol Psychiatry. Nov. 1985;26(6):865-77. X-3. [pmid: 4066813].
4495 Volkmar FR, Hoder EL, Cohen DJ. Inappropriate uses of stimulant medications. Clin Pediatr. Mar. 1985;24(3):127-30. X-1, X-3, X-4.
4496 Volkmar FR, Klin A, Schultz RT, et al. Asperger’s disorder. Am J Psychiatry. Feb. 2000;157(2):262-7. X-4. [pmid: 10671397].
4497 Volkmar FR, Rutter M. Childhood disintegrative disorder: results of the DSM-IV autism field trial. J Am Acad Child Adolesc Psychiatry. Aug. 1995;34(8):1092-5. X-4. [pmid: 7665448].
4498 Volkmar FR, Sparrow SS, Goudreau D, et al. Social deficits in autism: an operational approach using the Vineland Adaptive Behavior Scales. J Am Acad Child Adolesc Psychiatry. Mar. 1987;26(2):156-61. X-1, X-3, X-4. [pmid: 3584011].
4499 Vollmer TR, Borrero JC, Lalli JS, et al. Evaluating self-control and impulsivity in children with severe behavior disorders. J Appl Behav Anal. Winter. 1999;32(4):451-66. X-3. [pmid: 10641300].
4500 Von Benzon N. Moving on from ramps? The utility of the social model of disability for facilitating experiences of nature for disabled children. Disabil Soc. Aug. 2010;25(5):617-26. X-1, X-3, X-4.
4501 von der Embse N, Brown A, Fortain J. Facilitating inclusion by reducing problem behaviors for students with autism spectrum disorders. Interv School Clinic. Sep. 2011;47(1):22-30. X-1, X-2, X-3.
4502 Vonder Hulls DS, Walker LK, Powell JM. Clinicians’ perceptions of the benefits of aquatic therapy for young children with autism: a preliminary study. Phys Occup Ther Pediatr. 2006;26(1–2):13-22. X-1, X-3, X-4. [pmid: 16938823].
4503 Vorgraft Y, Farbstein I, Spiegel R, et al. Retrospective evaluation of an intensive method of treatment for children with pervasive developmental disorder. Autism. Sep. 2007;11(5):413-24. X-1, X-3, X-4. [pmid: 17942455].
4504 Vourc’h P, Martin I, Bonnet-Brilhault F, et al. Mutation screening and association study of the UBE2H gene on chromosome 7q32 in autistic disorder. Psychiatr Genet. Dec. 2003;13(4):221-5. X-1, X-3, X-4. [pmid: 14639049].
4505 Wachtel LE, Contrucci-Kuhn SA, Griffin M, et al. ECT for self-injury in an autistic boy. Eur Child Adoles Psychiatry. Jul. 2009;18(7):458-63. X-1, X-3, X-4.
4506 Wachtel LE, Dhossche DM. Self-injury in autism as an alternate sign of catatonia: implications for electroconvulsive therapy. Med Hypotheses. Jul. 2010;75(1):111-4. X-1, X-2, X-3, X-4. [pmid: 20202760].
4507 Wachtel LE, Dhossche DM, Kellner CH. When is electroconvulsive therapy appropriate for children and adolescents?. Med Hypotheses. Mar. 2011;76(3):395-9. X-1, X-2, X-3, X-4. [pmid: 21129852].
4508 Wachtel LE, Griffin MM, Dhossche DM, et al. Brief report: electroconvulsive therapy for malignant catatonia in an autistic adolescent. Autism. 2010;14(4):349-58. X-3. [pmid: 20591959].
4509 Waddington EM, Reed P. The impact of using the “Preschool Inventory of Repertoires for Kindergarten” (PIRK^®^) on school outcomes of children with autistic spectrum disorders. Res Autism Spectr Disord. Jul–Sep. 2009;3(3):809-27. X-1, X-3, X-4.
4510 Wager KM. The effects of music therapy upon an adult male with autism and mental retardation: a four-year case study. Music Ther Perspect. 2000;18(2):131-40. X-1, X-3, X-4.
4511 Wagner A, Lecavalier L, Arnold LE, et al. Developmental disabilities modification of the Children’s Global Assessment Scale. Biol Psychiatry. Feb. 15. 2007;61(4):504-11. X-1, X-3, X-4. [pmid: 17276748].
4512 Wagner EE, Wagner CF, Hilsenroth MJ, et al. A taxonomy of Rorschach autisms with implications for differential diagnosis among thinking-disordered patients. J Clin Psychol. Mar. 1995;51(2):290-3. X-4. [pmid: 7797654].
4513 Wainscot JJ, Naylor P, Sutcliffe P, et al. Relationships with peers and use of the school environment of mainstream secondary school pupils with asperger syndrome (high-functioning autism): a case-control study. Rev Int Psicol Ter Psicol. 2008;8(1):25-38. X-4.
4514 Wakschlag LS, Leventhal BL. Consultation with young autistic children and their families. J Am Acad Child Adolesc Psychiatry. Jul. 1996;35(7):963-5. X-1, X-3, X-4. [pmid: 8768359].
4515 Waldman HB, Perlman SP. Mega numbers, lobbying and providing care for individuals with autism. J Okla Dent Assoc. Oct. 8. 2009;100(7):16-20. X-2, X-4. [pmid: 19943502].
4516 Walker AN, Barry TD, Bader SH. Therapist and parent ratings of changes in adaptive social skills following a summer treatment camp for children with autism spectrum disorders: a preliminary study. Child Youth Care Forum. Oct. 2010;39(5):305-22. X-1, X-3, X-4.
4517 Wall JA. Group Homes in North Carolina for Children and Adults with Autism. J Autism Dev Disord. Sep. 1990;20(3):353-66. X-1, X-2, X-3, X-4. [pmid: 2228917].
4518 Wall ME, Gast DL. Caregivers’ use of constant time delay to teach leisure skills to adolescents or young adults with moderate or severe intellectual disabilities. Educ Train Ment Retard Dev Disabil. Dec. 1997;32(4):340-56. X-3.
4519 Wallace C, Leask J, Trevena LJ. Effects of a web based decision aid on parental attitudes to MMR vaccination: a before and after study. BMJ. Jan. 21. 2006;332(7534):146-9. X-4. [pmid: 16352657].
4520 Wallace GL, Dankner N, Kenworthy L, et al. Age-related temporal and parietal cortical thinning in autism spectrum disorders. Brain. Dec. 2010;133(Pt 12):3745-54. X-4. [pmid: 20926367].
4521 Wallace GL, Silvers JA, Martin A, et al. Brief report: further evidence for inner speech deficits in autism spectrum disorders. J Autism Dev Disord. 2009;39(12):1735-9. X-4. [pmid: 19565331].
4522 Wallace KS, Rogers SJ. Intervening in Infancy: implications for autism spectrum disorders. J Child Psychol Psychiatry. Dec. 2010;51(12):1300-20. X-1, X-2, X-3, X-4. [pmid: 20868374].
4523 Wallace S, Parsons S, Westbury A, et al. Sense of presence and atypical social judgments in immersive virtual environments. Responses of adolescents with autism spectrum disorders. Autism. May. 2010;14(3):199-213. X-3, X-4. [pmid: 20484000].
4524 Walters AS, Barrett RP, Feinstein C, et al. A case report of naltrexone treatment of self-injury and social withdrawal in autism. J Autism Dev Disord. Jun. 1990;20(2):169-76. X-3. [pmid: 2189867].
4525 Walworth DD. The use of music therapy within the SCERTS model for children with autism spectrum disorder. J Music Ther. Spring. 2007;44(1):2-22. X-1, X-3, X-4. [pmid: 17419661].
4526 Walworth DD, Register D, Engel JN. Using the SCERTS model assessment tool to identify music therapy goals for clients with autism spectrum disorder. J Music Ther. Fall. 2009;46(3):204-16. X-4. [pmid: 19757876].
4527 Wang H-T, Sandall SR, Davis CA, et al. Social skills assessment in young children with autism: a comparison evaluation of the SSRS and PKBS. J Autism Dev Disord. Nov. 2011;41(11):1487-95. X-1, X-3, X-4. [pmid: 21225453].
4528 Wang L, Leslie DL. Health care expenditures for children with autism spectrum disorders in Medicaid. J Am Acad Child Adolesc Psychiatry. Nov. 2010;49(11):1165-71. X-1, X-3, X-4. [pmid: 20970704].
4529 Wang PP. International adoption: A four-year-old child with unusual behaviors adopted at six months of age: Paul P. Wang, M.D. J Dev Behav Pediatr. Feb. 2003;24(1):68-9. X-4.
4530 Wank R. Schizophrenia and other mental disorders require long-term adoptive immunotherapy. Med Hypotheses. Aug. 2002;59(2):154-8. X-3. [pmid: 12208201].
4531 Ward P, Ayvazo S. Classwide peer tutoring in physical education: assessing its effects with kindergartners with autism. Adapt Phys Activ Q. 2006;23(3):233-44. X-1, X-3, X-4.
4532 Waring RH, Klovrza LV. Sulphur metabolism in autism. J Nutr Environ Med. 2000;10(1):25-32. X-4.
4533 Warner LA. Medical problems among adolescents in U.S. mental health services: relationship to functional impairment. J Behav Health Serv Res. Jul. 2006;33(3):366-79. X-1, X-3, X-4. [pmid: 16752113].
4534 Warren SF, Brady N, Sterling A, et al. Maternal responsivity predicts language development in young children with fragile X syndrome. Am J Intellect Dev Disabil. Jan. 2010;115(1):54-75. X-4. [pmid: 20025359].
4535 Warren Z, Stone W, Humberd Q. A training model for the diagnosis of autism in community pediatric practice. J Dev Behav Pediatr. Oct. 2009;30(5):442-6. X-4. [pmid: 19823138].
4536 Warwick TC, Griffith J, Reyes B, et al. Effects of vagus nerve stimulation in a patient with temporal lobe epilepsy and asperger syndrome: case report and review of the literature. Epilepsy Behav. Mar. 2007;10(2):344-7. X-3. [pmid: 17300990].
4537 Wasdell MB, Jan JE, Bomben MM, et al. A randomized, placebo-controlled trial of controlled release melatonin treatment of delayed sleep phase syndrome and impaired sleep maintenance in children with neurodevelopmental disabilities. J Pineal Res. Jan. 2008;44(1):57-64. X-1, X-3, X-4. [pmid: 18078449].
4538 Wasserman S, Iyengar R, Chaplin WF, et al. Levetiracetam versus placebo in childhood and adolescent autism: a double-blind placebo-controlled study. Int Clin Psychopharmacol. Nov. 2006;21(6):363-7. X-1, X-3. [pmid: 17012983].
4539 Watanabe M, Sturmey P. The effect of choice-making opportunities during activity schedules on task engagement of adults with autism. J Autism Dev Disord. Oct. 2003;33(5):535-8. X-3. [pmid: 14594333].
4540 Waters L. Reinforcing the empty fortress: an examination of recent research into the treatment of autism. Ed Stud. 1990;16(1):3-16. X-1, X-2, X-3, X-4.
4541 Waters MB, Lerman DC, Hovanetz AN. Separate and combined effects of visual schedules and extinction plus differential reinforcement on problem behavior occasioned by transitions. J Appl Behav Anal. Summer. 2009;42(2):309-13. X-3. [pmid: 19949517].
4542 Watling R, Asher A, Chandler B, et al. AOTA’s societal statement on autism spectrum disorders. Am J Occup Ther. Nov–Dec. 2009;63(6):843-4. X-2, X-4. [pmid: 20092121].
4543 Watling R, Deitz J, Kanny EM, et al. Current practice of occupational therapy for children with autism. Am J Occup Ther. Sep–Oct. 1999;53(5):498-505. X-4. [pmid: 10500858].
4544 Watling R, Tomchek S, LaVesser P. The scope of occupational therapy services for individuals with autism spectrum disorders across the lifespan. Am J Occup Ther. Nov–Dec. 2005;59(6):680-3. X-2. [pmid: 16363193].
4545 Watling RL, Deitz J, White O. Comparison of sensory profile scores of young children with and without autism spectrum disorders. Am J Occup Ther. Jul–Aug. 2001;55(4):416-23. X-4. [pmid: 11723986].
4546 Watling RL, Dietz J. Immediate effect of ayres’s sensory integration-based occupational therapy intervention on children with autism spectrum disorders. Am J Occup Ther. Sep–Oct. 2007;61(5):574-83. X-3. [pmid: 17944295].
4547 Watson AF, Blanco J, Hunt-Hurst P, et al. Caregivers’ perceptions of clothing for people with severe and profound intellectual disabilities. Percept Mot Skills. 2010;110(3 Part 1):961-4. X-4. [pmid: 20681346].
4548 Watson LR. Following the child’s lead: mothers’ interactions with children with autism. J Autism Dev Disord. Feb. 1998;28(1):51-9. X-4. [pmid: 9546302].
4549 Watson LR, Baranek GT, Roberts JE, et al. Behavioral and physiological responses to child-directed speech as predictors of communication outcomes in children with autism spectrum disorders. J Speech Lang Hear Res. Aug. 2010;53(4):1052-64. X-1, X-3, X-4. [pmid: 20631229].
4550 Watson R, Parr JR, Joyce C, et al. Models of transitional care for young people with complex health needs: a scoping review. Child Care Health Dev. Nov. 2011;37(6):780-91. X-1, X-2, X-3, X-4. [pmid: 22007977].
4551 Watson SF. Barriers to inclusive education in Ireland: the case for pupils with a diagnosis of intellectual and or pervasive developmental disabilities. Br J Learn Disabil. Dec. 2009;37(4):277-84. -1, X-2, X-3, X-4.
4552 Watters RG, Watters WE. Decreasing self-stimulatory behavior with physical exercise in a group of autistic boys. J Autism Dev Disord. Dec. 1980;10(4):379-87. X-3. [pmid: 6927742].
4553 Watters RG, Wheeler LJ, Watters WE. The relative efficiency of two orders for training autistic children in the expressive and receptive use of manual signs. J Commun Disord. Jul. 1981;14(4):273-85. X-3. [pmid: 7263933].
4554 Webb BJ, Miller SP, Pierce TB, et al. Effects of social skill instruction for high-functioning adolescents with autism spectrum disorders. Focus Autism Other Dev Disabil. 2004;19(1):53-62. X-3.
4555 Webb EVJ, Lobo S, Hervas A, et al. The changing prevalence of autistic disorder in a Welsh health district. Dev Med Child Neurol. Mar. 1997;39(3):150-7. X-4. [pmid: 9112962].
4556 Webb SJ, Jones EJH. Early identification of autism: early characteristics, onset of symptoms, and diagnostic stability. Infants Young Child. Apr–Jun. 2009;22(2):100-18. X-1, X-2, X-3, X-4.
4557 Webber CF. Mainstreaming a child with autism: one school’s experience. Focus Autistism Other Dev Disabil. Aug. 1990;5(3):8-12. X-1, X-3, X-4.
4558 Webber LS, McVilly KR, Chan J. Restrictive interventions for people with a disability exhibiting challenging behaviours: analysis of a population database. J Appl Res Intellect Disabil. Nov. 2011;24(6):495-507. X-4.
4559 Webber LS, McVilly KR, Stevenson E, et al. The use of restrictive interventions in Victoria, Australia: population data for 2007–2008. AM J Intellect Dev Disabil. 2010;35(3):199-206. X-4.
4560 Weber BP, Dillo W, Dietrich B, et al. Pediatric cochlear implantation in cochlear malformations. Am J Otol. Nov. 1998;19(6):747-53. X-4. [pmid: 9831148].
4561 Weber RC, Thorpe J. Teaching children with autism through task variation in physical education. Except Child. Sep. 1992;59(1):77-86. X-3. [pmid: 1396953].
4562 Webster A, Feiler A, Webster V. Early intensive family intervention and evidence of effectiveness: lessons from the South West Autism Programme. Early Child Dev Care. Aug. 2003;173(4):383-98. X-1, X-2, X-3, X-4.
4563 Webster A, Feiler A, Webster V, et al. Parental perspectives on early intensive intervention for children diagnosed with autistic spectrum disorder. Early Child Res Q. 2004;2(1):25-49. X-2.
4564 Weeden M, Porter LK, Durgin A, et al. Reporting of medication information in applied studies of people with autism. Res Autism Spectr Disord. Jan–Mar. 2011;5(1):108-11. X-1, X-2, X-3, X-4.
4565 Wegner LM, Macias MM. Services for children and adolescents with autism spectrum disorders: payment issues. Pediatr Ann. Jan. 2009;38(1):57-61. X-2, X-4. [pmid: 19213294].
4566 Wehman P. A New Era: revitalizing special education for children and their families. Focus Autism Dev Disabil. Win. 2002;17(4):194-97. X-1, X-2, X-3, X-4.
4567 Wehman P, Kregel J. Supported competitive employment for individuals with autism and severe retardation: two case studies. Focus Autistism Other Dev Disabl. Aug. 1988;3(3):14. X-3.
4568 Weil TN, Inglehart MR. Dental education and dentists’ attitudes and behavior concerning patients with autism. J Dent Educ. Dec. 2010;74(12):1294-307. X-1, X-3, X-4. [pmid: 21123497].
4569 Weinkauf SM, Zeug NM, Anderson CT, et al. Evaluating the effectiveness of a comprehensive staff training package for behavioral interventions for children with autism. Res Autism Spectr Disord. Apr–Jun. 2011;5(2):864-71. X-3, X-4.
4570 Weintraub FJ, Myers RM, Hehir T, et al. A contextual overview of the modified consent decree in the Los Angeles Unified School District. J Spec Educ Leadersh. Sep. 2008;21(2):51-7. X-2, X-4.
4571 Weiskop S, Matthews J, Richdale A. Treatment of sleep problems in a 5-year-old boy with autism using behavioural principles. Autism. Jun. 2001;5(2):209-21. X-1, X-3, X-4. [pmid: 11706867].
4572 Weiskop S, Richdale A, Matthews J. Behavioural treatment to reduce sleep problems in children with autism or fragile X syndrome. Dev Med Child Neurol. Feb. 2005;47(2):94-104. X-1, X-3, X-4. [pmid: 15707232].
4573 Weiss JA, Lunsky Y. Group cognitive behaviour therapy for adults with asperger syndrome and anxiety or mood disorder: A case series. Clin Psychol Psychother. Sep–Oct. 2010;17(5):438-46. X-3. [pmid: 20827741].
4574 Weiss MJ. Differential rates of skill acquisition and outcomes of early intensive behavioral intervention for autism. Behav Int. Jan–Mar. 1999;14(1):3-22. X-1, X-3, X-4.
4575 Weiss MJ, DelPizzo-Cheng E, LaRue RH, et al. ABA and PBS: the dangers in creating artificial dichotomies in behavioral intervention. Behav Anal Today. 2009;10(3–4):428-39. X-1, X-2, X-3, X-4.
4576 Weiss MJ, Pearson N, Foley K, et al. The importance of fluency outcomes in learners with autism. Behav Anal Today. 2010;11(4):245-52. X-1, X-2, X-3, X-4.
4577 Weiss SJ. Personality adjustment and social support of parents who care for children with pervasive developmental disorders. Arch Psychiatr Nurs. Feb. 1991;5(1):25-30. X-1, X-3, X-4. [pmid: 2039277].
4578 Weiss SJ. Stressors experienced by family caregivers of children with pervasive developmental disorders. Child Psychiatry Hum Dev. Spring. 1991;21(3):203-16. X-1, X-3, X-4. [pmid: 2007345].
4579 Weizman R, Gil-Ad I, Dick J, et al. Low plasma immunoreactive !b-endorphin levels in autism. J Am Acad Child Adolesc Psychiatry. Jul. 1988;27(4):430-3. [pmid: 2972691].
4580 Wek SR, Husak WS. Distributed and massed practice effects on motor performance and learning of autistic children. Percept Mot Skills. Feb. 1989;68(1):107-13. X-3. [pmid: 2928030].
4581 Welch MG. Toward prevention of developmental disorders. Pa Med. Mar. 1987;90(3):47-52. X-1, X-2, X-3, X-4. [pmid: 2436128].
4582 Welch MG, Chaput P. Mother-child holding therapy and autism. Pa Med. Oct. 1988;91(10):33-8. X-1, X-3, X-4. [pmid: 3226740].
4583 Wellman HM, Baron-Cohen S, Caswell R, et al. Thought-bubbles help children with autism acquire an alternative to a theory of mind. Autism. Dec. 2002;6(4):343-63. X-3. [pmid: 12540127].
4584 Welterlin A, LaRue RH. Serving the needs of immigrant families of children with autism. Disabil Soc. Dec. 2007;22(7):747-60. X-2.
4585 Weng SJ, Wiggins JL, Peltier SJ, et al. Alterations of resting state functional connectivity in the default network in adolescents with autism spectrum disorders. Brain Res. Feb. 8. 2010;1313:202-14. X-3, X-4. [pmid: 20004180].
4586 Werner S. Assessing female students’ attitudes in various health and social professions toward working with people with autism: a preliminary study. J Interprof Care. Mar. 2011;25(2):131-7. X-1, X-3, X-4. [pmid: 21182438].
4587 Werry JS. Child and Adolescent (Early Onset) Schizophrenia: a review in light of DSM-III-R. J Autism Dev Disord. Dec. 1992;22(4):601-24. X-1, X-2, X-3, X-4. [pmid: 1483979].
4588 West L, Waldrop J, Brunssen S. Pharmacologic treatment for the core deficits and associated symptoms of autism in children. J Pediatr Health Care. Mar–Apr. 2009;23(2):75-89. X-2. [pmid: 19232924].
4589 Westendorp M, Houwen S, Hartman E, et al. Are gross motor skills and sports participation related in children with intellectual disabilities?. Res Dev Disabil. May–Jun. 2011;32(3):1147-53. X-4. [pmid: 21310587].
4590 Wetherby AM. Ontogeny of communicative functions in autism. J Autism Dev Disord. Sep. 1986;16(3):295-316. X-1, X-2, X-3, X-4. [pmid: 3558289].
4591 Wetherby AM, Prizant BM, Hutchinson TA. Communicative, social/affective, and symbolic profiles of young children with autism and pervasive developmental disorders. Am J Speech Lang Pathol. 1998;7(2):79-91. X-1, X-3, X-4.
4592 Wetherby AM, Woods JJ. Early social interaction project for children with autism spectrum disorders beginning in the second year of life: a preliminary study. Topics Early Child Spec Educ. Sum. 2006;26(2):67-82. X-1, X-3, X-4.
4593 Whalen C, Moss D, Ilan AB, et al. Efficacy of TeachTown: basics computer-assisted intervention for the Intensive Comprehensive Autism Program in Los Angeles Unified School District. Autism. May. 2010;14(3):179-97. X-1, X-3, X-4. [pmid: 20484002].
4594 Whalen C, Schreibman L. Joint attention training for children with autism using behavior modification procedures. J Child Psychol Psychiatry. Mar. 2003;44(3):456-68. X-1, X-3, X-4. [pmid: 12635974].
4595 Whalen C, Schreibman L, Ingersoll B. The collateral effects of joint attention training on social initiations, positive affect, imitation, and spontaneous speech for young children with autism. J Autism Dev Disord. Jul. 2006;36(5):655-64. X-1, X-3, X-4. [pmid: 16810564].
4596 Whalon KJ, Hart JE. Children with autism spectrum disorder and literacy instruction: an exploratory study of elementary inclusive settings. Remedial Spec Educ. May–Jun. 2011;32(3):243-55. X-3, X-4.
4597 Wheeler AC, Hatton D, Holloway VT, et al. Maternal responses to child frustration and requests for help in dyads with fragile X syndrome. J Intellect Disabil Res. Jun. 2010;54(6):501-15. X-1, X-3, X-4. [pmid: 20426796].
4598 Wheeler DL, Jacobson JW, Paglieri RA, et al. An experimental assessment of facilitated communication. Ment Retard. Feb. 1993;31(1):49-59. X-3. [pmid: 8441353].
4599 Wheeler JJ, Baggett BA, Fox J, et al. Treatment integrity: a review of intervention studies conducted with children with autism. Focus Autism Dev Disabil. Spr. 2006;21(1):45-54. X-2, X-4.
4600 Wheeler JJ, Carter SL, Mayton MR, et al. Preventing challenging behaviour through the management of instructional antecedents. Dev Disabil Bull. 2006;34(1–2):1-14. X-1, X-2, X-3, X-4.
4601 Whipple J. Music in intervention for children and adolescents with Autism: a meta-analysis. J Music Ther. Sum. 2004;41(2):90-106. X-1, X-2, X-3, X-4. [pmid: 15307805].
4602 White SE. The influence of religiosity on well-being and acceptance in parents of children with autism spectrum disorder. J Relig Disabil Health. 2009;13(2):104-13. X-4.
4603 White SE, Weiss JA. Services for adults and adolescents with ASD in Ontario—parent and professional perspectives. J Dev Disabil. 2010;16(1):34-9. X-1, X-3, X-4.
4604 White SW, Albano AM, Johnson CR, et al. Development of a cognitive-behavioral intervention program to treat anxiety and social deficits in teens with high-functioning autism. Clin Child Fam Psychol Rev. Mar. 2010;13(1):77-90. X-1, X-2, X-3, X-4. [pmid: 20091348].
4605 White SW, Koenig K, Scahill L. Group social skills instruction for adolescents with high-functioning autism spectrum disorders. Focus Autism Dev Disabil. Dec. 2010;25(4):209-19. X-3.
4606 White SW, Ollendick T, Scahill L, et al. Preliminary efficacy of a cognitive-behavioral treatment program for anxious youth with autism spectrum disorders. J Autism Dev Disord. Dec. 2009;39(12):1652-62. X-3. [pmid: 19568924].
4607 White SW, Scahill L, Klin A, et al. Educational placements and service use patterns of individuals with autism spectrum disorders. J Autism Dev Disord. Sep. 2007;37(8):1403-12. X-1, X-3, X-4. [pmid: 17082975].
4608 Whitehouse AJ, Bishop DV. Do children with autism ‘switch off’ to speech sounds? An investigation using event-related potentials. Dev Sci. Jul. 2008;11(4):516-24. X-4. [pmid: 18576959].
4609 Whitehouse AJ, Maybery M, Wray JA, et al. No association between early gastrointestinal problems and autistic-like traits in the general population. Dev Med Child Neurol. May. 2011;53(5):457-62. X-4. [pmid: 21418197].
4610 Whitehouse AJO, Hird K. Is grammatical competence a precondition for belief-desire reasoning? Evidence from typically developing children and those with autism. Int J Speech Lang Pathol. 2004;6(1):39-51. X-3.
4611 Whitehouse AJO, Watt HJ, Line EA, et al. Adult psychosocial outcomes of children with specific language impairment, pragmatic language impairment and autism. Int J Lang Commun Disord. 2009;44(4):511-28. X-3, X-4. [pmid: 19340628].
4612 Whiteley P. Autism unravelled conference--’the biology of autism--unravelled’. Expert Opin Pharmacother. Jul. 2001;2(7):1191-3. X-2, X-4. [pmid: 11583070].
4613 Whiteley P, Haracopos D, Knivsberg AM, et al. The ScanBrit randomised, controlled, single-blind study of a gluten- and casein-free dietary intervention for children with autism spectrum disorders. Nutr Neurosci. Apr. 2010;13(2):87-100. X-1, X-3, X-4. [pmid: 20406576].
4614 Whiteley P, Haracopos D, Knivsberg A-M, et al. The ScanBrit randomized controlled, single-blind study of a gluten- and casein-free dietary intervention for children with autism spectrum disorders. Nutr Neurosci. Apr. 2010;13(2):87-100. X-1, X-3, X-4. [pmid: 20406576].
4615 Whiteley P, Rodgers J, Savery D, et al. A gluten-free diet as an intervention for autism and associated spectrum disorders: Preliminary findings. Autism. Mar. 1999;3(1):45-65. X-1, X-3, X-4.
4616 Whiteley P, Rodgers J, Shattock P. MMR and autism. Autism. Jun. 2000;4(2):207-11. X-4.
4617 Whiteley P, Shattock P. What makes trans-indolyl-3-acryloylglycine identified by high-performance liquid chromatography relevant to pervasive developmental disorders?. J Nutr Environ Med. 2003;13(4):231-7. X-4.
4618 Whitenstall M. My life with Asperger’s syndrome. Arch Dis Child. Mar. 2004;89(3):281. X-1, X-2, X-3, X-4. [pmid: 14977714].
4619 Whitney-Thomas J, Shaw D, Honey K, et al. Building a future: A study of student participation in person-centered planning. J Assoc Pers Sev Handicaps. Sum. 1998;23(2):119-33. X-3, X-4.
4620 Whittaker CA, Reynolds J. Hand signalling in dyadic proximal communication: social strengths of children with autism who do not speak. Child Lang Teach Ther. 2000;16(1):43-57. X-3.
4621 Whittingham K, Sofronoff K, Sheffield J, et al. Do parental attributions affect treatment outcome in a parenting program? An exploration of the effects of parental attributions in an RCT of stepping stones triple P for the ASD population. Res Autism Spectr Disord. Jan. 2009;3(1):129-44. X-1, X-3, X-4.
4622 Whittingham K, Sofronoff K, Sheffield J, et al. Stepping stones triple P: an rct of a parenting program with parents of a child diagnosed with an autism spectrum disorder. J Abnorm Child Psychol. May. 2009;37(4):469-80. X-1, X-3. [pmid: 19023654].
4623 Whittingham K, Sofronoff K, Sheffield JK. Stepping stones triple P: a pilot study to evaluate acceptability of the program by parents of a child diagnosed with an autism spectrum disorder. Res Dev Disabil. Jul–Aug. 2006;27(4):364-80. X-1, X-3, X-4. [pmid: 16051461].
4624 Wichnick AM, Vener SM, Keating C, et al. The effect of a script-fading procedure on unscripted social initiations and novel utterances among young children with autism. Res Autism Spectr Disord. Jan–Mar. 2010;4(1):51-64. X-1, X-3, X-4.
4625 Wick JY, Zanni GR. Autism and aging: hardly out of the woods. Consult Pharm. Sep. 2009;24(9):648-50. 53. 60. X-2, X-4. [pmid: 19842781].
4626 Wieder S. Integrated treatment approaches for young children with multisystem developmental disorder. Infants Young Child. Jan. 1996;8(3):24-34. X-1, X-2, X-3, X-4.
4627 Wiggins LD, Bakeman R, Adamson LB, et al. The utility of the social communication questionnaire in screening for autism in children referred for early intervention. Focus Autism Dev Disabil. Spr. 2007;22(1):33-8. X-4.
4628 Wilczynski SM, Fusilier I, Dubard M, et al. Experimental analysis of proximity as a social stimulus: increasing on-task behavior of an adolescent with autism. Psychol Sch. Feb. 2005;42(2):189-96. X-1, X-3, X-4.
4629 Wilczynski SM, Menousek K, Hunter M, et al. Individualized education programs for youth with autism spectrum disorders. Psychol Sch. Sep. 2007;44(7):653-66. X-2.
4630 Wilder DA, Allison J, Nicholson K, et al. Further evaluation of antecedent interventions on compliance: the effects of rationales to increase compliance among preschoolers. J Appl Behav Anal. Winter. 2010;43(4):601-13. X-1, X-3, X-4. [pmid: 21541147].
4631 Wilder DA, Register M, Register S, et al. Functional analysis and treatment of rumination using fixed-time delivery of a flavor spray. J Appl Behav Anal. Winter. 2009;42(4):877-82. X-3. [pmid: 20514197].
4632 Wiley S, Choo D, Meinzen-Derr J, et al. GJB2 mutations and additional disabilities in a pediatric cochlear implant population. Int J Pediatr Otorhinolaryngol. Mar. 2006;70(3):493-500. X-4. [pmid: 16154643].
4633 Wilkins D. I’m not sure what I want (and I don’t know how to get it): how do social care workers perceive the parental relationships of children with autistic spectrum conditions?. J Soc Work Pract. 2010;24(1):89-101. X-1, X-3, X-4.
4634 Wilkinson KM, Albert A. Adaptions [sic] of fast mapping for vocabulary intervention with augmented language users. AAC. 2001;17(2):120-32. X-3.
4635 Wilkinson KM, Rosenquist C. Demonstration of a method for assessing semantic organization and category membership in individuals with autism spectrum disorders and receptive vocabulary limitations. AAC: Augmentative & Alternative Communication. 2006;22(4):242-57. X-1, X-2, X-3, X-4.
4636 Wilkinson LA. Supporting the inclusion of a student with asperger syndrome: a case study using conjoint behavioural consultation and self-management. Educ Psychol Prac. Dec. 2005;21(4):307-26. X-1.
4637 Wilkinson LA. Self-management for children with high-functioning autism spectrum disorders. Interv School Clinic. 2008;43(3):150-7. X-2.
4638 Wilkinson LA. Facilitating the identification of autism spectrum disorders in school-age children. Remedial Spec Educ. Sep–Oct. 2010;31(5):350-7. X-1, X-2, X-3, X-4.
4639 Wilkinson LA. School-age children with autism spectrum disorders: screening and identification. Eur J Spec Needs Educ. Aug. 2010;25(3):211-23. X-1, X-2, X-3, X-4.
4640 Willemsen-Swinkels SH, Buitelaar JK, van Berckelaer-Onnes IA, et al. Brief report: six months continuation treatment in naltrexone-responsive children with autism: an open-label case-control design. J Autism Dev Disord. Apr. 1999;29(2):167-9. X-1, X-3, X-4. [pmid: 10382138].
4641 Willemsen-Swinkels SH, Buitelaar JK, van Engeland H. The effects of chronic naltrexone treatment in young autistic children: a double-blind placebo-controlled crossover study. Biol Psychiatry. Jun. 15. 1996;39(12):1023-31. X-1, X-3, X-4. [pmid: 8780837].
4642 Willemsen-Swinkels SH, Buitelaar JK, Weijnen FG, et al. Placebo-controlled acute dosage naltrexone study in young autistic children. Psychiatry Res. Oct. 16. 1995;58(3):203-15. X-1, X-3, X-4. [pmid: 8570776].
4643 Willemsen-Swinkels SHN, Buitelaar JK, van Berckelaer-Onnes IA, et al. Six months continuation treatment in naltrexone-responsive children with autism: An open-label case-control design. J Autism Dev Disord. Apr. 1999;29(2):167-9. X-1, X-3, X-4. [pmid: 10382138].
4644 Willette AA, Lubach GR, Knickmeyer RC, et al. Brain enlargement and increased behavioral and cytokine reactivity in infant monkeys following acute prenatal endotoxemia. Behav Brain Res. May. 16. 2011;219(1):108-15. X-1, X-3, X-4. [pmid: 21192986].
4645 Williams B. Mental handicap nursing. Autism--help for the family. Nurs Times. Aug. 21–27. 1991;87(34):61-3. X-2, X-4. [pmid: 1881792].
4646 Williams C, Wright B, Callaghan G, et al. Do children with autism learn to read more readily by computer assisted instruction or traditional book methods? A pilot study. Autism. Mar. 2002;6(1):71-91. X-1, X-3, X-4. [pmid: 11918110].
4647 Williams CM, Fan W, Goodman G. Preliminary analysis of the “survey of educators’ knowledge and value of research-based practices for students with autism”. Assess Eff Interv. Mar. 2011;36(2):113-30. X-1, X-3, X-4.
4648 Williams DE, Kirkpatrick-Sanchez S, Crocker WT. A long-term follow-up of treatment for severe self-injury. Res Dev Disabil. Nov–Dec. 1994;15(6):487-501. X-3. [pmid: 7871235].
4649 Williams E, Kendell-Scott L, Costall A. Parents’ experiences of introducing everyday object use to their children with autism. Autism. Dec. 2005;9(5):495-514. X-4. [pmid: 16287702].
4650 Williams E, Reddy V, Costall A. Taking a closer look at functional play in children with autism. J Autism Dev Disord. Feb. 2001;31(1):67-77. X-4. [pmid: 11439756].
4651 Williams G, Carnerero JJ, Perez-Gonzalez LA. Generalization of tacting actions in children with autism. J Appl Behav Anal. Summer. 2006;39(2):233-7. X-3. [pmid: 16813044].
4652 Williams G, Donley CR, Keller JW. Teaching children with autism to ask questions about hidden objects. J Appl Behav Anal. Special Issue: Establishing operations in applied behavior analysis. Win. 2000;33(4):627-30. X-1, X-3, X-4. [pmid: 11214038].
4653 Williams G, King J, Cunningham M, et al. Fetal valproate syndrome and autism: additional evidence of an association. Dev Med Child Neurol. Mar. 2001;43(3):202-6. X-4. [pmid: 11263692].
4654 Williams G, Perez-Gonzalez LA, Vogt K. The role of specific consequences in the maintenance of three types of questions. J Appl Behav Anal. Fall. 2003;36(3):285-96. X-3. [pmid: 14596570].
4655 Williams J, Brayne C. Screening for autism spectrum disorders: what is the evidence?. Autism. 2006;10(1):11-35. X-2, X-4. [pmid: 16522708].
4656 Williams JA, Koegel RL, Egel AL. Response-reinforcer relationships and improved learning in autistic children. J Appl Behav Anal. Spring. 1981;14(1):53-60. X-1, X-3, X-4. [pmid: 7216932].
4657 Williams JH, Massaro DW, Peel NJ, et al. Visual-auditory integration during speech imitation in autism. Res Dev Disabil. Nov–Dec. 2004;25(6):559-75. X-1, X-3, X-4. [pmid: 15541632].
4658 Williams K, Leonard H, Tursan d’Espaignet E, et al. Hospitalisations from birth to 5 years in a population cohort of western Australian children with intellectual disability. Arch Dis Child. Dec. 2005;90(12):1243-8. X-4. [pmid: 16301550].
4659 Williams K, Wishart JG. Combining school attendance with home-based interventions for autism. J Res Spec Educ Needs. 2001;1(1). X-7.
4660 Williams KE, Gibbons BG, Schreck KA. Comparing selective eaters with and without developmental disabilities. J Dev Phys Disabil. Sep. 2005;17(3):299-309. X-4.
4661 Williams KR. The son-rise program intervention for autism: prerequisites for evaluation. Autism. Jan. 2006;10(1):86-102. X-1, X-3, X-4. [pmid: 16522712].
4662 Williams KR, Wishart JG. The son-rise program intervention for autism: an investigation into family experiences. J Intellect Disabil Res. May–Jun. 2003;47(Pt 4-5):291-9. X-1, X-3, X-4. [pmid: 12787161].
4663 Williams PG, Allard A, Sears L, et al. Brief report: case reports on naltrexone use in children with autism: controlled observations regarding benefits and practical issues of medication management. J Autism Dev Disord. Feb. 2001;31(1):103-8. X-1, X-3, X-4. [pmid: 11439748].
4664 Williams PG, Dalrymple N, Neal J. Eating habits of children with autism. Pediatr Nurs. May–Jun. 2000;26(3):259-64. X-2, X-4. [pmid: 12026389].
4665 Williams SK, Johnson C, Sukhodolsky DG. The role of the school psychologist in the inclusive education of school-age children with autism spectrum disorders. J Sch Psychol. Mar. 2005;43(2):117-36. X-2, X-4.
4666 Williams SK, Scahill L, Vitiello B, et al. Risperidone and adaptive behavior in children with autism. J Am Acad Child Adolesc Psychiatry. Apr. 2006;45(4):431-9. X-1, X-3. [pmid: 16601648].
4667 Williams TI. A social skills group for autistic children. J Autism Dev Disord. Mar. 1989;19(1):143-55. X-3. [pmid: 2708297].
4668 Williams White S, Keonig K, Scahill L. Social skills development in children with autism spectrum disorders: a review of the intervention research. J Autism Dev Disord. Nov. 2007;37(10):1858-68. X-2. [pmid: 17195104].
4669 Williams-Diehm KL, Lynch PS. Student knowledge and perceptions of individual transition planning and its process. J Voc Spec Needs Educ. Spr. 2007;29(3):13-21. X-4.
4670 Williamson S, Craig J, Slinger R. Exploring the relationship between measures of self-esteem and psychological adjustment among adolescents with asperger syndrome. Autism. Jul. 2008;12(4):391-402. X-3, X-4. [pmid: 18579646].
4671 Wilson RR, Blades M, Coleman M, et al. Unfamiliar face recognition in children with autistic spectrum disorders. Infant & Child Development. 2009;18(6):545-55. X-1, X-3, X-4.
4672 Wilson S. On seeing and not seeing. J Child Psychother. Aug. 1994;20(2):165-84. X-4.
4673 Wilson TW, Rojas DC, Reite ML, et al. Children and adolescents with autism exhibit reduced MEG steady-state gamma responses. Biol Psychiatry. Aug. 1. 2007;62(3):192-7. X-4. [pmid: 16950225].
4674 Wilson WH. Diagnostic consultation to a state hospital. Hosp Community Psychiatry. Dec. 1989;40(12):1290-3. X-4. [pmid: 2591885].
4675 Wilson WH. Reassessment of state hospital patients diagnosed with schizophrenia. J Neuropsychiatry Clin Neurosci. Fall. 1989;1(4):394-7. X-3, X-4. [pmid: 2521089].
4676 Wimmer MC, Doherty MJ. Children with autism’s perception and understanding of ambiguous figures: evidence for pictorial metarepresentation, a research note. Br J Dev Psychol. 2010;28(3):627-41. X-4. [pmid: 20849037].
4677 Wimpory D. Mental handicap nursing. Autism--breaking through the barriers. Nurs Times. Aug. 21–27. 1991;87(34):58-61. X-2, X-4. [pmid: 1881791].
4678 Wimpory D, Chadwick P, Nash S. Brief report: musical interaction therapy for children with autism: an evaluative case study with two-year follow-up. J Autism Dev Disord. Oct. 1995;25(5):541-52. X-1, X-3, X-4. [pmid: 8567598].
4679 Wimpory DC, Nash S. Musical interaction therapy: therapeutic play for children with autism. Child Lang Teach Ther. Feb. 1999;15(1):17-28. X-1, X-3, X-4.
4680 Windsor J, Doyle SS, Siegel GM. Language acquisition after mutism: a longitudinal case study of autism. J Speech Hear Res. Feb. 1994;37(1):96-105. X-3. [pmid: 8170135].
4681 Wing L. Management of early childhood autism. Br J Hosp Med. Apr. 5. 1981;25(4):353-6. 9. X-1, X-2, X-3, X-4. [pmid: 7236955].
4682 Wing L, Shah A. Catatonia in autistic spectrum disorders. Br J Psychiatry. Apr. 2000;176:357-62. X-4. [pmid: 10827884].
4683 Winner E. Commentary: what drawings by atypical populations can tell us. Vis Arts Res. Fall. 1996;22(44):90-5. X-1, X-2, X-3, X-4.
4684 Winterling V, Gast DL, Wolery M, et al. Teaching safety skills to high school students with moderate disabilities. J Appl Behav Anal. Spring. 1992;25(1):217-27. X-3. [pmid: 1582967].
4685 Winterrowd E, Hepburn SL, Kimel LK, et al. Relationship of psychiatric disorders to measures of child function in parents of children with autism. Ment Health Asp Dev Disabil. 2008;11(2):42-54. X-3.
4686 Wirojanan J, Jacquemont S, Diaz R, et al. The efficacy of melatonin for sleep problems in children with autism, fragile X syndrome, or autism and fragile X syndrome. J Clin Sleep Med. Apr. 15. 2009;5(2):145-50. X-3. [pmid: 19968048].
4687 Wise MD, Little AA, Holliman JB, et al. Can state early intervention programs meet the increased demand of children suspected of having autism spectrum disorders?. J Dev Behav Pediatr. Jul–Aug. 2010;31(6):469-76. X-1, X-3, X-4. [pmid: 20585267].
4688 Wishart JG, Cebula KR, Willis DS, et al. Understanding of facial expressions of emotion by children with intellectual disabilities of differing aetiology. J Intellect Disabil Res. Jul. 2007;51(7):551-63. X-4. [pmid: 17537169].
4689 Witwer A, Lecavalier L. Treatment incidence and patterns in children and adolescents with autism spectrum disorders. J Child Adolesc Psychopharmacol. Aug. 2005;15(4):671-81. X-1, X-3, X-4. [pmid: 16190798].
4690 Wolery M. A model for developing individualized services. J Early Interv. Win. 1997;21(1):17-9. X-1, X-2, X-3, X-4.
4691 Wolery M. Commentary: the environment as a source of variability: implications for research with individuals who have autism. J Autism Dev Disord. Oct. 2000;30(5):379-81. X-2, X-4. [pmid: 11098872].
4692 Wolery M, Garfinkle AN. Measures in intervention research with young children who have autism. J Autism Dev Disord. Oct. 2002;32(5):463-78. X-1, X-2, X-3, X-4. [pmid: 12463520].
4693 Wolf L, Goldberg B. Autistic children grow up: an eight to twenty-four year follow-up study. Can J Psychiatry. Aug. 1986;31(6):550-6. X-4. [pmid: 3756758].
4694 Wolfberg P, LePage P, Cook E. Innovations in inclusive education: two teacher preparation programs at the san francisco state university. Int J Whole Schooling. 2009;5(2):16-36. X-2, X-4.
4695 Wolfberg PJ, Schuler AL. Integrated play groups: a model for promoting the social and cognitive dimensions of play in children with autism. J Autism Dev Disord. Sep. 1993;23(3):467-89. X-1, X-3, X-4. [pmid: 8226582].
4696 Wolff S. Childhood autism: its diagnosis, nature, and treatment. Arch Dis Child. Jun. 1991;66(6):737-41. X-2, X-4. [pmid: 2053803].
4697 Wong CS, Kasari C, Freeman S, et al. The acquisition and generalization of joint attention and symbolic play skills in young children with autism. Res Pract Persons Severe Disabl. Sum. 2007;32(2):101-9. X-1, X-3, X-4.
4698 Wong HH, Smith RG. Patterns of complementary and alternative medical therapy use in children diagnosed with autism spectrum disorders. J Autism Dev Disord. Oct. 2006;36(7):901-9. X-1, X-3. [pmid: 16897395].
4699 Wong SE, Floyd J, Innocent AJ, et al. Applying a DRO schedule and compliance training to reduce aggressive and self-injurious behavior in an autistic man: a case report. J Behav Ther Exp Psychiatry. Dec. 1991;22(4):299-304. X-1, X-3, X-4. [pmid: 1823666].
4700 Wong SK, Tam SF. Effectiveness of a multimedia programme and therapist-instructed training for children with autism. Int J Rehabil Res. Dec. 2001;24(4):269-78. X-1, X-3, X-4. [pmid: 11775031].
4701 Wong VC. Use of complementary and alternative medicine (CAM) in autism spectrum disorder (ASD): comparison of Chinese and western culture (Part A). J Autism Dev Disord. Mar. 2009;39(3):454-63. X-1, X-3, X-4. [pmid: 18784992].
4702 Wong VC, Hui SL. Brief report: emerging services for children with autism spectrum disorders in Hong Kong 1960–2004. J Autism Dev Disord. Feb. 2008;38(2):383-9. X-2, X-4. [pmid: 17605098].
4703 Wong VC, Kwan QK. Randomized controlled trial for early intervention for autism: a pilot study of the Autism 1-2-3 Project. J Autism Dev Disord. Jun. 2010;40(6):677-88. X-1, X-3, X-4. [pmid: 20020319].
4704 Wong VC-N, Sun JG. Randomized controlled trial of acupuncture versus sham acupuncture in autism spectrum disorder. J Altern Complement Med. May. 2010;16(5):545-53. X-1, X-3, X-4. [pmid: 20804366].
4705 Wood AL, Luiselli JK, Harchik AE. Training instructional skills with paraprofessional service providers at a community-based habilitation setting. Behav Modif. Nov. 2007;31(6):847-55. X-4. [pmid: 17932239].
4706 Wood BK, Wolery M, Kaiser AP. Treatment of food selectivity in a young child with autism. Focus Autism Dev Disabil. Sep. 2009;24(3):169-77. X-1, X-3, X-4.
4707 Wood JJ, Drahota A, Sze K, et al. Cognitive behavioral therapy for anxiety in children with autism spectrum disorders: a randomized, controlled trial. J Child Psychol Psychiatry. Mar. 2009;50(3):224-34. X-4. [pmid: 19309326].
4708 Wood JJ, Drahota A, Sze K, et al. Brief report: effects of cognitive behavioral therapy on parent-reported autism symptoms in school-age children with high-functioning autism. J Autism Dev Disord. Nov. 2009;39(11):1608-12. X-1, X-3, X-4. [pmid: 19562475].
4709 Woodard C, Groden J, Goodwin M, et al. A placebo double-blind pilot study of dextromethorphan for problematic behaviors in children with autism. Autism. Jan. 2007;11(1):29-41. X-3. [pmid: 17175572].
4710 Woodard C, Groden J, Goodwin M, et al. The treatment of the behavioral sequelae of autism with dextromethorphan: a case report. J Autism Dev Disord. Aug. 2005;35(4):515-8. X-1, X-3, X-4. [pmid: 16134036].
4711 Woodard CR, Van Reet J. Object identification and imagination: an alternative to the meta-representational explanation of autism. J Autism Dev Disord. Feb. 2011;41(2):213-26. X-1, X-2, X-3, X-4. [pmid: 20532603].
4712 Woods J, Goldstein H. When the toddler takes over: changing challenging routines into conduits for communication. Focus Autism Dev Disabil. Fall. 2003;18(3):176-81. X-1, X-2, X-3, X-4.
4713 Woods JJ, Wetherby AM. Early identification of and intervention for infants and toddlers who are at risk for autism spectrum disorder. Lang Speech Hear Serv Sch. Jul. 2003;34(3):180-93. X-1, X-2, X-3, X-4.
4714 Woods TS. The selective suppression of a stereotypy in an autistic child: A stimulus control approach. Behav Psychother. Jul. 1983;11(3):235-48. X-1, X-3, X-4.
4715 Woods TS. Generality in the verbal tacting of autistic children as a function of “naturalness” in antecedent control. J Behav Ther Exp Psychiatry. Mar. 1984;15(1):27-32. X-3. [pmid: 6470154].
4716 Woods TS. Programming common antecedents: A practical strategy for enhancing the generality of learning. Behav Psychother. Apr. 1987;15(2):158-80. X-1, X-3, X-4.
4717 Woolfson LM, Taylor RJ, Mooney L. Parental attributions of controllability as a moderator of the relationship between developmental disability and behaviour problems. Child Care Health Dev. Mar. 2011;37(2):184-94. X-1, X-4. [pmid: 20533916].
4718 Wright B, Brzozowski AM, Calvert E, et al. Is the presence of urinary indolyl-3-acryloylglycine associated with autism spectrum disorder?. Dev Med Child Neurol. Mar. 2005;47(3):190-2. X-4. [pmid: 15739724].
4719 Wright B, Sims D, Smart S, et al. Melatonin versus placebo in children with autism spectrum conditions and severe sleep problems not amenable to behaviour management strategies: a randomised controlled crossover trial. J Autism Dev Disord. Feb. 2011;41(2):175-84. X-1, X-3, X-4. [pmid: 20535539].
4720 Wright C, Conlon E, Wright M, et al. Sub-lexical reading intervention in a student with dyslexia and asperger’s disorder. Aust J Educ Dev Psychol. 2011;11:11-25. X-3.
4721 Wuang YP, Wang CC, Huang MH, et al. The effectiveness of simulated developmental horse-riding program in children with autism. Adapt Phys Activ Q. Apr. 2010;27(2):113-26. X-1, X-3, X-4. [pmid: 20440023].
4722 Wulffaert J, van Berckelaer-Onnes I, Kroonenberg P, et al. Simultaneous analysis of the behavioural phenotype, physical factors, and parenting stress in people with cornelia de lange syndrome. J Intellect Disabil Res. Jul. 2009;53(7):604-19. X-4. [pmid: 19522789].
4723 Wymbs BT, Robb JA, Chronis AM, et al. Long-term, multimodal treatment of a child with asperger’s syndrome and comorbid disruptive behavior problems: a case illustration. Cogn Behav Pract. Sum. 2005;12(3):338-50. X-3.
4724 Wynne ME, Rogers JJ. Variables discriminating residential placement of severely handicapped children. Am J Ment Defic. Mar. 1985;89(5):515-23. X-4. [pmid: 3158202].
4725 Xia RR. Effectiveness of nutritional supplements for reducing symptoms in autism-spectrum disorder: a case report. J Altern Complement Med. Mar. 2011;17(3):271-4. X-1, X-3, X-4. [pmid: 21417812].
4726 Xin JF, Sutman FX. Using the smart board in teaching social stories to students with autism. Teach Except Child. Mar–Apr. 2011;43(4):18-24. X-1, X-2, X-3, X-4.
4727 Xu X, Yang H, Lin YF, et al. Neuronal Abelson helper integration site-1 (Ahi1) deficiency in mice alters TrkB signaling with a depressive phenotype. Proc Natl Acad Sci U S A. Nov. 2. 2010;107(44):19126-31. X-1, X-3, X-4. [pmid: 20956301].
4728 Yahalom I. Infinity and the limits of the unconscious. Psychoanal Rev. Apr. 1998;85(2):205-15. X-2, X-4. [pmid: 9658451].
4729 Yalaz K, Vanli L, Yilmaz E, et al. Phenylketonuria in pediatric neurology practice: a series of 146 cases. J Child Neurol. Nov. 2006;21(11):987-90. X-4. [pmid: 17092471].
4730 Yalnizoglu D, Haliloglu G, Turanli G, et al. Neurologic outcome in patients with MRI pattern of damage typical for neonatal hypoglycemia. Brain Dev. Jun. 2007;29(5):285-92. X-4. [pmid: 17158011].
4731 Yamada A, Suzuki M, Kato M, et al. Emotional distress and its correlates among parents of children with pervasive developmental disorders. Psychiatry Clin Neurosci. Dec. 2007;61(6):651-7. X-4. [pmid: 18081627].
4732 Yamamoto Ji, Mochizuki A. Acquisition and functional analysis of manding with autistic students. J Appl Behav Anal. Spr. 1988;21(1):57-64. X-1, X-3, X-4. [pmid: 3372403].
4733 Yamashita Y, Mukasa A, Honda Y, et al. Short-term effect of American summer treatment program for Japanese children with attention deficit hyperactivity disorder. Brain Dev. Feb. 2010;32(2):115-22. X-1, X-3, X-4. [pmid: 19150587].
4734 Yanardağ M, Birkan B, Yılmaz İ, et al. The effects of least-to-most prompting procedure in teaching basic tennis skills to children with autism. Kinesiology. Jun. 2011;43(1):44-55. X-1, X-3, X-4.
4735 Yang M, Perry K, Weber MD, et al. Social peers rescue autism-relevant sociability deficits in adolescent mice. Autism Res. Feb. 2011;4(1):17-27. X-1, X-3, X-4. [pmid: 20928844].
4736 Yang NK, Huang T-A, Schaller JL, et al. Enhancing appropriate social behaviors for children with autism in general education classrooms: an analysis of six cases. Educ Train Dev Disabil. Dec. 2003;38(4):405-16. X-3.
4737 Yang TR, Wolfberg PJ, Wu SC, et al. Supporting children on the autism spectrum in peer play at home and school: piloting the integrated play groups model in Taiwan. Autism. Dec. 2003;7(4):437-53. X-1, X-3, X-4. [pmid: 14678682].
4738 Yanos PT, Lysaker PH, Roe D. Internalized stigma as a barrier to improvement in vocational functioning among people with schizophrenia-spectrum disorders. Psychiatry Res. Jun. 2010;178(1):211-3. X-1, X-3, X-4. [pmid: 20417973].
4739 Yarbrough E, Santat U, Perel I, et al. Effects of fenfluramine on autistic individuals residing in a state developmental center. J Autism Dev Disord. Sep. 1987;17(3):303-14. X-4. [pmid: 3308829].
4740 Yarwood J, Moreton J. MMR: midwives’ guide to providing information for parents. Midwives. May. 2003;6(5):208-10. X-2. [pmid: 12929353].
4741 Yaw JS, Skinner CH, Parkhurst J, et al. Extending research on a computer-based sight-word reading intervention to a student with autism. J Behav Educ. Mar. 2011;20(1):44-54. X-1, X-3, X-4.
4742 Yazaki N. Regression in schizophrenia and its therapeutic value. Jpn J Psychiatry Neurol. Mar. 1992;46(1):71-98. X-4. [pmid: 1353128].
4743 Yazbak FE, Diodati CJ. Postpartum live virus vaccination: lessons from veterinary medicine. Med Hypotheses. Sep. 2002;59(3):280-2. X-2, X-4. [pmid: 12208153].
4744 Yeh-Kennedy M. Brady, our firstborn son, has autism. Odyssey. Spr-Sum. 2008;9(1):26-30. X-1, X-3, X-4.
4745 Yell ML, Drasgow E. Litigating a free appropriate public education: the lovaas hearings and cases. J Spec Educ. Win. 2000;33(4):205-14. X-1, X-2, X-3, X-4.
4746 Yi JI, Christian L, Vittimberga G, et al. Generalized negatively reinforced manding in children with autism. Anal Verbal Behav. 2006;22:21-33. X-3. [pmid: 22477341].
4747 Yianni-Coudurier C, Darrou C, Lenoir P, et al. What clinical characteristics of children with autism influence their inclusion in regular classrooms?. J Intellect Disabil Res. Oct. 2008;52(10):855-63. X-1, X-3, X-4. [pmid: 18627431].
4748 Yirmiya N, Solomonica-Levi D, Shulman C, et al. Theory of mind abilities in individuals with autism, down syndrome, and mental retardation of unknown etiology: the role of age and intelligence. J Child Psychol Psychiatry. Nov. 1996;37(8):1003-14. X-1, X-2, X-3, X-4. [pmid: 9119934].
4749 Yoder P, Stone WL. A randomized comparison of the effect of two prelinguistic communication interventions on the acquisition of spoken communication in preschoolers with ASD. J Speech Lang Hear Res. Aug. 2006;49(4):698-711. X-1, X-3, X-4. [pmid: 16908870].
4750 Yoder P, Stone WL. Randomized comparison of two communication interventions for preschoolers with autism spectrum disorders. J Consult Clin Psychol. Jun. 2006;74(3):426-35. X-1, X-3, X-4. [pmid: 16822100].
4751 Yoder PJ. Predicting lexical density growth rate in young children with autism spectrum disorders. Am J Speech Lang Pathol. Nov. 2006;15(4):378-88. X-1, X-3, X-4. [pmid: 17102148].
4752 Yoder PJ, Layton TL. Speech following sign language training in autistic children with minimal verbal language. J Autism Dev Disord. Jun. 1988;18(2):217-29. X-1, X-3, X-4. [pmid: 3410812].
4753 Yoder PJ, Lieberman RG. Brief report: randomized test of the efficacy of picture exchange communication system on highly generalized picture exchanges in children with ASD. J Autism Dev Disord. May. 2010;40(5):629-32. X-1, X-4. [pmid: 19904596].
4754 Yokotani K. Educational level signals unobserved abilities of people with high functioning autism spectrum disorders. Psychol Rep. Aug. 2010;107(1):227-35. X-4. [pmid: 20923067].
4755 Yokoyama K, Naoi N, Yamamoto J-i. Teaching verbal behavior using the picture exchange communication system (pecs) with children with autistic spectrum disorders. Jpn J Spec Educ. Mar. 2006;43(6):485-503. X-1, X-3, X-4.
4756 Yoo JH, Williams DC, Napolitano DA, et al. Rate-decreasing effects of the atypical neuroleptic risperidone attenuated by conditions of reinforcement in a woman with mental retardation. J Appl Behav Anal. Sum. 2003;36(2):245-8. X-4. [pmid: 12858988].
4757 York A, von Fraunhofer N, Turk J, et al. Fragile-X syndrome, down’s syndrome and autism: awareness and knowledge amongst special educators. J Intellect Disabil Res. Aug. 1999;43(Pt 4):314-24. X-4. [pmid: 10466870].
4758 Young A, Ruble L, McGrew J. Public vs. private insurance: Cost, use, accessibility, and outcomes of services for children with autism spectrum disorders. Res Autism Spectr Disord. Oct–Dec. 2009;3(4):1023-33. X-4.
4759 Young B, Simpson RL, Myles BS, et al. An examination of paraprofessional involvement in supporting inclusion of students with autism. Focus Autism Dev Disabil. Spr. 1997;12(1):31-8. X-1, X-3, X-4.
4760 Young JG, Cohen DJ, Shaywitz SE, et al. Assessment of brain function in clinical pediatric research: behavioral and biological strategies. Schizophr Bull. 1982;8(2):205-35. X-1, X-2, X-3, X-4. [pmid: 6180470].
4761 Young RL, Posselt M. Using the transporters dvd as a learning tool for children with autism spectrum disorders (ASD). J Autism Dev Disord. 2011. Aug. 6. X-1, X-3, X-4. [pmid: 21822764].
4762 Young S, Amarasinghe JM. Practitioner review: Non-pharmacological treatments for ADHD: a lifespan approach. J Child Psychol Psychiatry. Feb. 2010;51(2):116-33. X-2, X-4. [pmid: 19891745].
4763 Yuan TF, Hoff R. Mirror neuron system based therapy for emotional disorders. Med Hypotheses. Nov. 2008;71(5):722-6. X-2. [pmid: 18703289].
4764 Yuill N, Strieth S, Roake C, et al. Brief report: designing a playground for children with autistic spectrum disorders--effects on playful peer interactions. J Autism Dev Disord. Jul. 2007;37(6):1192-6. X-1, X-3, X-4. [pmid: 17063401].
4765 Yung A, Wong V, Yeung R, et al. Outcome measure for paediatric rehabilitation: use of the functional independence measure for children (WeeFIM). A pilot study in Chinese children with neurodevelopmental disabilities. Pediatr Rehabil. Jan–Mar. 1999;3(1):21-8. X-4. [pmid: 10367290].
4766 Zachor DA, Itzchak EB. Treatment approach, autism severity and intervention outcomes in young children. Res Autism Spectr Disord. Jul–Sep. 2010;4(3):425-32. X-1, X-3, X-4.
4767 Zager D, Alpern CS. College-based inclusion programming for transition-age students with autism. Focus Autism Dev Disabil. Sep. 2010;25(3):151-7. X-2, X-4.
4768 Zaidman-Zait A, Mirenda P, Zumbo BD, et al. An item response theory analysis of the parenting stress index-short form with parents of children with autism spectrum disorders. J Child Psychol Psychiatry. Nov. 2010;51(11):1269-77. X-1, X-3, X-4. [pmid: 20546082].
4769 Zambolin K, Fabrizio M, Ferris K, et al. Tracking teachers’ behavior to concurrently decrease punishment use with and problem behavior in a child with autism while decreasing the child’s frequency of negative statements. J Precision Teach Celeration. 2007;23:27-9. X-3.
4770 Zanolli K, Daggett J. The effects of reinforcement rate on the spontaneous social initiations of socially withdrawn preschoolers. J Appl Behav Anal. Spring. 1998;31(1):117-25. X-4. [pmid: 9532755].
4771 Zanolli K, Daggett J, Adams T. Teaching preschool age autistic children to make spontaneous initiations to peers using priming. J Autism Dev Disord. Aug. 1996;26(4):407-22. X-1, X-3, X-4. [pmid: 8863092].
4772 Zanolli K, Daggett J, Ortiz K, et al. Using rapidly alternating multiple schedules to assess and treat aberrant behavior in natural settings. Behav Modif. Jul. 1999;23(3):358-78. X-1, X-3, X-4. [pmid: 10467889].
4773 Zappella M. Young autistic children treated with ethologically oriented family therapy. Fam Syst Med. Spr. 1990;8(1):14-27. X-1, X-3, X-4.
4774 Zappella M. Early-onset tourette syndrome with reversible autistic behaviour: a dysmaturational disorder. Eur Child Adolesc Psychiatry. Feb. 2002;11(1):18-23. X-2. [pmid: 11942423].
4775 Zappella M, Chiarucci P, Pinassi D, et al. Parental bonding in the treatment of autistic behavior. Ethol Sociobiol. Jan. 1991;12(1):1-11. X-1, X-3, X-4.
4776 Zarcone JR, et al. Analysis of free-time contingencies as positive versus negative reinforcement. J Appl Behav Anal. Sum. 1996;29(2):247-50. X-1, X-3, X-4. [pmid: 8682741].
4777 Zarcone JR, Hellings JA, Crandall K, et al. Effects of risperidone on aberrant behavior of persons with developmental disabilities: I. A double-blind crossover study using multiple measures. Am J Ment Retard. Nov. 2001;106(6):525-38. X-6. [pmid: 11708938].
4778 Zaroff CM, Devinsky O, Miles D, et al. Cognitive and behavioral correlates of tuberous sclerosis complex. J Child Neurol. Nov. 2004;19(11):847-52. X-2, X-4. [pmid: 15658788].
4779 Zaw FKM, Bates GDL, Murali V, et al. Catatonia, autism, and ECT. Dev Med Child Neurol. Dec. 1999;41(12):843-5. X-4. [pmid: 10619284].
4780 Zeiner P, Gjevik E, Weidle B. Response to atomoxetine in boys with high-functioning autism spectrum disorders and attention deficit/hyperactivity disorder. Acta Paediatr. Sep. 2011;100(9):1258-61. X-3. [pmid: 21392103].
4781 Zelazo PR. Infant-toddler information processing treatment of children with pervasive developmental disorder and autism: part ii. Infants Young Child. Oct. 1997;10(2):1-13. X-1, X-3, X-4.
4782 Zentall SS, Zentall TR. Optimal stimulation: a model of disordered activity and performance in normal and deviant children. Psychol Bull. Nov. 1983;94(3):446-71. X-1, X-2, X-3, X-4. [pmid: 6657825].
4783 Zercher C, Hunt P, Schuler A, et al. Increasing joint attention, play and language through peer supported play. Autism. Dec. 2001;5(4):374-98. X-1, X-3, X-4. [pmid: 11777255].
4784 Zhang C, Bennett T. Facilitating the meaningful participation of culturally and linguistically diverse families in the ifsp and IEP process. Focus Autism Dev Disabil. Spr. 2003;18(1):51-9. X-1, X-2, X-3, X-4.
4785 Zhang X, Ji CY. Autism and mental retardation of young children in China. Biomed Environ Sci. Oct. 2005;18(5):334-40. X-4. [pmid: 16370317].
4786 Zhu H, Sun Y, Zeng J, et al. Mirror neural training induced by virtual reality in brain-computer interfaces may provide a promising approach for the autism therapy. Med Hypotheses. May. 2011;76(5):646-7. X-1, X-2, X-3, X-4. [pmid: 21300442].
4787 Zimmerman AW. Commentary: immunological treatments for autism: in search of reasons for promising approaches. J Autism Dev Disord. Oct. 2000;30(5):481-4. X-2. [pmid: 11098888].
4788 Zimmerman RK, Wolfe RM, Fox DE, et al. Vaccine criticism on the world wide web. J Med Internet Res. 2005;7(2):e17. X-2, X-4. [pmid: 15998608].
4789 Zingale M, Belfiore G, Mongelli V, et al. Organization of a family training service pertaining to intellectual disabilities. J Pol Prac Intellect Disabil. Mar. 2008;5(1):69-72. X-4.
4790 Zingarelli G, Ellman G, Hom A, et al. Clinical effects of naltrexone on autistic behavior. Am J Ment Retard. Jul. 1992;97(1):57-63. X-3. [pmid: 1497864].
4791 Zingerevich C, Greiss-Hess L, Lemons-Chitwood K, et al. Motor abilities of children diagnosed with fragile X syndrome with and without autism. J Intellect Disabil Res. Jan. 2009;53(1):11-8. X-1, X-3, X-4. [pmid: 18771512].
4792 Zionts LT, Zionts P, Harrison S, et al. Urban african american families’ perceptions of cultural sensitivity within the special education system. Focus Autism Dev Disabil. Spr. 2003;18(1):41-50. X-1, X-2, X-3, X-4.
4793 Zirkel PA. What does the law say?. Teach Except Child. Sep–Oct. 2006;39(1):65-6. X-1, X-2, X-3, X-4.
4794 Zirkel PA. What does the law say?. Teach Except Child. May–Jun. 2008;40(5):73-5. X-2, X-4.
4795 Zirkel PA, Rose T. Scientifically based research and peer-reviewed research under the idea: the legal definitions, applications, and implications. J Spec Educ Leadersh. Mar. 2009;22(1):36-50. X-2, X-4.
4796 Zissermann L. The effects of deep pressure on self-stimulating behaviors in a child with autism and other disabilities. Am J Occup Ther. Jun. 1992;46(6):547-51. X-1, X-3, X-4. [pmid: 1605299].
4797 Ziviani J, Boyle M, Rodger S. An introduction to play and the preschool child with autistic spectrum disorder. Br J Occup Ther. 2001;64(1):17-22. X-1, X-2, X-3, X-4.
4798 Ziviani J, Rodger S, Peters S. The play behaviour of children with and without autistic disorder in a clinical environment. NZ J Occup Ther. 2005;52(2):22-30. X-1, X-3, X-4.
4799 Zollweg W, Palm D, Vance V. The efficacy of auditory integration training: a double blind study. Am J Audiol. 1997;6(3):39-47. X-1, X-3, X-4.
4800 Zoltak BB. Autism: recognition and management. Pediatr Nurs. Mar–Apr. 1986;12(2):90-4. X-1, X-2, X-3, X-4. [pmid: 3634294].
4801 Zuddas A, Di Martino A, Muglia P, et al. Long-term risperidone for pervasive developmental disorder: efficacy, tolerability, and discontinuation. J Child Adolesc Psychopharmacol. Summer. 2000;10(2):79-90. X-3. [pmid: 10933118].
4802 Zwaigenbaum L, Thurm A, Stone W, et al. Studying the emergence of autism spectrum disorders in high-risk infants: methodological and practical issues. J Autism Dev Disord. Mar. 2007;37(3):466-80. X-2, X-4. [pmid: 16897376].
4803 Israel ML, Connolly DA, von Heyn RE, et al. Teaching severely self-abusive and aggressive autistic residents to exit to fire alarms. J Behav Ther Exp Psychiatry. Dec. 1993;24(4):343-55. X-4. [pmid: 8077453].