# Evidence Tables

Table D-1 Interventions for adolescents and young adults with autism evidence table