# Sample Data Extraction Forms

Abstract Review Form

Full Text Review Form