# Acronyms and Abbreviations

ABC: Aberrant Behavior Checklist
ABC-C: Aberrant Behavior Checklist-Community Rating Scale
ABC-I: Aberrant Behavior Checklist-Community Rating Scale-Irritability
AHRQ: Agency for Healthcare Research and Quality
ASD: Autism spectrum disorders
BPVS: British Picture Vocabulary Scale
CARS: Childhood Autism Rating Scale
CGI-I: Clinical Global Impressions-Improvement
CGI-S: Clinical Global Impressions-Severity
DSM-III-R: Diagnostic and Statistical Manual of Mental Disorders, Third Edition, Revised
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition
FC: Facilitated communication
G: Group
IQ: Intelligence quotient
KBIT2: Kaufman Brief Intelligence Test-Second Edition
KQ: Key Question
mg: Milligram
N, n: Number
NA: Not applicable
NR: Not reported
nRCT: Nonrandomized controlled trial
PDA: Personal digital assistant
PDD-NOS: Pervasive developmental disorder-not otherwise specified
PEP: PsychoEducational Profile
RCT: Randomized controlled trial
SD: Standard deviation
SIB-Q: Self-Injurious Behavior Questionnaire
SRI: Serotonin reuptake inhibitor
TEACCH: Treatment and Education of Autistic and Communication related Handicapped Children
TEP: Technical Expert Panel
TOO: Task Order Officer
U.K.: United Kingdom
U.S.: United States
WAIS: Wechsler Adult Intelligence Scale
WASI: Wechsler Abbreviated Scale of Intelligence
Y-BOCS: Yale Brown Obsessive Compulsive Scale