# Results

## Introduction

Results of our searches are presented in Figure 2. We included 44 published articles reporting on 29 studies: 23 randomized controlled trials (RCTs) and 6 meta-analyses or systematic reviews. Our findings include studies rated good or fair for internal validity. Evidence tables for included studies, by Key Question (KQ), can be found in Appendix C.

Figure 2 Disposition of articles

M-A= meta-analysis; PICOTS = populations, interventions, comparators, outcomes, timing, settings or study duration; SR, systematic review

Figure 2 is titled “Disposition of articles.” The figure is a flow chart that summarizes the search and selection of articles: There were 8,981 citations of randomized trials identified by searching MEDLINE®, Embase®, the Cochrane Library, CINAHL®, PsycINFO®, and the International Pharmaceutical Abstracts databases. In addition, 227 references were identified by searching reference lists of selected articles, and 216 articles were identified by a search of the clinicaltrials.gov database. After removal of duplicate citations, titles and abstracts of 6,265 references were screened for potential inclusion. Of these, 718 were deemed appropriate for full-text review to determine eligibility. After full-text review, 674 were excluded: 9 were in a language other than English; 201 were the wrong type of publication or wrong study design; 448 failed to meet at least one PICOTS element; 10 were deemed poor quality; and 6 were systematic reviews older than 5 years. Forty-four articles representing 29 studies are included in this report's qualitative synthesis, and 19 studies are included in quantitative analyses.

In the 23 included trials, sample sizes ranged from 72 to 1,559, and study duration ranged from 6 to 48 months. Eleven were conducted solely in the United States; 10 took place outside the United States, and the remaining 2 were administered in a combination of U.S. and non-U.S. sites.

This chapter is organized by KQ; within applicable KQs, results are presented for the following populations: adults (including subgroups of men and women when possible), older adults, young adults or college students, and pregnant women. We did not find any studies in an adolescent population meeting inclusion criteria.

## Key Question 1 What is the direct evidence that screening for alcohol misuse followed by a behavioral counseling intervention, with or without referral, leads to reduced morbidity, reduced mortality, or changes in other long-term outcomes?

To answer this question, we searched for randomized controlled trials and nonrandomized trials with concurrent eligible controls that assigned subjects to screening compared with another screening approach, no screening, or usual care. Systematic reviews of such trials were also eligible for inclusion. Of note, unlike other Key Questions (4 to 6) in this report that included studies that randomized/assigned subjects who had positive screening tests to behavioral counseling interventions and to comparators, this question searched for studies that randomized/assigned subjects to screening versus no screening, usual care, or another screening approach.

### Summary of Findings

#### Morbidity, Mortality, Health Care Utilization, Sick Days, Costs, Legal Issues, Employment Stability, and Quality of Life

We found no studies meeting inclusion/exclusion criteria for any of these outcomes or for intermediate outcomes (i.e., rates of alcohol use, heavy drinking episodes, achieving recommended drinking limits, receipt of and followup with referrals, and abstinence) (insufficient strength of evidence).

## Key Question 2 How do specific screening modalities compare with one another for detecting alcohol misuse?

Screening tools used to identify alcohol misuse include but are not limited to the following:

- Alcohol Use Disorders Identification Test (AUDIT) and its abbreviated versions, including the AUDIT-C
- The single-question screening recommended by NIAAA, or similar single-question screening (e.g., the Single Alcohol Screening Question [SASQ])
- Cut-down, Annoyed, Guilty, Eye-opener (CAGE) questionnaire
- Michigan Alcoholism Screening Test (MAST) and its abbreviated and population-specific versions
- Rapid Alcohol Problems Screen (RAPS)
- Tolerance, Annoyed, Cut-down, Eye-opener (T-ACE) and Tolerance, Worried, Eye-opener, Amnesia, Kut-down (TWEAK) questionnaires, which are based on the CAGE questionnaire and designed for screening pregnant women
- Alcohol-Related Problems Survey (ARPS), shortened version (shARPS)
- Alcohol, Smoking and Substance Involvement Screening Test (ASSIST)

Additional description of screening tools is provided in Appendix F.

### Summary of Findings

#### Adults

We found adequate evidence that several screening instruments can detect alcohol misuse in adults with acceptable sensitivity and specificity.

- A single-question screen (covering the past 12 months), AUDIT-C, and AUDIT appear to be the best overall instruments for screening adults for the full spectrum of alcohol misuse in primary care, considering sensitivity, specificity, and time burden.
- Single-question screens covering the past 12 months have reported sensitivities of 0.82 to 0.87 and specificities of 0.61 to 0.79 for detecting alcohol misuse in adults in primary care.17, 58
- When focusing on adequately sized U.S. studies that reported sensitivity and specificity of screening for the full spectrum of alcohol misuse in primary care, data suggest that some often recommended cut-points for screening (i.e., AUDIT≥8) may need to be revised.
- The AUDIT had sensitivity of 0.44 to 0.51 and specificity of 0.96 to 0.97 for identifying alcohol misuse in adults using a cut-point of ≥8; more optimal balance of sensitivity and specificity were seen at cutoffs of 4 or 5. The sensitivity and specificity at a cutoff of ≥4 were 0.84 to 0.85 and 0.77 to 0.84, respectively; and at a cutoff of ≥5 were 0.70 to 0.92 and 0.73 to 0.94, respectively. Further, sex-specific cutoffs may be warranted because sensitivities for women at cutoffs of ≥4 and ≥5 were 0.47 to 0.65 and 0.35 to 0.53, respectively, but improved to 0.70 to 0.79 at ≥3 (with specificity of 0.86 to 0.87).
- Several instruments require as little as 1 to 2 minutes to administer (e.g., single-question screens, AUDIT-C).
- The CAGE has very low sensitivity for detecting risky/hazardous drinking and is therefore not a good screening test for identifying risky/hazardous drinking.

#### Young Adults and College Students

- The included systematic reviews identified only one study reporting the sensitivity and specificity of a screening instrument for this group, the full AUDIT (cutoff ≥8), which reported sensitivity of 0.82 and specificity of 0.78 for identifying risky/hazardous drinking.

#### Pregnant Women

- The AUDIT-C performed better than other instruments with available data for detecting both at-risk drinking and abuse or dependence, demonstrating both high sensitivity (0.95 or higher) and high specificity (up to 0.85).

#### Adolescents

- None of the included systematic reviews provided information about the use of screening instruments in adolescents. Of note, our methods for identifying all potentially relevant studies for this Key Question have some limitations: we did not review all individual publications assessing screening instruments. Instead, we relied on previously published systematic reviews to find information and we filled gaps with data from other sources (i.e., Technical Expert Panel members, peer and public reviewers, personal files).

### Detailed Assessment

Four systematic reviews compared screening instruments for detecting alcohol misuse,59-62 and a fifth review reported on the use of the AUDIT alone.63 All five reviews focused on primary care populations, with two focused on all adults,62, 63 one on adults age 60 or older, 59 one on women,60 and one on pregnant women.61 Outcomes of interest included the sensitivity and specificity of the screening tool to detect the full spectrum of alcohol misuse, risky/hazardous drinking, or alcohol use disorders (abuse or dependence) and cutoff scores used for the population included in the studies. Table 4 provides a summary of the five systematic reviews included in this report along with an overall quality rating for each article. Each systematic review included in this report was evaluated for quality (internal validity). Criteria for study quality are listed in Appendix D. We supplemented the findings of these systematic reviews with articles suggested by Technical Expert Panel members, peer and public reviewers, and personal files.17, 37, 58, 64-67

Table 4 Characteristics of included systematic reviews comparing screening modalities with one another for detecting alcohol misuse in primary care

Author/Year | Population | Number of Studies Included | Total Number of Patients | List of Screening Instruments Included | Alcohol Misuse | Quality Rating
Berks, McCormick, 2008^59^ | Primary care, adults 60 or older | 9 | 6,353 | CAGE, MAST, SMAST, AUDIT ARPS, shARPS SMAST-G | Hazardous drinking Alcohol abuse or dependence | Fair
Berner et al., 2007^63^ | Primary care, adults, college students, older adults | 13 PC 1 college health | 22,195 a | AUDIT | At-risk drinking | Good
Bradley et al., 1998^60^ | Primary care and OB, mostly women | 9 | Total:10,865 a Women: 10,522 a | CAGE, TWEAK, AUDIT, T-ACE | Heavy drinking Alcohol abuse or dependence | Fair
Burns et al., 2010^61^ | Pregnant women | 5 | 6,724 | T-ACE, TWEAK AUDIT-C, CAGE NET, SMAST | At-risk drinking Alcohol abuse or dependence | Fair
Fiellin et al., 2000^62^ | Primary care, adults | 38 | NR | AUDIT, CAGE SMAST, single question, QF | At-risk/ hazardous drinking Alcohol abuse or dependence | Fair

a These numbers do not include studies conducted in nonprimary care settings

Abbreviations: ARPS = Alcohol-Related Problems Survey; AUDIT = Alcohol Use Disorders Identification Test; AUDIT-C = Alcohol Use Disorders Identification Test – Consumption; CAGE = Cut-down, Annoyed, Guilty, Eye-opener questionnaire; MAST = Michigan Alcoholism Screening Test; NET = Normal drinker, Eye-opener, Tolerance questionnaire; OB = obstetrics; PC = primary care; QF = quantity / frequency; shARPS = shortened Alcohol-Related Problems Survey; SMAST = short Michigan Alcoholism Screening Test; SMAST-G = short Michigan Alcoholism Screening Test – geriatric version; T-ACE = Tolerance, Annoyed, Cut-down, Eye-opener questionnaire; TWEAK = Tolerance, Worried, Eye-opener, Amnesia, Kut-down questionnaire

The sensitivity of any instrument refers to the ability of the test to correctly identify those patients who have the disease or condition, whereas the specificity notes the ability of the instrument to correctly identify those who do not. A high sensitivity is clearly important where the test is used to identify a serious but treatable disorder. A test with high specificity correctly identifies patients without the disorder. A test with a high sensitivity but low specificity may result in many patients who do not have alcohol misuse being subjected to further investigation, potentially using valuable time/resources when they are not needed.

#### Screening for Alcohol Misuse (The Full Spectrum)

We found published data for the AUDIT, AUDIT-C, and single-screening questions reporting the sensitivity and specificity for detecting the full spectrum of alcohol misuse (from risky drinking to alcohol use disorders), which are the most relevant data for the purposes of this review (Table 5). Many studies report the sensitivity for risky drinking separately from alcohol use disorders, which may also be useful when trying to determine the best screening instrument for a particular population (Tables 6 and 7). The reference standard for the screening instruments was a structured diagnostic interview, generally including the timeline follow-back method68 or similar approaches to determine the quantity/frequency of consumption.

Table 5 Screening instrument performance for detecting the full spectrum of alcohol misuse in U.S. primary care populations

Instrument and Cutoff Score | All Adults Sens; Spec | Women Only Sens; Spec | Men Only Sens; Spec
AUDIT ≥2 | NR^a^ | 0.87^66^ to 0.92^64^; 0.71^66^ to 0.74^64,b^ | 0.98; 0.53^64^
AUDIT ≥3 | NR^a^ | 0.70^66^ to 0.79^64^; 0.86^66^ to 0.87^64,b^ | 0.96; 0.71^64^
AUDIT ≥4 | 0.84^58^ to 0.85^69^; 0.77^58^ to 0.84^69^ | 0.47^66^ to 0.65^64^; 0.92^66^ to 0.93^64,b^ | 0.87^70^ to 0.91^64^; 0.69^71^ to 0.80^64^
AUDIT ≥5 | 0.70 to 0.92; 0.73 to 0.94^72,c^ | 0.35^66^ to 0.53^64^; 0.95^64^ to 0.98^66,b^ | 0.77^70^ to 0.81^64, 71^; 0.84^70, 71^ to 0.90^64^
AUDIT ≥6 | 0.60^58^ to 0.69^69^; 0.93^58, 69^ | 0.42; 0.97^64^ | 0.66^70^ to 0.6^64, 71^; 0.90^70^ to 0.92^64^
AUDIT ≥7 | 0.48; 0.96^58^ | 0.34; 0.98^64^ | 0.59^70^ to 0.62^71^; 0.93^64^ to 0.94^70, 71^
AUDIT ≥8 | 0.44^58^ to 0.51^69^; 0.96^73^ to 0.97^69^ | 0.27; 0.98^64^ | 0.54^64^ to 0.58^71^; 0.95^64, 71^ to 0.96^70^
AUDIT-C ≥2 | 0.96; 0.32^58^ | 0.81^66^ to 0.89^64^; 0.78^64^ to 0.86^66,b^ | 0.98; 0.63^64^
AUDIT-C ≥3 | 0.74^17^ to 0.88^58^; 0.64^58^ to 0.83^17^ | 0.60^66^ to 0.73^64^; 0.91^64^ to 0.96^66,b^ | 0.92^64^ to 0.95^71^; 0.60^71^ to 0.79^64^
AUDIT-C ≥4 | 0.74^17^ to 0.76^58^; 0.80^58^ to 0.83^17^ | 0.38^66^ to 0.57^64^; 0.96^64^ to 0.98^66,b^ | 0.86^64, 71^; 0.72^71^ to 0.89^64^
AUDIT-C ≥5 | 0.63; 0.92^58^ | 0.36; 0.98^64^ | 0.68^71^ to 0.72^64^; 0.90^71^ to 0.96^64^
Single question: past 3 months^d^ | 0.62^65^ to 0.80^58^; 0.74^58^ to 0.93^65, 70^ | 0.78; 0.81^58^ | 0.81; 0.63^58^
Single question past 12 months^e^ | 0.82^17^ to 0.87^58^; 0.61^58^ to 0.79^17, 72^ | 0.81; 0.84^17^ | 0.83; 0.72^17^
AUDIT-3 ≥1^f^ | NR^a^ | 0.45^66^ to 0.60^64^; 0.92^64^ to 0.96^66,a^ | 0.77^71^ to 0.87^64^; 0.83^71^ to 0.84^64^

AUDIT = Alcohol Use Disorders Identification Test

a NR indicates that the instrument and cutoff score for the population were not reported by any of the studies in the body of evidence for this question.

b One study66 reported sensitivity and specificity for a sex-specific modification of the AUDIT, AUDIT-C, and AUDIT-3; the study used a lower threshold for the third question, asking how often subjects had four or more drinks on an occasion in the last year (rather than six or more). The study reported the following “sex-specific” results for women for the various screening instruments and cut-points (sensitivity; specificity): AUDIT ≥2, 0.89; 0.71; AUDIT ≥3, 0.74; 0.85; AUDIT ≥4, 0.57; 0.92; AUDIT ≥5, 0.38; 0.98; AUDIT-C ≥2, 0.84; 0.85; AUDIT-C ≥3, 0.66; 0.94; AUDIT-C ≥4, 0.48; 0.99; AUDIT-3 ≥1, 0.69; 0.94.

c Values are ranges from race/ethnicity and sex subsets; the study did not report results from the overall sample.

d A study65 conducted in a primary care setting reported sensitivity of 0.62 and specificity of 0.93 for the following single question for detecting at-risk drinking and current alcohol-use disorders: “On any single occasion during the past 3 months, have you had more than 5 drinks containing alcohol?” Another study conducted in primary care practices in Georgia reported a sensitivity of 0.80 and specificity of 0.74 for the following single question for detecting alcohol misuse, when considering a positive screen to be within the last 3 months: “When was the last time you had more than X drinks in 1 day?” where X was four for women and X was five for men.

e A study conducted in a primary care clinic in an urban safety net hospital reported a sensitivity of 0.82 and specificity of 0.79 for detecting unhealthy alcohol use, using the following single question (recommended by the NIAAA): “How many times in the past year have you had X or more drinks in a day?” (X = 5 for men and 4 for women). A positive response to this single-question screen was defined as one or more.26 Another study conducted in primary care practices in Georgia reported a sensitivity of 0.87 and specificity of 0.61 for the following single question for detecting alcohol misuse, when considering a positive screen to be within the last 12 months: “When was the last time you had more than X drinks in 1 day?” where X was four for women and X was five for men.

f This is a single question, the third question of the AUDIT. A response of ≥1 indicates having consumed six or more drinks on one occasion at least once in the past year.

Notes: One additional study74 reported full-spectrum results from a non-U.S. primary care population (AUDIT ≥5; sensitivity = 0.84; specificity = 0.90); two additional studies reported full-spectrum results from non-U.S., nonprimary care populations (AUDIT ≥8; sensitivity = 0.41^75^ to 0.67^76^; specificity = 0.96^75, 76^). One of those studies75 also reported data using AUDIT ≥5: sensitivity = 0.78 and specificity = 0.81.

Table 6 Screening instrument performance for detecting risky/hazardous drinking in primary care

Instrument and Cutoff Score If Reported | Adults Range of Sens; Range of Spec | Older Adults Range of Sens; Range of Spec | Pregnant Women Range of Sens; Range of Spec | Young Adults / College Students Range of Sens; Range of Spec
ARPS | NR | 0.93; 0.63^59^ | NR | NR
shARPS | NR | 0.92; 0.51^59^ | NR | NR
AUDIT ≥8^a^ | 0.25^63^ to 0.97^62^; 0.61 to 0.96^63^ | 0.28^59^ to 0.88^63^; 0.95 to 1.00^59^ | 0.23; 0.97^61^ | 0.82; 0.78^63^
AUDIT ≥5 | 0.84^62^ to 0.85^71^; 0.81^71^ to 0.90^62^ | NR | NR | NR
AUDIT ≥4 | 0.94; 0.66^71^ | NR | NR | NR
AUDIT-C ≥3 | 0.98; 0.57^62,b^ | 0.54 to 1.00; 0.81 to 0.93^59^ | 0.95; 0.85^61^ | NR
AUDIT-C ≥4 | 0.91; 0.70^71,b^ | NR | NR | NR
CAGE ≥2 | 0.49 to 0.84; 0.75 to 0.97^62^ | 0.14 to 0.39^59,c^; 0.97^59^ | 0.38 to 0.49; 0.92 to 0.93^60, 61^ | NR
SMAST ≥2 | 0.68; 0.92^62^ | 0.48; 1.00^59,d^ | NR^e^ | NR
NET ≥1^f^ | NR | NR | 0.71; 0.86^61^ | NR
T-ACE ≥2^g,h^ | NR | NR | 0.69 to 0.92; 0.38 to 0.89^60, 61^ | NR
TWEAK ≥2^g,i^ | NR | NR | 0.71 to 0.91; 0.73 to 0.83^60, 61^ | NR
QF >7 dr/wk | 0.50; 0.87^62^ Women: 0.29; 0.90 Men: 0.69; 0.79^60^ | NR | NR | NR

ARPS = Alcohol-Related Problems Survey; AUDIT = Alcohol Use Disorders Identification Test; AUDIT-C = Alcohol Use Disorders Identification Test – Consumption; CAGE = Cut-down, Annoyed, Guilty, Eye-opener questionnaire; dr = drinks; NET = Normal drinker, Eye-opener, Tolerance questionnaire; NR = not reported (indicates that the instrument and cutoff score for the population were not reported by any of the studies in the body of evidence for this question); QF = quantity/frequency; sens = sensitivity; shARPS = shortened Alcohol-Related Problems Survey; SMAST = short Michigan Alcoholism Screening Test; spec = specificity; T-ACE = Tolerance, Annoyed, Cut-down, Eye-opener questionnaire; TWEAK = Tolerance, Worried, Eye-opener, Amnesia, Kut-down questionnaire; wk = week

a Although the range of sensitivities for the AUDIT at a cutoff ≥8 includes a value as low as 0.25, five of eight studies in adults found sensitivities above 70%, with the largest, U.S.-based study (rated high quality) reporting sensitivity and specificity of 0.76 and 0.92, respectively. For adults, AUDIT with a positive screen being ≥5 has a sensitivity of 0.84 and a specificity of 0.90.^62^

b Results are from a VA General Medicine Clinic population.62, 71

c For older adults, CAGE with a positive screen being ≥1 has a sensitivity ranging from 0.79 to 0.88.^59^

d For older adults, SMAST-G ≥3 has sensitivity = 0.52 and specificity = 0.96.^59^

e For pregnant women, SMAST ≥3 has sensitivity = 0.11 and specificity = 0.96.^61^

f For pregnant women, NET ≥2 has sensitivity = 0.61 and specificity = 0.87 and NET ≥3 has sensitivity = 0.24 and specificity = 0.99.^61^

g Combined results for all the definitions of “tolerance” in T-ACE and TWEAK (including “high” and “hold”).

h For pregnant women, T-ACE ≥1 has sensitivity from 0.76 to 0.91 and specificity from 0.70 to 0.79, and T-ACE ≥3 has sensitivity from 0.38 to 0.61 and specificity from 0.94 to 0.97.^60, 61^

i For pregnant women, TWEAK ≥1 has sensitivity from 0.66 to 0.92 and specificity from 0.64 to 0.72, and TWEAK ≥3 has sensitivity from 0.59 to 0.67 and specificity from 0.92 to 0.94.^60, 61^

Table 7 Screening instrument performance for detecting alcohol abuse or dependence in primary care

Instrument | Adults Range of Sens; Range of Spec | Older Adults Range of Sens; Range of Spec | Pregnant Women Range of Sens; Range of Spec
ACI | 0.28; 0.86^62^ | NR | NR
AUDIT ≥8^a^ | 0.61 to 0.96; 0.85 to 0.96^62^ | 0.33; 0.91^59^ | 0.23; 0.9^61^
AUDIT-C ≥3 | 0.90; 0.45^62^ | NR | 0.96 to 1.00; 0.71^61^
CAGE ≥2 | 0.77 to 0.94; 0.79 to 0.97^62^ Women: 0.38; 0.92^60^ Men: 0.47; 0.93 | 0.63; 0.82^62^ | NR
HSS | 0.78; 0.71^62^ | NR | NR
LAST ≥2 | 0.63; 0.93^62^ | NR | NR
MAST ≥4^b^ | NR | 0.91; 0.84^59^ | NR
MAST-G ≥5 | NR | 0.70; 0.80^62^ | NR
SMAST ≥2^c^ | 1.00; 0.85^62^ | NR | NR
SAAST ≥3 | 0.13 to 0.69; 0.67 to 0.95^62^ | NR | NR
SDDS-PC | 0.38 to 0.75; 0.97 to 0.99^62^ | NR | NR
Single question: past 3 months^d^ | 0.77^58^; 0.60^58^ | NR | NR
Single question past 12 months^e^ | 0.87^58^ to 0.88^17^; 0.49^58^ to 0.67^17^ | NR | NR
T-ACE ≥2 | NR | NR | 0.60 to 0.88; 0.37 to 0.66^61^
TWEAK ≥3 | 0.75; 0.90^62^ | NR | NR
QF >20 dr/wk | 0.20; 0.97^62^ Women: 0.07; 0.99 Men: 0.36; 0.93^60^ | NR | NR
QF >4 dr/day | 0.47; 0.96^62^ | NR | NR
QF (unspecified) | | 0.48; 0.76^62^ | NR

ACI = Alcohol Clinical Index; AUDIT = Alcohol Use Disorders Identification Test; AUDIT-C = Alcohol Use Disorders Identification Test – Consumption; CAGE = Cut-down, Annoyed, Guilty, Eye-opener questionnaire; dr = drinks; HSS = Health Screening Survey; LAST = Luebeck Alcohol Dependence and Abuse Screening Test; MAST = Michigan Alcoholism Screening Test; MAST-G = Michigan Alcoholism Screening Test – geriatric version; NR = not reported (indicates that the instrument and cutoff score for the population were not reported by any of the studies in the body of evidence for this question); QF = quantity / frequency; SAAST = Self-administered Alcoholism Screening Tests; SDDS-PC = Symptom-Driven Diagnostic System for Primary Care; sens = sensitivity; SMAST = short Michigan Alcoholism Screening Test; spec = specificity; T-ACE = Tolerance, Annoyed, Cut-down, Eye-opener questionnaire; TWEAK = Tolerance, Worried, Eye-opener, Amnesia, Kut-down questionnaire; wk = week

a For adults, AUDIT >8 has sensitivity ranging from 0.38 to 0.96 and specificity ranging from 0.90 to 0.96.

b For older adults, MAST ≥3 has sensitivity ranging from 0.64 to 0.97 and specificity ranging from 0.67 to 0.79.

c For all adults, SMAST >5 has sensitivity ranging from 0.45 to 0.80 and specificity ranging from 0.79 to 0.88. For pregnant women, SMAST ≥3 has sensitivity = 0.15 and specificity = 0.98.

d A study conducted in primary care practices in Georgia reported a sensitivity of 0.77 and specificity of 0.60 for the following single question for detecting a current alcohol use disorder, when considering a positive screen to be within the last 3 months: “When was the last time you had more than X drinks in 1 day?” where X was four for women and X was five for men.

e A study conducted in a primary care clinic in an urban safety net hospital reported a sensitivity of 0.88 and specificity of 0.67 for detecting a current alcohol use disorder, using the following single question (recommended by the NIAAA): “How many times in the past year have you had X or more drinks in a day?” (X = 5 for men and 4 for women). A positive response to this single-question screen was defined as 1 or more. Another study conducted in primary care practices in Georgia reported a sensitivity of 0.87 and specificity of 0.49 for the following single question for detecting a current alcohol use disorder, when considering a positive screen to be within the last 12 months: “When was the last time you had more than X drinks in 1 day?” where X was four for women and X was five for men.

Note: When values for identifying both current and lifetime abuse/dependence were reported, the table reflects data for detecting a current disorder.

Our included systematic reviews did not report data on the performance of the following instruments for detecting alcohol abuse and/or dependence: ARPS (Alcohol-Related Problems Survey); shARPS, shortened Alcohol-Related Problems Survey; NET, Normal drinker, Eye-opener, Tolerance questionnaire.

Single-question screens covering the past 12 months appear similar to the AUDIT and the AUDIT-C, with reported sensitivities of 0.82 to 0.87 and specificities of 0.61 to 0.79 for detecting the full spectrum of alcohol misuse in adults in primary care. A single question was roughly comparable to that reported for longer questionnaires, supporting the use of the brief single-question screen endorsed by the NIAAA.26 Single-question screens typically ask people to report any occasions when they drank four (women) or five (men) drinks or more over a recent time period (e.g., past 12 months).

When focusing on the adequately sized U.S. studies (Table 5), data suggest that some often recommended cut-points for screening (i.e., AUDIT≥8^77^) may need to be revised. Given cultural differences in drinking patterns and drinking norms, we focused on validation studies from the United States. Four large U.S. studies58, 64, 66, 71, 73 (three settings: Texas, Georgia, and Seattle VAs) included appropriate detailed interview-based criterion standards for the full spectrum of alcohol misuse and adequate numbers of patients to have adequate precision for sensitivity. Some of these studies found screening thresholds of 8 on the AUDIT were so insensitive that they were not even reported. The AUDIT had sensitivity of 0.44 to 0.51 and specificity of 0.96 to 0.97 for identifying alcohol misuse in adults using a cut-point of ≥8; more optimal balance of sensitivity and specificity were seen at cutoffs of 4 or 5. The sensitivity and specificity at a cutoff of ≥4 were 0.84 to 0.85 and 0.77 to 0.84, respectively; and at a cutoff of ≥5 were 0.70 to 0.92 and 0.73 to 0.94, respectively. Further, sex-specific cutoffs may be warranted because sensitivities for women at cutoffs of ≥4 and ≥5 were 0.47 to 0.65 and 0.35 to 0.53, respectively, but improved to 0.70 to 0.79 at ≥3 (with specificity of 0.86 to 0.87).

For the AUDIT-C, the appropriate cut-points for balancing sensitivity and specificity appear to be ≥ 2 or 3 for women and ≥ 4 for men.64

#### Screening for Risky/Hazardous Drinking

Some studies reported sensitivity and specificity separately for risky drinking and for alcohol use disorders. We provide this information in this section and the following section. Data on sensitivity and specificity for the full spectrum of alcohol misuse are in the previous section. Sensitivity and specificity values for each of the screening instruments are reported in Table 6 for studies identifying risky/hazardous drinking. Where reported, cutoff scores for each instrument are also included.

Among the studies included in this report, the AUDIT appears to be the most widely assessed screening instrument. It has been studied across a variety of populations. For detecting risky drinking in adults, a wide range of sensitivities have been reported for the AUDIT at a cutoff of ≥8. The AUDIT-C had the highest reported sensitivity (0.98) for detecting risky drinking in adults. The AUDIT-C also showed excellent sensitivity and specificity for identifying risky drinking in pregnant women (0.95 and 0.85, respectively). The CAGE showed sensitivity ranging as low as 0.49 for detecting risky/hazardous drinking in adults.

#### Screening for Abuse/Dependence

Table 7 presents results for the sensitivity and specificity of the screening instruments for detecting alcohol abuse or dependence across the various populations.

In general, several of the screening instruments had adequate sensitivity for detecting alcohol abuse or dependence, with several studies reporting sensitivities above 0.90 (for the AUDIT, AUDIT-C, CAGE, SMAST) for adults. Specificity was better for the AUDIT (0.85 to 0.96 at a cutoff of ≥8) and CAGE (0.79 to 0.97) than for the AUDIT-C (0.45). For pregnant women, the three-question AUDIT-C had better sensitivity than the AUDIT for detecting abuse or dependence (0.96 to 1.0 vs. 0.23 at a cutoff of ≥3), but the AUDIT had greater specificity (0.97 vs. 0.71).

The CAGE showed much better sensitivity for detecting alcohol abuse/dependence than it did for at-risk drinking. However, the CAGE identifies lifetime abuse or dependence, and most patients in whom alcohol abuse is detected in primary care using the CAGE questionnaire are either actively addressing their substance abuse or are in recovery.78 The range of sensitivity reported for single-question screens was from 0.77 to 0.88 for detecting alcohol abuse or dependence, depending on whether the past 3 or 12 months was considered.

Some studies have reported the probability of alcohol dependence based on scores from screening instruments.79 From a family medicine clinic population including 392 men and 927 women with mean ages of 46 and 42 years, respectively, the AUDIT was found to have a post-screening probability of alcohol dependence of 87 percent for men for scores from 15-40 and 94 percent for women for scores from 13-40; the AUDIT-C was found to have a post-screening probability of alcohol dependence of 75 percent for men and 88 percent for women for scores from 10-12; AUDIT-3 (the 3rd question of the AUDIT, asking the frequency of drinking ≥6 drinks) was found to have a post-screening probability of alcohol dependence of 58 percent for men for scores from 3-4 and 88 percent for women for scores of 4; and a single question about the number of days drinking ≥5 drinks over the past month was found to have a post-screening probability of alcohol dependence of 83 percent for responses from 14-30 and 38 percent for women for responses from 3-30. The probability of alcohol dependence was much lower for lower scores.

The tables in this Key Question include information on instruments designed to screen only for alcohol misuse (either for the full spectrum or for part of the spectrum). Another instrument that deserves mention here is the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST),80 developed by the WHO to screen for all psychoactive substances, including alcohol, smoking, and other substances. The ASSIST is relatively brief, composed of eight questions or items, covering 10 substances: tobacco, alcohol, cannabis, cocaine, amphetamine-type stimulants, inhalants, sedatives, hallucinogens, opioids, and “other drugs.” The development, reliability, and feasibility of the ASSIST, which were published in 2002, were based on a multinational sample from Australia, Brazil, Ireland, India, Israel, the Palestinian Territories, Puerto Rico, the United Kingdom, and Zimbabwe.81 A total of 236 volunteer participants completed test and retest interviews. Sixty percent of the sample was recruited from alcohol and drug abuse treatment facilities, and the rest were from general medical settings and psychiatric facilities. A subsequent study enrolled 1,047 subjects (350 from drug treatment and 697 from primary health care settings) from seven countries, including the United States, to examine validity of the ASSIST.82 The study reported discriminative validity of the ASSIST (to discriminate between substance use, abuse, and dependence), as well as concurrent validity, demonstrated by significant correlations between ASSIST scores and scores from other validated instruments, including the AUDIT (r = 0.82).

#### Instrument Burden

The practitioner and patient time burdens are important considerations when choosing a screening instrument. The instruments included in our report varied from 1 to 60 questions, and administration time for the various instruments ranged from less than 1 minute to 16 minutes (Table 8). Briefer questionnaires may be more feasible to administer in a busy practice and are less likely to disrupt the flow of patients.

Table 8 Screening instrument details

Instrument | Number of Questions | Administration | Time Burden
ARPS | 60 | Written/Computer Scoring | 16 min
shARPS | 32 | Written/Computer Scoring | 2-5 min
AUDIT | 10 | Oral, written, computer | 2-5 min
AUDIT-C | 3 | Oral, written, computer | 1-2 min
CAGE | 4 | Written/Oral | 1 min
MAST | 22 | Written | 8 min
MAST-G | 24 | Written | 10 min
SMAST | 13 | Written | 5 min
SMAST-G | 10 | Written | NR
NET | 3 | Written/Oral | 1 min
Single question: 3 months | 1 | Oral | <1 min
Single question: 12 months | 1 | Oral | <1 min
T-ACE | 4 | Written/Oral | 1 min
TWEAK | 5 | Written/Oral | <2 min

ARPS = Alcohol-Related Problems Survey; AUDIT = Alcohol Use Disorders Identification Test; AUDIT-C = Alcohol Use Disorders Identification Test – Consumption; CAGE = Cut-down, Annoyed, Guilty, Eye-opener questionnaire; MAST = Michigan Alcoholism Screening Test; MAST-G = short Michigan Alcoholism Screening Test – geriatric version; NET = Normal drinker, Eye-opener, Tolerance questionnaire; shARPS = Alcohol-Related Problems Survey – shortened version; SMAST = Short Michigan Alcohol Screening Test; T-ACE = Tolerance, Annoyed, Cut-down, Eye-opener questionnaire; TWEAK = Tolerance, Worried, Eye-opener, Amnesia, Kut-down questionnaire

Some of the screening instruments can be asked by interview, some by self-administration or interview, and some are not feasible without either electronic forms or other aids (e.g., the AUDIT or ASSIST that require selecting across multiple responses and scoring).

## Key Question 3 What adverse effects are associated with screening for alcohol misuse and screening-related assessment?

Possible adverse effects of screening for alcohol misuse include anxiety; stigma, labeling, or discrimination; and interference with the doctor-patient relationship. Additionally, we considered the possible opportunity costs given that screening may take time away from other clinical activities. Finally, one could hypothesize that screening for unhealthy alcohol use might lead to increased smoking or illegal substance use if people replace one harmful substance with another. However, we found no studies that explicitly addressed any of these potential adverse effects (insufficient strength of evidence).

### Summary of Findings

#### Adverse Effects

We found no studies meeting inclusion/exclusion criteria (insufficient strength of evidence).

## Key Question 4a How do behavioral counseling interventions, with or without referral, compare with usual care for improving intermediate outcomes for people with alcohol misuse as identified by screening?

### Summary of Findings

In the bulleted text below we summarize the main findings for each population (adults, older adults, young adults and college students, and pregnant women) by outcome and report the strength of evidence (SOE) for each outcome. Overall, evidence supports the effectiveness of behavioral interventions for improving several intermediate outcomes for adults, older adults, and young adults/college students (moderate or low SOE, depending on the population and outcome). For pregnant women, the included studies did not provide evidence of the effectiveness of behavioral interventions for improving intermediate outcomes over 6 months or longer (low or insufficient SOE, depending on the outcome). Subgroup analyses did not identify differences between men and women. Brief multicontact interventions have the best evidence of effectiveness across populations, outcomes, and have followup data over several years. Our meta-analyses of studies in adults found very brief (up to 5 minutes) and brief (more than 5, up to 15 minutes) single-contact interventions to be ineffective for some outcomes and less effective than brief multicontact interventions for others. Table 9 summarizes findings for the three intermediate outcomes most commonly reported, by population.

Table 9 Summary of effectiveness and strength of evidence of behavioral interventions compared with controls for improving intermediate outcomes, by population

Population | Consumption^a^ (Mean Drinks/Week) | Heavy Drinking Episodes^b^ | Recommended Drinking Limits
Adults | Reduction of 3.6 (2.4 to 4.8) from baseline ∼23 Moderate SOE | 12% fewer subjects reported heavy drinking episodes (7%, 16%) from ∼52% at baseline Moderate SOE | 11% more subjects achieved (8%, 13%) Moderate SOE
Older adults | Reduction of 1.7 (0.6 to 2.8) from baseline ∼16 Moderate SOE | Insufficient SOE | 9% more subjects achieved (2%, 16%) Low SOE
Young adults or college students | Reduction of 1.7 (0.7 to 2.6) from baseline ∼15 Moderate SOE^c^ | 0.9 fewer heavy drinking days (0.3, 1.5) from ∼6.2 days per month at baseline Moderate SOE^c^ | Insufficient SOE
Pregnant women | Data from 1 study found no difference Low SOE | Insufficient SOE | Insufficient SOE
Adolescents | Insufficient SOE | Insufficient SOE | Insufficient SOE

SOE = strength of evidence

a Baseline consumption (drinks/week): adults, mean ∼23, median ∼19, range 8 – 62 (data from 16 trials); older adults, 15.2 to 16.6 (data from two trials); young adults/college students, mean ∼15, median ∼17, range 8 to 18 (two of the five trials did not report baseline consumption).

b Heavy drinking generally defined by consumption of five or more standard drinks for men and four or more for women. Baseline % with heavy drinking episodes: adults, mean ∼52, range 10 – 100.

c These data are 6-month outcomes; for consumption for young adults, we were unable to calculate pooled point estimate for 12-month data, but range of reduction was 1.2 to 4.1 drinks per week at 12 months (moderate SOE); for heavy drinking for young adults, differences were not statistically significant at 12 months (low SOE).

Notes: Data presented are effect size (95% CI) for all interventions regardless of intensity of counseling; the effect sizes for brief multicontact interventions were generally greater than those shown; all outcomes are 12 months unless otherwise indicated with a footnote; all percentages reported are absolute risk differences (difference between intervention and control groups) from our meta-analyses.

Intensity of intervention: Brief multicontact interventions have the best evidence of effectiveness. Our meta-analyses of studies in adults found (1) very brief (up to 5 minutes) single-contact interventions to be ineffective for improving consumption (data from one very-brief-intervention study83) and less effective than brief multicontact interventions for achieving recommended drinking limits (data from one very-brief-intervention study84); and (2) brief single-contact interventions to be ineffective for reducing heavy drinking episodes and less effective than brief multicontact interventions for reducing consumption and achieving recommended drinking limits.

#### Adults

- Consumption: Behavioral interventions resulted in a greater reduction in quantity of alcohol consumed than controls at 12 months (weighted mean difference [WMD], -3.6 drinks per week, 95% CI, -4.8 to -2.4, moderate SOE). Subgroup analyses for men and women found similar benefits. When stratifying by intensity of the intervention, we found no statistically significant difference between very brief interventions and controls (just one study contributed), but found greater reduction for brief, brief multicontact, and extended multicontact interventions than for controls. We found similar results for studies conducted in the United States compared with those conducted in other countries, a trend toward a greater reduction in consumption for interventions delivered primarily by primary care providers (WMD, -4.0 drinks per week, 95% CI, -5.4 to -2.6) than for those delivered primarily by research personnel (WMD, -3.0, 95% CI, -5.0 to -1.0), and that studies enrolling 10 percent or more subjects with alcohol dependence found behavioral interventions to be ineffective or less effective than other studies.
- Heavy drinking episodes: Behavioral interventions resulted in 12 percent more subjects reporting no heavy drinking episodes by 12 months compared with controls (risk difference 0.12, 95% CI, 0.07 to 0.16, moderate SOE). Subgroup analyses for men and women found similar results. When stratifying by intensity of the intervention, brief multicontact and extended multicontact interventions were efficacious at 12 months (with 11 percent and 19 percent absolute difference compared with controls, respectively), but brief interventions did not reach statistical significance compared with controls.
- Recommended drinking limits achieved: 11 percent more subjects receiving interventions achieved recommended drinking limits by 12 months compared with controls (risk difference 0.11, 95% CI, 0.08 to 0.13, moderate SOE). Subgroup analyses for men and women found similar magnitude of benefit. All of the intervention intensities studied were efficacious. The absolute difference in percentage of subjects achieving recommended drinking limits was numerically greatest for the brief multicontact interventions (15% compared with 8%for very brief and brief interventions at 12 months), but the confidence intervals overlap.
- Followup with referrals: None of the included studies reported (insufficient SOE).
- Abstinence: Three heterogeneous studies reporting abstinence among secondary outcome measures provided insufficient evidence to make a conclusion.84-86 Of note, none of the studies were designed to achieve abstinence, and it should probably not be a goal of behavioral interventions for most people.

#### Older Adults

- Consumption: Behavioral interventions resulted in a greater decrease than controls at 12 months (WMD, -1.7 drinks per week, 95% CI, -2.8 to -0.6, moderate SOE).
- Heavy drinking episodes: evidence was insufficient to make a conclusion (insufficient SOE).
- Recommended drinking limits achieved: 9 percent more subjects in the intervention groups than in control groups achieved recommended drinking limits by 12 months (risk difference 0.09, 95% CI, 0.02 to 0.16, low SOE).
- Followup with referrals: none of the included studies reported (insufficient SOE).
- Abstinence: none of the included studies reported (insufficient SOE).

#### Young Adults and College Students

- Consumption: Interventions resulted in greater reduction than controls at 6 months (WMD, -1.7 drinks per week, 95% CI, -2.6 to -0.7, moderate SOE) and at 12 months (from 1.2^87^ to 4.1^88^ drinks per week, moderate SOE).
- Heavy drinking episodes: In-person interventions resulted in a greater reduction in heavy drinking days per month compared with controls (WMD, -0.9 heavy drinking days, 95% CI, -1.5 to -0.3), as did Web-based interventions (rate ratio [RR], 0.76, 95% CI, 0.61 to 0.93) at 6 months (moderate SOE); but differences were not statistically significant at 12 months (low SOE).
- Recommended drinking limits achieved: None of the included studies reported (insufficient SOE).
- Followup with referrals: None of the included studies reported (insufficient SOE).
- Abstinence: None of the included studies reported (insufficient SOE).

#### Pregnant Women

- Consumption: Reduction in mean drinks per drinking day was not significantly different between groups (-0.3 vs. -0.4, p=NS, excluding patients who maintained abstinence through the end, low SOE).
- Heavy drinking episodes: None of the included studies reported (insufficient SOE).
- Recommended drinking limits achieved: None of the included studies reported (insufficient SOE).
- Followup with referrals: None of the included studies reported (insufficient SOE).
- Abstinence: One study provided insufficient evidence for the overall sample (insufficient SOE) but found maintenance of higher rates of abstinence for the subgroup of subjects who were abstinent prior to assessment (86% vs. 72%, p=0.04, low SOE).

### Evidence in Adults

#### Characteristics of Included Studies

Table 10 summarizes the characteristics of the 16 trials targeting adult populations meeting our inclusion criteria for this question. Further details are provided in Appendix C. All were RCTs conducted exclusively in primary care settings except for the WHO study,84 which included a variety of outpatient medical settings (including some emergency departments), depending on the country. The trials generally targeted those with risky/hazardous drinking. One study conducted in Spain enrolled exclusively those with “binge drinking.”89 Most studies excluded subjects with alcohol dependence or constructed inclusion/exclusion criteria to limit the number of potential subjects with alcohol dependence (e.g., exclusion of those with symptoms of withdrawal in the past year, with a history of receiving treatment for an alcohol problem, or who had been told by a clinician to cut down in the past). However, it was often not reported whether any subjects with alcohol dependence were enrolled. Three studies reported more than 10 percent of included subjects with alcohol dependence.83, 90, 91 These included a study conducted in 85 general practices in Germany with 30.4 percent meeting criteria for dependence (by DSM-IV diagnostic interview),90 a study conducted in rural primary care sites in Thailand with around 15 percent (based on an AUDIT score >25),91 and a study conducted in 40 primary care practices in Australia with 35 percent (those with moderate physical dependence based on the physical dependence on alcohol (Ph) score from the Comprehensive Drinker Profile, although the study excludes those with evidence of severe alcohol dependence based on Ph score >10, or those with severe levels of alcohol-related problems based on a MAST score of >20).83

Table 10 Characteristics of included trials comparing behavioral counseling interventions with usual care for improving intermediate outcomes for adults with alcohol misuse

Study | N % Dep | Duration (mths) | Country | Setting | Mean Age (y) | % Fem | % Non-white | Baseline Alcohol Use (Drinks/wk) | Quality
Anderson, Scott,1992^92^ | 154 NR | 12 | U.K. | 8 PC group practices | 43 to 45.1 | 0 | NR | 37.9 to 38.8 | Fair
WHO Brief Intervention Study, 1996^84^ | 1,559 0 | 9 | 8, including U.S. | Outpatient medical settings | 35.9 to 36.9 | 19.2 | NR | NR | Fair
Bischof et al., 2008^90^ Grothues et al., 2008^93^ Reinhardt al., 2008^94^ SIP study | 408 30.4 | 12 | Germany | 85 general practices | 35.9 to 36.8 | 31.9 | NR | 21 to 25.2 | Fair
Curry et al., 2003^95^ | 307 NR | 12 | U.S. Wash. State | 23 PCPs in an HMO, urban clinic | 47 | 35 | 20 | 14.2 | Fair
Fleming et al., 1997^88, 96-99^ Project TrEAT | 774 NR^a^ | 48 | U.S. Wisconsin | 17 community PC practices | NR^b^ | 38 | 5.6 to 11.9 | 18.9 to 19.1 | Good
Fleming et al., 2008^100, 101^ Healthy Moms | 235 NR | 6 | U.S. Wisconsin | 34 OB practices | Median 28 | 100 | 18.3 | 8 to 8.5^c^ | Good
Lock et al., 2006^102^ | 127 0 | 12 | U.K. | General practices | 44.1 | 50 | NR | 23 to 26.48 | Fair
Maisto et al., 2001^103-105^ ELM | 301 NR | 12 | U.S. Penn. | 12 PC clinics | 45.6 | 30.2 | 23.3 | 15.5 to 18.6 | Fair
Noknoy et al., 2010^91^ | 117 13.8 to 15.3^d^ | 6 | Thailand | Rural PC units | 37 | 8.5 | 100 (Thai) | 15.15 | Fair
Ockene et al., 1999^106-108^ Project Health | 530 2 | 48 | U.S. Mass. | 4 PC sites (93 clinicians) | 43.5 to 44.2 | 32.1 to 38.7 | 4.3 to 6.6 | 16.6 to 18.9 | Fair
Richmond et al., 1995^83^ Alcoholscreen | 378 35^e^ | 12 | Australia | 40 PC practices | 37.7 | 43 | NR | 38.5 | Fair
Rubio et al., 2010^89^ | 752 0 | 12 | Spain | 20 PC centers in Madrid | NR, >70% were 31-40 | 34.7 | NR | 26.90 to 27.42 | Fair
Saitz et al., 2003^86^ SIP | 312 NR^f^ | 6 | U.S. Mass. | Urban academic PC practice | 42.2 to 43.7 | 29 to 43 | 80 to 82 | Mean drinks per drinking day: 5.5 to 5.6 | Fair
Scott, Anderson, 1990^109^ | 72 NR | 12 | U.K. | 8 PC group practices | 44.4 to 47.2 | 100 | NR | 25.8 to 26.7 | Fair
Senft et al., 1997^85^ Freeborn et al., 2000^110^ | 516 0 | 24 | U.S. Oregon | 3 PC clinics in an HMO | 41.9 to 43 | 28.1 to 31.1 | 17.4 to 18.7 | 16.5 | Fair
Wallace et al., 1988^111^ | 909 NR | 12 | U.K. | 47 group practices | 41.7 to 44.6 | 29.1 to 29.8 | NR | 35.1 (females) and 62.2 (males) | Fair

% Dep = percentage of subjects with alcohol dependence; ELM = Early Lifestyle Modification; Fem = female; HMO = health maintenance organization; Mass = Massachusetts; mths = months; N = total number randomized/assigned to intervention and control groups; NR = not reported/unclear; OB = obstetrical; PC = primary care; PCP = primary care physician; Penn = Pennsylvania; SIP (Bischof et al.) = Stepped Intervention for Problem Drinkers; SIP (Saitz et al.) = Screening and Intervention in Primary Care Study; TrEAT = Trial for Early Alcohol Treatment; U.K. = United Kingdom; U.S. = United States; Wash = Washington; WHO = World Health Organization; wk = week; y = years

a Six subjects (per medical record audit) received formal alcohol treatment during the 1-year followup period; those may represent subjects ultimately diagnosed with alcohol dependence.

b Group 1: Men, 20.2% 18-30y; 27.2% 31-40y; 23.9% 41-50y; 28.8% 51-65y; Women, 43.5% 18-30y; 25.9% 31-40y; 15.6% 41-50y; 15.0% 51-65y. Group 2: Men, 26.0% 18-30y; 25.1% 31-40y; 21.3% 41-50y; 27.7% 51-65y; Women, 35.7% 18-30y; 35.7% 31-40y; 18.2% 41-50y; 10.5% 51-65y.

c Healthy Moms trial set the inclusion criteria below the NIAA-recommended limit of 30 drinks per month because they reasoned that postpartum women may be more vulnerable to alcohol-related harm and they wanted to see whether brief intervention could reduce drinking in this population.

d Based on AUDIT >25.

e Percentages with moderate physical dependence based on the Ph score from the Comprehensive Drinker Profile. The study excluded those with evidence of severe alcohol dependence (Ph score >10) or those with severe levels of alcohol-related problems (MAST >20).

f Mean (SD) Alcohol Dependence Scale (ADS) score 7.4 to 7.5 (ADS score can range from 0-47. A score of 9 or more is highly predictive of DSM diagnosis of alcohol dependence).

Note: When data were not reported for mean age, %female, % nonwhite, and baseline alcohol consumption for the total sample but was presented for each study group, we give the range of the means for the various study groups.

Seven studies were conducted exclusively in the United States, four in the United Kingdom, and one each in Germany, Thailand, Australia, and Spain (Table 10). Most studies followed subjects for 6 to 12 months; three studies reported outcomes beyond 12 months, up to 24 months,85, 110 or 48 months.88, 96-99, 106, 107

The mean age ranged from 35 to 47 for all but one study conducted in postpartum women (Healthy Moms), reporting a median age of 28.^100^ Women represented 30 percent or more of study participants in all U.S. studies. Rates of nonwhite participants were not reported in many studies, and were usually low when reported (generally 4% to 23%), except for two trials—one conducted in Thailand91 (100% Thai) and one conducted in an urban academic practice (80-82% nonwhite).86

Most studies reported a baseline alcohol consumption between 15 and 30 drinks per week. Two studies conducted in the United Kingdom92, 111 and one from Australia83 reported more than 30 drinks per week at baseline. One study, the Healthy Moms study, reported a median 8 to 8.5 drinks per week.100 It was the only study reporting fewer than 14 drinks per week at baseline. The authors explain that they set the inclusion criteria below the NIAAA–recommended limit of 30 drinks per month because they reasoned that postpartum women may be more vulnerable to alcohol-related harm, and they wanted to see whether brief intervention could reduce drinking in this population. As a result, some of the women included in this study would not meet criteria for alcohol misuse. Less than 30 percent of the included women were breastfeeding.

In the trials reviewed, methods to identify individuals with alcohol misuse generally involved two steps: (1) screening (of a population to identify those with probable alcohol misuse) and (2) screening-related assessment (confirming screening results and distinguishing patients suitable for the intervention and enrollment in the trial from those needing specialty care referral). This two-stage procedure was used by the oldest relevant study111 and was adapted by many of the subsequent studies. The screening-related assessment stage was often a longer in-person interview conducted by research personnel, including detailed questions about each day's drinking in the past week. Studies generally used validated, established screening instruments (e.g., AUDIT) as adjuncts to various quantity, frequency, and use-per-occasion measures. None of the studies relied on just the CAGE instrument to identify those with alcohol misuse, but several studies used it as a supplement to quantity-frequency measures. Research team personnel were most often involved in screening and determination of study eligibility, rather than primary care physicians or clinic staff. Additional details of screening methods for individual studies are provided in Appendix C.

The interventions of included studies for this section are described in Table 11, stratified by intervention intensity. Intervention intensity varied from very brief (single contact, 5 minutes or less) to brief (single contact, more than 5 and up to 15 minutes) to brief multicontact (multiple contacts, up to 15 minutes each) to extended multicontact (multiple contacts, one or more of them greater than 15 minutes). The most common were brief interventions, used by six studies, and brief multicontact interventions, included in seven studies. Four trials included multiple intervention arms.83, 84, 90, 93, 94, 103-105

Table 11 Description of behavioral counseling interventions for improving intermediate outcomes for adults with alcohol misuse, by intervention intensity

Intensity | Study | Intervention | Delivered By | Delivery Method | No. of Contacts | Length of Each Contact
Very brief | Richmond et al., 1995^83^ Alcoholscreen | Group 2: Physician advice and a self-help manual (after assessment) | PCP | In person | 1 | 5 min
Very brief | WHO Brief Intervention Study, 1996^84^ | Group 1: Advice, illustrated pamphlet | Various clinic staff | In person | 1 | 5 min
Brief | Anderson, Scott, 1992^92^ | Brief advice, feedback about own consumption and norms, and a self-help booklet | PCP | In person | 1 | 10 min
Brief | Lock et al., 2006^102^ | Brief advice (“drink-less” protocol) on standard drink units, recommended consumption levels, benefits of cutting down, tips on reducing consumption, advice on goal-setting, action plan, and self-help booklet/diary | Nurse or PA | In person | 1 | 5-10 min
Brief | Maisto et al., 2001^103-105^ ELM | Brief advice: emphasized feedback from baseline results and implications for drinking, coupled with advice regarding a goal to reduce or stop alcohol consumption | Research staff | In person | 1 | 10-15 min
Brief | Scott, Anderson, 1990^109^ | Brief advice, feedback about own consumption and norms, and a self-help booklet | PCP | In person | 1 | 10 min
Brief | Senft et al., 1997^85^ Freeborn et al., 2000^110^ | 30-second message from PCP and 15-minute session with health counselor immediately following PCP visit | PCP and study health counselor | In person | 1 | ∼15 min
Brief | WHO Brief Intervention Study, 1996^84^ | Group 2: Brief intervention, 30-page illustrated problem-solving manual | Various clinic staff | In person | 1 | 15 min
Brief multi-contact | Curry et al., 2003^95^ | Brief motivational message from PCP during regularly scheduled visit; self-help manual; written personalized feedback; up to 3 outreach phone counseling calls from health educator | PCP and research health educator | In person and phone | Up to 4 | 1-5 min for PCP; mean 14 min for phone calls
Brief multi-contact | Fleming et al., 1997^88, 96-99^ Project TrEAT | Two visits 1 month apart with PCP and a followup phone call from the clinic nurse 2 weeks after each visit; workbook containing feedback regarding current health behaviors, review of prevalence of problem drinking, list of adverse effects of alcohol, worksheet on drinking cues, drinking agreement/prescription, and drinking diary cards | PCP and nurse | In person and phone | 4 | 15 min for PCP contacts; NR for phone calls
Brief multi-contact | Fleming et al., 2008^100, 101^ Healthy Moms | Two visits, each with phone followup; a workbook containing scripted messages with feedback regarding current health behaviors, prevalence of problem drinking, list of adverse effects of alcohol focused on women and pregnancy, worksheet on drinking cues, drinking agreement in the form of a prescription, and drinking diary cards | Nurse (90%) or OB | In person and phone | 4 | 15 min for two in-person contacts; NR for phone calls
Brief multi-contact | Noknoy et al., 2010^91^ | Motivational enhancement protocol: brief counseling sessions using patient-centered interviewing style and considering stages of change | Nurse or PA | In person | 3 | 15 min
Brief multi-contact | Ockene et al., 1999^106-108^ Project Health | Tailored consultation with clinician plus followup visit. Counseling entailed talking about number of drinks per week, heavy drinking episodes, or both. RAs affixed patients' alcohol consumption info and patient education materials to patient's chart at regular office visit; also included a health booklet at enrollment. | PCP | In person | 2 | 5-10 min
Brief multi-contact | Rubio et al., 2010^89^ | Brief advice using intervention workbook (review of alcohol-related health effects, pie chart displaying frequency of types of at-risk drinkers, list of methods for cutting down, treatment contract, cognitive behavioral exercises) plus phone reinforcement by nurse and general health booklet. | PCP | In person | 2 | 10-15 min
Brief multi-contact | Wallace et al., 1988^111^ | Brief advice, an information booklet (“That's the Limit”), sex-based recommendation for limiting drinking, a drinking diary, and followup sessions. | PCP | In person | 1 to 5^a^ | NR^b^
Extended multi-contact | Bischof et al., 2008^90^ Grothues et al., 2008^93^ Reinhardt et al., 2008^94^ SIP study | Group 1: Full Care (FC): immediate computerized post-assessment feedback and multiple sessions of counseling by psychologist. | Trained psychologists from research team | Phone | 4 | Scheduled for 30 min each; mean received was 80.3 min
Extended multi-contact | Bischof et al., 2008^90, 93, 94^ SIP study | Group 2: Stepped Care (SC): immediate computerized post-assessment feedback and maximum of 3 counseling sessions with psychologist. Sessions were discontinued if patients indicated consumption below study criteria and high self-efficacy to maintain desired behavior. | Trained psychologists from research team | Phone | Up to 4 | Scheduled for 30-40 min each; mean received was 40 min
Extended multi-contact | Richmond et al., 1995^83^ Alcoholscreen | Group 1: “Alcoholscreen” program: 5 short consultations (introduction, patient education, 3 followups) designed to reduce drinking to recommended limits. Included self-help manual, daily alcohol diary, and personalized patient education and counseling. | PCP | In person | 5 | 15-20 min (intervention visit); 5-25 min (followup visits)
Extended multi-contact | Maisto et al., 2001^103-105^ ELM | Motivational enhancement: longer, main initial session, 2 shorter booster sessions, use of empathy and other techniques to enhance motivation; focus on delivery of feedback of assessment data and setting alcohol- use goals. | Research staff | In person | 3 | One 30-45 min; two 15-20 min booster sessions
NR/Unknown^c^ | Saitz et al., 2003^86^ SIP | Providing physicians with positive alcohol screening results and specific recommendations for their patients at a visit. | PCP | In person | NR/Unknown^c^ | NR/Unknown^c^

ELM = Early Lifestyle Modification; min = minutes; No. = number; NR = not reported; OB = Obstetrician; PA = Physician Assistant; PCP = primary care physician; RA = Research Assistant; SIP (Bischof et al.) = Stepped Intervention for Problem Drinkers; SIP (Saitz et al.) = Screening and Intervention in Primary Care Study; TrEAT = Trial for Early Alcohol Treatment; WHO = World Health Organization

a All intervention subjects received an invitation to a 1-month followup; other followup was offered at 4, 7, and 10 months at the discretion of the practitioner.

b Not reported in the article; per the author, they trained them to do “up to 15 minutes,” and he believes they were generally 10-15 minutes (Paul Wallace, personal email communication, December 2011).

c No particular behavioral intervention was required, the intervention was to provide physicians with positive screening results. Based on assessment immediately after the visit, some discussion about drinking was reported for 51% (residents) to 74% (faculty) of visits for the intervention group (and 70% for residents and 51% for faculty in the control group).

The majority of studies tested interventions delivered primarily by the patient's primary care physician (9 of 16 studies; 10 of 20 interventions).83, 88, 89, 92, 95-99, 106-109, 111 Three studies tested interventions delivered primarily by nurses,91, 100-102 three studies (contributing five interventions) tested interventions delivered primarily by research team personnel such as a health counselor or trained psychologist,85, 90, 93, 94, 103-105, 110 and one study from the WHO group (contributing two interventions) tested interventions delivered by various clinic staff.84 Among the interventions involving the patient's usual primary care physician, some used the physicians to deliver initial and any repeated intervention contacts whereas others also used educators, counselors, or nurses.

The majority of control groups received screening/assessment followed by usual care or by the provision of a general health pamphlet. A few studies included additional components in the control group that could bias the results toward the null—control group protocols in these studies included recording screening/assessment results on the chart,83 forwarding screening/assessment results to a physician,103 or advice from nurses on cutting down drinking and a leaflet with daily benchmark alcohol guides.102

The study by Saitz and colleagues was the only included study to focus on a systems intervention to provide physicians with positive alcohol screening results and simple recommendations for their patients at a visit.86 It was a cluster RCT conducted in urban primary care practices. Physicians in the control group did not receive any information from the study.

#### Alcohol Use, Number of Drinks

Results of our meta-analyses are summarized in Table 12. Additional details and forest plots are provided in Appendix E. Adults receiving behavioral interventions had a greater reduction in quantity of alcohol consumed than those in control groups by 3.2 and 3.6 drinks per week at 6 and 12 months, respectively. Similarly, subgroup analyses for men and women found greater reduction in alcohol consumption for those receiving behavioral interventions than those in control groups at 6 and 12 months, with reductions ranging from 2.5 to 4.6 drinks per week.

Table 12 Mean change in drinks per week for behavioral counseling interventions compared with controls: Summary of meta-analyses for adults

Population | Intensity | Timing | N | WMD^a^ | 95% CI | I^2^
Adults | All | 12 months | 14 (4,332 subjects) | -3.6 | -4.8, -2.4 | 14
Adults | Very brief | 12 months | 1 | 2.7 | -5.2, 10.6 | 0
Adults | Brief | 12 months | 4 | -3.7 | -6.3, -1.0 | 0
Adults | Brief, multicontact | 12 months | 5 | -4.4 | -6.1, -2.7 | 58
Adults | Extended, multicontact | 12 months | 4 | -2.5 | -4.8, -0.3 | 0
Adults | All | 6 months | 11 | -3.2 | -4.4, -2.0 | 28
Adults | Very brief | 6 months | 1 | 0.9 | -7.5, 9.3 | 0
Adults | Brief | 6 months | 1 | 1.1 | -9.5, 11.8 | 0
Adults | Brief, multicontact | 6 months | 6 | -3.5 | -4.9, -2.1 | 48
Adults | Extended, multicontact | 6 months | 1 | -2.1 | -10.9, 6.7 | 0
Adult men | All | 12 months | 6 | -4.0 | -6.6, -1.3 | 64
Adult men | All | 6 months | 4 | -4.1 | -7.9, -0.2 | 30
Adult women | All | 12 months | 6 | -4.6 | -5.9, -3.2 | 0
Adult women | All | 6 months | 5 | -2.4 | -3.4, -1.3 | 0

CI = confidence interval, rounded to tenths; N = number of comparisons contributing to the meta-analysis; WMD = weighted mean difference (for absolute difference for change in drinks per week), rounded to tenths

a Negative numbers favor behavioral counseling interventions over controls.

When stratifying by intensity of the intervention, we found no statistically significant difference between very brief interventions and controls (just one study contributed to the meta-analysis for this comparison), but found greater reduction in alcohol consumption for brief (by 3.7 drinks per week at 12 months), brief multicontact (by 3.5 drinks per week at 6 months and 4.4 drinks per week at 12 months) and extended multicontact interventions (by 2.5 drinks per week at 12 months) than for controls.

The meta-analyses for all adults did not have significant statistical heterogeneity at 6 or 12 months. The subgroup analyses for men at 12 months and the analyses for the brief multicontact interventions had moderate statistical heterogeneity (Table 12). From analyses removing each individual study one at a time, the moderate heterogeneity was no longer present after removing the study by Wallace and colleagues,111 which reported a greater effect size in males than any other study. Of note, this study reported one of the highest baseline rates of drinks per week of the included studies; it was one of three included studies reporting more than 30 drinks per week at baseline on average. Removing this study would decrease the effect size to -2.7 drinks per week (I^2^=0) for the subgroup analysis for men at 12 months and to -3.7 (I^2^=0) for the brief multicontact interventions among all adults at 12 months.

We conducted meta-regression and ran subgroup analyses for the change in consumption at 12 months for several variables to explore whether effectiveness differed significantly for certain populations, settings, or intervention characteristics (Appendix E). These included country (studies conducted in the United States compared with non-U.S. studies), person primarily responsible for delivering the intervention (primary care provider, nurse, or research personnel), and whether subjects with alcohol dependence were included in the sample. Subgroup analyses by country found similar effect sizes for studies conducted in the United States and for non-U.S. studies, and our meta-regression did not find country to be a significant contributor to the overall variance in the analysis. Thus, studies conducted in the United States and outside of the United States have found similar effectiveness of behavioral interventions for reducing alcohol consumption over 12 months, on average.

Our subgroup analyses found a trend toward a greater numerical reduction in drinks per week for interventions delivered primarily by primary care providers (WMD, -4.0, 95% CI, -5.4 to -2.6) than for those delivered primarily by research personnel (WMD, -3.0, 95% CI, -5.0 to -1.0). Just one intervention delivered by a nurse contributed to the analysis; the reduction in drinks per week was not statistically significant for that study (WMD, -0.2, 95% CI, -8.9 to 8.6). Our meta-regression did not find provider type to be a significant contributor to the overall variance in the analysis.

Our subgroup analyses suggested that studies enrolling 10 percent or more subjects with alcohol dependence found behavioral interventions to be less effective than those enrolling 0 to 10 percent of subjects with dependence or those not reporting sufficient data to determine the percentage with dependence (but likely including 0 to 10% based on inclusion/exclusion criteria). Of note, pooled analyses for the former subgroup did not find a statistically significant benefit of behavioral interventions (WMD, -2.4 drinks per week, 95% CI, -5.2 to 0.4), but this group included one very brief intervention83 that was not effective and could possibly explain the nonsignificant result. Removing the very brief intervention resulted in statistically significant benefit for studies enrolling 10 percent or more subjects with alcohol dependence (WMD, -3.1 drinks per week, 95% CI, -6.1 to -0.2), but still with a magnitude of effect lower than that for studies enrolling 0 to 10 percent of subjects with alcohol dependence or those not reporting sufficient data to determine the percentage (WMD, -3.6 to -4.7 drinks per week) (Appendix E). Our meta-regression did not find the percentage of subjects with alcohol dependence to be a significant contributor to the overall variance in the analysis.

The study from Saitz and colleagues stratified results by faculty and resident physicians.86 It reported that 51 percent of resident physicians and 74 percent of faculty physicians in the intervention group (physicians received positive alcohol screening results and simple recommendations they could give to their patients) had some discussion about drinking during the visit compared with 70 percent and 51 percent in the control group, respectively. Unexpectedly, resident physicians in the control group had higher rates of discussions and advice about drinking during the visit than those in the intervention group. The relatively high rates of discussions, advice, and counseling in the control group might be due to contamination, a high standard of usual care, physicians' awareness that they were being studied, or from assessments of alcohol use prompting patients to discuss alcohol. Although the intervention appeared to increase alcohol discussions among faculty but not residents, the effect on self-reported alcohol consumption was greater among patients of residents than faculty. The study reported that patients in the intervention group who saw resident physicians had fewer drinks per drinking day than those in the control group at 6 months (adjusted: 3.8, 95% CI, 1.9 to 5.7 compared with 11.6, 95% CI, 5.4 to 17.7). However, there was no difference for patients who saw faculty physicians. Some possible explanations for the findings include differences in patient mix between faculty and residents and random variation.

Two studies reported long-term alcohol consumption up to 48 months: Project TrEAT96, 98, 99 and Project Health.106, 107 In Project TrEAT, men and women in the intervention group maintained the reduction in alcohol consumption (mean drinks per week) achieved by 12 months through a 48-month followup. However, by 48 months, differences between intervention and control groups were no longer statistically significant, because of late onset (between 36 and 48 months) reductions in control group usage primarily among men. The relatively delayed reduction in control consumption to levels achieved by the intervention group at 12 months could reflect the natural history of alcohol consumption, the cumulative effect of yearly followups with the health care system, or (late) regression to the mean. Similarly, Project Health found that participants in the intervention group maintained the significant reductions in drinks per week seen at 6 and 12 months through the 48-month followup, but that there were no longer significant differences in drinks/week between the intervention and control groups at 48 months that had been seen at earlier followup.107 Of note, between 35 percent and 40 percent of subjects did not complete the 48-month follow up in Project Health (333 of 530 subjects were analyzed at 48 months), increasing the risk of attrition bias. The attrition, however, was not significantly different between groups (i.e., it was nondifferential).

#### Heavy Drinking Episodes

Results of our meta-analyses are summarized in Table 13. Additional details and forest plots are provided in Appendix E. Among adults receiving behavioral interventions, 12 percent more subjects (absolute difference) reported no heavy drinking episodes by 12 months compared with control groups. Subgroup analyses for men and women found similar results.

Table 13 Percentage of subjects with no heavy drinking episodes for behavioral counseling interventions compared with controls: Summary of meta-analyses for adults

Population | Intensity | Timing | N | Risk Difference^a^ | 95% CI | I^2^
Adults | All | 12 months | 8 (2,737 subjects) | 0.12 | 0.07, 0.16 | 17
Adults | Very brief | 12 months | NA | NA | NA | NA
Adults | Brief | 12 months | 2 | 0.10 | -0.03, 0.24 | 37
Adults | Brief, multicontact | 12 months | 4 | 0.11 | 0.06, 0.16 | 42
Adults | Extended, multicontact | 12 months | 2 | 0.19 | 0.07, 0.31 | 0
Adult men | All | 12 months | 3 | 0.13 | 0.07, 0.18 | 0
Adult women | All | 12 months | 3 | 0.13 | 0.02, 0.23 | 66^b^

CI = confidence interval, rounded to hundredths; N = number of comparisons contributing to the meta-analysis; NA = not applicable

a Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of subjects with no heavy drinking episodes.

b The subgroup analyses for women at 12 months had moderate to substantial statistical heterogeneity. From analyses removing each individual study one at a time, the moderate to substantial heterogeneity was no longer present after removing the study by Rubio and colleagues, which reduced the I^2^ to 0, but did not change the point estimate for the risk difference (without Rubio it was 0.13, 95% CI, 0.02 to 0.24). The study by Rubio and colleagues was the only study exclusively enrolling those with ‘binge drinking.’89

Note: Only two studies reported the outcome at 6 months; both were brief multicontact (risk difference 0.09, 95% CI, 0.02 to 0.16).

When stratifying by intensity of the intervention, the analyses for all adults included only brief, brief multicontact, and extended multicontact interventions. The brief multicontact and extended multicontact interventions were efficacious at 12 months (with 11% and 19%absolute difference compared with controls, respectively), but brief interventions did not reach statistical significance for percentage of subjects with no heavy drinking episodes compared with controls.

The study from Saitz and colleagues described in the previous section stratified results by faculty and resident physicians.86 The percentage of subjects with any binge drinking, defined as more than three drinks per occasion for women and older adults and more than four for men, was among the secondary outcomes reported at 6 months. Among patients in the intervention group who saw resident physicians, 44 percent (95% CI, 30 to 58) reported any binge drinking compared with 64 percent (95% CI, 45 to 79) in the control group. The percentages for those seeing faculty physicians were 51 percent (95% CI, 44 to 59) and 42 percent (95% CI, 30 to 55), respectively.

Long-term outcomes up to 48 months were reported by two studies: Project TrEAT96, 98, 99 and Project Health.106, 107 Project TrEAT found a significant reduction in the number of people who reported heavy drinking episodes, with the intervention group demonstrating a greater reduction than the control group. The difference between groups remained significant at 6, 12, 24, and 36 months (61.5%vs. 70.7%, p<0.01, at 36 months) but was not statistically significantly different at 48 months (63.8% vs. 70.4%, p<0.10).98 In Project Health, differences in heavy episodes per month between the intervention and control groups were not significant at 48 months.107 Of note, between 35 percent and 40 percent of subjects did not complete the 48-month follow up in Project Health (333 of 530 subjects were analyzed at 48 months), increasing the risk of attrition bias.

#### Recommended Drinking Limits Achieved

Results of our meta-analyses are summarized in Table 14 (additional details and forest plots are provided in Appendix E). Among adults receiving behavioral interventions, 11 percent more subjects (absolute difference) achieved recommended drinking limits by 12 months compared with control groups; subgroup analyses for men and women found similar magnitude of benefit.

Table 14 Percentage of subjects achieving recommended drinking limits for behavioral counseling interventions compared with controls: Summary of meta-analyses for adults

Population | Intensity | Timing | N | Risk Difference^a^ | 95% CI | I^2^
Adults | All | 12 months | 13 (5,973 subjects) | 0.11 | 0.08, 0.13 | 31
Adults | Very brief | 12 months | 2 | 0.08 | 0.02, 0.14 | 0
Adults | Brief | 12 months | 5 | 0.08 | 0.04, 0.12 | 0
Adults | Brief, multicontact | 12 months | 6 | 0.15 | 0.11, 0.19 | 28
Adults | Extended, multicontact | 12 months | NA | NA | NA | NA
Adults | All | 6 months | 5 | 0.13 | 0.10, 0.17 | 29
Adults | Very brief | 6 months | NA | NA | NA | NA
Adults | Brief | 6 months | 1 | 0.08 | 0.01, 0.15 | 0
Adults | Brief, multicontact | 6 months | 4 | 0.15 | 0.11, 0.19 | 7
Adults | Extended, multicontact | 6 months | NA | NA | NA | NA
Adult men | All | 12 months | 6 | 0.12 | 0.09, 0.15 | 27
Adult women | All | 12 months | 6 | 0.14 | 0.09, 0.20 | 39

CI = confidence interval, rounded to hundredths; N = number of comparisons contributing to the meta-analysis; NA = not applicable

a Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of subjects achieving recommended drinking limits.

Note: Only two studies reported data to contribute to a subgroup analysis for adult men at 6 months; both were brief multicontact (risk difference 0.12, 95% CI, 0.01 to 0.23). Similarly, only two reported data to contribute to a subgroup analysis for adult women at 6 months; both were brief multicontact (risk difference 0.19, 95% CI, 0.11 to 0.26).

When stratifying by intensity of the intervention, the analyses for all adults included only very brief, brief, and brief multicontact interventions; no included studies used extended multicontact interventions. All of the intervention intensities were efficacious. The magnitude of benefit was numerically greatest for the brief multicontact interventions (15% compared with 8% for very brief and brief interventions at 12 months), but the confidence intervals overlap.

Two studies reported long-term data up to 48 months: Project TrEAT96, 98, 99 and Project Health.106, 107 Project TrEAT showed a significant reduction in the percentage of heavier drinkers (men consuming >20 drinks or women consuming >13 drinks in the previous 7 days) in the intervention group compared with the control group. The difference between groups remained significant at 6, 12, 24, and 36 months (23.2% vs. 34.6%, p<0.01, at 36 months), but it was not statistically significantly different at 48 months (22.4% vs. 26.4%, p= NS).98 In Project Health, there were no longer significant differences in percentage of low-risk drinking between the intervention and control groups at 48 months that had been seen at earlier followup.107 Of note, between 35 percent and 40 percent of subjects did not complete the 48-month follow up in Project Health (333 of 530 subjects were analyzed at 48 months), increasing the risk of attrition bias.

#### Followup With Referrals

None of the included studies reported the percentage of subjects that followed up with referrals.

#### Abstinence

We identified three studies reporting abstinence among secondary outcomes.84-86 Of note, none of the studies were designed to achieve abstinence, and it should probably not be a goal of behavioral interventions for most people (because healthy alcohol use at recommended levels has been associated with improvements in health outcomes and is a more appropriate goal for most people). From these studies, evidence is insufficient to determine whether behavioral interventions increase rates of abstinence compared with controls. The WHO study reported numerical increases in the percentage of men and women in all study groups: brief counseling, simple advice, and control groups increased from 0 percent in the 6 months prior to intervention to 8 percent, 5 percent, and 2 percent for men and to 12 percent, 7 percent, and 4 percent for women, respectively (p-values not calculated due to small cell sizes).84 Senft and colleagues reported that between 8 percent and 11 percent of subjects were abstinent across study groups at both 6 and 12 months (exact data not reported, difference was not statistically significant).85 Saitz and colleagues reported the percentage of abstinent subjects, defined as no drinking during the 30-day period. Among patients in the intervention group who saw resident physicians, 18 percent (95% CI, 6 to 43) reported abstinence compared with 5 percent (95% CI, 1 to 25) in the control group. The percentages for those seeing faculty physicians were 22 percent (95% CI, 13 to 35) and 26 percent (95% CI, 15 to 42), respectively.

### Evidence in Older Adults

Table 15 summarizes the characteristics of included publications targeting older adult populations. We included two RCTs that enrolled exclusively older adults: Project GOAL112, 113 and the Healthy Living As You Age (HLAYA) study.114, 115 In addition, we identified one subgroup analysis of subjects 65 years or older enrolled in the Early Lifestyle Modification (ELM) study, an RCT included in the previous section on adults.105

Table 15 Characteristics of included trials comparing behavioral counseling interventions with usual care for improving intermediate outcomes for older adults with alcohol misuse

Study | N % Dep | Duration (mths) | Country | Setting | Mean Age (Y) | % Fem | % Non-white | Baseline Alcohol Use (Drinks/wk) | Quality
Fleming et al., 1999^112^ Mundt et al., 2005^113^ GOAL | 158 0 | 24 | U.S. Wisconsin | 24 PC practices | NR >92% age 65-75 | 33.5 | NR | 15.54 to 16.58 | Fair
Lin et al., 2010^114^ Moore, et al., 2011^115^ HLAYA | 631 NR | 12 | U.S. Calif. | PC practices (145 PCPs) | 68.4 | 29 | 13 | 15.2 | Fair

Calif = California; % Dep = percentage of subjects with alcohol dependence; Fem = female; GOAL = Guiding Older Adult Lifestyles; HLAYA = Healthy Living As You Age; mths = months; N = total number randomized/assigned to intervention and control groups; NR = not reported/unclear; PC = primary care; PCP = primary care physician; Penn = Pennsylvania; U.S. = United States; wk = week; y = years

The subgroup analysis of ELM103, 104 included 45 of the 301 enrolled subjects. The subgroup analysis has a high risk of selection bias and confounding compared with the main study results. There were significant differences in baseline measures of alcohol consumption for the brief advice group compared with the motivational enhancement and the standard care groups. Because of the high risk of bias in this subgroup analysis of 45 subjects, we determined that the best evidence in older adults was from Project GOAL and HLAYA; thus we focus on the evidence from those two trials below.

The studies generally targeted those with risky/hazardous drinking. Project GOAL included men consuming more than 11 drinks per week and women consuming more than 8, those with two or more positive responses on the CAGE, and binge drinkers (4 or more drinks per occasion for men two or more times in the last 3 months; 3 or more per occasion for women). The HLAYA study included at-risk drinkers based on Comorbidity Alcohol Risk Evaluation Tool (CARET) scores of 1-7, such as those drinking 3 drinks four or more times per week, 2 or more drinks at least twice per week and often having heartburn, or 2 drinks daily and taking alprazolam at least three to four times per week.

Both trials were conducted exclusively in the United States. Study duration ranged from 12 months for HLAYA105, 114, 115 to 24 months for Project GOAL.112, 113 The studies reported a baseline alcohol consumption between 15 and 17 drinks per week.

In the included trials, methods to identify those with alcohol misuse varied, but all included an assessment of the quantity and frequency of alcohol consumption. Project GOAL included men drinking 11 drinks or more per week and women drinking 8 or more, those with two or more positive responses to the CAGE, and those with binge drinking (4 or more drinks per occasion for men two or more times in the last 3 months or 3 or more per occasion for women).112 It also included a 30-minute face-to-face assessment using the Time Line Follow-Back (TLFB) method to determine whether potential subjects met inclusion criteria. HLAYA used the Comorbidity Alcohol Risk Evaluation Tool (CARET) to screen subjects for inclusion, including an assessment of the quantity and frequency of drinking over the past 12 months, assessment of binge/heavy episodic drinking, driving after drinking, medical and psychiatric history, symptoms that could be worsened by alcohol, and medications that could interact negatively with alcohol. Those with an at-risk score (1-7) on the CARET were eligible.115

The interventions of included studies for this section are described in Table 16, organized by intervention intensity. Project GOAL included a brief multicontact intensity intervention112, 113 (multiple contacts, up to 15 minutes each), and HLAYA included an extended multicontact intervention105, 114, 115 (multiple contacts, one or more of them longer than 15 minutes).

Table 16 Description of behavioral counseling interventions for improving intermediate outcomes for older adults with alcohol misuse, by intervention intensity

Intensity | Study | Intervention | Delivered By | Delivery Method | No. of Contacts | Length of Each Contact
Brief multicontact | Fleming et al., 1999^112^ Mundt et al., 2005^113^ GOAL | General health booklet plus drinking behavior feedback (workbook), review of problem-drinking prevalence, reasons for drinking, adverse effects of alcohol, drinking cues, a “prescribed” drinking agreement, drinking diary cards | PCP and nurse | In person and phone | 4 | 10-15 min for PCP contacts; NR for phone calls
Extended multicontact | Lin et al., 2010^114^ Moore, 2011^115^ HLAYA | Personalized risk report and diary for tracking alcohol use; PCP gave oral and written advice in prescription style via an alcohol education booklet; followed by additional feedback and counseling with motivational interviewing from health educator at weeks 2, 4, and 8 | PCP and health educator | In person and phone | 4 | 15-20 min

GOAL = Guiding Older Adult Lifestyles; HLAYA = Healthy Living As You Age; min = minutes; No. = number; NR = not reported/unclear; PCP = primary care physician

Project GOAL tested an intervention delivered by the patient's primary care physician112, 113 and HLAYA tested an intervention delivered by the physician and a health educator.114, 115

Project GOAL and HLAYA used control groups receiving screening/assessment followed by usual care and the provision of a general health booklet.112-115

#### Alcohol Use, Number of Drinks

Both trials focusing on older adults reported greater reduction in quantity of alcohol consumed for those receiving behavioral interventions compared with those in control groups. Project GOAL112, 113 reported a decrease of more than 5 drinks per week for subjects in the intervention group at 6, 12, and 24 months compared with a small decrease for those in the control group (-0.31 to -2.0 drinks per week, p<0.05 at 6, 12, and 24 months). The HLAYA study114, 115 reported approximately 1.2 fewer drinks in the past 7 days for those in the intervention group (OR, 0.87, 95% CI, 0.76 to 0.99). Pooling data from these two studies resulted in a decrease of 1.7 more drinks per week for subjects in the intervention groups than for those in control groups (WMD, -1.74, 95% CI, -2.8 to -0.6, Appendix E). We were unable to conduct subgroup analyses for men and women, because neither study reported results separately by sex.

#### Heavy Drinking Episodes

Project GOAL and the HLAYA study both reported measures of heavy drinking episodes for subjects in the intervention group at 12 months. In Project GOAL112, 113 about 69 percent of subjects in the intervention group reported no heavy drinking episodes in the previous 30 days compared with about 51 percent in the control group (p<0.025). The HLAYA study did not find a statistically significant difference between the intervention and control group in the percentage of subjects with 1 or more heavy drinking days in the past 7 days at 12 months (OR, 0.89, 95% CI, 0.4 to 1.97); however, the difference was significant at 3 months (OR, 0.46, 95% CI, 0.22 to 0.99).114, 115

#### Recommended Drinking Limits Achieved

Both trials focusing on older adults reported some measure of whether recommended drinking limits were achieved. Project GOAL112, 113 found a greater percentage of subjects not drinking excessively in the previous 7 days (more than 20 drinks per week for men and more than 13 per week for women) in the intervention group compared with the control group at both 6 and 12 months (84.6% vs. 65.7%, p<0.005 at 12 months). The differences were not statistically significant at 24 months (p<0.1). The HLAYA study114, 115 found a lower percentage of at-risk drinkers at 12 months in the intervention group, but the results were not statistically significant (OR, 0.68, 95% CI, 0.36 to 1.26). Pooling data from these two studies found that interventions resulted in a greater percentage of subjects achieving recommended drinking limits compared with controls (risk difference of 0.09, 95% CI, 0.02 to 0.16, Appendix E). We were unable to conduct subgroup analyses for men and women, because neither study reported results separately by sex.

#### Followup With Referrals

None of the included studies reported the percentage of subjects that followed up with referrals.

#### Abstinence

None of the included studies reported this outcome.

### Evidence in Young Adults or College Students

Table 17 summarizes the characteristics of included publications targeting young adults or college students. We did not find any studies meeting our inclusion/exclusion criteria that focused on adolescents. We included four RCTs (five publications)87, 116-119 and one subgroup analysis of subjects age 18 to 30 from Project TrEAT.88 The mean age of enrolled populations in the four trials was approximately 20.

Table 17 Characteristics of included trials comparing behavioral counseling interventions with usual care for improving intermediate outcomes for young adults or college students with alcohol misuse

Study | N % Dep | Duration (mths) | Country | Setting | Mean Age (y) | % Fem | % Non-white | Baseline Alcohol Use (Drinks/wk) | Quality
Fleming et al., 2010^87^ CHIPs | 986 0 | 12 | U.S. and Canada | 5 college health clinics | 21 | 50.5 to 51.3 | 8.1 to 10.5 | 17.3 to 17.8 | Good
Grossberg et al., 2004^88^ TrEAT | 226^a^ NR | 48 | U.S. Wisc. | 17 community PC practices | NR^b^ | 51 | 14 | 16.2 to 18.3 | Good^a^
Kypri et al., 2008^116^ Kypri et al., 2007^117^ | 576 NR | 12 | New Zealand | University primary health care service | 20.1 to 20.3 | 52 | NR | NR | Good
Kypri et al., 2004^118^ | 104 NR | 6 | New Zealand | University student health service | 19.9 to 20.4 | 50 | NR | NR | Fair
Schaus et al., 2009^119^ | 363 0 | 12 | U.S. Florida | College student health center | 20.6 | 52 | 22 | 8.38 to 9.59 | Fair

CHIPs = College Health Intervention Projects; % Dep = percentage of subjects with alcohol dependence; Fem = female; mths = months; N = total number randomized/assigned to intervention and control groups; NR = not reported/unclear; PC = primary care; TrEAT = Trial for Early Alcohol Treatment; U.S. = United States; Wisc = Wisconsin; wk = week; y = years

a This was a subgroup analysis of TrEAT,96 226 of the 774 enrolled subjects were young adults (age 18 to 30).

b 21% 18 to 21, 37% 22 to 25, and 47% 26 to 30.

The studies generally targeted those with risky/hazardous drinking. Two trials conducted in New Zealand enrolled subjects with an AUDIT score of 8 or more and who consumed more than recommended upper limits for episodic drinking on one or more occasion in the preceding 4 weeks (four for women, six for men).116-118 The College Health Intervention Projects (CHIPs) trial included those with heavy drinking defined by more than 50 drinks or 8 or more heavy drinking episodes (5 or more standard 14-g drinks) in the previous 28 days for male students or 40 drinks or 6 or more heavy drinking episodes for female students (4 or more standard drinks).87 Schaus et al. included men drinking 5 or more drinks in a row on at least one occasion during the past 2 weeks or women drinking 4 or more drinks in a row.119 The subgroup analysis of Project TrEAT88 included males who drank more than 14 drinks per week or females who drank more than 11 drinks per week in the past 90 days.

Some studies constructed inclusion/exclusion criteria to limit the number of potential subjects with alcohol dependence (e.g., exclusion of those with symptoms of withdrawal in the past year, with a history of receiving treatment for an alcohol problem, who had been told by a clinician to cut down in the past, or who consumed more than 200 drinks in the previous 28 days).87, 88, 119 Other studies did not collect or report information to allow the determination of whether any subjects met criteria for alcohol dependence.116-118

Two studies were conducted exclusively in the United States, two in New Zealand, and one in the United States and Canada. Study duration ranged from 6 to 12 months for the trials enrolling only young adults or college students.87, 116-119 For the subgroup analysis of Project TrEAT, outcomes were reported out to 48 months.88 One trial reported a baseline alcohol use of about 17 drinks per week,87 one about 9 drinks per week,119 and two trials did not report baseline alcohol use.116-118 The subgroup analysis from Project TrEAT reported a baseline alcohol use of about 17 drinks per week.88

In the included studies, methods to identify those with alcohol misuse varied somewhat. Three studies relied primarily on an assessment of the quantity-frequency of alcohol consumption,87, 88, 119 and two relied primarily on an AUDIT score of 8 or more with or without quantity-frequency criteria in addition.116-118 Quantity-frequency cutoffs ranged from 5 drinks for men or 4 for women on any occasion in the past 2 weeks (using a single-question screen), for Schaus and colleagues,119 to 50 or more drinks or 8 or more heavy drinking days (at least 5 drinks per occasion) over the past 28 days for men and 40 or more drinks or 6 or more heavy drinking days (4 drinks per occasion), for women in CHIPs.87

The interventions of included studies for this section are described in Table 18, organized by intervention intensity. Three trials evaluated interventions delivered in person by the PCP,87, 88, 119 and two evaluated Web-based interventions that were self-administered via computer.116-118

Table 18 Description of behavioral counseling interventions for improving intermediate outcomes for young adults or college students with alcohol misuse, by intervention intensity

Intensity | Study | Intervention | Delivered By | Delivery Method | No. of Contacts | Length of Each Contact
Brief | Kypri et al., 2008^116^ Kypri et al., 2007^117^ | Web-based assessment and personalized feedback on drinking | Self | Computer | 1 | 10-15 min
Brief | Kypri et al., 2004^118^ | Web-based assessment and personalized feedback on drinking | Self | Computer | 1 | 10-15 min
Brief multicontact | Fleming et al., 2010^87^ CHIPs | Two visits 1 month apart with PCP and a followup phone call or email from the PCP after each visit; feedback regarding current behaviors, review of prevalence of high-risk drinking among college students, list of alcohol's adverse consequences relevant to college students, lists of personal likes and dislikes of drinking, worksheets on drinking cues, BAC level calculator, life goals and alcohol effects, prescription agreement, drinking diary cards | PCP | In person | 4 | 15 min
Brief multicontact | Grossberg et al., 2004^88^ TrEAT | Two visits 1 month apart with PCP and a followup phone call from the clinic nurse 2 weeks after each visit; workbook containing feedback regarding current health behaviors, review of prevalence of problem drinking, list of adverse effects of alcohol, worksheet on drinking cues, drinking agreement/prescription, and drinking diary cards | PCP and nurse | In person | 4 | 15 min
Brief multicontact | Kypri et al., 2008^116^ Kypri et al., 2007^117^ | Web-based assessment and personalized feedback on drinking | Self | Computer | 3 | 10-15 min
Extended multicontact | Schaus et al., 2009^119^ | Motivational intervention sessions that combined patient-centered motivational interviewing and cognitive-behavioral skills training + booklet on alcohol prevention | PCP | In person | 2 | 20 min

BAC = blood alcohol content; CHIPs = College Health Intervention Projects; min = minutes; No. = number; PCP = primary care physician; TrEAT = Trial for Early Alcohol Treatment

All control groups included the delivery of usual care and some form of printed educational material. Control groups for the Web-based interventions received a pamphlet on the health effects of alcohol consumption.116-118 Control groups in the CHIPs study87 and Project Health88 received a general health booklet; the control group in the study by Schaus and colleagues received an alcohol problems–prevention booklet.119

#### Alcohol Use, Number of Drinks

All five studies (six of six comparisons) reported measures of alcohol consumption at 6 months. All six comparisons found greater reduction in consumption for interventions than controls. The three studies including subjects in the United States87, 88, 119 reported sufficient data to pool similar measures, resulting in an average 1.7 drinks per week reduction for subjects receiving interventions compared with those receiving controls (WMD, -1.7, 95% CI, -2.6 to -0.7, I^2^ 0%). The other two studies (three comparisons), conducted in New Zealand, reported rate ratios favoring the intervention groups for all comparisons that could not be pooled with the other data without making several statistical assumptions (RRs from 0.74 to 0.79, all with statistically significant 95% CIs).116-118

At 12 months, four of five studies (five of six comparisons) reported alcohol consumption outcomes. All but the study by Schaus and colleagues (contributing one comparison) found a statistically significant difference favoring behavioral interventions, from 1.2^87^ to 4.1^88^ drinks per week greater reduction for the intervention group compared with controls. Some possible reasons for the different findings in Schaus and colleagues include (1) that the control group received an alcohol problems–prevention booklet, which may bias results toward the null; and (2) the enrolled subjects had a much lower baseline alcohol consumption (around 8 to 9 drinks per week—half of what was reported in other studies), leaving less room for reduction in consumption.

The subgroup analysis from Project TrEAT88 reported long-term results beyond 12 months. Number of drinks consumed in the previous week decreased more in the intervention group than the control group through 36 months for young adults in the study (-6.8 vs. -4.4, p= 0.02); the differences were no longer significant at 48 months (-7.6 vs. -6.7, p= 0.06).

#### Heavy Drinking Episodes

Not enough studies reported the percentage of subjects with or without heavy drinking episodes to conduct quantitative synthesis. However, the three studies assessing in-person interventions reported the number of episodes of heavy drinking in the past month87, 88, 119 and the two studies (contributing three comparisons) assessing Web-based screening and intervention reported the rate ratio of episodic heavy drinking.116-118 For the former three studies, our meta-analyses found a reduction of 0.9 heavy drinking days at 6 months for behavioral interventions compared with controls (WMD, -0.9, 95% CI, -1.5 to -0.3), but no statistically significant difference at 12 months (WMD, -0.2, 95% CI, -1.2 to 0.8) (Appendix E).

For the studies assessing Web-based interventions, our meta-analyses found a reduction of episodic heavy drinking at 6 months (RR, 0.76, 95% CI, 0.61 to 0.93) (Appendix E). Just one of the studies assessing Web-based interventions followed subjects for 12 months; it found no statistically significant difference at 12 months (for the single-dose intervention group vs. placebo RR, 0.75, 95% CI, 0.53 to 1.07; for the multidose group vs. placebo 0.71, 95% CI, 0.51 to 1.01).116, 117

The subgroup analysis from Project TrEAT88 reported long-term results beyond 12 months. Episodes of binge drinking (6 or more drinks per occasion) in the previous 30 days were decreased more in the intervention group than the control group up through 24 months for young adults in the study (-1.7 vs. -0.7, p=0.03); the differences were no longer significant at 36 and 48 months (-1.7 vs. -0.7, p=NS, and -2.3 vs. -1.5, p=0.08, respectively).

#### Recommended Drinking Limits Achieved

None of the included studies reported this outcome.

#### Followup With Referrals

None of the included studies reported this outcome.

#### Abstinence

None of the included studies reported this outcome.

### Evidence in Pregnant Women

We found just one study enrolling pregnant women meeting our inclusion criteria (Table 19). The study randomized 250 pregnant women with a gestational age of 28 weeks or less to a comprehensive assessment only or a comprehensive assessment followed by a behavioral intervention.120

Table 19 Characteristics of included trials comparing behavioral counseling interventions with usual care for improving intermediate outcomes for pregnant women with alcohol misuse

Study | N % Dep | Duration (mths) | Country | Setting | Mean Age (y) | % Fem | % Non-white | Baseline Alcohol Use (Drinks/wk) | Quality
Chang et al., 1999^120^ | 250 0 current^a^ | About 6^b^ | U.S. Mass. | Obstetric practices | 30.7 | 100 | 22 | Mean drinks per drinking day: 0.6 to 0.9^c^ | Fair

% Dep = percentage of subjects with alcohol dependence; Fem = female; Mass. = Massachusetts; mths = months; N = total number randomized/assigned to intervention and control groups; U.S. = United States; wk = week; y = years

a None of the 250 subjects satisfied DSM-III-R criteria for current alcohol abuse or dependence at enrollment. But 40% satisfied criteria for lifetime alcohol abuse or dependence (not reported separately); 3 subjects had been previously treated for an alcohol problem.

b Some variation: mean # of weeks of antepartum drinking was 22.4 weeks; gestational age required to be <28 weeks at study entry; mean gestation at baseline was 16 weeks.

c These numbers are while pregnant and include abstainers. Excluding abstainers, they report 1.5 to 2.1 mean drinks per drinking day while pregnant.

Potential subjects were identified by screening pregnant women initiating prenatal care with a health survey that included the T-ACE. A score of 2 or more was considered positive.

The intervention for the included study120 is described in Table 20. We categorized the intensity as extended because it required 45 minutes to deliver. The comprehensive assessment (for both the intervention and control group) consisted of a 2-hour session that included a DSM-III-R SCID interview, the Addiction Severity Index, AUDIT, SMAST, TLFB, Alcohol Craving Scale, Global Assessment of Functioning, and Situational Confidence Questionnaire.

Table 20 Description of behavioral counseling interventions for improving intermediate outcomes for pregnant women with alcohol misuse, by intervention intensity

Intensity | Study | Intervention | Delivered By | Delivery Method | No. of Contacts | Length of Each Contact
Extended | Chang et al., 1999^120^ | Review of lifestyle changes made since pregnancy; articulation of drinking goals while pregnant; identification of circumstances in which she might be tempted to drink; identify alternatives to drinking in such situations; take-home manual with tailored notes; communication about U.S. Surgeon General recommendation | PCP and researcher | In person | 1 | 2-hr assessment; 45-min intervention

hr = hour; min = minute; No. = number; PCP = primary care physician; U.S. = United States

#### Alcohol Use, Number of Drinks

Both intervention and control groups had a reduction in consumption (mean drinks per drinking day), but the difference between groups was not statistically significant (-0.3 vs. -0.4, p= NS, excluding patients who maintained abstinence through the end).

#### Heavy Drinking Episodes

The study did not report this outcome.

#### Recommended Drinking Limits Achieved

The study did not report this outcome.

#### Followup With Referrals

The study did not report this outcome.

#### Abstinence

For the overall sample, data were not reported. For the subgroup of subjects who were abstinent prior to assessment, those who received the intervention maintained higher rates of abstinence than those in the control group (86% vs. 72%, p= 0.04).

### Applicability

The findings are generally applicable to people with risky/hazardous drinking identified by screening in primary care settings. It is uncertain whether findings are applicable to harmful drinkers or people with alcohol abuse. Most studies excluded all or most potential subjects with alcohol dependence; thus, our findings do not necessarily apply to people with alcohol dependence, who should perhaps be referred for specialty treatment. Most studies enrolled some subjects with heavy episodic drinking patterns of consumption, and one study focused only on those with binge drinking.89 Overall findings and those from the one study focused on binge drinking were consistent in finding interventions to be efficacious for reducing heavy episodic drinking. We did not identify any studies in adolescent populations, and results thus have uncertain applicability to adolescents. We did, however, identify a sufficient number of studies of young adults/college students and older adults to draw conclusions (of low to moderate strength) for several intermediate outcomes. Although we searched for studies conducted in settings with primary care–like relationships (e.g., infectious disease clinics for people with HIV), we did not find any, and our results have uncertain applicability to such settings/populations. We did not identify any studies conducted exclusively in veterans.

Effective interventions were generally delivered completely in person or also included phone followups, but two studies conducted with college student populations demonstrated benefits of Web-based interventions delivered via computer.116-118

## Key Question 4b How do specific behavioral counseling approaches, with or without referral, compare with one another for improving intermediate outcomes for people with alcohol misuse as identified by screening?

This Key Question addresses direct, head-to-head evidence comparing more than one specific behavioral intervention approach. Indirect evidence (i.e., from studies comparing behavioral interventions with usual care) is addressed in Key Question 4a. We have organized the comparisons for this question by intensity: very brief (up to 5 minutes, single contact), brief (from 6 to 15 minutes, single contact), extended (more than 15 minutes, single contact), brief multicontact, and extended multicontact.

Four RCTs enrolling adults and one enrolling college students provided evidence for this question. All five compared different types/intensities of interventions. Overall, head-to-head evidence from the five studies was insufficient to draw conclusions about whether different interventions (including different levels of intensity) have similar or different effectiveness for most intermediate outcomes of interest (Appendix G). None of the studies reported a statistically significant difference between the two groups of interest to this Key Question.

We did not identify any studies meeting inclusion criteria for older adults or pregnant women [insufficient strength of evidence (SOE) for all comparisons]. No studies compared a very brief intervention with a brief multicontact intervention (insufficient SOE). No studies compared a brief multicontact intervention with an extended multicontact intervention (insufficient SOE). No studies used an extended intensity intervention (insufficient SOE).

### Summary of Findings

#### Adults

- Very brief interventions compared with brief interventions: one head-to-head study provides insufficient evidence to determine how very brief and brief intensity interventions compare for improving intermediate outcomes.
- Very brief interventions compared with extended multicontact interventions: one head-to-head study provides insufficient evidence for most intermediate outcomes and low strength of evidence for a conclusion of no difference in achieving recommended drinking limits at 12 months.
- Brief interventions compared with extended multicontact interventions: one head-to-head study provides insufficient evidence for most intermediate outcomes and low strength of evidence for a conclusion of no difference in change in alcohol consumption (number of drinks in the past 30 days) at 12 months.
- Extended multicontact compared with extended multicontact interventions: one head-to-head study provides insufficient evidence for most intermediate outcomes and low strength of evidence for a conclusion of no difference in change in alcohol consumption (change from baseline in alcohol grams per day) at 12 months.

#### Young Adults and College Students

- Brief interventions compared with brief multicontact interventions: one head-to-head study provides low strength of evidence for a conclusion of no difference in alcohol consumption or heavy drinking episodes at 6 or 12 months, and insufficient evidence for other intermediate outcomes, when comparing a single-dose and a multidose Web-based intervention delivered via computer.

### Evidence in Adults

#### Characteristics of Included Studies

Four trials described in the previous section (KQ 4a) provided evidence in adults for this section (Table 21). All were multiarm (more than two study groups) RCTs conducted exclusively in primary care settings except for the WHO study,84 which included a variety of outpatient medical settings (including some emergency departments), depending on the country. The trials generally targeted those with risky/hazardous drinking. Two of the four studies reported more than 10 percent of included subjects likely having some degree of alcohol dependence.83, 90 These included a study conducted in 85 general practices in Germany with 30.4 percent meeting criteria for dependence (by DSM-IV diagnostic interview)90 and a study conducted in 40 primary care practices in Australia with 35 percent having moderate signs or symptoms of dependence, although they excluded those with evidence of severe dependence.83

Table 21 Characteristics of included trials comparing behavioral counseling interventions with each other for improving intermediate outcomes for adults with alcohol misuse

Study | N % Dep | Duration (mths) | Country | Setting | Mean Age (y) | % Fem | % Non-white | Baseline Alcohol Use (Drinks/wk) | Quality
WHO Brief Intervention Study, 1996^84^ | 1,559 0 | 9 | 8, including U.S. | Outpatient medical settings | 35.9 to 36.9 | 19.2 | NR | NR | Fair
Bischof et al., 2008^90^ SIP study | 408 30.4 | 12 | Germany | 85 general practices | 35.9 to 36.8 | 31.9 | NR | 21 to 25.2 | Fair
Maisto et al., 2001^103^ ELM | 301 NR | 12 | U.S. Penn. | 12 PC clinics | 45.6 | 30.2 | 23.3 | 15.5 to 18.6 | Fair
Richmond et al., 1995^83^ Alcoholscreen | 378 35^a^ | 12 | Australia | 40 PC practices | 37.7 | 43 | NR | 38.5 | Fair

% Dep = percentage of subjects with alcohol dependence; ELM = Early Lifestyle Modification; Fem = female; mths = months; N = total number randomized; NR = not reported/unclear; PC = primary care; Penn. = Pennsylvania; SIP = Stepped Intervention for Problem Drinkers; U.S. = United States; WHO = World Health Organization; wk = week; y = years

a Percentages with moderate physical dependence based on the physical dependence on alcohol (Ph) score from the Comprehensive Drinker Profile. The study excluded those with evidence of severe alcohol dependence (Ph score >10) or those with severe levels of alcohol-related problems (MAST >20).

Note: When data were not reported for mean age, %female, % nonwhite, and baseline alcohol consumption for the total sample but was presented for each study group, we give the range of the means for the various study groups.

One study was conducted exclusively in the United States, one was multinational including the United States, and one each in Germany and Australia (Table 21). Studies followed subjects for up to 12 months. The mean age ranged from 35 to 46 years. Women represented 19 to 43 percent of study participants. Rates of nonwhite participants were reported in only one study (23.3%).103

Two studies reported baseline alcohol consumption between 15 and 30 drinks per week,90, 103 similar to most adult studies included in the previous section; one study did not report baseline consumption, and the Australian study reported more than 30 drinks per week at baseline.83

The interventions compared in the included studies for this section are described in Table 22. Two studies directly compared a very brief intervention with one of greater intensity.83, 84 The WHO brief intervention study compared 5 minutes of simple advice with a 15-minute brief intervention of counseling about drinking, using a 30-page illustrated problem-solving manual that described the benefits of moderate drinking or abstinence, ways of coping with high-risk drinking situations, and constructive alternatives to drinking.84 Richmond and colleagues compared a single session of 5 minutes of advice from a general practitioner (GP) with a five-session intervention (the Alcoholscreen Program) by the GP in Australia.83

Table 22 Description of behavioral counseling interventions compared in head-to-head trials for improving intermediate outcomes for adults with alcohol misuse

Study | Intensity | Intervention | Delivered By | Delivery Method | No. of Contacts | Length of Each Contact
WHO Brief Intervention Study, 1996^84^ | Very brief | Group 1: Advice, illustrated pamphlet | Various clinic staff | In person | 1 | 5 min
WHO Brief Intervention Study, 1996^84^ | Brief | Group 2: Brief intervention, 30-page illustrated problem-solving manual | Various clinic staff | In person | 1 | 15 min
Richmond et al., 1995^83^ Alcoholscreen | Very brief | Group 2: Physician advice and a self-help manual (after assessment) | PCP | In person | 1 | 5 min
Richmond et al., 1995^83^ Alcoholscreen | Extended multicontact | Group 1: “Alcoholscreen” program: 5 short consultations (introduction, patient education, 3 followups) designed to reduce drinking to recommended limits. Included self-help manual, daily alcohol diary, and personalized patient education and counseling | PCP | In person | 5 | 15-20 min (intervention visit); 5-25 min (followup visits)
Maisto et al., 2001^103^ ELM | Brief | Brief advice: emphasized feedback from baseline results and implications for drinking, coupled with advice regarding a goal to reduce or stop alcohol consumption | Research staff | In person | 1 | 10-15 min
Maisto et al., 2001^103^ ELM | Extended multicontact | Motivational enhancement: longer, main initial session, 2 shorter booster sessions, use of empathy and other techniques to enhance motivation; focus on delivery of feedback of assessment data and setting alcohol-use goals | Research staff | In person | 3 | One 30–45 min; two 15–20-min booster sessions
Bischof et al., 2008^90^ SIP study | Extended multicontact | Group 1: Full Care (FC): immediate computerized post-assessment feedback and multiple sessions of counseling by psychologist | Trained psychologists from research team | Phone | 4 | Scheduled for 30 min each; mean received was 80.3 min
Bischof et al., 2008^90^ SIP study | Extended multicontact | Group 2: Stepped Care (SC): immediate computerized post-assessment feedback and maximum of 3 counseling sessions with psychologist. Sessions were discontinued if patients indicated consumption below study criteria and high self-efficacy to maintain desired behavior. | Trained psychologists from research team | Phone | Up to 4 | Scheduled for 30–40 min each; mean received was 40 min

ELM = Early Lifestyle Modification; min = minutes; No. = number; NR = not reported; PCP = primary care physician; SIP = Screening and Intervention in Primary Care; U.S. = United States; WHO = World Health Organization; y = years

The ELM study compared a brief intervention with a motivational enhancement (ME) intervention (an extended multicontact intensity intervention).103 Subjects in the brief intervention group received 10 to 15 minutes of advice and those in the ME group received a longer main initial session and two 15–20-minute booster sessions.

The SIP study compared a “full care” intervention with “stepped care”; both interventions were categorized as extended multicontact by our criteria.90 Both groups received a computerized intervention. The full-care group received a fixed number of four 30-minute telephone-based interventions. The stepped-care group received up to three telephone-based interventions, depending on the success of the previous interventions—if they no longer met criteria for at-risk drinking during the previous 4 weeks at each assessment (1, 3, and 6 months) and indicated a high self-efficacy to maintain the acquired behavioral change, the intervention was discontinued and no further contacts were made until the 12-month follow up.

#### Intermediate Outcomes

All four studies reported some intermediate outcome measures of interest (Table 23). All four reported measures of alcohol consumption with reductions in both intervention groups, one reported measures of heavy episodic drinking, and two reported measures of abstinence. No studies reported followup with referrals. For many of the outcomes reported, statistical testing to compare the different behavioral interventions was not reported. Among the studies that reported statistical tests to inform the comparison, p-values were not statistically significant or confidence intervals overlapped. In other words, none of the studies reported a statistically significant difference between the two groups of interest to this Key Question. However, the comparisons are limited by having only a single study and imprecise results for each comparison. Thus, the studies have inadequate power to justify a conclusion of no difference between interventions with any reasonable degree of confidence.

Table 23 Intermediate outcomes for behavioral counseling interventions compared in head-to-head trials for adults with alcohol misuse

Comparison | Study Duration | Alcohol Consumption | Heavy Drinking Episodes | Recommended Limits Achieved | Abstinence
Very brief vs. Brief | WHO Brief Intervention Study, 1996^84^ 9 mths | % of subjects decreasing average daily amount^a^ Men VB: 40.8 vs. B: 40.3 Women VB: 43.2 vs. B: 45.1 | NR | Improvement in % of subjects above recommended weekly limit^a^ Men VB: 21 vs. B: 17 Women VB: 27 vs. B: 25 | % abstinent^a^ Men VB: 5 vs. B: 8 Women VB: 7 vs. B: 12
Very brief vs. Extended multicontact | Richmond et al., 1995^83^ Alcoholscreen 12 mths | Reduction in weekly consumption at 12 months^a^ VB: -2.1 vs. EM: -7.0 | NR | % drinking above recommended limits (% change from baseline) at 12 months: VB: 77.1 (-2.1) vs. EM: 76.0 (-7.3), p= NS | NR
Brief vs. Extended multicontact | Maisto et al., 2001^103^ ELM 12 mths | Change in # of drinks in last 30 days at 12 months: B: -33.20 (-48.19, -18.21) vs. EM: -21.99 (-32.32, -11.65) | NR | NR | Change in # of days abstinent at 12 months: B: +2.54 (0.53, 4.56) vs. EM: +3.58 (1.58, 5.57)
Extended multicontact vs. Extended multicontact | Bischof et al., 2008^90^ SIP study 12 mths | Change in gram alcohol per day from baseline to 12 months: EM (FC): -13.0 vs. EM (SC): -12.2, p= 0.217 | Overall data NR, reported only for subgroups^b^ | NR | NR

B = brief intervention up to 15 minutes; ELM = Early Lifestyle Modification; EM = extended multicontact intervention (multiple contacts, some or all longer than 15 minutes); FC = full care; mths = months; NR = not reported; NS = not statistically significant; SC = stepped care; SIP = Screening and Intervention in Primary Care; VB = very brief intervention up to 5 minutes; vs. = versus; WHO = World Health Organization

a p-values or confidence intervals not reported.

b Among those with alcohol dependence: EM (FC): 61.2% vs. EM (SC): 51.4%, p= 0.387; among abusers/at-risk drinkers: EM (FC): 77.6% vs. EM (SC): 78.0%, p= 1.00; among those with heavy episodic drinking only: EM (FC): 80.6% vs. EM (SC): 72.5%, p= 0.577.

For the WHO study, both intervention groups reduced alcohol consumption compared with controls; the results were similar in magnitude for the very brief (VB) and the brief (B) interventions for intermediate outcomes; statistical significance (i.e., p-values or confidence intervals) directly comparing the two interventions was not reported. Some point estimates slightly favored the very brief intervention and others favored the brief intervention. Overall, evidence was insufficient to draw conclusions about the direct comparative effectiveness of very brief interventions with brief interventions (Appendix G). Our ability to make a conclusion about how very brief and brief interventions compare in primary care settings based on direct evidence is limited by heterogeneity of settings in the WHO study (with many settings outside of primary care, including those in emergency departments), heterogeneity of interventions (with various approaches or personnel used to deliver the intervention), and variations in the interventions across settings and countries.

Richmond and colleagues reported a reduction in weekly consumption and in the percentage of subjects drinking above recommended limits in those receiving a very brief intervention as well as those receiving an extended multicontact intervention.83 Both point estimates favored the extended multicontact group, but between-group differences either were not reported or were not statistically significant (Table 23).

The ELM study reported a reduction in the number of drinks in the last 30 days for both groups (brief and extended multicontact), without a statistically significant difference between groups (the confidence intervals for the two groups overlapped).103 The study also reported an increase in the number of days abstinent for both groups, without a statistically significant difference between groups (the confidence intervals for the two groups overlapped) (Table 23).

The SIP study reported a reduction of grams of alcohol consumed per day for two variations on extended multicontact interventions (full care and stepped care) that was not significantly different (p=0.217).90 The study also reported heavy episodic drinking outcomes by subgroup (but not for the overall sample) (Table 23).

### Evidence in Older Adults

We did not identify any trials meeting our inclusion/exclusion criteria that directly compared two behavioral intervention approaches in older adults.

### Evidence in Young Adults or College Students

One 12-month trial from New Zealand described in the previous section (KQ 4a) provided evidence for this section (Table 24).116, 117 It enrolled subjects with an AUDIT score of 8 or more and who consumed more than recommended upper limits for episodic drinking on one or more occasion in the preceding 4 weeks (four for women, six for men).116-118

Table 24 Characteristics of included trials comparing behavioral counseling interventions with each other for improving intermediate outcomes for young adults or college students with alcohol misuse

Study | N % Dep | Duration (mths) | Country | Setting | Mean Age (y) | % Fem | % Nonwhite | Baseline Alcohol Use (Drinks/wk) | Quality
Kypri, 2008^116, 117^ | 576 NR | 12 | New Zealand | University primary health care service | 20.1 to 20.3 | 52 | NR | NR | Good

% Dep = percentage of subjects with alcohol dependence; Fem = female; mths = months; N = total number randomized; NR = not reported/unclear; wk = week; y = years

Note: When data were not reported for mean age, %female, % nonwhite, and baseline alcohol consumption for the total sample but were presented for each study group, we give the range of the means for the various study groups.

The study compared a brief intensity intervention with a brief multicontact intervention (Table 25). Both interventions were Web based, self-administered by subjects via computer.116, 117 Those receiving the brief intervention underwent a single electronic screening and brief intervention. Those in the multidose group also received interventions 1 and 6 months later.

Table 25 Description of behavioral counseling interventions compared in head-to-head trials for improving intermediate outcomes for young adults or college students with alcohol misuse

Study | Intensity | Intervention | Delivered By | Delivery Method | No. of Contacts | Length of Each Contact
Kypri et al., 2008^116^ Kypri et cal., 2007^117^ | Brief | Web-based assessment and personalized feedback on drinking | Self | Computer | 1 | 10-15 min
Kypri et al., 2008^116^ Kypri et cal., 2007^117^ | Brief multi-contact | Web-based assessment and personalized feedback on drinking | Self | Computer | 3 | 10-15 min

min = minutes; No. = number

#### Intermediate Outcomes

The study reported measures of alcohol consumption and heavy drinking episodes for each intervention group compared with a control. Both groups reduced consumption (total drinks in the past 2 weeks) compared with the control group at 6 months (brief: RR, 0.77; 95% CI, 0.63 to 0.95; brief multicontact: RR, 0.79; 95% CI, 0.64 to 0.97). At 12 months, differences remained significant for the brief single-contact intervention (RR, 0.77, 95% CI, 0.63 to 0.95) but did not reach statistical significance for the multicontact intervention (RR, 0.87, 95% CI, 0.71 to 1.06).

For heavy drinking episodes in the past 2 weeks, the multicontact intervention resulted in lower rates than control at 6 months (RR, 0.65, 95% CI, 0.45 to 0.93), and results trended toward favoring the brief intervention over control, but it did not reach statistical significance (RR, 0.78, 95% CI, 0.55 to 1.12). At 12 months, neither group reached statistical significance compared with control, but results trended toward favoring the intervention groups (RRs from 0.71 to 0.75 with upper limits of CIs at 1.01 and 1.07).

For all of the intermediate outcomes reported, between-group differences were not reported, but similarities in results compared with controls (point estimates and confidence intervals) suggested that additional sessions provided in the multicontact intervention did not enhance the effect.

### Evidence in Pregnant Women

We did not identify any trials meeting our inclusion/exclusion criteria that directly compared two behavioral intervention approaches in pregnant women.

### Applicability

With much of the evidence in this section insufficient to draw conclusions about the comparative effectiveness of behavioral interventions, our ability to make statements about applicability is limited. Available evidence was either insufficient or did not find a difference between the behavioral interventions compared. The applicability of the WHO study comparing a very brief to a brief intervention has limited applicability to people identified with alcohol misuse by screening in primary care settings due to the heterogeneity (related to settings and interventions) described above. None of the included studies evaluated adolescents, older adults, pregnant women, or veterans, and results thus have uncertain applicability to those populations.

Whether the interventions can be easily incorporated into usual primary care practice is addressed in other Key Questions.

## Key Question 5 What adverse effects are associated with behavioral counseling interventions, with or without referral, for people with alcohol misuse as identified by screening?

### Summary of Findings

We reviewed all included studies for evidence of harms across 5 categories: (1) anxiety; (2) stigma, labeling, and/or discrimination; (3) interference with doctor-patient relationship; (4) opportunity costs/time; and (5) increased smoking and/or illegal substance use. Below we summarize the main findings by outcome and report the strength of evidence (SOE) for each outcome. All 23 trials included in Key Question 4a contributed evidence for opportunity costs (for the time required to deliver interventions). Five trials reported evidence for other outcomes relevant for this Key Question,92, 96, 99, 109, 111-113 all of which reported information about smoking and two of which reported anxiety.92, 109 We found no evidence of direct harms, aside from opportunity costs associated with the interventions.

#### Anxiety

- Two studies reported no changes in anxiety levels (low SOE).

#### Stigma, Labeling, Discrimination, or Interference With the Doctor-Patient Relationship

- No studies addressed these outcomes (insufficient SOE).

#### Opportunity Costs/Time

- One 1997 study reported about $39 in personal costs (worth approximately $53 in 2011–2012) for enrolled subjects due to lost work time and travel.
- The time required for interventions used in the included studies ranged from a minimum of 5 minutes to a maximum of approximately 2 hours dispersed over multiple in-person and/or telephone visits (moderate SOE).

#### Increased Smoking or Illegal Substance Use

- Limited evidence in adults and older adults suggests that behavioral interventions for alcohol misuse do not result in increased smoking rates (low SOE); we found no evidence in young adults, college students, or pregnant women (insufficient SOE).
- None of the included studies reported changes in illegal substance use (insufficient SOE).

### Evidence in Adults

In Project TrEAT, each patient incurred, on average, approximately $39 in personal costs for lost work time and travel for study-related visits.97

Across studies, the amount of time that participants invested in the interventions ranged from very brief (up to 5 minutes during a single interaction)83, 84 to more extensive (multiple brief contacts or combinations of brief and longer contacts lasting up to 45 minutes). Additional description of the time required for the interventions in each included study is provided in Key Question 4a.

Four studies reported no increases in smoking rates for individuals undergoing behavioral counseling interventions for alcohol misuse.92, 96, 109, 111 Studies did not report actual data (e.g., number of cigarettes smoked per week) for this outcome; thus we were unable to conduct quantitative synthesis. Studies reporting this outcome included just one sentence stating that there was no change in the mean number of cigarettes smoked,96 no changes in the reported frequencies of cigarette consumption,92, 109 or that cigarette consumption had dropped slightly in both groups.111

Two studies reported anxiety changes among individuals undergoing interventions for alcohol misuse. After the intervention, mean anxiety level was slightly higher in men 92but slightly lower in women109 than compared with before-treatment, but neither effect was significant nor differed significantly from those observed in sex-matched control groups.

### Evidence in Older Adults, Young Adults or College Students, and Pregnant Women

Project GOAL specifically targeted older adults and reported that tobacco use did not change during the course of the intervention.112, 113 Similarly, smoking status did not differ in women receiving behavioral interventions compared with those receiving usual care in Project TrEAT.99

### Applicability

With such limited findings and insufficient evidence for most of the potential outcomes of relevance to this section, our ability to make conclusions about applicability is limited. Few studies addressed potential harms. Of note, no studies specifically addressed harms in young adults or college students, pregnant women, or among racial or ethnic minority groups. It is unclear whether the current findings extrapolate or generalize to these groups.

## Key Question 6 How do behavioral counseling interventions, with or without referral, compare with one another and with usual care for reducing morbidity, reducing mortality, or changing other long-term outcomes for people with alcohol misuse as identified by screening?

### Summary of Findings

Here we summarize the main findings for each population (adults, older adults, young adults and college students) by outcome and report the strength of evidence (SOE) for each.

#### Adults

- Mortality: Our meta-analyses did not find a reduction in all-cause mortality for adults (four studies; RR, 0.64, 95% CI, 0.24 to 1.7) or for all age groups combined (adults, older adults, and young adults/college students) (six studies; RR, 0.52, 95% CI, 0.22 to 1.2). Point estimates trended toward favoring behavioral interventions, few studies reported mortality, additional studies would be needed to increase precision, and there is little long-term data (low SOE).
- Morbidity (e.g., alcohol-related accidents, alcohol-related liver problems): evidence was insufficient to draw conclusions for morbidity outcomes.
- Hospitalization: the best evidence comes from Project TrEAT (N=774). It reported a statistically significant difference in hospital days in the last 6 months for the intervention group compared with the control group at 6, 12, and 48 months (35 vs. 180, 91 vs. 146, and 420 vs. 664, p<0.001, p<0.001, and p<0.05, respectively) (low SOE).
- Emergency visits: the best evidence comes from Project TrEAT (N=774). The difference between groups did not reach statistical significance but trended in favor of the intervention group at 6, 12, and 48 months (visits in past 6 months: 47 vs. 70, 60 vs. 62, and 302 vs. 376, p>0.10, p>0.10, and p<0.10, respectively) (low SOE).
- Outpatient primary care visits: no significant difference between intervention and control groups (WMD, -0.14 visits, 95% CI, -0.5 to 0.2) (low SOE).
- Costs: Benefit-cost analyses from Project TrEAT (using 6- and 12-month follow up) reported a total potential economic benefit of the brief intervention of $423,519, including more than $190,000 savings in emergency department and hospital use and almost $230,000 in avoided costs of crime and motor vehicle accidents.97 The average per subject benefit was more than $1,100 and the benefit-cost ratio was 5.6:1 (95% CI, 0.4 to 11.0).97 Using data from the 48-month follow up, the authors reported an intervention cost per patient of $205, and a benefit per patient of $7,985, for a resulting benefit-cost ratio of 39 (95% CI, 5.4 to 72.5).98 (low SOE).
- Legal issues: one 48-month study (Project TrEAT) found no significant difference between the intervention and control groups for assault/battery/child abuse, resist/obstruct officer/disorderly conduct, criminal damage/property damage, theft/robbery, and other arrests, but reported a difference for controlled substance/liquor violations, with 2 in the intervention group compared with 11 in the control group (p<0.05) (low SOE).
- Quality of Life: Three 12-month studies (total N=353) reported no difference between intervention and control groups for quality of life measures (low SOE).92, 102, 109
- Sick days, employment stability: evidence was insufficient to draw conclusions.

#### Older Adults

- Morbidity and mortality: Evidence from one study was insufficient to draw conclusions for morbidity or mortality outcomes.
- Costs: An economic analysis of Project GOAL found no significant difference in economic outcomes through 24 months.113 The total costs of health care and social consequences were estimated to be $5,241 (95% CI, $2,995 to $7,487) per patient in the intervention group and $6,289 (95% CI, $3,549 to $9,029) per patient in the control group (low SOE).
- Other outcomes: Evidence was insufficient to draw conclusions for utilization, sick days, legal issues, employment stability, and quality of life outcomes for older adults.

#### Young Adults and College Students

- Mortality: One trial reported one death in the control group (insufficient SOE).
- Motor vehicle events: A subgroup analysis (N=226) of young adults from Project TrEAT88 found fewer motor vehicle crashes with nonfatal injuries for those in the intervention group than for controls (9 vs. 20, respectively; p<0.05) and fewer total motor vehicle events (114 vs. 149; p<0.05) after 48 months of followup (low SOE).
- Hospitalizations: The subgroup analysis from Project TrEAT reported a lower number of days of hospitalization for the intervention group that did not reach statistical significance (131 vs. 150, p=NS) (low SOE).88
- Emergency visits: The subgroup analysis from Project TrEAT reported fewer emergency department visits for the intervention group than for the control group (103 vs. 177, p<0.01) (low SOE).88
- Academic: Evidence from two trials (N=576 and N=104) conducted in New Zealand suggests that behavioral interventions result in fewer consequences related to academic role expectations (RR between 0.70 and 0.80, moderate SOE).116, 118
- Legal events: the subgroup analysis from Project TrEAT found no significant difference between the intervention and control groups for assault/battery/child abuse, resist/obstruct officer/disorderly conduct, criminal damage/property damage, theft/robbery, and other arrests, but did report a difference for controlled substance/liquor violations, with 0 in the intervention group compared with 8 in the control group (p<0.01) (low SOE).88
- Other outcomes: evidence was insufficient for alcohol-related liver problems, costs, and quality of life (no included studies).

#### Pregnant Women

- We did not identify any studies in pregnant women reporting outcomes for this Key Question.

### Evidence in Adults

#### Characteristics of Included Studies

Table 26 summarizes the characteristics of the eight trials (targeting adult populations) meeting our inclusion criteria for this question. All were RCTs conducted exclusively in primary care settings. The trials generally targeted those with risky/hazardous drinking. The study conducted in rural primary care sites in Thailand also enrolled around 15 percent of subjects with alcohol dependence (based on an AUDIT score >25).91

Table 26 Characteristics of included trials comparing behavioral counseling interventions with usual care or with one another for reducing morbidity, reducing mortality, or changing other long-term outcomes for adults with alcohol misuse

Study | N % Dep | Duration (mths) | Country | Setting | Mean Age (y) | % Fem | % Nonwhite | Baseline Alcohol Use (Drinks/wk) | Quality
Anderson, Scott, 1992^92^ | 154 NR | 12 | U.K. | 8 PC group practices | 43 to 45.1 | 0 | NR | 37.9 to 38.8 | Fair
Bischof et al., 2008^90^ Grothues et al., 2008^93^ Reinhardt et al., 2008^94^ SIP study | 408 30.4 | 12 | Germany | 85 general practices | 35.9 to 36.8 | 31.9 | NR | 21 to 25.2 | Fair
Fleming et al., 1997^96^ Fleming et al., 2000^97^ Fleming et al., 2002^98^ Grossberg et al., 2004^88^ Manwell et al., 2000^99^ Project TrEAT | 774 NR^a^ | 48 | U.S. Wisconsin | 17 community PC practices | NR^b^ | 38 | 5.6 to 11.9 | 18.9 to 19.1 | Good
Lock et al., 2006^102^ | 127 0 | 12 | U.K. | General practices | 44.1 | 50 | NR | 23 to 26.48 | Fair
Noknoy et al., 2010^91^ | 117 13.8 to 15.3^c^ | 6 | Thailand | Rural PC units | 37 | 8.5 | 100 (Thai) | 15.15 | Fair
Scott, Anderson, 1990^109^ | 72 NR | 12 | U.K. | 8 PC group practices | 44.4 to 47.2 | 100 | NR | 25.8 to 26.7 | Fair
Senft et al., 1997^85^ Freeborn et al., 2000^110^ | 516 0 | 24 | U.S. Oregon | 3 PC clinics in an HMO | 41.9 to 43 | 28.1 to 31.1 | 17.4 to 18.7 | 16.5 | Fair
Wallace et al., 1988^111^ | 909 NR | 12 | U.K. | 47 group practices | 41.7 to 44.6 | 29.1 to 29.8 | NR | 35.1 (females) and 62.2 (males) | Fair

% Dep = percentage of subjects with alcohol dependence; Fem = female; HMO = health maintenance organization; mths = months; N = total number randomized; NR = not reported/unclear; PC = primary care; SIP (Bischof et al) = Stepped Intervention for Problem Drinkers; TrEAT = Trial for Early Alcohol Treatment; U.K. = United Kingdom; U.S. = United States; wk = week; y = years

a Six subjects (per medical record audit) received formal alcohol treatment during the 1-year followup period; those may represent subjects ultimately diagnosed with alcohol dependence.

b Group 1: Men, 20.2% 18-30y; 27.2% 31-40y; 23.9% 41-50y; 28.8% 51-65y; Women, 43.5% 18-30y; 25.9% 31-40y; 15.6% 41-50y; 15.0% 51-65y. Group 2: Men, 26.0% 18-30y; 25.1% 31-40y; 21.3% 41-50y; 27.7% 51-65y; Women, 35.7% 18-30y; 35.7% 31-40y; 18.2% 41-50y; 10.5% 51-65y.

c Based on AUDIT >25.

Note: When data were not reported for mean age, %female, % nonwhite, and baseline alcohol consumption for the total sample but were presented for each study group, we give the range of the means for the various study groups.

Two of the studies were conducted exclusively in the United States, four in the United Kingdom, and one each in Germany and Thailand (Table 26). Most studies followed subjects for 12 months; two studies reported outcomes beyond 12 months, up to 24 months85, 110 or 48 months.88, 96-99

Most studies reported a baseline alcohol consumption between 15 and 30 drinks per week. Two studies conducted in the United Kingdom92, 111 reported more than 30 drinks per week at baseline.

Methods of screening used to identify subjects for the included trials are described in Key Question 4a and in Appendix C. Most studies used self-administered questions that assess the quantity and frequency of alcohol consumption for screening. The AUDIT and CAGE were commonly used in addition to quantity-frequency questions. The interventions of included studies for this section are described in Table 27, stratified by intervention intensity. Intervention intensity varied from brief (single contact, up to 15 minutes) to brief multicontact (multiple contacts, up to 15 minutes each) to extended multicontact (multiple contacts, one or more of them longer than 15 minutes).

Table 27 Description of behavioral counseling interventions for improving morbidity, mortality, or other long-term outcomes for adults with alcohol misuse, by intervention intensity

Intensity | Study | Intervention | Delivered By | Delivery Method | No. of Contacts | Length of Each Contact
Brief | Anderson, Scott, 1992^92^ | Brief advice, feedback about own consumption and norms, and a self-help booklet | PCP | In person | 1 | 10 min
Brief | Lock et al., 2006^102^ | Brief advice (“drink-less” protocol) on standard drink units, recommended consumption levels, benefits of cutting down, tips on reducing consumption, advice on goal-setting, action plan, and self-help booklet/diary | Nurse or PA | In person | 1 | 5-10 min
Brief | Scott, Anderson, 1990^109^ | Brief advice, feedback about own consumption and norms, and a self-help booklet | PCP | In person | 1 | 10 min
Brief | Senft et al., 1997^85^ Freeborn et al., 2000^110^ | 30-second message from PCP and 15-minute session with health counselor immediately following PCP visit | PCP and study health counselor | In person | 1 | ∼15 min
Brief multi-contact | Fleming et al., 1997^88, 96-99^ Project TrEAT | Two visits 1 month apart with PCP and a followup phone call from the clinic nurse 2 weeks after each visit; workbook containing feedback regarding current health behaviors, review of prevalence of problem drinking, list of adverse effects of alcohol, worksheet on drinking cues, drinking agreement/prescription, and drinking diary cards | PCP and nurse | In person and phone | 4 | 15 min for PCP contacts; NR for phone calls
Brief multi-contact | Noknoy et al., 2010^91^ | Motivational enhancement protocol: brief counseling sessions using patient-centered interviewing style and considering stages of change | Nurse or PA | In person | 3 | 15 min
Brief multi-contact | Wallace et al., 1988^111^ | Brief advice, an information booklet (“That's the Limit”), sex-based recommendation for limiting drinking, a drinking diary, and followup sessions | PCP | In person | 1 to 5^a^ | NR^b^
Extended multicontact | Bischof et al., 2008^90, 93, 94^ SIP study | Group 1: Full Care: immediate computerized post-assessment feedback and multiple sessions of counseling by psychologist | Trained psychologists from research team | Phone | 4 | Scheduled for 30 min each; mean received was 80.3 min
Extended multicontact | Bischof et al., 2008^90, 93, 94^ SIP study | Group 2: Stepped Care: immediate computerized post-assessment feedback and maximum of 3 counseling sessions with psychologist. Sessions were discontinued if patients indicated consumption below study criteria and high self-efficacy to maintain desired behavior. | Trained psychologists from research team | Phone | Up to 4 | Scheduled for 30-40 min each; mean received was 40 min

min = minutes; mths = months; No. = number; NR = not reported; OB = Obstetrician; PA = Physician Assistant; PCP = primary care physician; SIP = Screening and Intervention in Primary Care; TrEAT = Trial for Early Alcohol Treatment; U.S. = United States; y = years

a All intervention subjects received an invitation to a 1-month followup; other followup was offered at 4, 7, and 10 months at the discretion of the practitioner.

b Not reported in the article; per the author, they trained them to do “up to 15 minutes,” and he believes they were generally 10–15 minutes (Paul Wallace, personal email communication, December 2011).

Four studies tested interventions delivered primarily by the patient's primary care physician.92, 96, 109, 111 Two studies tested interventions delivered primarily by nurses or physician assistants,91, 102 and two studies (contributing three interventions) tested interventions delivered primarily by research team personnel, such as a health counselor85 or trained psychologist.90 Among the interventions involving patient's usual primary care physician, some used the physicians to deliver initial and any repeated intervention contacts111 whereas others also used educators, counselors, or nurses for followup contacts.96

The majority of control groups involved screening/assessment followed by usual care or by the provision of a general health pamphlet. One study included additional components in the control group that could bias the results toward the null, with advice from nurses on cutting down drinking and a leaflet with daily benchmark alcohol guides.102

#### Mortality

Four studies enrolling adults reported any deaths (all-cause mortality) in one or more study groups.90, 91, 96, 98, 111 The individual studies were not designed or powered to detect differences in mortality. Two of the four studies reported more deaths in the intervention group than the control group (one or two deaths in the intervention group and zero in the control group).91, 111 Of the 16 total deaths reported, none were definitely related to alcohol misuse. Just two of the studies reported causes of death; 6 deaths were from unspecified causes, 1 was suicide, 7 were due to cardiac or pulmonary problems, and 2 were in motor vehicle accidents.

We conducted meta-analysis using the four included studies conducted in adults for all-cause mortality for adults in person-years (Appendix E). Our meta-analysis did not find a statistically significant reduction in mortality (RR, 0.64, 95% CI, 0.24 to 1.7) (Figure 3). We conducted additional analyses with the addition of the included studies in older adults (GOAL)112 and in younger adults118 that reported mortality. Results trended toward favoring behavioral interventions but remained nonstatistically significant (RR, 0.52, 95% CI, 0.22 to 1.2) (Figure 3).

Figure 3 Meta-analysis results for all-cause mortality

Figure 3 displays two forest plots of studies reporting the rate ratio of mortality in person-years for behavioral counseling interventions versus control. Data for Figure 3 are presented in Appendix E. The first forest plot includes studies of adults, and the second includes adults, young adults, and older adults. This figure is described further in the section “Mortality” as follows: “Our meta-analysis did not find a statistically significant reduction in mortality (rate ratio 0.64, 95% CI, 0.24 to 1.7) (Figure 3). We conducted additional analyses with the addition of the included studies in older adults (GOAL) #111 and in younger adults (Kypri, 2004) #117 that reported mortality. Results trended toward favoring behavioral interventions, but remained nonstatistically significant (rate ratio 0.52, 95% CI, 0.22 to 1.2).”

#### Morbidity (e.g., Alcohol-Related Accidents and Injuries, Alcohol-Related Liver Problems)

Four studies reported data on accidents in adults (for data in young adults, see section below). Studies were not designed or powered to detect differences in these outcomes. Two studies (Anderson, 1992; and Scott, 1990) reported accident scores (from an alcohol-related problems scale), both with endpoint scores numerically favoring the intervention group.92, 109 Neither found a significant change from baseline data for the intervention group or for the control group (Appendix C). One study conducted in Thailand reported alcohol-related accidents (1 in the intervention group and 4 in the control group) and alcohol-related traffic accidents (3 in the intervention group and 5 in the control group).91 The best available evidence comes from Project TrEAT (N=774),98 which reported outcomes after 48 months of followup. The study found lower numbers of motor vehicle crashes with fatalities (0 vs. 2), motor vehicle crashes with nonfatal injuries (20 vs. 31), and motor vehicle crashes with property damage only (67 vs. 72), that were not statistically significantly different between the intervention and control groups.

No studies reported other morbidity outcomes (e.g., alcohol-related liver problems) in adults. Overall, evidence was insufficient to draw conclusions for adults for morbidity outcomes (Appendix G).

#### Health Care Utilization

Six studies reported utilization outcomes among secondary outcomes (Appendix G).85, 91, 92, 98, 102, 109 The majority of utilization outcomes reported revealed trends favoring lower utilization in the intervention group compared with the control group that were not statistically significant. These included mean consultations or care episodes per year,92, 109 general practitioner visits,102 nurse practitioner visits,102 accident and emergency visits,102 outpatient visits by 24 months,85, 110 number of hospital days,85, 110 emergency department visits,96, 98 and visits to primary care physicians due to alcohol consumption.91 Five of the studies reported outcomes (listed in the previous sentence) reflecting primary care utilization. Our meta-analysis for primary care practitioner utilization did not find a significant difference between intervention and control groups (WMD, -0.14 visits, 95% CI, -0.5 to 0.2) (Appendix E).

The best evidence for number of days hospitalized and number of emergency department visits (based on the quality, size, design, and duration of the study) comes from Project TrEAT. It reported a statistically significant difference in hospital days in the last 6 months for the intervention group compared with the control group at 6, 12, and 48 months (35 vs. 180, 91 vs. 146, and 420 vs. 664, p<0.001, p<0.001, and p<0.05, respectively). Two smaller studies of shorter duration reported no statistically significant difference between groups for hospitalization outcomes. Specifically, Senft and colleagues (N=516) reported a slightly lower percentage of subjects hospitalized in the intervention group than the control group at 24 months that was not significant (21.2% vs. 22.0%, p=0.81) and a trend toward fewer mean hospital days for those hospitalized that was not significant (4.7 vs. 6.6, p=0.37); Lock and colleagues (N=127) reported no significant difference between groups for hospital inpatient stays.

In Project TrEAT, the difference between groups for emergency department visits in the last 6 months did not reach statistical significance, but trended in favor of the intervention group at 6, 12, and 48 months (47 vs. 70, 60 vs. 62, and 302 vs. 376, p>0.10, p>0.10, and p<0.10, respectively). In a smaller 12-month study, Lock and colleagues reported fewer accident and emergency visits for the intervention group than the control, but the difference was not statistically significant.102

#### Costs

Two included studies enrolling adults reported costs.97, 98, 102 One study102 (N=127) conducted in the United Kingdom reported numerically lower mean total health care costs (British pounds) for the nurse-led intervention group than for the control group over 12 months, but the difference was not statistically significant (263 vs. 392, p=NS; when including intervention delivery costs: 291 vs. 392, p=NS).102 The health economic evaluation in this study included both National Health Service resource costs and individuals' personal costs (e.g., time and transportation costs).

The best evidence comes from benefit-cost analyses from Project TrEAT (N=774), conducted from the societal perspective. Analyses using 6- and 12-month followup data reported a total potential economic benefit of the brief intervention of $423,519 (95% CI, $35,947 to $884,848), including more than $190,000 savings in emergency department and hospital use and almost $230,000 in avoided costs of crime and motor vehicle accidents.97 The average per subject benefit was more than $1,100, and the benefit-cost ratio was 5.6:1 (95% CI, 0.4 to 11.0), or just over $56,000 in total benefit for every $10,000 invested.97 Using data from the 48-month followup from Project TrEAT and the societal perspective, Fleming and colleagues reported an intervention cost per patient of $205, a benefit per patient of $7,985, for a resulting benefit-cost ratio of 39 (95% CI, 5.4 to 72.5).98

#### Legal Issues

Only one study, Project TrEAT, reported outcomes related to legal issues.98 After 48 months, the number of the following events was not statistically significantly different between the intervention and control groups: assault/battery/child abuse (8 vs. 11), resist/obstruct officer/disorderly conduct (8 vs. 6), criminal damage/property damage (2 vs. 1), theft/robbery (3 vs. 3), and other arrests (5 vs. 9). However, the study reported a difference for controlled substance/liquor violations: 2 in the intervention group compared with 11 in the control group (p<0.05).

#### Quality of Life

Three studies reported quality of life outcomes. Detailed data from these studies are included in Appendix C. A 12-month study of 154 men reported no difference in change in mean life quality scores between the intervention and control groups (0 vs. 0).92 Similarly, a 12-month study that enrolled 72 women reported no difference in change in mean life quality scores between the intervention and control groups (-0.3 vs. -0.3).109 A nurse-led intervention (N=127) reported no significant differences between the intervention and control groups at 6 or 12 months for change in SF-12 physical or mental health scores.102

#### Sick Days, Employment Stability

We did not identify any studies reporting these outcomes.

### Evidence in Older Adults

Just one of the included studies (Project GOAL) focused on older adults reported outcomes relevant for this Key Question (Table 28).112, 113 Further description of the study and the intervention used is provided in Key Question 4a.

Table 28 Characteristics of included trials comparing behavioral counseling interventions with usual care or with each other for improving morbidity, mortality, or other long-term outcomes for older adults with alcohol misuse

Study | N % Dep | Duration (mths) | Country | Setting | Mean Age (y) | % Fem | % Nonwhite | Baseline Alcohol Use (Drinks/wk) | Quality
Fleming, 1999^112^ Mundt, 2005^113^ GOAL | 158 0 | 24 | U.S. Wisconsin | 24 PC practices | NR >92% age 65-75 | 33.5 | NR | 15.54 to 16.58 | Fair

% Dep = percentage of subjects with alcohol dependence; Fem = female; GOAL = Guiding Older Adult Lifestyles; mths = months; N = total number randomized; NR = not reported/unclear; PC = primary care; U.S. = United States; wk = week; y = years

Note: When data were not reported for mean age, %female, % nonwhite, and baseline alcohol consumption for the total sample but was presented for each study group, we give the range of the means for the various study groups.

#### Morbidity and Mortality

Project GOAL reported all-cause mortality at 24 months (causes not reported), with 1 death in the intervention group and 4 in the control group (p not reported).112, 113 We incorporated this information in one of our meta-analyses for all-cause mortality described in the previous section. The study did not report morbidity. Evidence is insufficient to draw conclusions for older adults for morbidity or mortality outcomes.

#### Costs

An economic analysis of Project GOAL found no significant difference in economic outcomes through 24 months.113 The total costs of health care and social consequences were estimated to be $5,241 (95% CI, $2,995 to $7,487) per patient in the intervention group and $6,289 (95% CI, $3,549 to $9,029) per patient in the control group.

#### Health Care Utilization, Sick Days, Legal Issues, Employment Stability, and Quality of Life

We did not identify any studies in older adults reporting these outcomes. But, some costs of these outcomes were included in the economic analysis of Project GOAL, and it found no significant differences for hospital days, emergency department visits, office visits, medications, lab and x-ray procedures, or legal events. Overall, evidence is insufficient to draw conclusions for older adults for these outcomes.

### Evidence in Young Adults or College Students

All of the studies described in Key Question 4a for young adults or college students also reported outcomes relevant for this question (Table 29). For further description of these studies and the interventions utilized see Key Question 4a.

Table 29 Characteristics of included trials comparing behavioral counseling interventions with usual care or with each other for improving morbidity, mortality, or other long-term outcomes for young adults or college students with alcohol misuse

Study | N % Dep | Duration (mths) | Country | Setting | Mean Age (y) | % Fem | % Non-white | Baseline Alcohol Use (Drinks/wk) | Quality
Fleming et al., 2010^87^ CHIPs | 986 0 | 12 | U.S. and Canada | 5 college health clinics | 21 | 50.5 to 51.3 | 8.1 to 10.5 | 17.3 to 17.8 | Good
Grossberg et al., 2004^88^ TrEAT | 226^a^ NR | 48 | U.S. Wisconsin | 17 community PC practices | NR^b^ | 51 | 14 | 16.2 to 18.3 | Fair^c^
Kypri et al., 2008^116^ Kypri et al., 2007^117^ | 576 NR | 12 | New Zealand | University primary health care service | 20.1 to 20.3 | 52 | NR | NR | Good
Kypri et al., 2004^118^ | 104 NR | 6 | New Zealand | University student health service | 19.9 to 20.4 | 50 | NR | NR | Fair
Schaus et al., 2009^119^ | 363 0 | 12 | U.S. Florida | College student health center | 20.6 | 52 | 22 | 8.38 to 9.59 | Fair

% Dep = percentage of subjects with alcohol dependence; CHIPs = College health Intervention Projects; Fem = female; mths = months; N = total number randomized; NR = not reported/unclear; PC = primary care; TrEAT = Trial for Early Alcohol Treatment; U.S. = United States; wk = week; y = years

a This was a subgroup analysis of TrEAT,96 226 of the 774 enrolled subjects were young adults (age 18 to 30). The main study was rated good, this subgroup analysis was rated fair quality.

b 21% 18 to 21, 37% 22 to 25, and 47% 26 to 30.

c This was a subgroup analysis of TrEAT.96 The main study was rated good, and this subgroup analysis was rated fair quality.

Note: When data were not reported for mean age, %female, % nonwhite, and baseline alcohol consumption for the total sample but were presented for each study group, we give the range of the means for the various study groups.

#### Mortality

One of the trials (Kypri 2004)118 reported one death in the control group and zero in the intervention group (causes not reported, insufficient evidence to make a conclusion). We incorporated this information in one of our meta-analyses for all-cause mortality described in the section on adults above.

#### Morbidity

A subgroup analysis of young adults (18 to 30) from Project TrEAT reported significantly fewer motor vehicle crashes with nonfatal injuries than controls (9 vs. 20, respectively; p<0.05) and fewer total motor vehicle events (114 vs. 149; p<0.05) after 48 months of followup.88 Between-group differences were not statistically significant for motor vehicle crashes with fatalities (0 vs. 1) or property damage only (19 vs. 28, p= NS).

#### Health Care Utilization

Two studies reported utilization outcomes.87, 88 The CHIPs study reported a composite outcome, finding no significant difference between groups for the percentage of subjects with at least one hospitalization or emergency department visit or urgent care visit or admission to local detoxification unit in the previous 6 months.87 At baseline, between 29 percent and 30 percent of both groups reported at least one of the utilization events. Both groups showed a similar decrease in utilization by 12 months (percentages reporting at least one event at 12 months: 18.5% vs. 18.3%, p=0.93).

The subgroup analysis of young adults from Project TrEAT reported fewer emergency department visits for the intervention group than for the control group (103 vs. 177, p<0.01).88 It reported a lower number of days of hospitalization for the intervention group that did not reach statistical significance (131 vs. 150, p=NS).88

#### Academic, Legal, or Social Problems

Two studies conducted in New Zealand reported academic outcomes, using the Academic Role Expectations and Alcohol Scale (AREAS).116, 118 The larger trial (N=576) reported fewer academic consequences for the intervention groups than control groups at 12 months (RR: single-contact intervention 0.80, 95% CI, 0.66 to 0.97; multicontact intervention 0.75, 95% CI, 0.62 to 0.90).116 In the smaller trial (N=104), results did not quite reach statistical significance at 6 months, but point estimates for rate ratios were similar (0.72, 95% CI, 0.51 to 1.02).118

The subgroup analysis of young adults from Project TrEAT reported legal events after 48 months of follow up; findings were not statistically significantly different between the intervention and control groups for total legal events (16 vs. 26), assault/battery/child abuse (6 vs. 6), resist/obstruct officer/disorderly conduct (6 vs. 3), criminal damage/property damage (1 vs. 3), theft/robbery (1 vs. 3), and other arrests (2 vs. 3). However, the study reported a difference for controlled substance/liquor violations: 0 in the intervention group compared with 8 in the control group (p<0.01).88

Four trials reported outcome measures that reflect a composite of alcohol-related problems. The two trials conducted in New Zealand used the Alcohol Problems Scale (APS); two trials used the Rutgers Alcohol Problem Index (RAPI). Both trials reporting the APS found numerical trends favoring the intervention group; results reached significance in the smaller 6-month trial (RR, 0.76, 95% CI, 0.60 to 0.97) but did not quite reach statistical significance in the larger 12-month trial (RR, 0.82, 95% CI, 0.67 to 1.01).116, 118 The CHIPs study found a greater reduction in alcohol-related harm in favor of the experimental group at 12 months (p=0.33).87 Schaus and colleagues found a similar difference at 6 months (p= 0.028) and 9 months (p=0.041).119

The subgroup analysis of young adults from Project TrEAT reported no difference in operating while intoxicated, or for other moving violations.88

#### Costs or Quality of Life

We did not identify any studies in young adults or college students reporting these outcomes.

### Evidence in Pregnant Women

We did not find any studies meeting our inclusion/exclusion criteria for this Key Question.

### Applicability

The findings are generally applicable to people with risky/hazardous drinking identified by screening in primary care settings. Most studies enrolled some subjects with heavy episodic drinking patterns of consumption. We did not identify any studies in adolescent populations, veterans, or pregnant women, and results thus have uncertain applicability to these populations. We identified only one study in older adults and therefore were unable to make conclusions for most outcomes for older adults. We identified a sufficient number, however, of studies of young adults/college students and adults to draw some conclusions (of low to moderate strength) for several outcomes. Although we searched for studies conducted in settings with primary care–like relationships (e.g., infectious disease clinics for people with HIV), we did not find any, and our results have uncertain applicability to such settings/populations.

## Key Question 7 To what extent do health care system influences promote or hinder effective screening and interventions for alcohol misuse?

### Summary of Findings

- All interventions required sufficient support systems in order to provide screening and screening-related assessment, and in some cases, provider prompting. Such supports are likely required for effective screening and intervention.
- The country in which studies were conducted (United States compared with non–United States) did not have a significant impact on the effectiveness of interventions for consumption outcomes.
- Interventions conducted in academic/research-oriented settings and those conducted in community-based primary care settings were both effective for reducing alcohol consumption, with data showing a trend toward greater reduction for interventions delivered in academic/research-oriented settings (WMD, -5.0 drinks/week, 95% CI, -7.6 to -2.5) than for those delivered in community-based settings (WMD, -3.2, 95% CI, -4.3 to -2.2).
- Interventions delivered by primary care providers and by research personnel were both effective for reducing alcohol consumption, with data showing a trend toward greater reduction for interventions delivered primarily by primary care providers (WMD, -4.0 drinks per week, 95% CI, -5.4 to -2.6) than for those delivered primarily by research personnel (WMD, -3.0, 95% CI, -5.0 to -1.0).
- Most interventions required training of providers and/or staff. Such training may be required for practices to deliver effective screening and interventions for alcohol misuse.

### Country/Health Care System

Although non-U.S. health care systems may be substantially different from those in the United States, we have included studies from all countries in this report because they provide valid and reliable outcome data for behavioral interventions in medical settings. RCT study settings were located in Australia, Canada, Germany, Kenya, Mexico, New Zealand, Norway, Russia, Spain, Thailand, United States, United Kingdom, and Zimbabwe. For our main meta-analysis (change in consumption for adults at 12 months), we conducted subgroup analyses by country that found similar effect sizes for studies conducted in the United States and for non-U.S. studies (Appendix E). In addition, our meta-regression did not find country to be a significant contributor to the overall variance in the analysis (p= 0.27) (Appendix E). Thus, studies conducted in the United States and outside of the United States have found similar effectiveness of behavioral interventions for reducing alcohol consumption, on average.

### Health Care Settings

Settings for the 23 RCTs were categorized as academic/research-oriented (n=5), community-based primary care (n=12), HMO (n=2), or student health clinic (N=4). Four of the U.S. studies86, 88, 96-99, 106-108, 112, 113 and one foreign study111 were conducted in academic/research-oriented practice settings, which may influence provider and clinic staff adherence to protocols. They reported the use of an average of four screening and/or assessment instruments. Two of the RCTs85, 95, 110 were in HMO settings. One95 used seven screening/assessment instruments and provided a single session with a PCP followed by approximately 6 weeks of phone counseling provided by a clinical psychology student. The other85, 110 used two screening/assessment instruments and provided a 30-second intervention with a provider followed by 15 minutes with a trained counselor. Twelve of the studies83, 84, 89-94, 100-105, 109, 114, 115, 120 were conducted in community-based primary care settings (4 U.S. and 7 non-U.S.). U.S.-based studies used slightly more screening/assessment instruments 6 versus 3.3 in the non-U.S. studies.

Four studies87, 116-119 were conducted in university student health clinic settings. Two116-118 of the four studies were in non-U.S. settings. The U.S. studies also reported on their training protocols, which were extensive. Both also monitored adherence to protocol through the use of a form verifying that the interventionist had followed the protocol and had gained student agreement that they would decrease their alcohol use. Identification of patients was done via self-administered computerized assessment in the non-U.S. studies.116-118 These studies included one encounter of 11 to 15 minutes. Both used the AUDIT and relied on computers for both assessment and intervention.

For our main meta-analysis (change in consumption for adults at 12 months), we conducted subgroup analyses by setting to assess whether there were differences in effectiveness of interventions delivered in academic/research-oriented settings compared with community-based primary care settings. The number of HMO settings was insufficient to assess differences, and all of the interventions delivered in student health clinics were in a young adult population (which we evaluated separately from studies conducted in adults). Our subgroup analyses found a trend toward greater reduction in alcohol consumption for studies of behavioral interventions conducted in academic/research-oriented settings than for those conducted in community-based primary care settings, although confidence intervals overlap (WMD, -5.0 drinks/week, 95% CI, -7.6 to -2.5 compared with -3.2 drinks/week, 95% CI, -4.3 to -2.2) (Appendix E).

### Personnel Involved With the Study

Research staff conducted the screening and screening-related assessments to identify those with alcohol misuse prior to intervention in nearly every study; most of these processes were relatively time intensive (>30 minutes) and took place outside of the routine care encounter either in the patient waiting room or telephonically. In one study of pregnant women,120 screening and assessment lasted up to 2 hours. In several studies, research staff screened patients via telephone interviews and also used telephone to conduct brief followups and booster sessions with patients.

Fourteen of the interventions83, 86-89, 92, 95-99, 106-109, 111-115, 119, 120 were delivered by a primary care physician alone or in conjunction with a health educator or nurse. Three91, 100-102 were delivered by a nurse or physician assistant; one was conducted by a psychologist;90, 93, 94 two by a researcher;85, 103-105, 110 and one by unspecified interventionists.84 Two interventions116-118 conducted in college students were provided via a computer, and both reported some evidence of effectiveness.

For our main meta-analysis (change in consumption for adults at 12 months), we conducted subgroup analyses by type of provider primarily delivering the intervention (primary care provider, research personnel, or nurse). We found a trend toward a greater numerical reduction in drinks per week for interventions delivered primarily by primary care providers (WMD, -4.0, 95% CI, -5.4 to -2.6) than for those delivered primarily by research personnel (WMD, -3.0, 95% CI, -5.0 to -1.0) (Appendix E). Just one intervention delivered by a nurse contributed to the analysis; the reduction in drinks per week was not statistically significant for that study (WMD, -0.2, 95% CI, -8.9 to 8.6). Two other studies that did not provide sufficient data for our main meta-analysis reported benefits of interventions delivered primarily by nurses100, 101 or by nurses and physician assistants91 for some consumption outcomes. Our meta-regression did not find provider type to be a significant contributor to the overall variance in the analysis (Appendix E).

### Incentives

Limited mention was made of the use of incentives in the included trials. One trial120 used incentives to compensate pregnant women for completing the assessment ($50) and postpartum followup ($75).120 This study also provided compensation for collaterals ($10). Another119 paid participants up to $100 for completing study instruments ($30 at baseline; $10 each at 3, 6, and 9 months; $40 at 12 months). Project TrEAT88, 96-99 reported $250 compensation paid to participating physicians and $50 paid to patients. The Healthy Moms study100, 101 paid patients $150 if they completed the required procedures.

### Training

Of the 23 RCTs we included in this report, 16 included at least some mention of training. Provider and/or staff trainings were reported in most studies. When reported, training duration ranged from as little as 15 minutes92, 109 to as long as 6 to 8 hours,91, 119 full-day workshops,87 or a 4-week training in motivational interviewing principles.90 Nine studies87, 88, 90, 91, 93, 94, 96-108 reported trainings of research staff and interventionists that were 30 minutes and longer and also provided feedback, booster sessions, or weekly conference calls to maintain adherence to protocol. Five others85, 89, 95, 110, 111, 114, 115 reported trainings of 30 minutes or more but did not provide information on booster sessions. One RCT90, 93, 94 reported that counselors completed a 4-week training in motivational interviewing.

The type of training received was often described fairly briefly, possibly due to space limitations. For example, in Project TrEAT,96 physicians “were trained to administer the intervention protocol through role playing and general skills techniques in educational programs…also received additional training in booster sessions that occurred at least twice during the trial.” Some studies provided much greater detail. For example, in Project Health,106 “training generally occurred in 2 sessions…a 2-hour small-group session and a 10 to 20 minute individual tutorial session 2 to 6 weeks after the group session. In addition, at the beginning of the recruitment period research assistants generally gave a brief (1-2 minute) refresher orientation to providers about their use of the intervention tools (i.e., goal statement, tip sheets) just before a study patient was seen. In total, providers received about 2.5 to 3 hours of training.”

### Use of Electronic Health Records

None of the included studies reported a discussion or description of the use of electronic health records.

### Limitations

This question was confined to examining RCTs that were included in the other questions in this report (RCTs primarily examining the efficacy or effectiveness of screening and brief intervention). This report does not address the dissemination and implementation literature that may shed further light on health care system influences that promote or hinder effective screening and interventions for alcohol misuse.