# References

1 Whitlock EP, Green CA, Polen MR. Behavioral Counseling Interventions in Primary Care to Reduce Risky/Harmful Alcohol Use. Systematic Evidence Review No. 30. AHRQ Publication No. 04-0533B. (Prepared by Oregon Evidence-based Practrice Center under Contract No. 290-97-0018, Task Order No. 2). Rockville, MD. Agency for Healthcare Research and Quality. April. 2004.
2 U.S. Department of Veterans Affairs. AUDIT-C Frequently Asked Questions. Updated April 28, 2010. www.queri.research.va.gov/tools/alcohol-misuse/alcohol-faqs.cfm. June 27, 2011.
3 Saitz R. Clinical practice. Unhealthy alcohol use. N Engl J Med. Feb. 10. 2005;352(6):596-607. [pmid: 15703424].
4 Mokdad AH, Marks JS, Stroup DF, et al. Actual causes of death in the United States, 2000. JAMA. Mar. 10. 2004;291(10):1238-45. [pmid: 15010446].
5 Bouchery EE, Harwood HJ, Sacks JJ, et al. Economic costs of excessive alcohol consumption in the U.S., 2006. Am J Prev Med. Nov. 2011;41(5):516-24. [pmid: 22011424].
6 Harwood HJ, Fountain D, Fountain G. Economic cost of alcohol and drug abuse in the United States, 1992: a report. Addiction. May. 1999;94(5):631-5. [pmid: 10563025].
7 Centers for Disease Control and Prevention. FastStats: Alcohol Use. Updated October 22, 2009. www.cdc.gov/nchs/fastats/alcohol.htm. June 26, 2011.
8 Corrao G, Bagnardi V, Zambon A, et al. A meta-analysis of alcohol consumption and the risk of 15 diseases. Prev Med. May. 2004;38(5):613-9. [pmid: 15066364].
9 Schuckit MA. Alcohol-use disorders. Lancet. Feb. 7. 2009;373(9662):492-501. [pmid: 19168210].
10 Cherpitel CJ, Ye Y. Alcohol-attributable fraction for injury in the U.S. general population: data from the 2005 National Alcohol Survey. J Stud Alcohol Drugs. Jul. 2008;69(4):535-8. [pmid: 18612569].
11 Centers for Disease Control and Prevention. Alcohol-attributable deaths and years of potential life lost--United States, 2001. MMWR Morb Mortal Wkly Rep. Sep. 24. 2004;53(37):866-70. [pmid: 15385917].
12 National Highway Traffic Safety Administration. Traffic Safety Facts 2008 Data: Alcohol-Impaired Driving: Fatal Crashes and Fatalities Involving Alcohol-Impaired Drivers. Washington, DC. National Highway Traffic Safety Administration. 2009. www-nrd.nhtsa.dot.gov/Pubs/811155.PDF. June 27, 2011.
13 Hasin DS, Grant BF. The co-occurrence of DSM-IV alcohol abuse in DSM-IV alcohol dependence: results of the National Epidemiologic Survey on Alcohol and Related Conditions on heterogeneity that differ by population subgroup. Arch Gen Psychiatry. Sep. 2004;61(9):891-6. [pmid: 15351767].
14 Hasin DS, Stinson FS, Ogburn E, et al. Prevalence, correlates, disability, and comorbidity of DSM-IV alcohol abuse and dependence in the United States: results from the National Epidemiologic Survey on Alcohol and Related Conditions. Arch Gen Psychiatry. Jul. 2007;64(7):830-42. [pmid: 17606817].
15 Pleis JR, Lucas JW. Summary health statistics for U.S. adults: National Health Interview Survey, 2007. Vital Health Stat 10. May. 2009;(240):1-159. [pmid: 19645319].
16 Rigler SK. Alcoholism in the elderly. Am Fam Physician. Mar. 15. 2000;61(6):1710-6. 883. 4. 887. 8. passim. [pmid: 10750878].
17 Smith PC, Schmidt SM, Allensworth-Davies D, et al. Primary care validation of a single-question alcohol screening test. J Gen Intern Med. Jul. 2009;24(7):783-8. [pmid: 19247718].
18 Reid MC, Fiellin DA, O'Connor PG. Hazardous and harmful alcohol consumption in primary care. Arch Intern Med. Aug. 9-23. 1999;159(15):1681-9. [pmid: 10448769].
19 Vinson DC, Manning BK, Galliher JM, et al. Alcohol and sleep problems in primary care patients: a report from the AAFP National Research Network. Ann Fam Med. Nov-Dec. 2010;8(6):484-92. [pmid: 21060117].
20 Fleming MF, Manwell LB, Barry KL, et al. At-risk drinking in an HMO primary care sample: prevalence and health policy implications. Am J Public Health. Jan. 1998;88(1):90-3. [pmid: 9584040].
21 U.S. Department of Health and Human Services. Healthy People 2010. 2nd ed. Washington, D.C. U.S. Government Printing Office. 2000.
22 Isaac M, Janca A, Sartorius N. ICD-10 symptom glossary for mental disorders. Geneva. Division of Mental Health, World Health Organization. 1994.
23 Janca A, Ustun TB, van Drimmelen J, et al. ICD-10 symptom checklist for mental disorders, version 1.1. Geneva. Division of Mental Health, World Health Organization. 1994.
24 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 4th ed. Text rev. Washington, DC. American Psychiatric Publishing, Inc. 2000.
25 The physician's guide to helping patients with alcohol problems. NIH Publication No. 95-3769. Rockville, MD. National Institute on Alcohol Abuse and Alcoholism (NIAAA). 1995.
26 National Institute on Alcohol Abuse and Alcoholism. Helping Patients Who Drink Too Much: A Clinician's Guide. Washington, DC. U.S. Department of Health and Human Services. 2005. pubs.niaaa.nih.gov/publications/practitioner/cliniciansguide2005/guide.pdf. June 27, 2011.
27 Shalala DE. 10th Special Report to the U.S. Congress on Alcohol and Health: Highlights From Current Research: From the Secretary of Health and Human Services. Washington, DC. U.S. Department of Health and Human Services. June. 2000. pubs.niaaa.nih.gov/publications/10report/intro.pdf. June 27, 2011.
28 O'Connor PG, Schottenfeld RS. Patients with alcohol problems. N Engl J Med. Feb. 26. 1998;338(9):592-602. [pmid: 9475768].
29 American Society of Addiction Medicine. Public Policy Statement on Screening for Addiction in Primary Care Settings. Chevy Chase, MD. American Society of Addiction Medicine. 1997. www.asam.org/advocacy/find-a-policy-statement/view-policy-statement/public-policy-statements/2011/12/16/screening-for-addiction-in-primary-care-settings. March 12 2012.
30 National Institute on Alcohol Abuse and Alcoholism. Brief Interventions. Alcohol Alert. Jul. 2005;(66). pubs.niaaa.nih.gov/publications/AA66/AA66.htm. June 27 2011.
31 Whitlock EP, Orleans CT, Pender N, et al. Evaluating primary care behavioral counseling interventions: an evidence-based approach. Am J Prev Med. May. 2002;22(4):267-84. [pmid: 11988383].
32 Substance Abuse and Mental Health Services Administration. Screening, Brief Intervention, and Referral to Treatment. www.samhsa.gov/prevention/SBIRT/index.aspx. June 27, 2011.
33 Babor T. The social and public health significance of individually directed interventions. Holder HD, Edwards G, editors. Alcohol and public policy: evidence and issues. Oxford, England. Oxford University Press. 1995:164-89.
34 Bondy SJ, Rehm J, Ashley MJ, et al. Low-risk drinking guidelines: the scientific evidence. Can J Public Health. Jul-Aug. 1999;90(4):264-70. [pmid: 10489725].
35 Holman CD, English DR, Milne E, et al. Meta-analysis of alcohol and all-cause mortality: a validation of NHMRC recommendations. Med J Aust. Feb. 5. 1996;164(3):141-5. [pmid: 8628131].
36 Cherpitel CJ, Tam T, Midanik L, et al. Alcohol and non-fatal injury in the U.S. general population: a risk function analysis. Accid Anal Prev. Oct. 1995;27(5):651-61. [pmid: 8579696].
37 U.S. Preventive Services Task Force. Screening and behavioral counseling interventions in primary care to reduce alcohol misuse: recommendation statement. Ann Intern Med. Apr. 6. 2004;140(7):554-6. [pmid: 15068984].
38 Helping Patients with Alcohol Problems. A Practitioner's Guide. NIH publication no. 03-3769. Rockville, MD. National Institute on Alcohol Abuse and Alcoholism (NIAAA). 2003.
39 Fleming MF, Graham AW. Screening and brief interventions for alcohol use disorders in managed care settings. Recent Dev Alcohol. 2001;15:393-416. [pmid: 11449755].
40 Friedmann PD, McCullough D, Chin MH, et al. Screening and intervention for alcohol problems. A national survey of primary care physicians and psychiatrists. J Gen Intern Med. Feb. 2000;15(2):84-91. [pmid: 10672110].
41 McGlynn EA, Asch SM, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. Jun. 26. 2003;348(26):2635-45. [pmid: 12826639].
42 Willenbring ML, Massey SH, Gardner MB. Helping patients who drink too much: an evidence-based guide for primary care clinicians. Am Fam Physician. Jul. 1. 2009;80(1):44-50. [pmid: 19621845].
43 Goldberg HI, Mullen M, Ries RK, et al. Alcohol counseling in a general medicine clinic. A randomized controlled trial of strategies to improve referral and show rates. Med Care. Jul. 1991;29(7 Suppl):JS49-56. [pmid: 1857135].
44 Cisler RA, Kowalchuk RK, Saunders SM, et al. Applying clinical significance methodology to alcoholism treatment trials: determining recovery outcome status with individual- and population-based measures. Alcohol Clin Exp Res. Nov. 2005;29(11):1991-2000. [pmid: 16340456].
45 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
46 Centre for Reviews and Dissemination. Systematic reviews: CRD's guidance for undertaking reviews in healthcare. York, England. University of York. 2009.
47 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical Heterogeneity. Methods Research Report. Prepared by RTI International -- University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I. Rockville, MD. Agency for Healthcare Research and Quality. September. 2010. AHRQ Publication No. 10-EHC070-EF.
48 Centers for Disease Control and Prevention. What is a standard drink in the United States?. www.cdc.gov/alcohol/faqs.htm#standDrink. August 12, 2011.
49 Follmann D, Elliott P, Suh I, et al. Variance imputation for overviews of clinical trials with continuous response. J Clin Epidemiol. Jul. 1992;45(7):769-73. [pmid: 1619456].
50 Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. [updated March, 2011]. The Cochrane Collaboration. 2011.
51 Sutton AJ, Abrams KR, Jones DR, et al. Methods for Meta-Analysis in Medical Research. (Wiley Series in Probability and Statistics - Applied Probability and Statistics Section). London. Wiley. 2000.
52 Lewis S, Clarke M. Forest plots: trying to see the wood and the trees. BMJ. Jun. 16. 2001;322(7300):1479-80. [pmid: 11408310].
53 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
54 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
55 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.2. The Cochrane Collaboration. Updated September 2009. www.cochrane-handbook.org.
56 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions -- Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
57 Atkins D, Chang S, Gartlehner G, et al. Chapter 6. Assessing the Applicability of Studies When Comparing Medical Interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011:70-80.
58 Seale JP, Boltri JM, Shellenberger S, et al. Primary care validation of a single screening question for drinkers. J Stud Alcohol. Sep. 2006;67(5):778-84. [pmid: 16847548].
59 Berks J, McCormick R. Screening for alcohol misuse in elderly primary care patients: a systematic literature review. Int Psychogeriatr. Dec. 2008;20(6):1090-103. [pmid: 18538045].
60 Bradley KA, Boyd-Wickizer J, Powell SH, et al. Alcohol screening questionnaires in women: a critical review. JAMA. Jul. 8. 1998;280(2):166-71. [pmid: 9669791].
61 Burns E, Gray R, Smith LA. Brief screening questionnaires to identify problem drinking during pregnancy: a systematic review. Addiction. Apr. 2010;105(4):601-14. [pmid: 20403013].
62 Fiellin DA, Reid MC, O'Connor PG. Screening for alcohol problems in primary care: a systematic review. Arch Intern Med. Jul. 10. 2000;160(13):1977-89. [pmid: 10888972].
63 Berner MM, Kriston L, Bentele M, et al. The alcohol use disorders identification test for detecting at-risk drinking: a systematic review and meta-analysis. J Stud Alcohol Drugs. May. 2007;68(3):461-73. [pmid: 17446987].
64 Bradley KA, DeBenedetti AF, Volk RJ, et al. AUDIT-C as a brief screen for alcohol misuse in primary care. Alcohol Clin Exp Res. Jul. 2007;31(7):1208-17. [pmid: 17451397].
65 Taj N, Devera-Sales A, Vinson DC. Screening for problem drinking: does a single question work?. The Journal of family practice. Apr. 1998;46(4):328-35. [pmid: 9564375].
66 Bradley KA, Bush KR, Epler AJ, et al. Two brief alcohol-screening tests From the Alcohol Use Disorders Identification Test (AUDIT): validation in a female Veterans Affairs patient population. Arch Intern Med. Apr. 14. 2003;163(7):821-9. [pmid: 12695273].
67 Williams R, Vinson DC. Validation of a single screening question for problem drinking. The Journal of family practice. Apr. 2001;50(4):307-12. [pmid: 11300981].
68 Sobell LC, Sobell MB. Timeline Follow-back: A technique for assessing self-reported ethanol consumption. Allen J, Litten RZ, editors. Measuring Alcohol Consumption: Psychological and Biological Methods. Totowa, NJ. Humana Press. 1992:41-72.
69 Volk RJ, Steinbauer JR, Cantor SB, et al. The Alcohol Use Disorders Identification Test (AUDIT) as a screen for at-risk drinking in primary care patients of different racial/ethnic backgrounds. Addiction. Feb. 1997;92(2):197-206. [pmid: 9158231].
70 Bradley KA, Bush KR, McDonell MB, et al. Screening for problem drinking: comparison of CAGE and AUDIT. Ambulatory Care Quality Improvement Project (ACQUIP). Alcohol Use Disorders Identification Test. J Gen Intern Med. Jun. 1998;13(6):379-88. [pmid: 9669567].
71 Bush K, Kivlahan DR, McDonell MB, et al. The AUDIT alcohol consumption questions (AUDIT-C): an effective brief screening test for problem drinking. Ambulatory Care Quality Improvement Project (ACQUIP). Alcohol Use Disorders Identification Test. Arch Intern Med. Sep. 14. 1998;158(16):1789-95. [pmid: 9738608].
72 Steinbauer JR, Cantor SB, Holzer CE 3rd, et al. Ethnic and sex bias in primary care screening tests for alcohol use disorders. Ann Intern Med. Sep. 1. 1998;129(5):353-62. [pmid: 9735062].
73 Babor TF, Steinberg K, Anton R, et al. Talk is cheap: measuring drinking outcomes in clinical trials. J Stud Alcohol. Jan. 2000;61(1):55-63. [pmid: 10627097].
74 Beich A, Gannik D, Malterud K. Screening and brief intervention for excessive alcohol use: qualitative interview study of the experiences of general practitioners. BMJ. Oct. 19. 2002;325(7369):870. [pmid: 12386040].
75 Rumpf HJ, Hapke U, Meyer C, et al. Screening for alcohol use disorders and at-risk drinking in the general population: psychometric performance of three questionnaires. Alcohol Alcohol. May-Jun. 2002;37(3):261-8. [pmid: 12003915].
76 Philpot M, Pearson N, Petratou V, et al. Screening for problem drinking in older people referred to a mental health service: a comparison of CAGE and AUDIT. Aging Ment Health. May. 2003;7(3):171-5. [pmid: 12775396].
77 Babor TF, Higgins-Biddle JC, Saunders JB, et al. The Alcohol Use Disorders Identification Test: Guidelines for Use in Primary Health Care. Second ed. Geneva. World Health Organization. 2001.
78 Samet JH, O'Connor PG. Alcohol abusers in primary care: readiness to change behavior. Am J Med. Oct. 1998;105(4):302-6. [pmid: 9809691].
79 Rubinsky AD, Kivlahan DR, Volk RJ, et al. Estimating risk of alcohol dependence using alcohol screening scores. Drug Alcohol Depend. Apr. 1. 2010;108(1-2):29-36. [pmid: 20042299].
80 World Health Organization. The ASSIST project - Alcohol, Smoking and Substance Involvement Screening Test. www.who.int/substance_abuse/activities/assist/en/index.html. Jan 14, 2012.
81 The Alcohol Smoking and Substance Involvement Screening Test (ASSIST): development, reliability and feasibility. Addiction. Sep. 2002;97(9):1183-94. [pmid: 12199834].
82 Rumpf HJ, Hapke U, Hill A, et al. Development of a screening questionnaire for the general hospital and general practices. Alcohol Clin Exp Res. Aug. 1997;21(5):894-8. [pmid: 9267540].
83 Richmond R, Heather N, Wodak A, et al. Controlled evaluation of a general practice-based brief intervention for excessive drinking. Addiction. Jan. 1995;90(1):119-32. [pmid: 7888970].
84 World Health Organization Brief Interventions Study Group. A cross-national trial of brief interventions with heavy drinkers. WHO Brief Intervention Study Group. Am J Public Health. Jul. 1996;86(7):948-55. [pmid: 8669518].
85 Senft RA, Polen MR, Freeborn DK, et al. Brief intervention in a primary care setting for hazardous drinkers. Am J Prev Med. Nov-Dec. 1997;13(6):464-70. [pmid: 9415794].
86 Saitz R, Horton NJ, Sullivan LM, et al. Addressing alcohol problems in primary care: a cluster randomized, controlled trial of a systems intervention. The screening and intervention in primary care (SIP) study. Ann Intern Med. Mar. 4. 2003;138(5):372-82. [pmid: 12614089].
87 Fleming MF, Balousek SL, Grossberg PM, et al. Brief physician advice for heavy drinking college students: a randomized controlled trial in college health clinics. J Stud Alcohol Drugs. Jan. 2010;71(1):23-31. [pmid: 20105410].
88 Grossberg PM, Brown DD, Fleming MF. Brief physician advice for high-risk drinking among young adults. Ann Fam Med. Sep-Oct. 2004;2(5):474-80. [pmid: 15506584].
89 Rubio G, Jimenez-Arriero MA, Martinez I, et al. Efficacy of physician-delivered brief counseling intervention for binge drinkers. Am J Med. Jan. 2010;123(1):72-8. [pmid: 20102995].
90 Bischof G, Grothues JM, Reinhardt S, et al. Evaluation of a telephone-based stepped care intervention for alcohol-related disorders: a randomized controlled trial. Drug Alcohol Depend. Mar. 1. 2008;93(3):244-51. [pmid: 18054443].
91 Noknoy S, Rangsin R, Saengcharnchai P, et al. RCT of effectiveness of motivational enhancement therapy delivered by nurses for hazardous drinkers in primary care units in Thailand. Alcohol Alcohol. May-Jun. 2010;45(3):263-70. [pmid: 20236990].
92 Anderson P, Scott E. The effect of general practitioners' advice to heavy drinking men. Br J Addict. 1992;6:891-900. [pmid: 1525531].
93 Grothues JM, Bischof G, Reinhardt S, et al. Effectiveness of brief alcohol interventions for general practice patients with problematic drinking behavior and comorbid anxiety or depressive disorders. Drug Alcohol Depend. Apr. 1. 2008;94(1-3):214-20. [pmid: 18207336].
94 Reinhardt S, Bischof G, Grothues J, et al. Gender differences in the efficacy of brief interventions with a stepped care approach in general practice patients with alcohol-related disorders. Alcohol Alcohol. May-Jun. 2008;43(3):334-40. [pmid: 18263901].
95 Curry SJ, Ludman EJ, Grothaus LC, et al. A randomized trial of a brief primary-care-based intervention for reducing at-risk drinking practices. Health Psychol. Mar. 2003;22(2):156-65. [pmid: 12683736].
96 Fleming MF, Barry KL, Manwell LB, et al. Brief physician advice for problem alcohol drinkers. A randomized controlled trial in community-based primary care practices. JAMA. Apr. 2. 1997;277(13):1039-45. [pmid: 9091691].
97 Fleming MF, Mundt MP, French MT, et al. Benefit-cost analysis of brief physician advice with problem drinkers in primary care settings. Med Care. Jan. 2000;38(1):7-18. [pmid: 10630716].
98 Fleming MF, Mundt MP, French MT, et al. Brief physician advice for problem drinkers: long-term efficacy and benefit-cost analysis. Alcohol Clin Exp Res. Jan. 2002;26(1):36-43. [pmid: 11821652].
99 Manwell LB, Fleming MF, Mundt MP, et al. Treatment of problem alcohol use in women of childbearing age: results of a brief intervention trial. Alcohol Clin Exp Res. Oct. 2000;24(10):1517-24. [pmid: 11045860].
100 Fleming MF, Lund MR, Wilton G, et al. The Healthy Moms Study: the efficacy of brief alcohol intervention in postpartum women. Alcohol Clin Exp Res. Sep. 2008;32(9):1600-6. [pmid: 18627361].
101 Wilton G, Moberg DP, Fleming MF. The effect of brief alcohol intervention on postpartum depression. MCN Am J Matern Child Nurs. Sep-Oct. 2009;34(5):297-302. [pmid: 19713798].
102 Lock CA, Kaner E, Heather N, et al. Effectiveness of nurse-led brief alcohol intervention: a cluster randomized controlled trial. J Adv Nurs. May. 2006;54(4):426-39. [pmid: 16671972].
103 Maisto SA, Conigliaro J, McNeil M, et al. Effects of two types of brief intervention and readiness to change on alcohol use in hazardous drinkers. J Stud Alcohol. Sep. 2001;62(5):605-14. [pmid: 11702799].
104 Maisto SA, Conigliaro J, McNeil M, et al. The relationship between eligibility criteria for participation in alcohol brief intervention trials and other alcohol and health-related variables. Am J Addict. Summer. 2001;10(3):218-31. [pmid: 11579620].
105 Gordon AJ, Conigliaro J, Maisto SA, et al. Comparison of consumption effects of brief interventions for hazardous drinking elderly. Subst Use Misuse. Jun. 2003;38(8):1017-35. [pmid: 12901447].
106 Ockene JK, Adams A, Hurley TG, et al. Brief physician- and nurse practitioner-delivered counseling for high-risk drinkers: does it work?. Arch Intern Med. Oct. 11. 1999;159(18):2198-205. [pmid: 10527297].
107 Ockene JK, Reed GW, Reiff-Hekking S. Brief patient-centered clinician-delivered counseling for high-risk drinking: 4-year results. Ann Behav Med. Jun. 2009;37(3):335-42. [pmid: 19707840].
108 Reiff-Hekking S, Ockene JK, Hurley TG, et al. Brief physician and nurse practitioner-delivered counseling for high-risk drinking. Results at 12-month followup. J Gen Intern Med. Jan. 2005;20(1):7-13. [pmid: 15693921].
109 Scott E, Anderson P. Randomized controlled trial of general practitioner intervention in women with excessive alcohol consumption. Drug Alcohol Rev. 1990;10(4):313-21. [pmid: 16818295].
110 Freeborn DK, Polen MR, Hollis JF, et al. Screening and brief intervention for hazardous drinking in an HMO: effects on medical care utilization. J Behav Health Serv Res. Nov. 2000;27(4):446-53. [pmid: 11070638].
111 Wallace P, Cutler S, Haines A. Randomised controlled trial of general practitioner intervention in patients with excessive alcohol consumption. BMJ. Sep. 10. 1988;297(6649):663-8. [pmid: 3052668].
112 Fleming MF, Manwell LB, Barry KL, et al. Brief physician advice for alcohol problems in older adults: a randomized community-based trial. J Fam Pract. May. 1999;48(5):378-84. [pmid: 10334615].
113 Mundt MP, French MT, Roebuck MC, et al. Brief physician advice for problem drinking among older adults: an economic analysis of costs and benefits. J Stud Alcohol. May. 2005;66(3):389-94. [pmid: 16047528].
114 Lin JC, Karno MP, Tang L, et al. Do health educator telephone calls reduce at-risk drinking among older adults in primary care?. J Gen Intern Med. 2010;25(4):334-9. [pmid: 20101471].
115 Moore AA, Blow FC, Hoffing M, et al. Primary care-based intervention to reduce at-risk drinking in older adults: a randomized controlled trial. Addiction. Jan. 2011;106(1):111-20. [pmid: 21143686].
116 Kypri K, Langley JD, Saunders JB, et al. Randomized controlled trial of web-based alcohol screening and brief intervention in primary care. Arch Intern Med. Mar. 10. 2008;168(5):530-6. [pmid: 18332300].
117 Kypri K, Langley JD, Saunders JB, et al. Assessment may conceal therapeutic benefit: findings from a randomized controlled trial for hazardous drinking. Addiction. Jan. 2007;102(1):62-70. [pmid: 17207124].
118 Kypri K, Saunders JB, Williams SM, et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. Nov. 2004;99(11):1410-7. [pmid: 15500594].
119 Schaus JF, Sole ML, McCoy TP, et al. Alcohol screening and brief intervention in a college student health center: a randomized controlled trial. J Stud Alcohol Drugs Suppl. Jul. 2009;(16):131-41. [pmid: 19538921].
120 Chang G, Wilkins-Haug L, Berman S, et al. Brief intervention for alcohol use in pregnancy: a randomized trial. Addiction. Oct. 1999;94(10):1499-508. [pmid: 10790902].
121 Stade BC, Bailey C, Dzendoletas D, et al. Psychological and/or educational interventions for reducing alcohol consumption in pregnant women and women planning pregnancy. Cochrane Database Syst Rev. 2009;(2):CD004228. [pmid: 19370597].
122 Handmaker NS, Miller WR, Manicke M. Findings of a pilot study of motivational interviewing with pregnant drinkers. J Stud Alcohol. Mar. 1999;60(2):285-7. [pmid: 10091968].
123 Reynolds KD, Coombs DW, Lowe JB, et al. Evaluation of a self-help program to reduce alcohol consumption among pregnant women. Int J Addict. Mar. 1995;30(4):427-43. [pmid: 7607777].
124 O'Connor MJ, Whaley SE. Brief intervention for alcohol use by pregnant women. Am J Public Health. Feb. 2007;97(2):252-8. [pmid: 17194863].
125 Armstrong MA, Kaskutas LA, Witbrodt J, et al. Using drink size to talk about drinking during pregnancy: a randomized clinical trial of Early Start Plus. Soc Work Health Care. Jan. 2009;48(1):90-103. [pmid: 19197768].
126 Budd KW, Ross-Alaolmolki K, Zeller RA. Two prenatal alcohol use screening instruments compared with a physiologic measure. J Obstet Gynecol Neonatal Nurs. Mar-Apr. 2000;29(2):129-36. [pmid: 10750678].
127 Bull LB, Kvigne VL, Leonardson GR, et al. Validation of a self-administered questionnaire to screen for prenatal alcohol use in Northern Plains Indian women. Am J Prev Med. Apr. 1999;16(3):240-3. [pmid: 10198664].
128 Chang G, Goetz MA, Wilkins-Haug L, et al. A brief intervention for prenatal alcohol use: an in-depth look. J Subst Abuse Treat. Jun. 2000;18(4):365-9. [pmid: 10812310].
129 Chang G, Goetz MA, Wilkins-Haug L, et al. Identifying prenatal alcohol use: screening instruments versus clinical predictors. Am J Addict. Spring. 1999;8(2):87-93. [pmid: 10365188].
130 Chang G, Wilkins-Haug L, Berman S, et al. Alcohol use and pregnancy: improving identification. Obstet Gynecol. Jun. 1998;91(6):892-8. [pmid: 9610992].
131 Chang G, McNamara TK, Orav EJ, et al. Brief intervention for prenatal alcohol use: a randomized trial. Obstet Gynecol. May. 2005;105(5 Pt 1):991-8. [pmid: 15863535].
132 Chang G, McNamara TK, Orav EJ, et al. Brief intervention for prenatal alcohol use: the role of drinking goal selection. J Subst Abuse Treat. Dec. 2006;31(4):419-24. [pmid: 17084796].
133 Floyd RL, Sobell M, Velasquez MM, et al. Preventing alcohol-exposed pregnancies: a randomized controlled trial. Am J Prev Med. Jan. 2007;32(1):1-10. [pmid: 17218187].
134 Flynn HA, Marcus SM, Barry KL, et al. Rates and correlates of alcohol use among pregnant women in obstetrics clinics. Alcohol Clin Exp Res. Jan. 2003;27(1):81-7. [pmid: 12544010].
135 Grant TM, Ernst CC, Streissguth A, et al. Preventing alcohol and drug exposed births in Washington state: intervention findings from three parent-child assistance program sites. Am J Drug Alcohol Abuse. 2005;31(3):471-90. [pmid: 16161730].
136 Meberg A, Halvorsen B, Holter B, et al. Moderate alcohol consumption--need for intervention programs in pregnancy?. Acta Obstet Gynecol Scand. 1986;65(8):861-4. [pmid: 3825527].
137 Centers for Disease Control and Prevention. Motivational intervention to reduce alcohol-exposed pregnancies--Florida, Texas, and Virginia, 1997-2001. MMWR Morb Mortal Wkly Rep. May. 16. 2003;52(19):441-4. [pmid: 12807086].
138 Halmesmaki E. Alcohol counselling of 85 pregnant problem drinkers: effect on drinking and fetal outcome. Br J Obstet Gynaecol. Mar. 1988;95(3):243-7. [pmid: 3370196].
139 Waterson EJ, Murray-Lyon IM. Preventing alcohol related birth damage: a review. Soc Sci Med. 1990;30(3):349-64. [pmid: 2408151].
140 Johnson M, Jackson R, Guillaume L, et al. Barriers and facilitators to implementing screening and brief intervention for alcohol misuse: a systematic review of qualitative evidence. J Public Health (Oxf). Sep. 2011;33(3):412-21. [pmid: 21169370].
141 Saitz R, Horton NJ, Cheng DM, et al. Alcohol counseling reflects higher quality of primary care. J Gen Intern Med. Sep. 2008;23(9):1482-6. [pmid: 18618204].
142 Saitz R. Alcohol screening and brief intervention in primary care: Absence of evidence for efficacy in people with dependence or very heavy drinking. Drug Alcohol Rev. Nov. 2010;29(6):631-40. [pmid: 20973848].
143 Miller WR, Walters ST, Bennett ME. How effective is alcoholism treatment in the United States?. J Stud Alcohol. Mar. 2001;62(2):211-20. [pmid: 11327187].
144 Maisto SA, Clifford PR, Stout RL, et al. Drinking in the year after treatment as a predictor of three-year drinking outcomes. J Stud Alcohol. Nov. 2006;67(6):823-32. [pmid: 17060998].
145 O'Brien CP, McLellan AT. Myths about the treatment of addiction. Lancet. Jan. 27. 1996;347(8996):237-40. [pmid: 8551886].
146 Kranzler HR, Van Kirk J. Efficacy of naltrexone and acamprosate for alcoholism treatment: a meta-analysis. Alcohol Clin Exp Res. Sep. 2001;25(9):1335-41. [pmid: 11584154].
147 Del Boca FK, Noll JA. Truth or consequences: the validity of self-report data in health services research on addictions. Addiction. Nov. Suppl 3. 2000;95:S347-60. [pmid: 11132362].