# Peer Reviewers

Peer Reviewers are invited to provide written comments on the draft report based on their clinical, content, or methodologic expertise. Peer review comments on the preliminary draft of the report are considered by the EPC in preparation of the final draft of the report. Peer Reviewers do not participate in writing or editing of the final report or other products. The synthesis of the scientific literature presented in the final report does not necessarily represent the views of individual reviewers. The dispositions of the peer review comments are documented and will, for CERs and Technical briefs, be published 3 months after the publication of the Evidence Report.

Potential reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Invited Peer Reviewers may not have any financial conflict of interest greater than $10,000. Peer Reviewers who disclose potential business or professional conflicts of interest may submit comments on draft reports through the public comment mechanism.

Susan Curry, Ph.D. *

* Member of the U.S. Preventive Services Task Force

University of Iowa

Iowa City, IA

John Higgins-Biddle, Ph.D.

University of Connecticut (ret.)

Bethany, CT

Stephen Holt, M.D., M.S.

Yale University

New Haven CT

Bonnie McRee, M.P.H.

University of Connecticut

Farmington, CT

Jennifer Mertens, Ph.D.

Kaiser Permanente Northern California Division of Research

Oakland, CA

Richard Saitz, M.D., M.P.H.

Boston University

Boston, MA

John B. Saunders, M.D., F.R.A.C.P.

University of Queensland; Prince Charles Hospital; and Royal Brisbane Hospital

Queensland, Australia