# Technical Expert Panel

Technical Experts comprise a multidisciplinary group of clinical, content, and methodologic experts who provide input in defining populations, interventions, comparisons, or outcomes as well as identifying particular studies or databases to search. They are selected to provide broad expertise and perspectives specific to the topic under development. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, study questions, design, and/or methodological approaches do not necessarily represent the views of individual technical and content experts. Technical Experts provide information to the EPC to identify literature search strategies and recommend approaches to specific issues as requested by the EPC. Technical Experts do not do analysis of any kind nor contribute to the writing of the report and have not reviewed the report, except as given the opportunity to do so through the peer or public review mechanism

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals are invited to serve as Technical Experts, and those who present with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

David Boyd, M.D.C.M., F.A.C.S.

Indian Health Service

Rockville, MD

No potential conflict of interest reported.

Susan Curry, Ph.D.^*^;

* Member of the U.S. Preventive Services Task Force

University of Iowa

Iowa City, IA

No potential conflict of interest reported.

Michael Fleming, M.D., M.P.H.

Northwestern University

Evanston, IL

No potential conflict of interest reported.

Shelly Greenfield, M.D., M.P.H.

Harvard University

Cambridge, MA

No potential conflict of interest reported.

Joy Melnikow, M.D., M.P.H. *

University of California at Davis

Davis, CA

No potential conflict of interest reported.

Richard Saitz, M.D., M.P.H.

Boston University

Boston, MA

Dr. Saitz coined the term “unhealthy alcohol use” as a way to describe the spectrum of alcohol problems, in an article in the New England Journal of Medicine.

Evelyn Whitlock, M.D., M.P.H.

Oregon Evidence-based Practice Center

Portland, OR

No potential conflict of interest reported.