# Key Informants

Key Informants are the end users of research, including patients and caregivers, practicing clinicians, relevant professional and consumer organizations, purchasers of health care, and others with experience in making health care decisions. Within the EPC program, the Key Informant role is to provide input into identifying the Key Questions for research that will inform health care decisions. The EPC solicits input from Key Informants when developing questions for systematic review or when identifying high-priority research gaps and needed new research. Key Informants are not involved in analyzing the evidence or writing the report and have not reviewed the report, except as given the opportunity to do so through the peer or public review mechanism.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end users, individuals are invited to serve as Key Informants and those who present with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

David Boyd, M.D.C.M., F.A.C.S.

Indian Health Service

Rockville, MD

No potential conflict of interest reported.

Susan Curry, Ph.D. *

* Member of the U.S. Preventive Services Task Force

University of Iowa

Iowa City, IA

No potential conflict of interest reported.

Michael Fleming, M.D., M.P.H.

Northwestern University

Evanston, IL

No potential conflict of interest reported.

Shelly Greenfield, M.D., M.P.H.

Harvard University

Cambridge, MA

No potential conflict of interest reported.

Joy Melnikow, M.D., M.P.H. *

University of California at Davis

Davis, CA

No potential conflict of interest reported.

Richard Saitz, M.D., M.P.H.

Boston University

Boston, MA

Dr. Saitz coined the term “unhealthy alcohol use” as a way to describe the spectrum of alcohol problems, in an article in the New England Journal of Medicine.

Evelyn Whitlock, M.D., M.P.H.

Oregon Evidence-based Practice Center

Portland, OR

No potential conflict of interest reported.