# Executive Summary

## Background

Alcohol misuse, which includes the full spectrum from drinking above recommended limits (i.e., risky/hazardous drinking) to alcohol dependence,1-3 is associated with numerous health and social problems and more than 85,000 deaths per year in the United States 1, 4 and an estimated annual cost to society of more than $220 billion.5, 6 Alcohol misuse is estimated to be the third leading cause of preventable mortality in the United States following tobacco use and being overweight.7 Alcohol misuse contributes to a variety of conditions, including hypertension, cirrhosis, gastritis and gastric ulcers, pancreatitis, breast cancer, neuropathy, cardiomyopathy, anemia, osteoporosis, cognitive impairment, depression, insomnia, anxiety, and suicide.8, 9 Excessive alcohol consumption is a major factor in injury and violence.10

Definitions of the spectrum of alcohol misuse (i.e., unhealthy alcohol use3) continue to evolve. For the purposes of this report, we use the definitions described in Table A.

Table A Definitions of the spectrum of alcohol misuse

Term | Definition
Risky or hazardous use | Consumption of alcohol above recommended daily, weekly, or per occasion amounts.1 Consumption levels that increase the risk for health consequences.
Harmful use11, 12 | A pattern of drinking that is already causing damage to health. The damage may be either physical (e.g., liver damage from chronic drinking) or mental (e.g., depressive episodes secondary to drinking)
Alcohol abuse13 | A. A maladaptive pattern of alcohol use leading to clinically significant impairment or distress, as manifested by one (or more) of the following, occurring within a 12-month period:; 1. Recurrent alcohol use resulting in a failure to fulfill major role obligations at work, school, or home (e.g., repeated absences or poor work performance related to alcohol use; alcohol-related absences, suspensions, or expulsions from school; neglect of children or household);; 2. Recurrent alcohol use in situations in which it is physically hazardous (e.g., driving an automobile or operating a machine when impaired);; 3. Recurrent alcohol-related legal problems (e.g., arrests for alcohol-related disorderly conduct); or; 4. Continued alcohol use despite having persistent or recurrent social or interpersonal problems caused or exacerbated by the effects of alcohol (e.g., arguments with spouse about consequences of intoxication, physical fights).; B. The symptoms have never met the criteria for alcohol dependence.
Alcohol dependence13 (alcoholism, alcohol addiction) | A maladaptive pattern of alcohol use, leading to clinically significant impairment or distress, as manifested by three (or more) of the following, occurring at any time in the same 12-month period:; 1. Tolerance, as defined by either of the following:; a. A need for markedly increased amounts of alcohol to achieve intoxication or desired effect; b. Markedly diminished effect with continued use of the same amount of alcohol; 2. Withdrawal, as manifested by either of the following:; a. The characteristic withdrawal syndrome for alcohol; b. Alcohol (or a closely related drug) is taken to relieve or avoid withdrawal symptoms; 3. Alcohol is often taken in larger amounts or over a longer period than was intended;; 4. There is a persistent desire or unsuccessful efforts to cut down or control alcohol use;; 5. A great deal of time is spent in activities necessary to obtain alcohol, use alcohol, or recover from its effects;; 6. Important social, occupational, or recreational activities are given up or reduced because of alcohol use;; 7. Alcohol use is continued despite knowledge of having a persistent or recurrent physical or psychological problem that is likely to have been caused or exacerbated by alcohol (e.g., continued drinking despite recognition that an ulcer was made worse by alcohol consumption).

Though estimating the prevalence of alcohol misuse is challenging, it has been estimated that about 30 percent of the U.S. population is affected, with the majority of these individuals engaging in what is considered risky drinking.3 Older studies report a range of risky drinkers from 4 to 29 percent across primary care populations, with prevalence estimates of 0.3 to 10.0 percent for harmful drinkers and 2.0 to 9.0 percent for alcohol dependence.14 More recent data from the American Academy of Family Physicians National Research Network reveal that 21.3 percent of primary care patients reported risky/hazardous drinking (based on the three quantity and frequency questions from the Alcohol Use Disorders Identification Test [AUDIT-C]).15 Alcohol dependence has lifetime prevalence rates on the order of 17 percent for men and 8 percent for women;16 prevalence of current dependence (within the last 12 months and as defined by the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition [DSM-IV]) is approximately 4 percent in the general adult population.17 Some studies have reported that one in five of those who screen positive for unhealthy alcohol use in primary care will have alcohol dependence (four in five will not).18, 19 Rates of alcohol-use disorders among medical outpatients are similar to those seen in the general population and are generally higher in males and younger people of all races/ethnicities.14, 20

The National Institute on Alcohol Abuse and Alcoholism (NIAAA) has proposed epidemiologically based alcohol-use guidelines to limit risks for drinking-related consequences by establishing age- and sex-specific recommended consumption thresholds.21 Maximum recommended consumption is three or fewer standard drinks per day (seven per week) for adult women and for anyone older than 65 years of age, and four or fewer standard drinks per day (14 per week) for adult men. A standard drink is defined as one 12-ounce bottle of beer, one 5-ounce glass of wine, or 1.5 ounces of distilled spirits.22, 23 These guidelines do not apply to certain people (such as adolescents, pregnant women, and people with alcohol dependence or medical conditions or medication use) for whom alcohol intake is contraindicated, or to circumstances (driving) in which no consumption is considered safe.

## Screening and Behavioral Counseling

Several screening questionnaires can be used to identify alcohol misuse. The most commonly studied instruments include AUDIT and its abbreviated versions (e.g., the AUDIT-C), the CAGE questionnaire (Cut-down, Annoyed, Guilty, Eye-opener), the Michigan Alcoholism Screening Test (MAST), and versions of the single-question screen.

Behavioral interventions and patient education are often used for patients who engage in less severe alcohol misuse (i.e., risky/hazardous drinking).1 Brief interventions, as shown in Table B, generally aim to moderate a patient's alcohol consumption to sensible levels and eliminate risky drinking practices, rather than insist on complete abstinence.

Table B What are brief behavioral counseling interventions delivered in primary care settings?

- Behavioral counseling interventions include the range of personal counseling and related behavior-change interventions that are employed in primary care to help patients change health-related behaviors.24; - Counseling here denotes a cooperative mode of work demanding active participation from both patient and clinician that aims to facilitate the patient's independent initiative.24; - SAMHSA defines brief intervention as “a single session or multiple sessions of motivational discussion focused on increasing insight and awareness regarding substance use and motivation toward behavioral change.”25; - Range from very brief interventions within a primary care visit to multicontact interventions that entail multiple, often more lengthy, visits and nonvisit contacts over an extended period.1; - Can include the following elements: advice, feedback, motivational interviews of varying length and number, or cognitive behavioral strategies (e.g., self-completed action plans, written health education or self-help materials, drinking diaries, problem-solving exercises to complete at home).

SAMHSA = Substance Abuse and Mental Health Services Administration

The assumption underlying brief behavioral counseling interventions in primary care is that, for identified risky drinkers, reducing overall alcohol consumption or adopting safer drinking patterns (that is, fewer drinks per occasion and not drinking before driving) will reduce the risk for medical, social, and psychological problems.26 Cross-sectional and cohort studies have consistently related high average alcohol consumption to short- or long-term health consequences.23, 27 A meta-analysis of studies examining the association between all-cause mortality and average alcohol consumption found that men averaging at least four drinks per day and women averaging two or more drinks per day experienced significantly increased mortality relative to nondrinkers.28 Studies also relate heavy per-occasion alcohol use (i.e., binge drinking) to acute injury risks and alcohol-related life problems.23, 27

The NIAAA and others encourage physicians to identify patients with alcohol-related risks or problems and to provide office-based brief interventions or referrals as needed.21, 29, 30 In everyday practice, screening and screening-related assessment procedures are necessary to identify the range of alcohol users in order to offer appropriate interventions.31, 32

Even so, few primary care clinicians use recommended screening protocols or offer screening and interventions, and rates of intervening for alcohol misuse remain low.32 Most patients who misuse alcohol receive care from their primary care provider, where they represent as much as one-fifth of patients seen, a proportion similar to that seen for diabetes and hypertension.9, 14

In 2004, the U.S. Preventive Services Task Force (USPSTF) developed recommendations for screening and behavioral counseling interventions in primary care to reduce alcohol misuse.33 The summary of the recommendations states:

- The USPSTF recommends screening and behavioral counseling interventions to reduce alcohol misuse by adults, including pregnant women, in primary care settings. Grade: B Recommendation (i.e., the USPSTF recommends that clinicians provide the service to eligible patients. The USPSTF found at least fair evidence that the service improves important health outcomes and concludes that benefits outweigh harms).
- The USPSTF concludes that the evidence is insufficient to recommend for or against screening and behavioral counseling interventions to prevent or reduce alcohol misuse by adolescents in primary care settings. Grade: I Statement (insufficient evidence to make a recommendation).

## Objective

This report's main objective is to conduct a systematic review of the effectiveness of screening followed by behavioral counseling, with or without referral, for alcohol misuse in primary care settings, addressing seven questions (Table C). This new review differs from the report on which the USPSTF 2004 recommendations were based in the following ways: We allowed inclusion of screening and behavioral interventions for the full spectrum of alcohol misuse, as long as subjects were identified by screening in a primary care or primary care-like setting; we added referral as an intervention of interest and changed the title to reflect this; we expanded the eligible settings from traditional primary care to also include settings with primary care-like relationships (e.g., infectious disease clinics for people with HIV); and we added additional outcomes of interest to our inclusion/exclusion criteria and analytic framework (Figure A).

Table C Key Questions addressed by this review

KQ 1 What is the direct evidence that screening for alcohol misuse followed by a behavioral counseling intervention, with or without referral, leads to reduced morbidity, reduced mortality, or changes in other long-term (6 months or longer) outcomes (e.g., health care utilization, sick days, costs, legal issues, employment stability)?; KQ 2 How do specific screening modalities compare with one another for detecting alcohol misuse?; KQ 3 What adverse effects are associated with screening for alcohol misuse and screening-related assessment?; KQ 4a How do behavioral counseling interventions, with or without referral, compare with usual care for improving intermediate outcomes for people with alcohol misuse as identified by screening?; KQ 4b How do specific behavioral counseling approaches, with or without referral, compare with one another for improving intermediate outcomes for people with alcohol misuse as identified by screening?; KQ 5 What adverse effects are associated with behavioral counseling interventions, with or without referral, for people with alcohol misuse as identified by screening?; KQ 6 How do behavioral counseling interventions, with or without referral, compare with one another and with usual care for reducing morbidity, reducing mortality, or changing other long-term (6 months or longer) outcomes (e.g., health care utilization, sick days, costs, legal issues, employment stability) for people with alcohol misuse as identified by screening?; KQ 7 To what extent do health care system influences promote or hinder effective screening and interventions for alcohol misuse?

KQ = Key Question

Note: Intermediate outcomes eligible for this report included the following: Rates of alcohol use (e.g., drinks per week, grams of alcohol per week), heavy drinking episodes, achieving recommended drinking limits, receipt of and followup with referrals, and abstinence from any use of alcohol (of greatest interest for pregnant women and adolescents).

Figure A Analytic framework for screening, behavioral counseling, and referral in primary care to reduce alcohol misuse

KQ = Key Question

Figure A is titled “Analytic framework for screening, behavioral counseling, and referral in primary care to reduce alcohol misuse.” The framework begins on the left with our patient population of interest: adolescents and adults. We also specify the following subgroups of interest: college students, older adults (age 65 or older), veterans, pregnant women, racial or ethnic minorities, those with co-occurring mental health or chronic medical conditions, and those with varying severity of alcohol problems. An arrow with the word “screening” goes from the population on the left to a box containing the words “alcohol misuse.” “KQ 2” is also above this arrow, to indicate that the second key question focuses on screening instruments for alcohol misuse. A curvy arrow labeled “KQ 3” descends from the “screening” arrow to an elliptical shape with the words “adverse effects of screening” to illustrate the focus of KQ 3. Another arrow goes from the “alcohol misuse” box to the right to an “intermediate outcomes” box, with the words “intervention” and “KQ 4”. A curvy arrow labeled “KQ 5” descends from this “intervention” arrow to an elliptical shape with the words “adverse effects of intervention” to illustrate the focus of KQ 5. A dashed line going to the right connects the “intermediate outcomes” box to a “long-term outcomes” box. The intermediate outcomes include measures of alcohol consumption. The long-term outcomes include all-cause and alcohol-related mortality, alcohol-related morbidity, alcohol-related accidents and injuries, quality of life, health care utilization, sick days, costs, legal issues, and employment stability. KQ 1 is depicted by an overarching arrow that goes all the way from the “screening” arrow on the left to the “long-term outcomes” box. The focus of KQ 6 is depicted by an overarching arrow that goes from the “intervention” arrow to the long-term outcomes. A diamond-shaped kite containing the words “health care system influences” is located near the top of the figure and is connected to the screening and intervention arrows with dashed lines to illustrate the focus of KQ 7.

## Methods

The topic development and refinement processes were guided by the information provided by the topic nominator, a scan of the literature, methods and content experts, and Key Informants. Key Informants and Technical Expert Panel members participated in conference calls and discussions through email to review the analytic framework, Key Questions, search strategy, inclusion/exclusion criteria, research protocol, and to discuss the literature.

We searched MEDLINE^®^, Embase^®^, the Cochrane Library, CINAHL^®^, PsycINFO^®^, and the International Pharmaceutical Abstracts from January 1, 1985, to August 30, 2011. We used either Medical Subject Headings (MeSH) as search terms when available or keywords when appropriate, focusing on terms to describe the relevant population and the screening and behavioral interventions of interest. We limited searches to English-language publications.

We developed inclusion and exclusion criteria with respect to Populations, Interventions, Comparators, Outcomes, Timing, Settings, and study designs (PICOTS). We included studies enrolling adults and/or adolescents (ages 12 years or older) with alcohol misuse identified by screening in primary care settings or settings with a primary care-type relationship.

For Key Question 2, we focused on systematic reviews and meta-analyses, and we did not restrict the publication date. We supplemented the findings with information from other sources to fill in important gaps. For all other Key Questions, we included controlled trials published in 1985 or later and systematic reviews and meta-analyses published in the last 5 years that directly address our Key Questions. Studies of at least 6 months' duration were eligible. For Key Questions 1 and 3, we searched for studies that assigned patients to screening compared with another screening approach, no screening, or usual care. For Key Questions 4, 5, and 6, we searched for studies that assigned subjects that had a positive screening test to an intervention of interest and to at least one eligible comparator. For Key Question 7, studies included in any of the earlier Key Questions were eligible.

All titles and abstracts identified through searches were independently reviewed by two trained members of the research team. Studies marked for possible inclusion by either reviewer were retrieved for full-text review. Each full-text article retrieved was independently reviewed by two trained members of the team for final inclusion/exclusion. If the reviewers disagreed, conflicts were resolved by discussion with an experienced team member.

We designed and used structured data abstraction forms to extract pertinent information from each included article, including characteristics of study populations, settings, interventions, comparators, study designs, methods, and results. All data abstractions were completed by trained reviewers and then reviewed for completeness and accuracy by a second member of the team.

To assess the quality of studies, we used predefined criteria, based on those developed by the USPSTF34 and the University of York Centre for Reviews and Dissemination,35 rating studies as good, fair, or poor. Two independent reviewers assigned quality ratings for each study. Disagreements between the two reviewers were resolved by consulting an experienced member of the team.

When analyzing data for this report, we stratified evidence by population (adults, older adults, young adults/college students, and pregnant women). Quantitative analyses were conducted of outcomes reported by a sufficient number of studies that were homogeneous enough to justify combining their results. We used subgroup analyses to explore whether results differed by intensity, sex, country, provider delivering the intervention, or setting. The chi-squared statistic and the I2 statistic were calculated to assess statistical heterogeneity in effects between studies.36, 37 Heterogeneity was also explored through sensitivity analyses. When quantitative analyses were not appropriate (e.g., because of clinical heterogeneity, insufficient numbers of similar studies, or insufficiency or variation in outcome reporting), we synthesized the data qualitatively.

To assess the differential effects of interventions using more or less time and those using single or multiple contacts, we grouped interventions by intensity of counseling, as measured by duration and number of contacts: very brief (up to 5 minutes, single contact), brief (more than 5 and up to 15 minutes, single contact), extended (beyond 15 minutes, single contact), brief multicontact (each contact up to 15 minutes), and extended multicontact (some contacts beyond 15 minutes).

We graded the strength of evidence (SOE) as high, moderate, low, or insufficient based on established methods guidance.38 Two reviewers assessed each domain for each key outcome, and differences were resolved by consensus. We assessed applicability of the evidence following established methods guidance. We used the PICOTS framework to explore factors that affect applicability.

## Results

We included 44 published articles reporting on 29 studies: 23 randomized controlled trials (RCTs) and 6 meta-analyses or systematic reviews (Figure B). In the 23 included trials, sample sizes ranged from 72 to 1,559, and study duration ranged from 6 to 48 months. Eleven were conducted solely in the United States; 10 took place outside the United States, and the remaining 2 were conducted in a combination of U.S. and non-U.S. sites. We summarize the main findings for each Key Question by population and outcome, and report the SOE for each.

Figure B Disposition of articles

M-A = meta-analysis; PICOTS = populations, interventions, comparators, outcomes, timing, settings or study duration; SR = systematic review

Figure B is titled “Disposition of articles.” The figure is a flow chart that summarizes the search and selection of articles: There were 8,981 citations of randomized trials identified by searching MEDLINE®, Embase®, the Cochrane Library, CINAHL®, PsycINFO®, and the International Pharmaceutical Abstracts databases. In addition, 227 references were identified by searching reference lists of selected articles, and 216 articles were identified by a search of the clinicaltrials.gov database. After removal of duplicate citations, titles and abstracts of 6,265 references were screened for potential inclusion. Of these, 718 were deemed appropriate for full-text review to determine eligibility. After full-text review, 674 were excluded: 9 were in a language other than English; 201 were the wrong type of publication or wrong study design; 448 failed to meet at least one PICOTS element; 10 were deemed poor quality; and 6 were systematic reviews older than 5 years. Forty-four articles representing 29 studies are included in this report's qualitative synthesis and 19 studies are included in quantitative analyses.

### Key Question 1 What is the direct evidence that screening for alcohol misuse followed by a behavioral counseling intervention, with or without referral, leads to reduced morbidity, reduced mortality, or changes in other long-term (6 months or longer) outcomes?

We did not find any studies directly addressing this question.

### Key Question 2 How do specific screening modalities compare with one another for detecting alcohol misuse?

We found adequate evidence that several screening instruments can detect alcohol misuse in adults with acceptable sensitivity and specificity. A single-question screen (covering the past 12 months), AUDIT-C, and AUDIT appear to be the best overall instruments for screening adults for the full spectrum of alcohol misuse in primary care, considering sensitivity, specificity, and time burden. Several instruments require as little as 1 to 2 minutes to administer (e.g., single-question screens, AUDIT-C).

Single-question screens covering the past 12 months have reported sensitivities of 0.82 to 0.87 and specificities of 0.61 to 0.79 for detecting alcohol misuse in adults in primary care.

When focusing on adequately sized U.S. studies that reported sensitivity and specificity of screening for the full spectrum of alcohol misuse in primary care, data suggest that some often recommended cut-points for screening (i.e., AUDIT≥8) may need to be revised. The AUDIT had sensitivity of 0.44 to 0.51 and specificity of 0.96 to 0.97 for identifying alcohol misuse in adults using a cut-point of ≥8; more optimal balance of sensitivity and specificity was seen at cutoffs of 4 or 5. The sensitivity and specificity at a cutoff of ≥4 were 0.84 to 0.85 and 0.77 to 0.84, respectively; and at a cutoff of ≥5 were 0.70 to 0.92 and 0.73 to 0.94, respectively. Further, sex-specific cutoffs may be warranted because sensitivities for women at cutoffs of ≥4 and ≥5 were 0.47 to 0.65 and 0.35 to 0.53, respectively, but improved to 0.70 to 0.79 at ≥3 (with specificity of 0.86 to 0.87).The CAGE has very low sensitivity for detecting risky/hazardous drinking and is therefore not a good screening test for identifying risky/hazardous drinking or for screening for the full spectrum of alcohol misuse.

For young adults and college students, the included systematic reviews identified only one study reporting the sensitivity and specificity of a screening instrument, the full AUDIT (≥8), which had a sensitivity of 0.82 and specificity of 0.78.

For pregnant women, the AUDIT-C performed better than other instruments for detecting both risky drinking and abuse or dependence, demonstrating both high sensitivity (0.95 or higher) and high specificity (up to 0.85).

The reference standard for the screening instruments was a structured diagnostic interview, generally including the timeline followback method39 or similar approaches to determine the quantity/frequency of consumption.

### Key Question 3 What adverse effects are associated with screening for alcohol misuse and screening-related assessment?

We did not find any studies directly addressing this question.

### Key Question 4a How do behavioral counseling interventions, with or without referral, compare with usual care for improving intermediate outcomes for people with alcohol misuse as identified by screening?

Overall, evidence supports the effectiveness of behavioral interventions for improving several intermediate outcomes for adults, older adults, and young adults/college students (moderate or low SOE, depending on the population and outcome). For pregnant women, the one included study40 did not provide evidence of the effectiveness of behavioral interventions for improving intermediate outcomes over 6 months or longer (low or insufficient SOE, depending on the outcome), but it found higher rates of abstinence maintained for the subgroup of subjects who were abstinent pre-assessment for the intervention group compared with the control group. Table D summarizes findings for the three intermediate outcomes most commonly reported, by population. None of the included studies reported followup with referrals as an outcome.

Table D Effectiveness and strength of evidence of behavioral interventions compared with controls for improving intermediate outcomes, by population

Population | Consumption^a^ (Mean Drinks/Week) | Heavy Drinking Episodes^b^ | Recommended Drinking Limits
Adults | Reduction of 3.6 (2.4 to 4.8) from baseline ∼23 Moderate SOE | 12% fewer subjects reported heavy drinking episodes (7%, 16%), from ∼52% at baseline Moderate SOE | 11% more subjects achieved (8%, 13%) Moderate SOE
Older adults | Reduction of 1.7 (0.6 to 2.8) from baseline ∼16 Moderate SOE | Insufficient SOE | 9% more subjects achieved (2%, 16%) Low SOE
Young adults or college students | Reduction of 1.7 (0.7 to 2.6) from baseline ∼15 Moderate SOE c | 0.9 fewer heavy drinking days (0.3, 1.5) from ∼6.2 days per month at baseline Moderate SOE c | Insufficient SOE
Pregnant women | Data from 1 study found no difference Low SOE | Insufficient SOE | Insufficient SOE
Adolescents | Insufficient SOE | Insufficient SOE | Insufficient SOE

SOE = strength of evidence

a Baseline consumption (drinks/week): adults, mean ∼23, median ∼19, range 8 – 62 (data from 16 trials); older adults, 15.2–16.6 (data from 2 trials); young adults/college students, mean ∼15, median ∼17, range 8 – 18 (2 of the 5 trials did not report baseline consumption).

b Heavy drinking generally defined by consumption of 5 or more standard drinks for men and 4 or more for women. Baseline % with heavy drinking episodes: adults, mean ∼52, range 10 – 100.

c These data are 6-month outcomes; for consumption for young adults, we were unable to calculate pooled point estimate for 12-month data, but range of reduction was 1.2 to 4.1 drinks per week at 12 months (moderate SOE); for heavy drinking for young adults, differences were not statistically significant at 12 months (low SOE).

Notes: Data presented are effect size (95% confidence interval) for all interventions regardless of intensity of counseling; the effect sizes for brief multicontact interventions were generally greater than those shown; all outcomes are 12 months unless otherwise indicated with a footnote; all percentages reported are absolute risk differences (difference between intervention and control groups) from our meta-analyses.

Intensity of intervention: Brief multicontact interventions have the best evidence of effectiveness. Our meta-analyses of studies in adults found (a) very brief (up to 5 minutes) single contact interventions to be ineffective for improving consumption (data from 1 very brief intervention study41) and less effective than brief multicontact interventions for achieving recommended drinking limits (data from 1 very brief intervention study42); and (b) brief single-contact interventions to be ineffective for reducing heavy drinking episodes and less effective than brief multicontact interventions for reducing consumption and achieving recommended drinking limits.

Subgroup analyses did not identify differences between men and women. Brief multicontact interventions have the best evidence of effectiveness across populations, outcomes, and have followup data over several years. Our meta-analyses of studies in adults found very brief (up to 5 minutes) and brief (more than 5 minutes, up to 15 minutes) single-contact interventions to be ineffective for some outcomes and less effective than brief multicontact interventions for others.

### Key Question 4b How do specific behavioral counseling approaches, with or without referral, compare with one another for improving intermediate outcomes for people with alcohol misuse as identified by screening?

This Key Question addressed direct, head-to-head evidence comparing more than one specific behavioral intervention approach. We identified four RCTs enrolling adults and one enrolling college students. All five compared different types/intensities of interventions. Overall, head-to-head evidence from the five studies was insufficient to draw firm conclusions about whether specific types of interventions (i.e., different levels of intensity) differ in effectiveness for most intermediate outcomes of interest (insufficient SOE). None of the studies reported a statistically significant difference between the two groups of interest; for a few intermediate outcomes, some studies found no statistically significant difference between interventions (low SOE).

### Key Question 5 What adverse effects are associated with behavioral counseling interventions, with or without referral, for people with alcohol misuse as identified by screening?

We found no evidence of direct harms, aside from opportunity costs associated with the interventions, which ranged from a minimum of 5 minutes to a maximum of approximately 2 hours dispersed over multiple in-person and/or telephone visits (moderate SOE) (Table E).

Table E Adverse effects associated with behavioral counseling interventions compared with controls for adults

Outcome | Results Effect Size (95% CI) | Strength of Evidence
Increased smoking | No difference between groups (unable to calculate effect size). | Low
Opportunity costs/time | Range from about 5 minutes to approximately 2 hours dispersed over multiple in-person and/or telephone visits, depending on planned intervention intensity. | Moderate
Anxiety | No difference between groups (unable to calculate effect size). | Low
Stigma, labeling, discrimination, or interference with doctor–patient relationship | Evidence was insufficient to draw conclusions. | Insufficient
Illegal substance use | Evidence was insufficient to draw conclusions. | Insufficient

CI = confidence interval

### Key Question 6 How do behavioral counseling interventions, with or without referral, compare with one another and with usual care for reducing morbidity, reducing mortality, or changing other long-term (6 months or longer) outcomes for people with alcohol misuse as identified by screening?

The tables below provide a summary of the main results for adults (Table F), older adults (Table G), and young adults and college students (Table H). For most health outcomes, available evidence either demonstrated no difference between interventions and controls (e.g., mortality: low SOE) or was insufficient to draw conclusions (e.g., accidents, injuries, alcohol-related liver problems: insufficient SOE). Some evidence suggests that interventions improve some utilization outcomes for adults (e.g., hospital days and costs: low SOE). Our meta-analyses did not find a reduction in all-cause mortality for adults (four studies; rate ratio 0.64, 95% confidence interval [CI], 0.24 to 1.7) or for all age groups combined (adults, older adults, and young adults/college students) (six studies; rate ratio 0.52, 95% CI, 0.22 to 1.2). Point estimates trended toward favoring behavioral interventions, few studies reported mortality, and there is little long-term data; additional studies would be needed to increase precision. We did not identify any studies enrolling pregnant women reporting outcomes for this question (insufficient SOE).

Table F Effectiveness of behavioral interventions compared with controls for adults: Health, utilization, and other outcomes

Type of Outcomes | Specific Outcome | Results Effect Size (95% CI) | Strength of Evidence
Health | Mortality | Our meta-analyses did not find a reduction in all-cause mortality for adults (4 studies; rate ratio 0.64, 95% CI, 0.24 to 1.7^a^). | Low
Health | Alcohol-related accidents^b^ | Evidence was insufficient to draw conclusions. | Insufficient
Health | Alcohol-related liver problems | Evidence was insufficient to draw conclusions. | Insufficient
Utilization | Hospitalization | Fewer hospital days in last 6 months for intervention group compared with the control group at 6, 12, and 48 months: 35 vs. 180, 91 vs. 146, and 420 vs. 664, p<0.001, p<0.001, and p<0.05, respectively.^c^ | Low
Utilization | Emergency visits | Difference between groups for visits in past 6 months did not reach statistical significance.^d^ | Low
Utilization | Primary care visits | No significant difference between intervention and control groups: WMD, -0.14 visits, 95% CI, -0.5 to 0.2. | Low
Utilization | Costs | Over 12 months Project TrEAT reported a total potential economic benefit of the brief intervention of $423,519, including more than $190,000 savings in emergency department and hospital use and almost $230,000 in avoided costs of crime and motor vehicle accidents. Using data from 48-month followup, the authors reported an intervention cost per patient of $205, and a benefit per patient of $7,985, for a resulting benefit-cost ratio of 39 (95% CI, 5.4 to 72.5) (societal perspective).^c,e^ | Low
Other | Legal problems | One 48-month RCT found no significant difference between the intervention and control groups for several legal problems,^f^ but did report a difference for controlled substance/liquor violations, with 2 in the intervention group compared with 11 in control group (p<0.05).^c^ | Low
Other | Quality of life | Three 12-month studies (total N=353) reported no difference between intervention and control groups for general quality of life measures. | Low

CI = confidence interval; N = number; RCT = randomized controlled trial; TrEAT = Trial for Early Alcohol Treatment; vs. = versus; WMD = weighted mean difference

a Meta-analysis including all age groups combined (adults, older adults, and young adults/college students) also found no statistically significant reduction in mortality (6 studies; rate ratio 0.52, 95% CI, 0.22 to 1.2), although point estimates trended toward favoring behavioral interventions. Few studies reported mortality, additional studies would be needed to increase precision, and there is little long-term data.

b “Accidents” is used here to indicate motor vehicle events and injuries.

c These data are from Project TrEAT;43-45 the best available evidence.

d But results trended in favor of the intervention group at 6, 12, and 48 months: 47 vs. 70, 60 vs. 62, and 302 vs. 376, p>0.10, p>0.10, and p<0.10, respectively.43-45

e The $205 per patient cost includes $166 borne by the clinics per patient and $39 borne by patients (for lost work time and travel costs).

f Legal problems included assault/battery/child abuse, resist/obstruct officer/disorderly conduct, criminal damage/property damage, theft/robbery, and other arrests

Note: Evidence was insufficient to draw conclusions for sick days or employment stability. Data are reported for 12-month outcomes unless otherwise noted.

Table G Effectiveness of behavioral interventions compared with controls for older adults: Health, and utilization, and other outcomes

Type of Outcome | Specific Outcome | Results Effect Size (95% CI) | Strength of Evidence
Health | Mortality | Evidence from 1 study was insufficient to draw conclusions. | Insufficient
Health | Alcohol-related accidents^a^ | Evidence was insufficient to draw conclusions. | Insufficient
Health | Alcohol-related liver problems | Evidence was insufficient to draw conclusions. | Insufficient
Utilization | Hospitalization | Evidence was insufficient to draw conclusions. | Insufficient
Utilization | Emergency visits | Evidence was insufficient to draw conclusions. | Insufficient
Utilization | Primary care visits | Evidence was insufficient to draw conclusions. | Insufficient
Utilization | Costs | An economic analysis of Project GOAL found no significant difference in economic outcomes through 24 months.46 The total costs of health care and social consequences were estimated to be $5,241 (95% CI, $2,995 to $7,487) per patient in the intervention group and $6,289 (95% CI, $3,549 to $9,029) per patient in the control group. | Low

CI = confidence interval, GOAL = Guiding Older Adult Lifestyle

a “Accidents” is used here to indicate motor vehicle events and injuries.

Notes: Evidence was insufficient to draw conclusions for sick days, legal issues, employment stability, and quality of life. Data are reported for 12-month outcomes unless otherwise noted.

Table H Effectiveness of behavioral interventions compared with controls for young adults and college students: Health, utilization, and other outcomes

Type of Outcome | Specific Outcome | Results Effect Size (95% CI) | Strength of Evidence
Health | Mortality | One trial reported one death in the control group. | Insufficient
Health | Motor vehicle events | A subgroup analysis (N=226) of young adults from Project TrEAT47 found fewer motor vehicle crashes with nonfatal injuries for those in the intervention group than for controls (9 vs. 20, respectively; p<0.05) and fewer total motor vehicle events (114 vs. 149; p<0.05) after 48 months of followup. | Low
Health | Alcohol-related liver problems | Evidence was insufficient to draw conclusions. | Insufficient
Utilization | Hospitalization | The subgroup analysis from Project TrEAT reported a lower number of days of hospitalization for the intervention group that did not reach statistical significance (131 vs. 150, p=NS).47 | Low
Utilization | Emergency visits | The subgroup analysis from Project TrEAT reported fewer emergency department visits for the intervention group than for the control group (103 vs. 177, p<0.01).47 | Low
Utilization | Primary care visits | Evidence was insufficient to draw conclusions. | Insufficient
Utilization | Costs | Evidence was insufficient to draw conclusions. | Insufficient
Other | Academic problems | Evidence from two trials (N=576 and N=104) conducted in New Zealand suggests that behavioral interventions result in fewer consequences related to academic role expectations (rate ratio between 0.70 and 0.80).48, 49 | Moderate
Other | Legal problems | The subgroup analysis from Project TrEAT found no significant difference between the intervention and control groups for assault/battery/child abuse, resist/obstruct officer/disorderly conduct, criminal damage/property damage, theft/robbery, and other arrests, but did report a difference for controlled substance/liquor violations, with 0 in the intervention group compared with 8 in the control group (p<0.01).47 | Low

CI = confidence interval; N = number; NS = not sufficient; TrEAT = Trial for Early Alcohol Treatment; vs. = versus

Note: Evidence was insufficient to draw conclusions for quality of life. Data are reported for 12-month outcomes unless otherwise noted.

### Key Question 7 To what extent do health care system influences promote or hinder effective screening and interventions for alcohol misuse?

Interventions required sufficient support systems in order to provide screening and screening-related assessment, and in some cases, provider prompting. Such supports are likely required for effective screening and intervention. The country in which studies were conducted (United States compared with non-United States) did not have a significant impact on the effectiveness of interventions for consumption outcomes. Interventions conducted in academic/research-oriented settings and those conducted in community-based primary care settings were both effective for reducing alcohol consumption, with data showing a trend toward greater reduction for interventions delivered in academic/research-oriented settings (weighted mean difference [WMD], -5.0 drinks/week, 95% CI, -7.6 to -2.5) than for those delivered in community-based settings (WMD, -3.2, 95% CI, -4.3 to -2.2). Interventions delivered by primary care providers and by research personnel were both effective for reducing alcohol consumption, with data showing a trend toward greater reduction for interventions delivered mostly by primary care providers (WMD, -4.0 drinks per week, 95% CI, -5.4 to -2.6) than for those delivered primarily by research personnel (WMD, -3.0, 95% CI, -5.0 to -1.0). Just one intervention delivered by a nurse contributed to the drinks per week meta-analysis; the reduction in drinks per week was not statistically significant for that study (WMD, -0.2, 95% CI, -8.9 to 8.6). Two other studies that did not provide sufficient data for our drinks per week meta-analysis reported benefits of interventions delivered primarily by nurses,50, 51 or by nurses and physician assistants52 for some consumption outcomes. In addition, two interventions48, 49, 53 conducted via computer reported some evidence of effectiveness for college students.

Most interventions required training of providers and/or staff. Such training may be required for practices to deliver effective screening and interventions for alcohol misuse. When reported, training duration ranged from as little as 15 minutes54, 55 to as long as 6 to 8 hours,52, 56 full-day workshops,57 or a 4-week training in motivational interviewing principles.58 Nine studies43-45, 47, 50-52, 57-68 reported trainings of research staff and interventionists that were 30 minutes or longer and also provided feedback, booster sessions, or weekly conference calls to maintain adherence to protocol. Five others69-75 reported trainings of 30 minutes or more but did not provide information on booster sessions.

## Discussion

We aimed to conduct a systematic review of the effectiveness of screening followed by behavioral counseling for alcohol misuse in primary care settings. In the Background section, we describe several categories of alcohol misuse (i.e., risky/hazardous use, harmful use, alcohol abuse, and alcohol dependence). It is important to note that the categories are not all discrete categories (i.e., an individual may meet the definition for more than one category for some of these categories). It appears that the included trials of behavioral counseling generally enrolled subjects with risky/hazardous drinking, but the trials use varying terminology to describe the included populations and often enrolled heterogeneous populations (i.e., included subjects with various types of alcohol misuse). Nevertheless, the vast majority of trials excluded subjects with alcohol dependence or constructed inclusion/exclusion criteria to substantially limit the number of potential subjects with alcohol dependence.

Given the heterogeneity in terminology used by the included trials and the potential overlap of some categories of alcohol misuse, our best assessment is that our overall findings from behavioral counseling intervention trials are applicable to risky/hazardous drinkers, and are unlikely to be applicable to those with alcohol dependence. It is uncertain whether findings are applicable to harmful drinkers or people with alcohol abuse.

### Summary of Main Findings

#### Screening for Alcohol Misuse

We found adequate evidence that several screening instruments can detect alcohol misuse in adults with acceptable sensitivity and specificity. A single-question screen, AUDIT-C, and AUDIT appear to be the best overall instruments for screening adults for alcohol misuse in primary care, considering sensitivity, specificity, and time burden. Several instruments require as little as 1 to 2 minutes to administer (e.g., single-question screens, AUDIT-C). For people with positive screening tests, screening-related assessments are still necessary to determine whether an individual has risky/hazardous drinking or if they meet criteria for alcohol abuse or dependence.

None of the included systematic reviews provided information about the use of screening instruments in adolescents. Of note, our methods for identifying all potentially relevant studies for Key Question 2 have some limitations: we did not review all individual publications assessing screening instruments. Instead, we relied on previously published systematic reviews to find information, and we filled gaps with data from other sources (i.e., Technical Expert Panel members, peer and public reviewers, personal files).

#### Behavioral Counseling Interventions in Primary Care

##### All Adults (Age 18 and Older)

We found that behavioral counseling interventions improved intermediate outcomes (moderate SOE) and some utilization outcomes (including hospital days and costs, low SOE) for adults with alcohol misuse. For most health outcomes, available evidence either found no difference between interventions and controls (e.g., mortality, low SOE) or was insufficient to draw conclusions about the effectiveness of behavioral interventions compared with controls (e.g., alcohol-related liver problems, insufficient SOE).

We found an average reduction of 3.6 drinks per week for adults receiving interventions compared with those in control groups and an 11 percent increase in the percentage of adults achieving recommended drinking limits over 12 months. This translates to a number needed to treat (NNT) of 9.1 to get 1 person to change from risky/hazardous drinking to drinking recommended limits over 12 months with a behavioral intervention, and a range for the number needed to screen (NNS) of 31 to 227, depending on the prevalence of risky/hazardous drinking in the population (Table I). When using effectiveness data for brief (more than 5, and up to 15 minutes) multicontact interventions, these improve to an NNT of 6.7 and range of NNS from 23 to 167.

Table I Projected range of outcomes of screening 1,000 adults in primary care and providing a behavioral counseling intervention for those identified with risky/hazardous drinking

Outcome | Lower Estimate of Range | Upper Estimate of Range
Prevalence of risky/hazardous drinking^a^ | 4% | 29%
People identified with risky/hazardous drinking^a^ | 40 | 290
Potential behavioral interventions delivered | 40 | 290
People achieving recommended drinking limits by 12 months with behavioral intervention^b^ | 4.4 | 31.9
NNT to get 1 person to change from risky/hazardous drinking to drinking recommended amounts with behavioral intervention^b^ | 9.1 | 9.1
NNS to get 1 person to change from risky/hazardous drinking to drinking recommended amounts with behavioral intervention^b^ | 227 | 31
People achieving recommended drinking limits by 12 months with brief multicontact behavioral intervention^c^ | 6 | 43.5
NNT to get 1 person to change from risky/hazardous drinking to drinking recommended amounts with brief multicontact behavioral intervention^c^ | 6.7 | 6.7
NNS to get 1 person to change from risky/hazardous drinking to drinking recommended amounts with brief multicontact behavioral intervention^c^ | 167 | 23
Prevalence of alcohol dependence^a^ | 2% | 9%
People identified with alcohol dependence^a^ | 20 | 90

NNS = number needed to screen; NNT = number needed to treat

a Number identified from screening and screening-related assessment; a range of risky drinkers (4% to 29%) has been found across multiple primary care populations, with prevalence estimates of 2.0% to 9.0% for alcohol dependence.14 The prevalence of risky drinking and alcohol dependence are not linked in this table. In other words, although the prevalence of 4% for risky drinking and 2% for alcohol dependence are in the same column (as are 29% and 9%, respectively), there are no data to suggest that the prevalence of dependence is 2% when the prevalence of risky drinking is 4%.

b Based on absolute difference of 11% (that would achieve recommended drinking limits) from our meta-analysis including interventions of all intensity.

c Based on absolute difference of 15% (that would achieve recommended drinking limits) from our subgroup meta-analysis for brief multicontact interventions.

Notes: Data in table are number of people unless specified as percentage; the 1,000 people screened are those that have not been previously screened and have no known history of alcohol misuse. The scenario in this table is optimistic, because it assumes that screening identifies all those with alcohol misuse (100% sensitive) and that all those identified with misuse potentially get an intervention. We conducted sensitivity analyses to explore how NNT and NNS would change using other assumptions. The NNT does not change much using a variety of different assumptions; it ranges from 6.7 to 18.2. Using a sensitivity of 81% for the screening instrument (representative of the single question19) changes the NNS range to 39 to 281 (from 31 to 227). If only half of all those with a positive screening test receive an intervention, then the NNS range increases to 63 to 455. If 90% of those with a positive screen receive an intervention, the NNS range increases to 35 to 253. If the screening instrument sensitivity is 81% and only half of those with a positive screen receive an intervention, then the NNS range increases to 155 to 1,122.

The evidence for effectiveness in adults is strongest for brief multicontact interventions; these studies consistently found statistically significant improvements in consumption, heavy drinking episodes, and achieving recommended drinking limits. The brief multicontact interventions were generally 10 to15 minutes per contact. The effect sizes for brief multicontact interventions were greater than for other intensities (although confidence intervals generally overlapped). In addition, the best studies show that the effect of brief multicontact interventions remains for several years of followup,44, 45, 66 and show improvement for some utilization outcomes (fewer hospital days44, 45) and costs (benefit-cost ratio of 39:1 over 48 months, 95% CI, 5.4 to 72.5^44^).

Our meta-analyses of studies in adults found very brief (up to 5 minutes) and brief (more than 5, up to 15 minutes) single-contact interventions to be ineffective for some outcomes and less effective than brief multicontact interventions for others. Although extended multicontact interventions appear to be effective for improving intermediate outcomes, we did not find evidence that they are more effective than brief multicontact interventions.

Long-term outcomes up to 48 months revealed that participants in the intervention groups maintained reductions in consumption or continued to reduce consumption further, but differences between intervention and control groups were no longer statistically significant by 48 months. Studies identified relatively delayed reduction in consumption in control groups to levels achieved by the intervention group that could reflect the natural history of alcohol consumption, the cumulative effect of yearly followups with the health care system, attrition (if more subjects lost to followup from the control group were risky drinkers than those lost to followup from the intervention group), or (late) regression to the mean.

Our subgroup analyses found similar benefits for men and women and for studies conducted in the United States compared with those conducted in other countries. We found a trend toward a greater reduction in consumption for interventions delivered primarily by primary care providers (WMD, 4.0 drinks/week, 95% CI, 2.6 to 5.4) than for those delivered primarily by research personnel (3.0 drinks/week, 95% CI, 1.0 to 5.0); and for interventions delivered in academic/research-oriented settings (WMD, 5.0 drinks/week, 95% CI, 2.5 to 7.6) than for those delivered in community-based settings (3.2 drinks/week, 95% CI, 2.2 to 4.3).

##### Older Adults

Two studies enrolling older adults provided evidence of the effectiveness of behavioral interventions for reducing consumption and improving the percentage drinking beneath recommended limits, but effect sizes were smaller than those found for all adults (Table B). Evidence for health outcomes was insufficient to draw conclusions.

##### Young Adults and College Students

We found evidence of effectiveness of behavioral interventions for improving intermediate outcomes and some accident, utilization, and academic outcomes (Tables B and H), including fewer motor vehicle events, hospitalization days, and emergency department visits for those in the intervention group compared with the control group (low SOE).47 Unlike studies in adults, which generally found benefits to last for several years for intermediate outcomes, some benefits of interventions for college students found at 6 months were no longer statistically significantly different for intervention versus control groups at 12 months. This could be due to the natural history of drinking among college students or could indicate the need for additional booster sessions to maintain benefits.

##### Pregnant Women

We found just one study enrolling pregnant women (N=250)40 that met our inclusion criteria. The study did not find a significant difference for reduction in consumption (low SOE), but found higher rates of abstinence maintained for subjects who were abstinent pre-assessment for the intervention group compared with the control group.

Our searches identified other studies focusing on pregnant women that did not meet our inclusion criteria.76-93 Several did not take place in a primary care setting, but instead were conducted in other settings, such as those that included jails and specialized drug and alcohol treatment centers; these included, for example, the Project CHOICES study.84 Others were excluded because they did not include a control group or because they followed participants after the intervention for less than 6 months.82, 93 Several of these studies reported benefits of behavioral interventions for pregnant women, including reduction of alcohol consumption,82, 93 reduced risk of an alcohol-exposed pregnancy,84 higher rates of abstinence,88 and better fetal and newborn outcomes (birthweights and birth lengths, and fetal mortality rates).88

#### Potential Adverse Effects of Behavioral Counseling Interventions

Published trials have given little attention to potential adverse effects of screening and behavioral counseling interventions for alcohol misuse. We found no trials reporting on illegal substance use, stigma, labeling, discrimination, or interference with the doctor-patient relationship. We found very limited evidence reporting no difference between intervention and control groups for smoking rates and anxiety (low SOE).

The time required for interventions used in the included studies ranged from a minimum of 5 minutes to a maximum of approximately 2 hours dispersed over multiple in-person and/or telephone visits (moderate SOE). The brief multicontact intervention used in Project TrEAT (which provides some of the best evidence of effectiveness of behavioral interventions for risky/hazardous drinking in primary care) required two 15-minute visits with the primary care physician 1 month apart and two followup phone calls from a nurse.

Although trial data are limited regarding adverse effects of screening and behavioral interventions for alcohol misuse in primary care settings, other types of studies may offer some insights. Among a group of 24 general practitioners in Denmark who were interviewed about their participation in a screening and brief intervention program for alcohol misuse, nearly all reported experiencing negative reactions from some patients.94 Such reactions ranged from feelings of uneasiness or embarrassment to finding another physician. The physicians themselves noted that the added work of screening and brief intervention was onerous and hampered the establishment of rapport with patients. They also expressed concerns that screening identified people for whom intervention was unnecessary, yet took valuable time and resources, while at the same time failing to detect and help some for whom alcohol misuse was a real problem. However, other studies have found that patients view screening favorably, even perceiving higher quality of care when screening is followed by counseling.95 For example, one prospective cohort study found that communication and whole-person knowledge were perceived as better among patients who were counseled about their alcohol misuse compared with those who were not counseled.96

#### Treatments for Alcohol Dependence

Although we did not systematically examine the efficacy/effectiveness of various treatments for alcohol dependence (Table J), we provide contextual information regarding such treatments because screening for alcohol misuse will inevitably identify some individuals with alcohol dependence; thus, providers and those making recommendations need some information about whether there are effective interventions available for alcohol dependence. However, a detailed review and comparison of treatments for alcohol dependence are beyond the scope of this review.

Table J Treatments for alcohol dependence

- Cognitive behavioral therapy; - Motivational enhancement therapy; - 12-step programs (e.g., Alcoholics Anonymous); - Intensive outpatient programs using group or individual counseling; - Alcoholism treatment centers; - Pharmacotherapy^a^ (disulfiram, naltrexone, acamprosate); - Detoxification (inpatient, residential, day treatment, or outpatient)

a Pharmacotherapy can be used in addition to psychosocial therapy but is not recommended for use alone.

Note: this is not an exhaustive list of all treatments that have been studies or used for alcohol dependence but rather includes the most common.

Very few studies have examined the efficacy of brief interventions for alcohol dependence in a primary care setting. A systematic review of the literature concluded that there was no evidence for efficacy of brief behavioral interventions for patients with alcohol dependence in a primary care setting.97 Similarly, our review did not find any studies demonstrating efficacy of behavioral interventions for people with alcohol dependence in a primary care setting; studies included in our review that enrolled more than 10 percent of subjects with alcohol dependence reported behavioral interventions to be less effective or ineffective compared with studies not enrolling subjects with alcohol dependence. Thus, whereas the overall evidence for the effectiveness of treatment for alcohol dependence is considerable,98 the same cannot be said for the effectiveness of brief interventions for alcohol dependence in primary care settings.

Studies of pharmacotherapy for patients with alcohol dependence have generally enrolled subjects responding to advertisements or those being treated in specialty alcohol treatment centers. We were unable to identify any double-blind RCTs of pharmacotherapy that identified subjects by screening in a primary care setting or that assessed the efficacy or comparative effectiveness of pharmacotherapy in a primary care setting. Further, we were unable to identify any studies of pharmacotherapy for people with risky/hazardous drinking.

### Applicability

The findings are generally applicable to people with risky/hazardous drinking identified by screening in primary care settings (see beginning of Discussion). It is uncertain whether findings are applicable to harmful drinkers or people with alcohol abuse. Most studies excluded all or most potential subjects with alcohol dependence; thus, our findings for behavioral interventions in primary care settings likely do not apply to people with alcohol dependence, who probably require other treatments (e.g., referred for specialty treatment). Compared with the results of studies that enrolled few or no subjects with alcohol dependence, our subgroup analyses found that studies enrolling 10 percent or more subjects with alcohol dependence found behavioral interventions to be ineffective or less effective. This supports the theory that people with alcohol dependence are not likely to respond to the types of interventions evaluated in this report.

We did not identify any studies in adolescent populations or any conducted exclusively among veterans, and the results thus have uncertain applicability to these populations. We did, however, identify a sufficient number of studies of young adults/college students and older adults to draw conclusions (of low to moderate strength) for several intermediate outcomes for these populations. Although we searched for studies conducted in settings with primary care-like relationships (e.g., nontraditional primary care settings such as infectious disease clinics for people with HIV), we did not find any, and our results have uncertain applicability to such settings.

All interventions required support systems to provide screening and screening-related assessment, and, in some cases, provider prompting. Screenings to identify subjects for the included studies were often extensive, multistep processes that included face-to-face interviews lasting up to 30 minutes by research personnel. Less time would be required for screening and screening-related assessments in primary care practice; we estimate less than 2 minutes for negative screens and 5 to10 minutes for positive screens, with most of the time for screening-related assessment to determine whether the patient has an alcohol use disorder as opposed to risky/hazardous drinking. Nevertheless, supports are likely required for effective screening and intervention. In addition, most interventions required training of providers and/or staff. Such training may be required to ensure that practices conduct effective screening and interventions for alcohol misuse.

Effective interventions were generally delivered either completely in person or also included phone followups. However, one study of adults in Germany demonstrated some benefits resulting from a telephone-based intervention,58 and two studies conducted in college student populations demonstrated benefits resulting from Web-based interventions delivered via computer.48, 49, 53

It is unclear whether our findings are applicable to people with comorbid medical or psychiatric conditions, including those with multiple substance use disorders, and some researchers have suggested that brief behavioral interventions may be ineffective or less effective in people with comorbid psychiatric conditions. A subgroup analysis (N=88) from a study conducted in Germany found that brief interventions did not significantly reduce drinking for subjects with comorbid anxiety and/or depression.60

We did not find any evidence that would inform decisions about the appropriate frequency of screening (i.e., whether it should be done annually, every 5 years, or something else).

### Limitations

The scope of this report is limited to primary care settings. Emergency departments or other health care settings may also offer opportunities to provide behavioral interventions to reduce alcohol misuse.

Studies were generally not designed to assess the impact of the interventions on morbidity and mortality; their focus was primarily on behavioral outcomes. In addition, most of the evidence we identified in this report was in the form of intermediate outcomes that rely on self-report of alcohol use. Some studies verified self-report using collaterals, such as a family member. Although there are no biomarkers accurate enough to be widely accepted to measure changes in alcohol use, self-report of alcohol use has been found to be accurate if collected carefully.99, 100 Nevertheless, it remains a concern that social desirability bias could play a role in the results of the included studies (i.e., although self-report is from both randomized groups in these studies, the group that gets more attention and advice to decrease their drinking may be more likely to report that they decreased their drinking).

It is possible that the assessments of alcohol misuse conducted in the included trials conceal therapeutic benefits of the behavioral interventions (i.e., bias results toward the null). Many studies included extensive assessment of alcohol-related behaviors, which could directly result in behavior changes. The control groups in the included studies generally reduced alcohol consumption. Some possible explanations for changes in behavior as a result of the screening and screening-related assessment include (1) increased awareness of the extent of their drinking; (2) the screening questions prompted them to discuss drinking with their primary care provider at a subsequent visit; (3) receipt of some minimal intervention, such as printed educational materials about general health or about alcohol specifically (control groups in the included studies often received some printed materials); or (4) regression to the mean. One study empirically tested whether brief assessment (without a behavioral intervention) reduces hazardous drinking by comparing brief assessment with a control that did not include assessment. The study concluded that assessment appears to reduce hazardous drinking but noted a potential limitation of measurement artifact due to social desirability bias.53

### Future Research

Several gaps in the evidence were identified that could be potential targets for future research (see full report for details).

### Conclusions

Behavioral counseling interventions improve intermediate outcomes (i.e., alcohol consumption, heavy drinking episodes, drinking above recommended amounts: moderate SOE) and some health care utilization outcomes (including hospital days and costs: low SOE) for adults with risky/hazardous drinking. For most health outcomes, available evidence either found no difference between interventions and controls (e.g., mortality: low SOE) or was insufficient to draw conclusions about the effectiveness of behavioral interventions compared with controls (e.g., alcohol-related liver problems, alcohol-related accidents, quality of life: insufficient SOE). Brief multicontact interventions (usually 10 to 15 minutes per contact) have the best evidence of effectiveness for adults (compared with very brief single-contact or brief single-contact interventions).

## References

1 Whitlock EP, Green CA, Polen MR. Behavioral Counseling Interventions in Primary Care to Reduce Risky/Harmful Alcohol Use. Systematic Evidence Review No. 30. AHRQ Publication No 04-0533B. (Prepared by Oregon Evidence-based Practrice Center under Contract No 290-97-0018, Task Order No 2). Rockville, MD. Agency for Healthcare Research and Quality. April. 2004.
2 U.S. Department of Veterans Affairs. AUDIT-C Frequently Asked Questions. Updated April 28, 2010. www.queri.research.va.gov/tools/alcohol-misuse/alcohol-faqs.cfm. June 27, 2011.
3 Saitz R. Clinical practice. Unhealthy alcohol use. N Engl J Med. Feb. 10. 2005;352(6):596-607. [pmid: 15703424].
4 Mokdad AH, Marks JS, Stroup DF, et al. Actual causes of death in the United States, 2000. JAMA. Mar. 10. 2004;291(10):1238-45. [pmid: 15010446].
5 Bouchery EE, Harwood HJ, Sacks JJ, et al. Economic costs of excessive alcohol consumption in the U.S., 2006. Am J Prev Med. Nov. 2011;41(5):516-24. [pmid: 22011424].
6 Harwood HJ, Fountain D, Fountain G. Economic cost of alcohol and drug abuse in the United States, 1992: a report. Addiction. May. 1999;94(5):631-5. [pmid: 10563025].
7 Centers for Disease Control and Prevention. FastStats: Alcohol Use. Updated October 22, 2009. www.cdc.gov.nchs/fastats/alcohol.htm. June 26, 2011.
8 Corrao G, Bagnardi V, Zambon A, et al. A meta-analysis of alcohol consumption and the risk of 15 diseases. Prev Med. May. 2004;38(5):613-9. [pmid: 15066364].
9 Schuckit MA. Alcohol-use disorders. Lancet. Feb. 7. 2009;373(9662):492-501. [pmid: 19168210].
10 Cherpitel CJ, Ye Y. Alcohol-attributable fraction for injury in the U.S. general population: data from the 2005 National Alcohol Survey. J Stud Alcohol Drugs. Jul. 2008;69(4):535-8. [pmid: 18612569].
11 Isaac M, Janca A, Sartorius N. ICD-10 symptom glossary for mental disorders. Geneva. Division of Mental Health, World Health Organization. 1994.
12 Janca A, Ustun TB, van Drimmelen J, et al. ICD-10 symptom checklist for mental disorders, version 1.1. Geneva. Division of Mental Health, World Health Organization. 1994.
13 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 4th ed. Text rev. Washington, DC. American Psychiatric Publishing, Inc. 2000.
14 Reid MC, Fiellin DA, O'Connor PG. Hazardous and harmful alcohol consumption in primary care. Arch Intern Med. Aug. 9-23. 1999;159(15):1681-9. [pmid: 10448769].
15 Vinson DC, Manning BK, Galliher JM, et al. Alcohol and sleep problems in primary care patients: a report from the AAFP National Research Network. Ann Fam Med. Nov-Dec. 2010;8(6):484-92. [pmid: 21060117].
16 Hasin DS, Grant BF. The co-occurrence of DSM-IV alcohol abuse in DSM-IV alcohol dependence: results of the National Epidemiologic Survey on Alcohol and Related Conditions on heterogeneity that differ by population subgroup. Arch Gen Psychiatry. Sep. 2004;61(9):891-6. [pmid: 15351767].
17 Hasin DS, Stinson FS, Ogburn E, et al. Prevalence, correlates, disability, and comorbidity of DSM-IV alcohol abuse and dependence in the United States: results from the National Epidemiologic Survey on Alcohol and Related Conditions. Arch Gen Psychiatry. Jul. 2007;64(7):830-42. [pmid: 17606817].
18 Fleming MF, Manwell LB, Barry KL, et al. At-risk drinking in an HMO primary care sample: prevalence and health policy implications. Am J Public Health. Jan. 1998;88(1):90-3. [pmid: 9584040].
19 Smith PC, Schmidt SM, Allensworth-Davies D, et al. Primary care validation of a single-question alcohol screening test. J Gen Intern Med. Jul. 2009;24(7):783-8. [pmid: 19247718].
20 U.S. Department of Health and Human Services. Healthy People 2010. 2nd ed. Washington, D.C. U.S. Government Printing Office. 2000.
21 The physician's guide to helping patients with alcohol problems. NIH Publication No. 95-3769. Rockville, MD. National Institute on Alcohol Abuse and Alcoholism (NIAAA). 1995.
22 National Institute on Alcohol Abuse and Alcoholism. Helping Patients Who Drink Too Much: A Clinician's Guide. Washington, DC. U.S. Department of Health and Human Services. 2005. pubs.niaaa.nih.gov/publications/practitioner/cliniciansguide2005/guide.pdf. June 27, 2011.
23 Shalala DE. 10th Special Report to the U.S. Congress on Alcohol and Health: Highlights From Current Research: From the Secretary of Health and Human Services. Washington, DC. U.S. Department of Health and Human Services. June. 2000. pubs.niaaa.nih.gov/publications/10report/intro.pdf. June 27, 2011.
24 Whitlock EP, Orleans CT, Pender N, et al. Evaluating primary care behavioral counseling interventions: an evidence-based approach. Am J Prev Med. May. 2002;22(4):267-84. [pmid: 11988383].
25 Substance Abuse and Mental Health Services Administration. Screening, Brief Intervention, and Referral to Treatment. www.samhsa.gov/prevention/SBIRT/index.aspx. June 27, 2011.
26 Babor T. The social and public health significance of individually directed interventions. Holder HD, Edwards G, editors. Alcohol and public policy: evidence and issues. Oxford, England. Oxford University Press. 1995:164-89.
27 Bondy SJ, Rehm J, Ashley MJ, et al. Low-risk drinking guidelines: the scientific evidence. Can J Public Health. Jul-Aug. 1999;90(4):264-70. [pmid: 10489725].
28 Holman CD, English DR, Milne E, et al. Meta-analysis of alcohol and all-cause mortality: a validation of NHMRC recommendations. Med J Aust. Feb. 5. 1996;164(3):141-5. [pmid: 8628131].
29 O'Connor PG, Schottenfeld RS. Patients with alcohol problems. N Engl J Med. Feb. 26. 1998;338(9):592-602. [pmid: 9475768].
30 Helping Patients with Alcohol Problems. A Practitioner's Guide. NIH publication no. 03-3769. Rockville, MD. National Institute on Alcohol Abuse and Alcoholism (NIAAA). 2003.
31 Fleming MF, Graham AW. Screening and brief interventions for alcohol use disorders in managed care settings. Recent Dev Alcohol. 2001;15:393-416. [pmid: 11449755].
32 Friedmann PD, McCullough D, Chin MH, et al. Screening and intervention for alcohol problems. A national survey of primary care physicians and psychiatrists. J Gen Intern Med. Feb. 2000;15(2):84-91. [pmid: 10672110].
33 U.S. Preventive Services Task Force. Screening and behavioral counseling interventions in primary care to reduce alcohol misuse: recommendation statement. Ann Intern Med. Apr. 6. 2004;140(7):554-6. [pmid: 15068984].
34 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
35 Centre for Reviews and Dissemination. Systematic reviews: CRD's guidance for undertaking reviews in healthcare. York, England. University of York. 2009.
36 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
37 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
38 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions -- Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
39 Sobell LC, Sobell MB. Timeline Follow-back: A technique for assessing self-reported ethanol consumption. Allen J, Litten Rz, editors. Measuring Alcohol Consumption: Psychological and Biological Methods. Totowa, NJ. Humana Press. 1992:41-72.
40 Chang G, Wilkins-Haug L, Berman S, et al. Brief intervention for alcohol use in pregnancy: a randomized trial. Addiction. Oct. 1999;94(10):1499-508. [pmid: 10790902].
41 Richmond R, Heather N, Wodak A, et al. Controlled evaluation of a general practice-based brief intervention for excessive drinking. Addiction. Jan. 1995;90(1):119-32. [pmid: 7888970].
42 World Health Organization Brief Interventions Study Group. A cross-national trial of brief interventions with heavy drinkers. WHO Brief Intervention Study Group. Am J Public Health. Jul. 1996;86(7):948-55. [pmid: 8669518].
43 Fleming MF, Barry KL, Manwell LB, et al. Brief physician advice for problem alcohol drinkers. A randomized controlled trial in community-based primary care practices. JAMA. Apr. 2. 1997;277(13):1039-45. [pmid: 9091691].
44 Fleming MF, Mundt MP, French MT, et al. Brief physician advice for problem drinkers: long-term efficacy and benefit-cost analysis. Alcohol Clin Exp Res. Jan. 2002;26(1):36-43. [pmid: 11821652].
45 Fleming MF, Mundt MP, French MT, et al. Benefit-cost analysis of brief physician advice with problem drinkers in primary care settings. Med Care. Jan. 2000;38(1):7-18. [pmid: 10630716].
46 Mundt MP, French MT, Roebuck MC, et al. Brief physician advice for problem drinking among older adults: an economic analysis of costs and benefits. J Stud Alcohol. May. 2005;66(3):389-94. [pmid: 16047528].
47 Grossberg PM, Brown DD, Fleming MF. Brief physician advice for high-risk drinking among young adults. Ann Fam Med. Sep-Oct. 2004;2(5):474-80. [pmid: 15506584].
48 Kypri K, Saunders JB, Williams SM, et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. Nov. 2004;99(11):1410-7. [pmid: 15500594].
49 Kypri K, Langley JD, Saunders JB, et al. Randomized controlled trial of web-based alcohol screening and brief intervention in primary care. Arch Intern Med. Mar. 10. 2008;168(5):530-6. [pmid: 18332300].
50 Fleming MF, Lund MR, Wilton G, et al. The Healthy Moms Study: the efficacy of brief alcohol intervention in postpartum women. Alcohol Clin Exp Res. Sep. 2008;32(9):1600-6. [pmid: 18627361].
51 Wilton G, Moberg DP, Fleming MF. The effect of brief alcohol intervention on postpartum depression. MCN Am J Matern Child Nurs. Sep-Oct. 2009;34(5):297-302. [pmid: 19713798].
52 Noknoy S, Rangsin R, Saengcharnchai P, et al. RCT of effectiveness of motivational enhancement therapy delivered by nurses for hazardous drinkers in primary care units in Thailand. Alcohol Alcohol. May-Jun. 2010;45(3):263-70. [pmid: 20236990].
53 Kypri K, Langley JD, Saunders JB, et al. Assessment may conceal therapeutic benefit: findings from a randomized controlled trial for hazardous drinking. Addiction. Jan. 2007;102(1):62-70. [pmid: 17207124].
54 Anderson P, Scott E. The effect of general practitioners' advice to heavy drinking men. Br J Addict. 1992;6:891-900. [pmid: 1525531].
55 Scott E, Anderson P. Randomized controlled trial of general practitioner intervention in women with excessive alcohol consumption. Drug Alcohol Rev. 1990;10(4):313-21. [pmid: 16818295].
56 Schaus JF, Sole ML, McCoy TP, et al. Alcohol screening and brief intervention in a college student health center: a randomized controlled trial. J Stud Alcohol Drugs Suppl. Jul. 2009;(16):131-41. [pmid: 19538921].
57 Fleming MF, Balousek SL, Grossberg PM, et al. Brief physician advice for heavy drinking college students: a randomized controlled trial in college health clinics. J Stud Alcohol Drugs. Jan. 2010;71(1):23-31. [pmid: 20105410].
58 Bischof G, Grothues JM, Reinhardt S, et al. Evaluation of a telephone-based stepped care intervention for alcohol-related disorders: a randomized controlled trial. Drug Alcohol Depend. Mar. 1. 2008;93(3):244-51. [pmid: 18054443].
59 Gordon AJ, Conigliaro J, Maisto SA, et al. Comparison of consumption effects of brief interventions for hazardous drinking elderly. Subst Use Misuse. Jun. 2003;38(8):1017-35. [pmid: 12901447].
60 Grothues JM, Bischof G, Reinhardt S, et al. Effectiveness of brief alcohol interventions for general practice patients with problematic drinking behavior and comorbid anxiety or depressive disorders. Drug Alcohol Depend. Apr. 1. 2008;94(1-3):214-20. [pmid: 18207336].
61 Lock CA, Kaner E, Heather N, et al. Effectiveness of nurse-led brief alcohol intervention: a cluster randomized controlled trial. J Adv Nurs. May. 2006;54(4):426-39. [pmid: 16671972].
62 Maisto SA, Conigliaro J, McNeil M, et al. Effects of two types of brief intervention and readiness to change on alcohol use in hazardous drinkers. J Stud Alcohol. Sep. 2001;62(5):605-14. [pmid: 11702799].
63 Maisto SA, Conigliaro J, McNeil M, et al. The relationship between eligibility criteria for participation in alcohol brief intervention trials and other alcohol and health-related variables. Am J Addict. Summer. 2001;10(3):218-31. [pmid: 11579620].
64 Manwell LB, Fleming MF, Mundt MP, et al. Treatment of problem alcohol use in women of childbearing age: results of a brief intervention trial. Alcohol Clin Exp Res. Oct. 2000;24(10):1517-24. [pmid: 11045860].
65 Ockene JK, Adams A, Hurley TG, et al. Brief physician- and nurse practitioner-delivered counseling for high-risk drinkers: does it work?. Arch Intern Med. Oct. 11. 1999;159(18):2198-205. [pmid: 10527297].
66 Ockene JK, Reed GW, Reiff-Hekking S. Brief patient-centered clinician-delivered counseling for high-risk drinking: 4-year results. Ann Behav Med. Jun. 2009;37(3):335-42. [pmid: 19707840].
67 Reiff-Hekking S, Ockene JK, Hurley TG, et al. Brief physician and nurse practitioner-delivered counseling for high-risk drinking. Results at 12-month followup. J Gen Intern Med. Jan. 2005;20(1):7-13. [pmid: 15693921].
68 Reinhardt S, Bischof G, Grothues J, et al. Gender differences in the efficacy of brief interventions with a stepped care approach in general practice patients with alcohol-related disorders. Alcohol Alcohol. May-Jun. 2008;43(3):334-40. [pmid: 18263901].
69 Freeborn DK, Polen MR, Hollis JF, et al. Screening and brief intervention for hazardous drinking in an HMO: effects on medical care utilization. J Behav Health Serv Res. Nov. 2000;27(4):446-53. [pmid: 11070638].
70 Senft RA, Polen MR, Freeborn DK, et al. Brief intervention in a primary care setting for hazardous drinkers. Am J Prev Med. Nov-Dec. 1997;13(6):464-70. [pmid: 9415794].
71 Moore AA, Blow FC, Hoffing M, et al. Primary care-based intervention to reduce at-risk drinking in older adults: a randomized controlled trial. Addiction. Jan. 2011;106(1):111-20. [pmid: 21143686].
72 Lin JC, Karno MP, Tang L, et al. Do health educator telephone calls reduce at-risk drinking among older adults in primary care?. J Gen Intern Med. 2010;25(4):334-9. [pmid: 20101471].
73 Curry SJ, Ludman EJ, Grothaus LC, et al. A randomized trial of a brief primary-care-based intervention for reducing at-risk drinking practices. Health Psychol. Mar. 2003;22(2):156-65. [pmid: 12683736].
74 Rubio G, Jimenez-Arriero MA, Martinez I, et al. Efficacy of physician-delivered brief counseling intervention for binge drinkers. Am J Med. Jan. 2010;123(1):72-8. [pmid: 20102995].
75 Wallace P, Cutler S, Haines A. Randomised controlled trial of general practitioner intervention in patients with excessive alcohol consumption. BMJ. Sep. 10. 1988;297(6649):663-8. [pmid: 3052668].
76 Armstrong MA, Kaskutas LA, Witbrodt J, et al. Using drink size to talk about drinking during pregnancy: a randomized clinical trial of Early Start Plus. Soc Work Health Care. Jan. 2009;48(1):90-103. [pmid: 19197768].
77 Budd KW, Ross-Alaolmolki K, Zeller RA. Two prenatal alcohol use screening instruments compared with a physiologic measure. J Obstet Gynecol Neonatal Nurs. Mar-Apr. 2000;29(2):129-36. [pmid: 10750678].
78 Bull LB, Kvigne VL, Leonardson GR, et al. Validation of a self-administered questionnaire to screen for prenatal alcohol use in Northern Plains Indian women. Am J Prev Med. Apr. 1999;16(3):240-3. [pmid: 10198664].
79 Chang G, Goetz MA, Wilkins-Haug L, et al. A brief intervention for prenatal alcohol use: an in-depth look. J Subst Abuse Treat. Jun. 2000;18(4):365-9. [pmid: 10812310].
80 Chang G, Goetz MA, Wilkins-Haug L, et al. Identifying prenatal alcohol use: screening instruments versus clinical predictors. Am J Addict. Spring. 1999;8(2):87-93. [pmid: 10365188].
81 Chang G, Wilkins-Haug L, Berman S, et al. Alcohol use and pregnancy: improving identification. Obstet Gynecol. Jun. 1998;91(6):892-8. [pmid: 9610992].
82 Chang G, McNamara TK, Orav EJ, et al. Brief intervention for prenatal alcohol use: a randomized trial. Obstet Gynecol. May. 2005;105(5 Pt 1):991-8. [pmid: 15863535].
83 Chang G, McNamara TK, Orav EJ, et al. Brief intervention for prenatal alcohol use: the role of drinking goal selection. J Subst Abuse Treat. Dec. 2006;31(4):419-24. [pmid: 17084796].
84 Floyd RL, Sobell M, Velasquez MM, et al. Preventing alcohol-exposed pregnancies: a randomized controlled trial. Am J Prev Med. Jan. 2007;32(1):1-10. [pmid: 17218187].
85 Flynn HA, Marcus SM, Barry KL, et al. Rates and correlates of alcohol use among pregnant women in obstetrics clinics. Alcohol Clin Exp Res. Jan. 2003;27(1):81-7. [pmid: 12544010].
86 Grant TM, Ernst CC, Streissguth A, et al. Preventing alcohol and drug exposed births in Washington state: intervention findings from three parent-child assistance program sites. Am J Drug Alcohol Abuse. 2005;31(3):471-90. [pmid: 16161730].
87 Meberg A, Halvorsen B, Holter B, et al. Moderate alcohol consumption--need for intervention programs in pregnancy?. Acta Obstet Gynecol Scand. 1986;65(8):861-4. [pmid: 3825527].
88 O'Connor MJ, Whaley SE. Brief intervention for alcohol use by pregnant women. Am J Public Health. Feb. 2007;97(2):252-8. [pmid: 17194863].
89 Reynolds KD, Coombs DW, Lowe JB, et al. Evaluation of a self-help program to reduce alcohol consumption among pregnant women. Int J Addict. Mar. 1995;30(4):427-43. [pmid: 7607777].
90 Centers for Disease Control and Prevention. Motivational intervention to reduce alcohol-exposed pregnancies--Florida, Texas, and Virginia, 1997-2001. MMWR Morb Mortal Wkly Rep. May. 16. 2003;52(19):441-4. [pmid: 12807086].
91 Halmesmaki E. Alcohol counselling of 85 pregnant problem drinkers: effect on drinking and fetal outcome. Br J Obstet Gynaecol. Mar. 1988;95(3):243-7. [pmid: 3370196].
92 Waterson EJ, Murray-Lyon IM. Preventing alcohol related birth damage: a review. Soc Sci Med. 1990;30(3):349-64. [pmid: 2408151].
93 Handmaker NS, Miller WR, Manicke M. Findings of a pilot study of motivational interviewing with pregnant drinkers. J Stud Alcohol. Mar. 1999;60(2):285-7. [pmid: 10091968].
94 Beich A, Gannik D, Malterud K. Screening and brief intervention for excessive alcohol use: qualitative interview study of the experiences of general practitioners. BMJ. Oct. 19. 2002;325(7369):870. [pmid: 12386040].
95 Johnson M, Jackson R, Guillaume L, et al. Barriers and facilitators to implementing screening and brief intervention for alcohol misuse: a systematic review of qualitative evidence. J Public Health (Oxf). Sep. 2011;33(3):412-21. [pmid: 21169370].
96 Saitz R, Horton NJ, Cheng DM, et al. Alcohol counseling reflects higher quality of primary care. J Gen Intern Med. Sep. 2008;23(9):1482-6. [pmid: 18618204].
97 Saitz R. Alcohol screening and brief intervention in primary care: Absence of evidence for efficacy in people with dependence or very heavy drinking. Drug Alcohol Rev. Nov. 2010;29(6):631-40. [pmid: 20973848].
98 Miller WR, Walters ST, Bennett ME. How effective is alcoholism treatment in the United States?. J Stud Alcohol. Mar. 2001;62(2):211-20. [pmid: 11327187].
99 Babor TF, Steinberg K, Anton R, et al. Talk is cheap: measuring drinking outcomes in clinical trials. J Stud Alcohol. Jan. 2000;61(1):55-63. [pmid: 10627097].
100 Del Boca FK, Noll JA. Truth or consequences: the validity of self-report data in health services research on addictions. Addiction. Nov. Suppl 3. 2000;95:S347-60. [pmid: 11132362].