# List of Abbreviations

ADS: Alcohol Dependence Scale
ALT: alanine transaminase
ARPS: Alcohol-Related Problems Survey
AST: aspartate transaminase
AUDADIS: Alcohol Use Disorder and Associated Disabilities Interview Schedule;
AUDIT: Alcohol Use Disorders Identification Test
AUDIT-C: Alcohol Use Disorders Identification Test - Consumption
auROC: area under receiving operator characteristic;
BAC: blood alcohol content
BI: brief intervention
BMAST: brief Michigan Alcohol Screening Test
BP: blood pressure
CAGE: Cut-down, Annoyed, Guilty, Eye-opener questionnaire
CARET: Comorbidity-Alcohol Risk Evaluation Tool
CDT: carbohydrate-deficient transferrin
CI: confidence interval
DrInC: Drinker Inventory of Consequences
DSM-III-R: Diagnostic and Statistical Manual of Mental Disorders (3^rd^ Edition, Revised)
ED: emergency department
EPDS: Edinburgh Postnatal Depression Score
ER: emergency room
EtOH: ethanol
f/up: followup
g: gram
G: group
GGT: gamma-glutamyl transferase
GHQ: General Health Questionnaire
GP: general practitioner
HG: mercury
HSQ: Health Status Questionnaire
HSS: Health Screening Survey
ICD: International Classification of Diseases
ITT: intent to treat
LAST: Lübeck Alcohol dependence and abuse Screening Test
LOCF: last observation carried forward
M-CIDI: Munich-Composite International Diagnostic Interview
MAST: Michigan Alcoholism Screening Test
MCV: mean corpuscular erythrocyte volume
MD: medical doctor
Min: minutes
mths: months
NA: not applicable
NET: Normal drinker, Eye opener, Tolerance questionnaire
NP: nurse practitioner
NR: not reported
NS: not significant
OR: odds ratio
OTC: over the counter
PA: physician's assistant
PCP: primary care provider
QF: quantity/frequency
QOL: quality of life;
RA: research assistant
RAPI: Rutgers Alcohol Problem Index
RCT: randomized controlled trials
RR: relative risk
Rx: prescription
SCID: Structured Clinical Interview for DSM
SD: standard deviation
SE: standard error
SF-12: 12-Item Short-Form Survey
SMAST: short Michigan Alcoholism Screening Test
SOCRATES: Stages of Change Readiness and Treatment Eagerness Scale
T-ACE: Tolerance, Annoyed, Cut-down, Eye-opener questionnaire
TLFB: Timeline Followback
TrEAT: Trial for Early Alcohol Treatment
tx: treatment
UC: usual care
var: variance
WHO: World Health Organization
Wk: week
y: year