# Strength of Evidence Tables

## STRENGTH of EVIDENCE for KQ 1

Table G-1 Screening (followed by a behavioral counseling intervention) compared with another screening approach, no screening, or usual care

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Morbidity
0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality
0; 0 | NA | NA | NA | NA | NA | Insufficient
Other long-term outcomes
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable.

## STRENGTH of EVIDENCE for KQ 3

Table G-2 Harms of screening for alcohol misuse and screening-related assessment

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/ Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Stigma, labeling, or discrimination
0; 0 | NA | NA | NA | NA | NA | Insufficient
Interference with the doctor-patient relationship
0; 0 | NA | NA | NA | NA | NA | Insufficient
Opportunity costs (e.g., time taken away from other clinical activities)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Increased alcohol, tobacco, or illegal substance use
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable.

## STRENGTH of EVIDENCE for KQ 4a

Table G-3 Behavioral counseling interventions for adults compared with usual care

| Domains Pertaining to strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Alcohol use, mean change in drinks per week at 12 months
14; 4,332 | Low; RCTs/Fair and Good | Consistent (I^2^ 14%) | Indirect | Precise | WMD -3.6 (95% CI, -4.8 to -2.4) | Moderate^a^
Heavy drinking episodes, % without by 12 months
8; 2,737 | Low; RCTs/ Fair and Good | Consistent (I^2^ 17%) | Indirect | Precise | Risk difference 0.12 (95% CI, 0.07 to 0.16) | Moderate^a^
Recommended drinking limits achieved, % at 12 months
13; 5,973 | Low; RCTs/Fair and Good | Consistent (I^2^ 31%) | Indirect | Precise | Risk difference 0.11 (95% CI, 0.08 to 0.13) | Moderate^a^
Followup with referrals
0; 0 | NA | NA | NA | NA | NA | Insufficient
Abstinence
3; 2,387 | Low; RCTs/Fair | Inconsistent | Indirect | Imprecise | Heterogeneous results reported with little data reported | Insufficient^b^

a These were graded moderate, rather than high, because they are intermediate outcomes (thus the Indirect ratings in the Directness column).

b Unable to pool data or make a conclusion with the limited data reported among the secondary outcomes of the three studies reporting abstinence.

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial; WMD = weighted mean difference.

Table G-4 Behavioral counseling interventions for older adults compared with usual care

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Alcohol use, mean change in drinks per week at 12 months
2; 789 | Low; RCTs/Fair | Consistent | Indirect | Imprecise | WMD -1.74 (95% CI, -2.8 to -0.6) | Moderate^a^
Heavy drinking episodes at 12 months
2; 789 | Low; RCTs/Fair | Inconsistent | Indirect | Imprecise | Mixed results^b^ | Insufficient^b^
Recommended drinking limits achieved at 12 months
2; 789 | Low; RCTs/Fair | Inconsistent | Indirect | Imprecise | Risk difference 0.09 (95% CI, 0.02 to 0.16) | Low^c^
Followup with referrals
0; 0 | NA | NA | NA | NA | NA | Insufficient
Abstinence
0; 0 | NA | NA | NA | NA | NA | Insufficient

a We have moderate confidence that behavioral interventions are beneficial in older adults because both trials found a benefit, but the magnitude of benefit is less certain, as one trial (Project GOAL1, 2) found a reduction of over 5 drinks per week for those in the intervention group compared with controls and the other (HLAYA3, 4) found a reduction of between 1 and 2 drinks per week compared with controls.

b Project GOAL was a positive study, finding greater reduction in binge drinking in the previous 30 days (18% more subjects reported no binge drinking in the intervention group, p<0.025). The HLAYA study did not find a statistically significant difference for one or more heavy drinking days in the past 7 days at 12 months (OR, 0.89, 95% CI, 0.4v 1.97).

c Both point estimates for the individual studies favored behavioral interventions, although the difference in GOAL reached statistical significance and the difference in HLAYA did not quite. Pooling the data for the two studies found a 9% absolute difference favoring behavioral interventions.

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial; WMD = weighted mean difference.

Table G-5 Behavioral counseling interventions for young adults and college students compared with usual care

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Alcohol use, mean change in drinks per week at 6 months
5; 2,255 | Low; RCTs/Fair and Good | Consistent | Indirect | Precise | Greater reduction with behavioral counseling interventions in 5 of 5 studies (6/6 comparisons); WMD, -1.7 drinks per week (95% CI, -2.6 to -0.7) for 3 studies reporting drinks per week; RRs from 0.74 to 0.79 for the 2 studies reporting rate ratios (all with statistically significant 95% CIs). | Moderate
Alcohol use, mean change in drinks per week at 12 months
4; 2,151 | Low; RCTs/Fair and Good | Inconsistent^a^ | Indirect | Imprecise^a^ | Greater reduction with behavioral counseling interventions with effect sizes ranging from 1.2^5^ to 4.1^6^ drinks per week. | Moderate^a^
Heavy drinking episodes at 6 months
5; 2,255 | Low; RCTs/Fair and Good | Consistent | Indirect | Precise | Greater reduction with in-person interventions of 0.9 heavy drinking days per month (WMD, -0.9, 95% CI, -1.5 to -0.3) and with web-based interventions (RR, 0.76, 95% CI, 0.61 to 0.93) | Moderate
Heavy drinking episodes at 12 months
4; 2,151 | Low; RCTs/Fair and Good | Inconsistent | Indirect | Imprecise | No difference between groups for heavy drinking days per month (WMD, -0.2, 95% CI, -1.2 to 0.8) | Low
Recommended drinking limits achieved
0; 0 | NA | NA | NA | NA | NA | Insufficient
Followup with referrals
0; 0 | NA | NA | NA | NA | NA | Insufficient
Abstinence
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Although there is some inconsistency because one of four studies (one of five comparisons) did not find a difference between groups, the best evidence suggests a difference, and there are several reasons why the study by Schaus and colleagues7 may not have found a difference: (1) the control group received an alcohol problems prevention booklet, which may bias results toward the null, and (2) the enrolled subjects had a much lower baseline alcohol consumption (around 8 to 9 drinks per week—half of what was reported in other studies), leaving less room for reduction in consumption. Thus, we graded this moderate, rather than low.

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial; RR = relative risk; WMD = weighted mean difference.

Table G-6 Behavioral counseling interventions for pregnant women compared with usual care

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/ Quality | Consistency | Directness | Precision | Summary Effect Size (95%CI) | High, Moderate, Low, Insufficient
Alcohol use, mean change in drinks per week
1; 250 | Medium; RCT/Fair | NA, single study | Indirect | Imprecise | Difference between groups was not statistically significant (-0.3 vs. -0.4, p=NS, excluding patients who maintained abstinence through the end). | Low
Heavy drinking episodes
0; 0 | NA | NA | NA | NA | NA | Insufficient
Recommended drinking limits achieved
0; 0 | NA | NA | NA | NA | NA | Insufficient
Followup with referrals
0; 0 | NA | NA | NA | NA | NA | Insufficient
Abstinence
1; 250 | Medium; RCT/Fair | NA, single study | Indirect | Imprecise | For the overall sample, data were not reported^a^ | Insufficient^a^

a For the subgroup of subjects who were abstinent prior to assessment, those who received the intervention maintained higher rates of abstinence than those in the control group (86% vs. 72%, p=0.04, low strength of evidence).

Abbreviations: CI = confidence interval; NA = not applicable; NS = not significant; RCT = randomized controlled trial.

## STRENGTH of EVIDENCE for KQ 4b

Table G-7 Behavioral counseling interventions for adults compared with each other: Very brief interventions compared with brief interventions

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/ Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Alcohol use, % decreasing average daily amount at 9 months
1; 1072^a^ | Medium;^b^ RCT/Fair | NA, single study | Indirect | Imprecise | Men VB: 40.8 vs. B: 40.3^c^ Women VB: 43.2 vs. B: 45.1^c^ | Insufficient
Heavy drinking episodes
0; 0 | NA | NA | NA | NA | NA | Insufficient
Recommended drinking limits: Improvement in % of subjects above recommended weekly limit at 9 months
1; 1072^a^ | Medium;^b^ RCT/Fair | NA, single study | Indirect | Imprecise | Men VB: 21 vs. B: 17^c^ Women VB: 27 vs. B: 25^c^ | Insufficient
Followup with referrals
0; 0 | NA | NA | NA | NA | NA | Insufficient
Abstinence, % abstinent at 9 months
1; 1072^a^ | Medium;^b^ RCT/Fair | NA, single study | Indirect | Imprecise | Men VB: 5 vs. B: 8^c^ Women VB: 7 vs. B: 12^c^ | Insufficient

a Total number of subjects randomized in the study was 1,559;^8^ 1,072 were randomized to the 2 study groups relevant for this comparison

b One study making the comparison: WHO Brief Intervention Study, 1996.^8^ Interpretation of the head-to-head information to make a conclusion about how very brief and brief interventions compare in primary care settings is limited by heterogeneity of settings (with many settings outside of primary care, including those in emergency departments), heterogeneity of interventions (with various approaches or personnel used to deliver the intervention), and variations in the interventions across settings and countries.

c p-values or confidence intervals not reported.

Abbreviations: B = brief intervention up to 15 minutes; CI = confidence interval; NA = not applicable; NS = not statistically significant; RCT = randomized controlled trial; VB = very brief intervention up to 5 minutes.

Table G-8 Behavioral counseling interventions for adults compared with each other: Very brief interventions compared with extended multicontact interventions

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; (Design/Quality) | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Alcohol use, reduction in weekly consumption (drinks/week) at 12 months
1; 192^a^ | Medium; RCT/Fair | NA, single study | Indirect | Imprecise | VB: -2.1 vs. EM: -7.0^b^ | Insufficient^b^
Heavy drinking episodes
0; 0 | NA | NA | NA | NA | NA | Insufficient
Recommended drinking limits: % of subjects above recommended limits (%change from baseline) at 12 months
1; 192^a^ | Medium; RCT/Fair | NA, single study | Indirect | Imprecise | VB: 77.1 (-2.1) vs. EM: 76.0 (-7.3), p=NS | Low
Followup with referrals
0; 0 | NA | NA | NA | NA | NA | Insufficient
Abstinence, % abstinent at 9 months
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Total number of subjects randomized in the study was 378;^9^ 192 were randomized to the 2 study groups relevant for this comparison.

b p-values or confidence intervals not reported to determine statistical significance.

Abbreviations: CI = confidence interval; EM = extended multicontact intervention (multiple contacts, some or all longer than 15 minutes); NA = not applicable; NS = not statistically significant; RCT = randomized controlled trial; VB = very brief intervention up to 5 minutes; vs. = versus.

Table G-9 Behavioral counseling interventions for adults compared with each other: Brief interventions compared with extended multicontact interventions

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/ Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Alcohol use, Change in # of drinks in last 30 days at 12 months
1; 201^a^ | Medium; RCT/Fair | NA, single study | Indirect | Imprecise | B: -33.20 (-48.19 to -18.21) vs. EM: -21.99 (-32.32 to -11.65) | Low
Heavy drinking episodes
0; 0 | NA | NA | NA | NA | NA | Insufficient
Recommended drinking limits
0; 0 | NA | NA | NA | NA | NA | Insufficient
Followup with referrals
0; 0 | NA | NA | NA | NA | NA | Insufficient
Abstinence, Change in # of days abstinent at 12 months
1; 201^a^ | Medium; RCT/Fair | NA, single study | Indirect | Imprecise | B: +2.54 (0.53 to 4.56) vs. EM: +3.58 (1.58 to 5.57) | Low

a Total number of subjects randomized in the study was 301;^10^ 201 were randomized to the 2 study groups relevant for this comparison.

Abbreviations: B = brief intervention up to 15 minutes; CI = confidence interval; EM = extended multicontact intervention (multiple contacts, some or all longer than 15 minutes); NA = not applicable; NS = not statistically significant; RCT = randomized controlled trial; vs. = versus.

Table G-10 Behavioral counseling interventions for adults compared with each other: Extended multicontact interventions compared with extended multicontact interventions

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Alcohol use, Change from baseline in alcohol grams per day at 12 months
1; 269^a^ | Medium; RCT/Fair | NA, single study | Indirect | Imprecise | EM (FC): -13.0 vs. EM (SC): -12.2, p=0.217 | Low
Heavy drinking episodes
1; 269^a^ | Medium; RCT/Fair | NA, single study | Indirect | Imprecise | Overall data NR, only reported for subgroups b | Insufficient
Recommended drinking limits
0; 0 | NA | NA | NA | NA | NA | Insufficient
Followup with referrals
0; 0 | NA | NA | NA | NA | NA | Insufficient
Abstinence, Change in # of days abstinent at 12 months
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Total number of subjects randomized in the study was 408;^11^ 269 were randomized to the 2 study groups relevant for this comparison.

b Among those with alcohol dependence: EM (FC): 61.2% vs. EM (SC): 51.4%, p=0.387; among abusers/at-risk drinkers: EM (FC): 77.6% vs. EM (SC): 78.0%, p=1.00; among those with heavy episodic drinking only: EM (FC): 80.6% vs. EM (SC): 72.5%, p=0.577

Abbreviations: CI = confidence interval; EM = extended multicontact intervention (multiple contacts, some or all longer than 15 minutes); FC = full care; NA = not applicable; NR = not reported; RCT = randomized controlled trial; SC = stepped care; vs. = versus.

Table G-11 Behavioral counseling interventions for young adults or college students compared with each other: Brief interventions compared with brief multicontact interventions

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Alcohol use, total drinks in the past 2 weeks at 6 months
1; 283^a^ | Low; RCT/Good | NA, single study | Indirect | Imprecise | For each group compared with the control group: B: RR, 0.77 (95% CI, 0.63 to 0.95) BM: RR, 0.79 (95% CI, 0.64 to 0.97) | Low
Alcohol use, total drinks in the past 2 weeks at 12 months
1; 283^a^ | Low; RCT/Good | NA, single study | Indirect | Imprecise | For each group compared with the control group: B: RR, 0.77 (95% CI, 0.63 to 0.95), BM: RR, 0.87 (95% CI, 0.71 to 1.06) | Low
Heavy drinking episodes, heavy drinking episodes in the past 2 weeks at 6 months
1; 283^a^ | Low; RCT/Good | NA, single study | Indirect | Imprecise | For each group compared with the control group: B: RR, 0.78 (95% CI, 0.55 to 1.12) BM: RR, 0.65 (95% CI, 0.45 to 0.93) | Low
Heavy drinking episodes, heavy drinking episodes in the past 2 weeks at 12 months
1; 283^a^ | Low; RCT/Good | NA, single study | Indirect | Imprecise | Neither group reached statistical significance compared with control, but results trended toward favoring the intervention groups (RRs from 0.71 to 0.75 with upper limits of CIs at 1.01 and 1.07). | Low
Recommended drinking limits
0; 0 | NA | NA | NA | NA | NA | Insufficient
Followup with referrals
0; 0 | NA | NA | NA | NA | NA | Insufficient
Abstinence, Change in # of days abstinent at 12 months
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Total number of subjects randomized in the study was 576;^12, 13^ 283 were randomized to the 2 study groups relevant for this comparison.

Abbreviations: B = brief intervention up to 15 minutes; BM = brief multicontact intervention; CI = confidence interval; NA = not applicable; RCT = randomized controlled trial; RR = rate ratio.

## STRENGTH of EVIDENCE for KQ 5

Table G-12 Adverse effects associated with behavioral counseling interventions compared with usual care

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Increased smoking
5;^a^ 2,067 | Low RCTs/Fair and Good | Consistent | Direct | Imprecise | No difference between groups (unable to calculate effect size) | Low
Opportunity costs/time
23; 10,519 | Low RCTs/Fair and Good | Consistent, within a given intensity category | Indirect^b^ | Imprecise | Range from about 5 minutes to approximately 2 hours, depending on planned intervention intensity | Moderate
Anxiety
2; 226 | Low to medium RCTs/Fair | Consistent | Direct | Imprecise | No difference between groups (unable to calculate effect size) | Low
Stigma, labeling, discrimination, or interference with doctor-patient relationship
0; 0 | NA | NA | NA | NA | NA | Insufficient
Illegal substance use
0; 0 | NA | NA | NA | NA | NA | Insufficient

a 4 of the studies were conducted in adult populations; 1 study enrolled older adults, and a subgroup analysis of TrEAT also provided information on older adults. We found no evidence in young adults/college students or pregnant women.

b We considered this indirect because the time for the intervention was not actually measured in most studies. Authors generally reported the estimated/planned time for interventions, rather than measured/actual time.

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial.

## STRENGTH of EVIDENCE for KQ 6

Table G-13 Behavioral counseling interventions for adults compared with usual care or with each other

Number of Studies; Number of Subjects | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/ Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Mortality, all-cause mortality (person-years)
4; 2,006 | Low to medium; RCTs/Fair and Good | Inconsistent | Direct | Imprecise | Rate ratio 0.64 (95% CI, 0.24 to 1.7)^a^ | Low
Alcohol-related accidents
4; 1,117 | Medium; RCTs/Fair and Good | Consistent | Direct | Imprecise | Unable to determine a magnitude of effect^b^ | Insufficient
Alcohol-related liver problems
0; 0 | NA | NA | NA | NA | NA | Insufficient
Outpatient/primary care visits c
5; 876 | Low; RCTs/Fair and Good | Inconsistent | Direct | Imprecise | No significant difference (WMD, 0.14 visits, 95% CI, -0.5 to 0.2) | Low
Hospitalizations (hospital days)
3; 1,417 | Low; RCTs/Fair and Good | Inconsistent | Direct | Imprecise | Best evidence found a significant difference in hospital days in the last 6 months for the intervention group than the control group at 6, 12, and 48 months (35 vs. 180, 91 vs. 146, and 420 vs. 664, p<0.001, p<0.001, and p<0.05, respectively).^d^ | Low
Emergency visits
2; 901 | Low; RCTs/Fair and Good | Consistent | Direct | Imprecise | Trend favoring control, but not statistically significant. At 6, 12, and 48 months for intervention vs. control: 47 vs. 70, 60 vs. 62, and 302 vs. 376, p>0.10, p>0.10, and p<0.10, respectively^d^ | Low
Costs
2; 901 | Low RCTs/Fair and Good | Inconsistent | Direct | Imprecise | 12 months: average per subject benefit over $1,100 and benefit-cost ratio 5.6:1 (95% CI, 0.4 to 11.0). 48 months: cost per patient of $205, benefit per patient of $7,985, for a resulting benefit-cost ratio of 39 (95% CI, 5.4 to 72.5)^d^ | Low
Legal events: assault/battery/child abuse, resist/obstruct officer/disorderly conduct, criminal damage/property damage, theft/robbery, other arrests, controlled substance/liquor violations
1; 774 | Low RCT/Good | NA, single study | Direct | Imprecise | No statistically significant differences reported except for controlled substance/liquor violations (2 vs. 11, p<0.05)^a^ | Low
Sick days and employment stability
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
3; 353 | Medium RCTs/Fair | Consistent | Direct | Imprecise | No difference^e^ | Low

a Analyses with the addition of the included studies in older adults (GOAL) and in younger adults14 trended further toward favoring behavioral interventions, but remained nonstatistically significant (rate ratio 0.52, 95% CI 0.22 to 1.2; 6 studies, 2,255 subjects).

b Four studies reported data on accidents in adults. Studies were not designed or powered to detect differences in these outcomes. The best available evidence comes from Project TrEAT (N=774),15 which reported outcomes after 48 months of followup. The study found lower numbers of motor vehicle crashes with fatalities (0 vs. 2), motor vehicle crashes with nonfatal injuries (20 vs. 31), and motor vehicle crashes with property damage only (67 vs. 72), that were not statistically significantly different between the intervention and control groups. Two studies (Anderson 1992 and Scott 1990) reported accident scores (from an alcohol-related problems scale), both with endpoint scores numerically favoring the intervention group.16, 17 Neither found a significant change from baseline data for the intervention group or for the control group. One study conducted in Thailand reported alcohol-related accidents (1 in the intervention group and 4 in the control group) and alcohol-related traffic accidents (3 in the intervention group and 5 in the control group).18

c List the actual outcome measures that were reported for primary care utilization.

d Summary effect sizes and data are from Project TrEAT, as it provided the best evidence (due to design, sample size of 774, risk of bias, and duration of followup). For hospitalizations, two smaller studies of shorter duration reported no statistically significant difference between groups for hospitalization outcomes, but Senft and colleagues (N=516) reported a slightly lower percentage of subjects hospitalized in the intervention group than the control group at 24 months that was not significant (21.2% vs. 22.0%, p=0.81) and a trend toward fewer mean hospital days for those hospitalized (4.7 vs. 6.6, p=0.37); Lock and colleagues (N=127) reported no significant difference between groups for hospital inpatient stays. 48-month cost data are from the societal perspective.15, 19

e Two 12-month studies reported no difference in change in mean life quality scores between the intervention and control groups (0 vs. 0 and -0.3 vs. -0.3).16, 17 A nurse-led intervention (N=127) reported no significant differences between the intervention and control groups at 6 or 12 months for change in SF-12 physical or mental health scores.20

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial; vs. = versus; WMD = weighted mean difference.

Table G-14 Behavioral counseling interventions for older adults compared with usual care or with each other

| Domains Pertaining to strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/ Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Mortality, all-cause mortality (person-years)
1; 158 | Medium; RCT/Fair | NA, single study | Direct | Imprecise | Intervention vs. control: 1 death vs. 4, p=NR | Insufficient
Morbidity
0; 0 | NA | NA | NA | NA | NA | Insufficient
Utilization
0; 0 | NA | NA | NA | NA | NA | Insufficient
Costs
1; 158 | Medium; RCT/Fair | NA, single study | Direct | Imprecise | No statistically significant difference in economic outcomes through 24 months^a^ | Low
Legal events, sick days, and employment stability
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life
0; 0 | NA | NA | NA | NA | NA | Insufficient

a The total costs of health care and social consequences were estimated to be $5,241 (95% CI, $2,995 to $7,487) per patient in the treatment group and $6,289 (95% CI, $3,549 to $9,029) per patient in the control group.2

Abbreviations: CI = confidence interval; NA = not applicable; NR = not reported; RCT = randomized controlled trial; vs. = versus.

Table G-15 Behavioral counseling interventions for young adults and college students compared with usual care or with each other

| Domains Pertaining to Strength of Svidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Mortality
1; 104 | Medium; RCT/Fair | NA, single study | Direct | Imprecise | One of the trials (Kypri 2004) reported one death in the control group and zero in the intervention group. | Insufficient
Motor vehicle events
1; 226 | Medium; RCT/Fair | NA, single study | Direct | Imprecise | Fewer events in intervention group than control group^a^ | Low
Alcohol-related liver problems
0; 0 | NA | NA | NA | NA | NA | Insufficient
Hospitalizations (hospital days)
1; 226 | Medium; RCT/Fair | NA, single study | Direct | Imprecise | Lower number of days of hospitalization for the intervention group, but did not reach statistical significance: 131 vs. 150, p=NS^a^ | Low
Emergency visits
1; 226 | Medium; RCT/Fair | NA, single study | Direct | Imprecise | Fewer emergency department visits for the intervention group than for the control group: 103 vs. 177, p<0.01 | Low
Academic outcomes
2; 680 | Low; RCTs/Fair and Good | Consistent | Direct | Imprecise | Fewer consequences related to academic role expectations (rate ratio between 0.70 and 0.80)^d^ | Moderate
Legal events
1; 226 | Medium; RCT/Fair | NA, single study | Direct | Imprecise | No statistically significant differences reported except for controlled substance/liquor violations: 0 vs. 8, p<0.01^b^ | Low
Costs
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Evidence is from a subgroup analysis of young adults (18 to 30) from Project TrEAT. The study reported significantly fewer motor vehicle crashes with nonfatal injuries for those in the intervention group than for controls (9 vs. 20, respectively; p<0.05) and fewer total motor vehicle events (114 vs. 149; p<0.05) after 48 months of followup.6

b No statistically significant difference for total legal events (16 vs. 26), assault/battery/child abuse (6 vs. 6), resist/obstruct officer/disorderly conduct (6 vs. 3), criminal damage/property damage (1 vs. 3), theft/robbery (1 vs. 3), and other arrests (2 vs. 3). However, the study did report a difference for controlled substance/liquor violations, with 0 in the intervention group compared with 8 in the control group (p<0.01).6

c Both studies used the Academic Role Expectations and Alcohol Scale (AREAS).12, 14 The larger (N=576) trial reported fewer academic consequences for the intervention groups than control groups at 12 months (rate ratio: single-contact intervention 0.80, 95% CI, 0.66 to 0.97; multicontact intervention 0.75, 95% CI, 0.62 to 0.90).12 In the smaller trial (N=104), results did not quite reach statistical significance at 6 months, but point estimates for rate ratios were similar (0.72, 95% CI, 0.51 to 1.02).14

Abbreviations: CI = confidence interval; NR = not reported; NS = not sufficient; RCT = randomized controlled trial; vs. = versus.

Table G-16 Behavioral counseling interventions for pregnant women compared with usual care or with each other

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/ Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Mortality
0; 0 | NA | NA | NA | NA | NA | Insufficient
Morbidity
0; 0 | NA | NA | NA | NA | NA | Insufficient
Other long-term outcomes
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable.

## References

1 Fleming MF, Manwell LB, Barry KL, et al. Brief physician advice for alcohol problems in older adults: a randomized community-based trial. J Fam Pract. May. 1999;48(5):378-84. [pmid: 10334615].
2 Mundt MP, French MT, Roebuck MC, et al. Brief physician advice for problem drinking among older adults: an economic analysis of costs and benefits. J Stud Alcohol. May. 2005;66(3):389-94. [pmid: 16047528].
3 Lin JC, Karno MP, Tang L, et al. Do health educator telephone calls reduce at-risk drinking among older adults in primary care?. Journal of General Internal Medicine. 2010;25(4):334-9. [pmid: 20101471].
4 Moore AA, Blow FC, Hoffing M, et al. Primary care-based intervention to reduce at-risk drinking in older adults: a randomized controlled trial. Addiction. Jan. 2011;106(1):111-20. [pmid: 21143686].
5 Fleming MF, Balousek SL, Grossberg PM, et al. Brief physician advice for heavy drinking college students: a randomized controlled trial in college health clinics. J Stud Alcohol Drugs. Jan. 2010;71(1):23-31. [pmid: 20105410].
6 Grossberg PM, Brown DD, Fleming MF. Brief physician advice for high-risk drinking among young adults. Ann Fam Med. Sep-Oct. 2004;2(5):474-80. [pmid: 15506584].
7 Schaus JF, Sole ML, McCoy TP, et al. Alcohol screening and brief intervention in a college student health center: a randomized controlled trial. J Stud Alcohol Drugs Suppl. Jul. 2009;(16):131-41. [pmid: 19538921].
8 World Health Organization Brief Interventions Study Group. A cross-national trial of brief interventions with heavy drinkers. WHO Brief Intervention Study Group. Am J Public Health. Jul. 1996;86(7):948-55. [pmid: 8669518].
9 Richmond R, Heather N, Wodak A, et al. Controlled evaluation of a general practice-based brief intervention for excessive drinking. Addiction. Jan. 1995;90(1):119-32. [pmid: 7888970].
10 Maisto SA, Conigliaro J, McNeil M, et al. Effects of two types of brief intervention and readiness to change on alcohol use in hazardous drinkers. J Stud Alcohol. Sep. 2001;62(5):605-14. [pmid: 11702799].
11 Bischof G, Grothues JM, Reinhardt S, et al. Evaluation of a telephone-based stepped care intervention for alcohol-related disorders: a randomized controlled trial. Drug Alcohol Depend. Mar. 1. 2008;93(3):244-51. [pmid: 18054443].
12 Kypri K, Langley JD, Saunders JB, et al. Randomized controlled trial of web-based alcohol screening and brief intervention in primary care. Arch Intern Med. Mar. 10. 2008;168(5):530-6. [pmid: 18332300].
13 Kypri K, Langley JD, Saunders JB, et al. Assessment may conceal therapeutic benefit: findings from a randomized controlled trial for hazardous drinking. Addiction. Jan. 2007;102(1):62-70. [pmid: 17207124].
14 Kypri K, Saunders JB, Williams SM, et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. Nov. 2004;99(11):1410-7. [pmid: 15500594].
15 Fleming MF, Mundt MP, French MT, et al. Brief physician advice for problem drinkers: long-term efficacy and benefit-cost analysis. Alcohol Clin Exp Res. Jan. 2002;26(1):36-43. [pmid: 11821652].
16 Anderson P, Scott E. The effect of general practitioners' advice to heavy drinking men. British journal of addiction. 1992:891-900. [pmid: 1525531].
17 Scott E, Anderson P. Randomized controlled trial of general practitioner intervention in women with excessive alcohol consumption. Drug Alcohol Rev. 1990;10(4):313-21. [pmid: 16818295].
18 Noknoy S, Rangsin R, Saengcharnchai P, et al. RCT of effectiveness of motivational enhancement therapy delivered by nurses for hazardous drinkers in primary care units in Thailand. Alcohol Alcohol. May-Jun. 2010;45(3):263-70. [pmid: 20236990].
19 Fleming MF, Mundt MP, French MT, et al. Benefit-cost analysis of brief physician advice with problem drinkers in primary care settings. Med Care. Jan. 2000;38(1):7-18. [pmid: 10630716].
20 Lock CA, Kaner E, Heather N, et al. Effectiveness of nurse-led brief alcohol intervention: a cluster randomized controlled trial. J Adv Nurs. May. 2006;54(4):426-39. [pmid: 16671972].