# Quantitative Analysis Results

## Change in drinks/week

### Drinks/week BI vs. control: adult men, 6 months

Comparison of behavioral counseling interventions vs. control in adult men: 6 month change in alcohol consumption (drinks/weeks)

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. In addition, the analysis was stratified by intensity of the intervention and the figure shows the pooled result for studies with similar intensity. The figure shows the difference in means of drinks per week among adult men at 6 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adult men who received brief counseling interventions drank less at 6-month followup compared with those who were in the control arms (difference in means, -4.066; 95% CI, -7.890 to -0.241). Overall I-squared = 29.5%. For studies of very brief interventions the difference in means was 3.300 (95% CI, -10.365 to 16.95). For studies of brief, multicontact interventions, the difference in means was -4.776 (95% CI, -8.926 to -0.626). For studies of extended, multicontact interventions, the difference in means was -3.700 (95% CI, -17.936 to 10.536).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
_Very Brief | 0.000 | 0 | 1.000 | 0.000
Brief, multicontact | 3.195 | 1 | 0.074 | 68.703
Extended, multicontact | 0.000 | 0 | 1.000 | 0.000
Overall | 4.256 | 3 | 0.235 | 29.519

Model | Study name | Intensity | Statistics with study removed
| | | WMD | Lower limit | Upper limit | p-Value
| Richmond 1995 | _Very Brief | 0.000 | 0.000 | 0.000 | 1.000
Random | | | 3.300 | -10.365 | 16.965 | 0.636
| TrEAT 1997 | Brief, multicontact | -7.300 | -12.837 | -1.763 | 0.010
| Wallace 1998 | Brief, multicontact | -3.000 | -5.222 | -0.778 | 0.008
Random | | | -4.776 | -8.926 | -0.626 | 0.024
| Richmond 1995 | Extended, multicontact | -3.700 | -17.936 | 10.536 | 0.610
Random | | | -3.700 | -17.936 | 10.536 | 0.610
Random | Overall | | -4.066 | -7.890 | -0.241 | 0.037

### Drinks/week BI vs. control: adult men, 12 months

Comparison of behavioral counseling interventions vs. control in adult men: 12 month change in alcohol consumption (drinks/week)

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. In addition, the analysis was stratified by intensity of the intervention and the figure shows the pooled result for studies with similar intensity. The figure shows the difference in means of drinks per week among adult men at 12 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adult men who received brief counseling interventions drank less at 12-month followup compared with those who were in the control arms (difference in means, -3.980; 95% CI, -6.617 to -1.343). Overall I-squared = 63.6%. For studies of very brief interventions the difference in means was -7.500 (95% CI, -5.003 to 20.003). For studies of brief interventions, the difference in means was -4.740 (95% CI, -9.544 to 0.064). For studies of brief, multicontact interventions, the difference in means was -4.609 (95% CI, -7.948 to -1.269). For studies of extended, multicontact interventions, the difference in means was -0.400 (95% CI, -15.424 to 14.624).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
_Very Brief | 0.000 | 0 | 1.000 | 0.000
Brief | 0.000 | 0 | 1.000 | 0.000
Brief, multicontact | 10.380 | 2 | 0.006 | 80.732
Extended, multicontact | 0.000 | 0 | 1.000 | 0.000
Overall | 13.745 | 5 | 0.017 | 63.622

Model | Study name | Intensity | Statistics with study removed
| | | WMD | Lower limit | Upper limit | p-Value
| Richmond 1995 | _Very Brief | 0.000 | 0.000 | 0.000 | 1.000
Random | | | 7.500 | -5.003 | 20.003 | 0.240
| Anderson 1992 | Brief | -4.740 | -11.112 | 1.632 | 0.145
Random | | | -4.740 | -9.544 | 0.064 | 0.053
| TrEAT 1997 | Brief, multicontact | -5.878 | -11.482 | -0.274 | 0.040
| Rubio 2010 | Brief, multicontact | -6.146 | -11.663 | -0.628 | 0.029
| Wallace 1998 | Brief, multicontact | -2.713 | -4.067 | -1.359 | 0.000
Random | | | -4.609 | -7.948 | -1.269 | 0.007
| Richmond 1995 | Extended, multicontact | -0.400 | -15.424 | 14.624 | 0.958
Random | | | -0.400 | -15.424 | 14.624 | 0.958
Random | Overall | | -3.980 | -6.617 | -1.343 | 0.003

### Drinks/week BI vs. control: adult women, 6 months

Comparison of behavioral counseling interventions vs. control in adult women: 6 month change in alcohol consumption

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. In addition, the analysis was stratified by intensity of the intervention and the figure shows the pooled result for studies with similar intensity. The figure shows the difference in means of drinks per week among adult women at 6 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adult women who received brief counseling interventions drank less at 6-month followup compared with those who were in the control arms (difference in means, -2.370; 95% CI, -3.415 to -1.325). Overall I-squared = 0.00%. For studies of very brief interventions the difference in means was -1.000 (95% CI, -6.964 to 4.964). For studies of brief, multicontact interventions, the difference in means was -2.467 (95% CI, -3.539 to -1.394). For studies of extended, multicontact interventions, the difference in means was 0.200 (95% CI, -7.297 to 7.697).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
_Very Brief | 0.000 | 0 | 1.000 | 0.000
Brief, multicontact | 0.331 | 2 | 0.847 | 0.000
Extended, multicontact | 0.000 | 0 | 1.000 | 0.000
Overall | 1.017 | 4 | 0.907 | 0.000

Model | Study name | Intensity | Statistics with study removed
| | | WMD | Lower limit | Upper limit | p-Value
| Richmond 1995 | _Very Brief | 0.000 | 0.000 | 0.000 | 1
Random | | | -1.000 | -6.964 | 4.964 | 0.742434
| TrEAT 1997 | Brief, multicontact | -2.277 | -3.529 | -1.026 | 3.62E-04
| Healthy Moms 2008 | Brief, multicontact | -2.847 | -4.698 | -0.995 | 2.58E-03
| Wallace 1998 | Brief, multicontact | -2.479 | -3.591 | -1.368 | 1.24E-05
Random | | | -2.467 | -3.539 | -1.394 | 6.53E-06
| Richmond 1995 | Extended, multicontact | 0.200 | -7.297 | 7.697 | 0.958301
Random | | | 0.200 | -7.297 | 7.697 | 0.958301
Random | | | -2.370 | -3.415 | -1.325 | 8.82E-06

### Drinks/week BI vs. control: adult women, 12 months

Comparison of behavioral counseling interventions vs. control in adult women: 12 month change in alcohol consumption (drinks/week)

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. In addition, the analysis was stratified by intensity of the intervention and the figure shows the pooled result for studies with similar intensity. The figure shows the difference in means of drinks per week among adult women at 12 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adult women who received brief counseling interventions drank less at 12-month followup compared with those who were in the control arms (difference in means, -4.551; 95% CI, -5.859 to -3.242). Overall I-squared = 0.00%. For studies of very brief interventions the difference in means was -2.000 (95% CI, -8.798 to 4.798). For studies of brief interventions the difference in means was -1.600 (95% CI, -8.227 to 5.027). For studies of brief, multicontact interventions, the difference in means was -4.955 (95% CI, -6.346 to -3.565). For studies of extended, multicontact interventions, the difference in means was -0.600 (95% CI, -7.336 to 6.136).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
_Very Brief | 0.000 | 0 | 1.000 | 0.000
Brief | 0.000 | 0 | 1.000 | 0.000
Brief, multicontact | 0.199 | 2 | 0.905 | 0.000
Extended, multicontact | 0.000 | 0 | 1.000 | 0.000
Overall | 3.149 | 2 | 0.677 | 0.000

Model | Study name | Intensity | Statistics with study removed
| | | WMD | Lower limit | Upper limit | p-Value
| Richmond 1995 | _Very Brief | 0.000 | 0.000 | 0.000 | 1.000
Random | | | -2.000 | -8.798 | 4.798 | 0.564
| Scott 1990 | Brief | -1.600 | -8.227 | 5.027 | 0.636
Random | | | -1.600 | -8.227 | 5.027 | 0.636
| TrEAT 1997 | Brief, multicontact | -5.191 | -6.924 | -3.458 | 0.000
| Rubio 2010 | Brief, multicontact | -4.647 | -6.762 | -2.533 | 0.000
| Wallace 1998 | Brief, multicontact | -4.935 | -6.381 | -3.489 | 0.000
Random | | | -4.955 | -6.346 | -3.565 | 0.000
| Richmond 1995 | Extended, multicontact | -0.600 | -7.336 | 6.136 | 0.861
Random | | | -0.600 | -7.336 | 6.136 | 0.861
Random | Overall | | -4.551 | -5.859 | -3.242 | 0.000

### Drinks/week BI vs. control: adults, 6 months

Comparison of behavioral counseling interventions vs. control in adults: 6 month change in alcohol consumption (drinks/week)

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. In addition, the analysis was stratified by intensity of the intervention and the figure shows the pooled result for studies with similar intensity. The figure shows the difference in means of drinks per week among adults at 6 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adults who received brief counseling interventions drank less at 6-month followup compared with those who were in the control arms (difference in means, -3.187; 95% CI, -4.425 to -1.950). Overall I-squared = 28.4%. For studies of very brief interventions the difference in means was 0.900 (95% CI, -7.531 to 9.331). For studies of brief interventions, the difference in means was -3.136 (95% CI, -7.480 to 1.209). For studies of brief, multicontact interventions, the difference in means was -3.507 (95% CI, -4.898 to -2.116). For studies of extended, multicontact interventions, the difference in means was -1.681 (95% CI, -5.474 to 2.113).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
_Very Brief | 0.000 | 0 | 1.000 | 0.000
Brief | 0.000 | 0 | 1.000 | 0.000
Brief, multicontact | 9.672 | 5 | 0.085 | 48.305
Extended, multicontact | 0.000 | 0 | 1.000 | 0.000
Overall | 11.171 | 8 | 0.192 | 28.385

Model | Study name | Intensity | Statistics with study removed
| | | WMD | Lower limit | Upper limit | p-Value
| Richmond 1995 | _Very Brief | 0.000 | 0.000 | 0.000 | 1.000
Random | | | 0.900 | -7.531 | 9.331 | 0.834
| ELM 2001 | Brief | 1.140 | -9.619 | 11.899 | 0.835
| Lock 2006 | Brief | -3.990 | -8.950 | 0.970 | 0.115
Random | | | -3.136 | -7.480 | 1.209 | 0.157
| TrEAT 1997 | Brief, multicontact | -3.295 | -4.702 | -1.887 | 0.000
| Healthy Moms 2008 | Brief, multicontact | -3.812 | -5.111 | -2.514 | 0.000
| Noknoy 2010 | Brief, multicontact | -2.992 | -3.855 | -2.129 | 0.000
| Project Health 1999 | Brief, multicontact | -3.568 | -4.998 | -2.138 | 0.000
| Wallace 1998 (Men) | Brief, multicontact | -2.923 | -3.796 | -2.050 | 0.000
| Wallace 1998 (Women) | Brief, multicontact | -3.446 | -4.673 | -2.220 | 0.000
Random | | | -3.507 | -4.898 | -2.116 | 0.000
| Richmond 1995 | Extended, multicontact | -1.586 | -6.068 | 2.896 | 0.488
| ELM 2001 | Extended, multicontact | -2.100 | -11.063 | 6.863 | 0.646
Random | | | -1.681 | -5.474 | 2.113 | 0.385
Random | | | -3.187 | -4.425 | -1.950 | 0.000

### Drinks/week BI vs. control: adults, 12 months

Comparison of behavioral counseling interventions vs. control in adults: 12 month change in alcohol consumption (drinks/week)

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. In addition, the analysis was stratified by intensity of the intervention and the figure shows the pooled result for studies with similar intensity. The figure shows the difference in means of drinks per week among adults at 12 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adults who received brief counseling interventions drank less at 12-month followup compared with those who were in the control arms (difference in means, -3.573; 95% CI, -4.758 to -2.389). Overall I-squared = 13.7%. For studies of very brief interventions the difference in means was 2.700 (95% CI, -5.212 to 10.612). For studies of brief interventions the difference in means was -3.660 (95% CI, -6.349 to -0.970). For studies of brief, multicontact interventions, the difference in means was -4.407 (95% CI, -6.084 to -2.730). For studies of extended, multicontact interventions, the difference in means was -2.546 (95% CI, -4.767 to -2.389).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
_Very Brief | 0.000 | 0 | 1.000 | 0.000
Brief | 1.305 | 3 | 0.728 | 0.000
Brief, multicontact | 9.478 | 4 | 0.050 | 57.797
Extended, multicontact | 0.382 | 3 | 0.944 | 0.000
Overall | 15.066 | 13 | 0.303 | 13.714

Model | Study name | Intensity | Statistics with study removed
| | | WMD | Lower limit | Upper limit | p-Value
| Richmond 1995 | _Very Brief | 0.000 | 0.000 | 0.000 | 1.000
Random | | | 2.700 | -5.212 | 10.612 | 0.504
| Anderson 1992 (Men) | Brief | -3.091 | -6.508 | 0.325 | 0.076
| Scott 1990 (Women) | Brief | -4.031 | -7.129 | -0.932 | 0.011
| Lock 2006 | Brief | -3.999 | -6.958 | -1.039 | 0.008
| ELM 2001 | Brief | -3.029 | -6.728 | 0.670 | 0.108
Random | | | -3.660 | -6.349 | -0.970 | 0.008
| TrEAT 1997 | Brief, multicontact | -4.231 | -5.818 | -2.643 | 0.000
| Project Health 1999 | Brief, multicontact | -4.510 | -5.900 | -3.119 | 0.000
| Rubio 2010 | Brief, multicontact | -4.637 | -6.383 | -2.891 | 0.000
| Wallace 1998 (Men) | Brief, multicontact | -3.681 | -4.632 | -2.731 | 0.000
| Wallace 1998 (Women) | Brief, multicontact | -4.110 | -5.402 | -2.817 | 0.000
Random | | | -4.407 | -6.084 | -2.730 | 0.000
| Richmond 1995 | Extended, multicontact | -2.595 | -5.070 | -0.119 | 0.040
| ELM 2001 | Extended, multicontact | -3.103 | -6.168 | -0.039 | 0.047
| SIP 2008 (Bischof)-FC | Extended, multicontact | -2.269 | -5.065 | 0.528 | 0.112
| SIP 2008 (Bischof)-SC | Extended, multicontact | -2.414 | -5.203 | 0.374 | 0.090
Random | | | -2.546 | -4.767 | -0.325 | 0.025
Random | Overall | | -3.573 | -4.758 | -2.389 | 0.000

### Drinks/week BI vs. control: older adults, 12 months

Comparison of behavioral counseling interventions vs. control in older adults: 12 month change in alcohol consumption (drinks/week)

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. In addition, the analysis was stratified by intensity of the intervention and the figure shows the pooled result for studies with similar intensity. The figure shows the difference in means of drinks per week among older adults at 12 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that older adults who received brief counseling interventions drank less at 12-month followup compared with those who were in the control arms (difference in means, -1.739; 95% CI, -2.874 to -0.604). Overall I-squared = 82.2%. For studies of brief, multicontact interventions, the difference in means was -5.310 (95% CI, -8.470 to -2.150). For studies of extended, multicontact interventions, the difference in means was -1.210 (95% CI, -2.426 to 0.006).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Brief, multicontact | 0.000 | 0 | 1.000 | 0.000
Extended, multicontact | 0.000 | 0 | 1.000 | 0.000
Overall | 5.631 | 1 | 0.018 | 82.241

Model | Study name | Intensity | Statistics with study removed
| | | WMD | Lower limit | Upper limit | p-Value
| GOAL 1999 | Brief, multicontact | 0.000 | 0.000 | 0.000 | 1.000
Random | | | -5.310 | -8.470 | -2.150 | 0.001
| HLAYA 2010 | Extended, multicontact | -1.210 | -2.426 | 0.006 | 0.051
Random | | | -1.210 | -2.426 | 0.006 | 0.051
Random | | | -1.739 | -2.874 | -0.604 | 0.003

### Drinks/week BI vs. control: young adults, 6 months

Comparison of behavioral counseling interventions vs. control in young adults: 6 month change in alcohol consumption (drinks/week)

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. In addition, the analysis was stratified by intensity of the intervention and the figure shows the pooled result for studies with similar intensity. The figure shows the difference in means of drinks per week among young adults at 6 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that young adults who received brief counseling interventions drank less at 6-month followup compared with those who were in the control arms (difference in means, -1.665; 95% CI, -2.631 to -0.700). Overall I-squared = 0.00%. For studies of brief, multicontact interventions, the difference in means was -1.705 (95% CI, -2.802 to -0.607). For studies of extended, multicontact interventions, the difference in means was -1.530 (95% CI, -3.564 to 0.504).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Brief, multicontact | 0.628 | 1 | 0.428 | 0.000
Extended, multicontact | 0.000 | 0 | 1.000 | 0.000
Overall | 0.650 | 2 | 0.723 | 0.000

Model | Study name | Intensity | Statistics with study removed
| | | WMD | Lower limit | Upper limit | p-Value
| CHIPs 2010 | Brief, multicontact | -2.800 | -5.723 | 0.123 | 0.060
| TrEAT Subgroup, Grossberg 2000 | Brief, multicontact | -1.525 | -2.709 | -0.341 | 0.012
Random | | | -1.705 | -2.802 | -0.607 | 0.002
| Schaus 2009 | Extended, multicontact | -1.530 | -3.564 | 0.504 | 0.140
Random | | | -1.530 | -3.564 | 0.504 | 0.140
Random | | Overall | -1.665 | -2.631 | -0.700 | 0.001

### Drinks/week BI vs. control: young adults, 12 months

Comparison of behavioral counseling interventions vs. control in young adults: 12 month change in alcohol consumption (drinks/week)

The figure contains one row for the results of each study. The figure shows the difference in means of drinks per week among young adults at 12 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that in four of the five studies, young adults who received brief counseling interventions drank less at 12-month followup compared with those who were in the control arms. In the fifth study, there was no significant difference between intervention and control (p = 0.674).

### Drinks/week BI vs. control by intervention provider: adults, 12 months

Comparison of behavioral counseling interventions vs. control, by provider subgroup: 12 month change in alcohol consumption (drinks/week)

Provider subtypes:

1.000 = Primary care physician

2.000 = Nurse

3.000 = Researcher

The figure contains one row for the results of each study and pooled results for each provider type from a meta-analysis of all relevant trials. The figure shows the difference in means of drinks per week among adults at 12 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adults who received brief counseling interventions from primary care providers and from study personnel drank less at 12-month followup compared with those who were in the control arms (difference in means, -4.000; 95% CI, -5.419 to -2.518, I-squared = 37.9% for primary care providers and difference in means, -3.008; 95% CI, -5.009 to -1.007, I-squared = 0.0% for study personnel). For the single study in which the intervention was delivered by a nurse, the difference in means was -0.190 (95% CI, -8.935 to 8.555, I-squared = 0.000).

12-month Adult - Provider Subgroup
Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
PCP | 12.886 | 8 | 0.116 | 37.918
Nurse | 0.000 | 0 | 1.000 | 0.000
Researcher | 0.977 | 3 | 0.807 | 0.000

### Drinks/week BI vs. control by country: adults, 12 months

Comparison of behavioral counseling interventions vs. control, by country subgroup: 12 month change in alcohol consumption (drinks/week)

Country subtypes:

1.000 = United States only

2.000 = includes non-United States

The figure contains one row for the results of each study and pooled results for each country subgroup from a meta-analysis of all relevant trials. The figure shows the difference in means of drinks per week among adults at 12 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adults who received brief counseling interventions in both U.S. and non-U.S. locations drank less at 12-month followup compared with those who were in the control arms (difference in means, -3.511; 95% CI, -4.745 to -2.276, I-squared =0.0% for U.S.-based studies and difference in means, -3.947; 95% CI, -5.673 to -2.221, I-squared = 29.4% for studies conducted outside the U.S.).

12-month Adult - Country Subgroup
Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
U.S, | 2.177 | 3 | 0.537 | 0.000
Non-U.S. | 12.748 | 9 | 0.174 | 29.398

### Drinks/week BI vs. control by alcohol dependence: adults, 12 months

Comparison of behavioral counseling interventions vs. control, by alcohol dependent subgroup: 12 month change in alcohol consumption (drinks/week)

Alcohol dependence subtypes:

1.000 = Study included dependent people

2.000 = Study did not include dependent people

3.000 = Unclear whether study included dependent people

The figure contains one row for the results of each study and pooled results for each alcohol dependence subgroup from a meta-analysis of all relevant trials. The figure shows the difference in means of drinks per week among adults at 12 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adults in studies that did not include people dependent on alcohol and studies that did not report whether they included people with alcohol dependence who received brief counseling interventions drank less at 12-month followup compared with those who were in the control arms (difference in means, -3.584; 95% CI, -4.546 to -2.622, I-squared = 0.0% for studies that did not include dependent people and difference in means, -4.729; 95% CI, -7.323 to -2.134, I-squared = 48.8% for studies that did not report whether dependent people were included). For the studies in which alcohol dependent patients were included, the difference in means was -2.399 (95% CI, -5.166 to 0.367, I-squared = 0.000).

12-month Adult - Alcohol Dependent Subgroup
Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Yes | 1.877 | 3 | 0.598 | 0.000
No | 1.546 | 3 | 0.672 | 0.000
NR/Unclear | 9.764 | 5 | 0.082 | 48.790

### Drinks/week BI vs. control by alcohol dependence: adults, 12 months; very brief removed

Comparison of behavioral counseling interventions vs. control, by alcohol dependent subgroup: 12 month change in alcohol consumption (drinks/week)

Alcohol dependence subtypes:

1.000 = Study included dependent people

2.000 = Study did not include dependent people

3.000 = Unclear whether study included dependent people

The figure contains one row for the results of each study and pooled results for each alcohol dependence subgroup from a meta-analysis of all relevant trials. The figure shows the difference in means of drinks per week among adults at 12 months with the single very brief intervention study removed, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adults in all studies who received brief counseling interventions drank less at 12-month followup compared with those who were in the control arms (difference in means, -3.109; 95% CI, -6.062 to -0.157 for studies that included dependent people, difference in means, -3.584; 95% CI, -4.546 to -2.622 for studies that did not include dependent people, and difference in means, -4.729; 95% CI, -7.323 to -2.134 for studies that did not report whether dependent people were included).

### Drinks/week BI vs. control by practice setting: adults, 12 months

Comparison of behavioral counseling interventions vs. control in adults, by setting: 12 month change in alcohol consumption (drinks/week)

Practice setting subtypes:

A/R = academic or research

Community = private or community-based practice

The figure contains one row for the results of each study and pooled results for each practice setting subgroup from a meta-analysis of all relevant trials. The figure shows the difference in means of drinks per week among adults at 12 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adults who received brief counseling interventions in both academic/research practices and private or community-based practices drank less at 12-month followup compared with those who were in the control arms (difference in means, -5.037; 95% CI, -7.622 to -2.453, I-squared =65.7% for academic or research practice-based studies and difference in means, -3.241; 95% CI, -4.287 to -2.196, I-squared = 0.0% for studies conducted in private or community-based practices).

12-month Adult - Setting Subgroup
Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
A/R | 8.747 | 3 | 0.033 | 65.702
Community | 4.540 | 9 | 0.872 | 0.000

## Binge drinking

### Risk of binge BI vs. control: adult men, 12 months

Comparison of behavioral counseling interventions vs. control in adult men: no binge alcohol use at 12 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the risk difference for no binge alcohol use among adult men at 12 months, behavioral counseling interventions versus control. Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of people with no binge episodes. Data for this figure are presented in Appendix C. This figure depicts that more adult men who received brief counseling interventions had no episodes of binge drinking at 12-month followup compared with those who were in the control arms (risk difference, 0.129; 95% CI, 0.074 to 0.184). Overall I-squared = 0.0%.

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Brief | 0.000 | 0 | 1.000 | 0.000
Brief, multicontact | 1.140 | 1 | 0.286 | 12.284
Overall | 1.451 | 2 | 0.484 | 0.000

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| Anderson 1992 | Brief | 0.000 | 0.000 | 0.000 | 1.000
Random | | | 0.167 | 0.023 | 0.311 | 0.023
| TrEAT 1997 | Brief, multicontact | 0.089 | 0.004 | 0.175 | 0.041
| Rubio 2010 | Brief, multicontact | 0.154 | 0.071 | 0.237 | 0.000
Random | | | 0.123 | 0.059 | 0.186 | 0.000
Random | | Overall | 0.130 | 0.072 | 0.188 | 0.000

### Risk of binge BI vs. control: adult women, 12 months

Comparison of behavioral counseling interventions vs. control in adult women: no binge alcohol use at 12 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the risk difference for no binge alcohol use among adult women at 12 months, behavioral counseling interventions versus control. Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of people with no binge episodes. Data for this figure are presented in Appendix C. This figure depicts that more adult women who received brief counseling interventions had no episodes of binge drinking at 12-month followup compared with those who were in the control arms (risk difference; 0.126; 95% CI, 0.024 to 0.227). Overall I-squared = 66.2%. For studies of brief interventions, the risk difference was not significant (0.030; 95% CI, -0.128 to 0.188). For studies of brief, multicontact interventions, the risk difference was significant (0.193; 95% CI, 0.061 to 0.326).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Brief | 0.000 | 0 | 1.000 | 0.000
Brief, multicontact | 2.724 | 1 | 0.099 | 63.290
Overall | 5.921 | 2 | 0.052 | 66.220

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| Scott 1990 | Brief | 0.000 | 0.000 | 0.000 | 1.000
Random | | | 0.030 | -0.128 | 0.188 | 0.709
| TrEAT 1997 | Brief, multicontact | 0.262 | -0.051 | 0.576 | 0.101
| Rubio 2010 | Brief, multicontact | 0.127 | 0.016 | 0.238 | 0.025
Random | | | 0.193 | 0.061 | 0.326 | 0.004
Random | | Overall | 0.126 | 0.024 | 0.227 | 0.015

### Risk of binge BI vs. control: adults, 6 months

Comparison of behavioral counseling interventions vs. control in adults: no binge alcohol use at 6 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the risk difference for no binge alcohol use among adults at 6 months, behavioral counseling interventions versus control. Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of people with no binge episodes. Data for this figure are presented in Appendix C. This figure depicts that more adults who received brief counseling interventions had no episodes of binge drinking at 6-month followup compared with those who were in the control arms (risk difference, 0.092; 95% CI, 0.021 to 0.163). Overall I-squared = 44.4%. Both studies were of brief interventions.

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Brief, multicontact | 1.735 | 1 | 0.188 | 42.351
Overall | 1.735 | 1 | 0.188 | 42.351

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| TrEAT 1997 | Brief, multicontact | 0.050 | -0.036 | 0.136 | 0.257
| Project Health 1999 | Brief, multicontact | 0.123 | 0.057 | 0.189 | 0.000
Random | | | 0.092 | 0.021 | 0.163 | 0.011
Random | | Overall | 0.092 | 0.021 | 0.163 | 0.011

### Risk of binge BI vs. control: adults, 12 months

Comparison of behavioral counseling interventions vs. control in adults: no binge alcohol use at 12 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the risk difference for no binge alcohol use among adults at 12 months, behavioral counseling interventions versus control. Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of people with no binge episodes. Data for this figure are presented in Appendix C. This figure depicts that more adults who received brief counseling interventions had no episodes of binge drinking at 12-month followup compared with those who were in the control arms (risk difference, 0.118; 95% CI, 0.074 to 0.162). Overall I-squared = 17.2%. For studies of brief interventions, the risk difference was not significant (0.102; 95% CI, -0.032 to 0.188). For studies of brief, multicontact interventions, the risk difference was significant (0.106; 95% CI, 0.056 to 0.157). For studies of extended, multicontact interventions, the risk difference was significant (0.191; 95% CI, 0.074 to 0.162).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Brief | 1.581256 | 1 | 0.20858 | 36.75915
Brief, multicontact | 5.183 | 3 | 0.159 | 42.118
Extended, multicontact | 0.001 | 1 | 0.973 | 0.000
Overall | 8.457416 | 7 | 0.293991 | 17.2324

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| Anderson 1992 (Men) | Brief | 0.030 | -0.137 | 0.197 | 0.724837
| Scott 1990 (Women) | Brief | 0.167 | 0.017 | 0.317 | 2.96E-02
Random | | | 0.102 | -0.032 | 0.236 | 0.134307
| Curry 2003 | Brief, multicontact | 0.127 | 0.084 | 0.169 | 5.59E-09
| TrEAT 1997 | Brief, multicontact | 0.092 | 0.035 | 0.150 | 1.77E-03
| Project Health 1999 | Brief, multicontact | 0.120 | 0.073 | 0.166 | 5.46E-07
| Rubio 2010 | Brief, multicontact | 0.091 | 0.036 | 0.146 | 1.15E-03
Random | | | 0.106 | 0.056 | 0.157 | 3.64E-05
| SIP 2008 (Bischof)-FC | Extended, multicontact | 0.193 | 0.023 | 0.363 | 2.63E-02
| SIP 2008 (Bischof)-SC | Extended, multicontact | 0.189 | 0.013 | 0.365 | 3.57E-02
Random | | | 0.191 | 0.074 | 0.308 | 1.40E-03
Random | | Overall | 0.118 | 0.074 | 0.162 | 1.38E-07

### Reduction in heavy episodic drinking BI vs. control: young adults, 6 months

Comparison of behavioral counseling interventions vs. control in young adults: reduction in heavy episodic drinking at 6 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. In addition, the analysis was stratified by intensity of the intervention and the figure shows the pooled result for studies with similar intensity. The figure shows the difference in means of heavy drinking episodes among young adults at 6 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that young adults who received brief counseling interventions had fewer heavy drinking episodes at 6-month followup compared with those who were in the control arms (difference in means, -0.872; 95% CI, -1.490 to -0.255). Overall I-squared = 0.0%. For studies of brief, multicontact interventions, the difference in means was significant (-0.824; 95% CI, -1.529 to -0.120). For studies of extended, multicontact interventions, the difference in means was not significant (-1.030; 95% CI, -2.313 to 0.253).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Brief, multicontact | 1.590 | 1.000 | 0.207 | 37.125
Extended, multi | 0.000 | 0.000 | 1.000 | 0.000
Overall | 1.790 | 2.000 | 0.409 | 0.000

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| CHIPs 2010 | Brief, multicontact | -1.400 | -2.546 | -0.254 | 0.017
| TrEAT Subgroup, Grossberg 2000 | Brief, multicontact | -0.600 | -1.083 | -0.117 | 0.015
Random | | | -0.824 | -1.529 | -0.120 | 0.022
| Schaus 2009 | Extended, multicontact | -1.030 | -2.313 | 0.253 | 0.116
Random | | | -1.030 | -2.313 | 0.253 | 0.116
Random | | | -0.872 | -1.490 | -0.255 | 0.006

### Reduction in heavy episodic drinking BI vs. control: young adults, 12 months

Comparison of behavioral counseling interventions vs. control in young adults: reduction in heavy episodic drinking at 12 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. In addition, the analysis was stratified by intensity of the intervention and the figure shows the pooled result for studies with similar intensity. The figure shows the difference in means of heavy drinking episodes among young adults at 12 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that young adults who received brief counseling interventions did not have a significantly different number of heavy drinking episodes at 12-month followup compared with those who were in the control arms (difference in means, -0.206; 95% CI, -1.242 to 0.831). Overall I-squared = 78.6%. For studies of brief, multicontact interventions, the difference in means was not significant (-1.074; 95% CI, -2.733 to 0.585). For studies of extended, multicontact interventions, the difference in means was not significant (0.350; 95% CI, -0.977 to 1.677).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Brief, multicontact | 7.721 | 1.000 | 0.005 | 87.049
Extended, multi | 0.000 | 0.000 | 1.000 | 0.000
Overall | 9.367 | 2.000 | 0.009 | 78.648

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| CHIPs 2010 | Brief, multicontact | -2.000 | -5.215 | 1.215 | 0.223
| TrEAT Subgroup, Grossberg 2000 | Brief, multicontact | -0.300 | -0.772 | 0.172 | 0.213
Random | | | -1.074 | -2.733 | 0.585 | 0.205
| Schaus 2009 | Extended, multicontact | 0.350 | -0.977 | 1.677 | 0.605
Random | | | 0.350 | -0.977 | 1.677 | 0.605
Random | | | -0.206 | -1.242 | 0.831 | 0.697

## Achievement of safe/recommended drinking limits

### Achieved recommended level: adult men, 6 months

Comparison of behavioral counseling interventions vs. control in adult men: achieved recommended drinking at 6 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the risk difference for achieving recommended drinking limits among adult men at 6 months, behavioral counseling interventions versus control. Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of people with no binge episodes. Data for this figure are presented in Appendix C. This figure depicts that more adult men who received brief counseling interventions achieved recommended drinking limits at 6-month followup compared with those who were in the control arms (risk difference, 0.120; 95% CI, 0.013 to 0.227). Overall I-squared = 75.3%. Both studies were of brief, multicontact interventions.

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Brief, multicontact | 4.050 | 1 | 0.044 | 75.308
Overall | 4.050 | 1 | 0.044 | 75.308

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| TrEAT 1997 | Brief, multicontact | 0.173 | 0.102 | 0.244 | 0.000
| Wallace 1998 | Brief, multicontact | 0.064 | -0.015 | 0.143 | 0.111
Random | | | 0.120 | 0.013 | 0.227 | 0.028
Random | | Overall | 0.120 | 0.013 | 0.227 | 0.028

### Achieved recommended level: adult men, 12 months

Comparison of behavioral counseling interventions vs. control in adult men: achieved recommended drinking at 12 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the risk difference for no binge alcohol use among adult men at 12 months, behavioral counseling interventions versus control. Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of people with no binge episodes. Data for this figure are presented in Appendix C. This figure depicts that more adult men who received brief counseling interventions achieved recommended drinking limits at 12-month followup compared with those who were in the control arms (risk difference, 0.121; 95% CI, 0.090 to 0.151). Overall I-squared = 26.8%. For studies of very brief interventions, the risk difference was 0.080 (95% CI, 0.012 to 0.148). For studies of brief interventions, the risk difference was 0.095 (95% CI, 0.041 to 0.149). For studies of brief, multicontact interventions, the risk difference was 0.156 (95% CI, 0.111 to 0.201).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
_Very Brief | 0.000 | 0 | 1.000 | 0.000
Brief | 0.700 | 1 | 0.403 | 0.000
Brief, multicontact | 1.477 | 2 | 0.478 | 0.000
Overall | 6.830 | 5 | 0.234 | 26.793

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| WHO 1996 | _Very Brief | 0.000 | 0.000 | 0.000 | 1.000
Random | | | 0.080 | 0.012 | 0.148 | 0.021
| WHO 1996 | Brief | 0.130 | 0.026 | 0.234 | 0.015
| Anderson 1992 | Brief | 0.080 | -0.009 | 0.169 | 0.077
Random | | | 0.095 | 0.041 | 0.149 | 0.001
| TrEAT 1997 | Brief, multicontact | 0.175 | 0.104 | 0.247 | 0.000
| Rubio 2010 | Brief, multicontact | 0.152 | 0.089 | 0.214 | 0.000
| Wallace 1998 | Brief, multicontact | 0.140 | 0.083 | 0.198 | 0.000
Random | | | 0.156 | 0.111 | 0.201 | 0.000
Random | | Overall | 0.121 | 0.090 | 0.151 | 0.000

### Achieved recommended level: adult women, 6 months

Comparison of behavioral counseling interventions vs. control in adult women: achieved recommended drinking at 6 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the risk difference for achieving recommended drinking limits among adult women at 6 months, behavioral counseling interventions versus control. Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of people with no binge episodes. Data for this figure are presented in Appendix C. This figure depicts that more adult women who received brief counseling interventions achieved recommended drinking limits at 6-month followup compared with those who were in the control arms (risk difference, 0.187; 95% CI, 0.112 to 0.263). Overall I-squared = 0.0%. Both studies were of brief, multicontact interventions.

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Brief, multicontact | 0.192 | 1 | 0.661 | 0.000
Overall | 0.192 | 1 | 0.661 | 0.000

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| TrEAT 1997 | Brief, multicontact | 0.206 | 0.093 | 0.319 | 0.000
| Wallace 1998 | Brief, multicontact | 0.172 | 0.071 | 0.273 | 0.001
Random | | | 0.187 | 0.112 | 0.263 | 0.000
Random | | Overall | 0.187 | 0.112 | 0.263 | 0.000

### Achieved recommended level: adult women, 12 months

Comparison of behavioral counseling interventions vs. control in adult women: achieved recommended drinking at 12 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the risk difference for no binge alcohol use among adult women at 12 months, behavioral counseling interventions versus control. Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of people with no binge episodes. Data for this figure are presented in Appendix C. This figure depicts that more adult women who received brief counseling interventions achieved recommended drinking limits at 12-month followup compared with those who were in the control arms (risk difference, 0.144; 95% CI, 0.092 to 0.196). Overall I-squared = 39.0%. For studies of very brief interventions, the risk difference was not significant (0.080; 95% CI, -0.058 to 0.218). For studies of brief interventions, the risk difference was not significant (0.031; 95% CI, -0.084 to 0.145). For studies of brief, multicontact interventions, the risk difference was significant (0.193; 95% CI, 0.092 to 0.196).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
_Very Brief | 0.000 | 0 | 1.000 | 0.000
Brief | 0.057 | 1 | 0.812 | 0.000
Brief, multicontact | 1.314 | 2 | 0.518 | 0.000
Overall | 8.201 | 5 | 0.145 | 39.035

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| WHO 1996 | _Very Brief | 0.000 | 0.000 | 0.000 | 1.000
Random | | | 0.080 | -0.058 | 0.218 | 0.257
| WHO 1996 | Brief | 0.010 | -0.211 | 0.231 | 0.929
| Scott 1990 | Brief | 0.040 | -0.128 | 0.208 | 0.640
Random | | | 0.031 | -0.084 | 0.145 | 0.602
| TrEAT 1997 | Brief, multicontact | 0.216 | 0.089 | 0.344 | 0.001
| Rubio 2010 | Brief, multicontact | 0.170 | 0.087 | 0.253 | 0.000
| Wallace 1998 | Brief, multicontact | 0.200 | 0.082 | 0.318 | 0.001
Random | | | 0.193 | 0.129 | 0.257 | 0.000
Random | | Overall | 0.144 | 0.092 | 0.196 | 0.000

### Achieved recommended level: adults, 6 months

Comparison of behavioral counseling interventions vs. control in adults: achieved recommended drinking at 6 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the risk difference for no binge alcohol use among adults at 6 months, behavioral counseling interventions versus control. Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of people with no binge episodes. Data for this figure are presented in Appendix C. This figure depicts that more adults who received brief counseling interventions achieved recommended drinking limits at 6-month followup compared with those who were in the control arms (risk difference, 0.132; 95% CI, 0.096 to 0.167). Overall I-squared = 28.8%. For studies of brief interventions, the risk difference was 0.080 (95% CI, 0.006 to 0.154). For studies of brief, multicontact interventions, the risk difference was 0.147 (95% CI, 0.107 to 0.188).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Brief | 0.000 | 0 | 1.000 | 0.000
Brief, multicontact | 3.224 | 3 | 0.358 | 6.947
Overall | 5.621 | 4 | 0.229 | 28.843

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| Senft 1997; Freeborn 2000 | Brief | 0.000 | 0.000 | 0.000 | 1.000
Random | | | 0.080 | 0.006 | 0.154 | 0.035
| TrEAT 1997 | Brief, multicontact | 0.173 | 0.111 | 0.235 | 0.000
| Project Health 1999 | Brief, multicontact | 0.152 | 0.091 | 0.212 | 0.000
| Wallace 1998 (Men) | Brief, multicontact | 0.139 | 0.085 | 0.194 | 0.000
| Wallace 1998 (Women) | Brief, multicontact | 0.139 | 0.092 | 0.187 | 0.000
Random | | | 0.147 | 0.107 | 0.188 | 0.000
Random | | Overall | 0.132 | 0.096 | 0.167 | 0.000

### Achieved recommended level: adults, 12 months

Comparison of behavioral counseling interventions vs. control in adults: achieved recommended drinking at 12 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the risk difference for no binge alcohol use among adults at 12 months, behavioral counseling interventions versus control. Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of people with no binge episodes. Data for this figure are presented in Appendix C. This figure depicts that more adults who received brief counseling interventions achieved recommended drinking limits at 12-month followup compared with those who were in the control arms (risk difference, 0.109; 95% CI, 0.083 to 0.134). Overall I-squared = 30.9%. For studies of very brief interventions, the risk difference was 0.080 (95% CI, 0.019 to 0.141). For studies of brief interventions, the risk difference was 0.079 (95% CI, 0.039 to 0.120). For studies of brief, multicontact interventions, the risk difference was 0.149 (95% CI, 0.109 to 0.188).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
_Very Brief | 0.000 | 1 | 1.000 | 0.000
Brief | 1.845 | 4 | 0.764 | 0.000
Brief, multicontact | 6.954 | 5 | 0.224 | 28.098
Overall | 17.366 | 12 | 0.136 | 30.900

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| WHO 1996 (Men) | _Very Brief | 0.080 | -0.071 | 0.231 | 0.299
| WHO 1996 (Women) | _Very Brief | 0.080 | -0.012 | 0.172 | 0.089
Random | | | 0.080 | 0.019 | 0.141 | 0.010
| WHO 1996 (Men) | Brief | 0.078 | 0.015 | 0.140 | 0.015
| WHO 1996 (Women) | Brief | 0.083 | 0.030 | 0.137 | 0.002
| Anderson 1992 (Men) | Brief | 0.065 | 0.007 | 0.124 | 0.029
| Senft 1997; Freeborn 2000 | Brief | 0.082 | 0.022 | 0.142 | 0.007
| Scott 1990 (Women) | Brief | 0.083 | 0.031 | 0.134 | 0.002
Random | | | 0.079 | 0.039 | 0.120 | 0.000
| Curry 2003 | Brief, multicontact | 0.149 | 0.104 | 0.195 | 0.000
| TrEAT 1997 | Brief, multicontact | 0.153 | 0.103 | 0.202 | 0.000
| Project Health 1999 | Brief, multicontact | 0.165 | 0.121 | 0.208 | 0.000
| Rubio 2010 | Brief, multicontact | 0.139 | 0.098 | 0.180 | 0.000
| Wallace 1998 (Men) | Brief, multicontact | 0.141 | 0.098 | 0.183 | 0.000
| Wallace 1998 (Women) | Brief, multicontact | 0.144 | 0.101 | 0.188 | 0.000
Random | | | 0.149 | 0.109 | 0.188 | 0.000
Random | | Overall | 0.109 | 0.083 | 0.134 | 0.000

### Achieved recommended level: older adults, 12 months

Comparison of behavioral counseling interventions vs. control in older adults: achieved recommended drinking at 12 months

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the risk difference for no binge alcohol use among older adults at 12 months, behavioral counseling interventions versus control. Positive numbers favor behavioral counseling interventions and reflect the absolute difference between groups for the percentage of people with no binge episodes. Data for this figure are presented in Appendix C. This figure depicts that more older adults who received brief counseling interventions achieved recommended drinking limits at 12-month followup compared with those who were in the control arms (risk difference, 0.089; 95% CI, 0.021 to 0.156). Overall I-squared = 61.6%. For studies of brief multicontact interventions, the risk difference was 0.189 (95% CI, 0.050 to 0.328). For studies of extended, multicontact interventions, the risk difference was not significant (0.058; 95% CI, -0.019 to 0.135).

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Brief, multicontact | 0.000 | 0 | 1.000 | 0.000
Extended, multicontact | 0.000 | 0 | 1.000 | 0.000
Overall | 2.607 | 1 | 0.106 | 61.639

Model | Study name | Intensity | Statistics with study removed
| | | RD | Lower limit | Upper limit | p-Value
| GOAL 1999 | Brief, multicontact | 0.000 | 0.000 | 0.000 | 1.000
Random | | | 0.189 | 0.050 | 0.328 | 0.008
| HLAYA 2010 | Extended, multicontact | 0.058 | -0.019 | 0.135 | 0.141
Random | | | 0.058 | -0.019 | 0.135 | 0.141
Random | | Overall | 0.089 | 0.021 | 0.156 | 0.010

## Mortality

### All-cause mortality in person-years: all adults

Comparison of behavioral interventions vs. control in adults, older adults, and young adults: all-cause mortality in person-years

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the rate ratio for all-cause mortality in person-years among adults, older adults, and young adults, behavioral counseling interventions versus control. Numbers less than 1 favor behavioral counseling interventions. Data for this figure are presented in Appendix C. This figure depicts that there was no significant difference in mortality between adults, older adults and young adults who received brief counseling interventions and those who were in the control arms (rate ratio, 0.516; 95% CI, 0.218 to 1.224). Overall I-squared = 0.0%.

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Overall | 4.040 | 6 | 0.671 | 0.000

Model | Study name | Intensity | Statistics with study removed
| | | RR | Lower limit | Upper limit | p-Value
| TrEAT 1997 | Brief, multicontact | 0.597 | 0.194 | 1.835 | 0.368
| Noknoy 2010 | Brief, multicontact | 0.457 | 0.187 | 1.121 | 0.087
| SIP 2008 (Bischof)-FC | Extended, multicontact | 0.548 | 0.223 | 1.349 | 0.190
| SIP 2008 (Bischof)-SC | Extended, multicontact | 0.511 | 0.202 | 1.289 | 0.155
| GOAL 1999 | Brief, multicontact | 0.607 | 0.237 | 1.552 | 0.297
| Kypri 2004 | Brief | 0.533 | 0.217 | 1.306 | 0.169
| Wallace 1998 | Brief, multicontact | 0.422 | 0.171 | 1.039 | 0.060
Random | | | 0.516 | 0.218 | 1.224 | 0.133

### All-cause mortality in person-years: all adults; Wutzke added

Comparison of behavioral counseling interventions vs. control in adults, older adults, and young adults: all-cause mortality in person-years

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials, including one that reported data at 10 years (Wutzke). The figure shows the rate ratio for all-cause mortality in person-years among adults, older adults, and young adults, behavioral counseling interventions versus control. Numbers less than 1 favor behavioral counseling interventions. Data for this figure are presented in Appendix C. This figure depicts that there was no significant difference in mortality between adults, older adults and young adults who received brief counseling interventions and those who were in the control arms (rate ratio, 0.571; 95% CI, 0.315 to 1.033). Overall I-squared = 0.0%.

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Overall | 4.139 | 7 | 0.764 | 0.000

Model | Study name | Intensity | Statistics with study removed
| | | RR | Lower limit | Upper limit | p-Value
| TrEAT 1997 | Brief, multicontact | 0.615 | 0.318 | 1.190 | 0.149
| Noknoy 2010 | Brief, multicontact | 0.542 | 0.296 | 0.992 | 0.047
| SIP 2008 (Bischof)-FC | Extended, multicontact | 0.589 | 0.321 | 1.078 | 0.086
| SIP 2008 (Bischof)-SC | Extended, multicontact | 0.572 | 0.310 | 1.055 | 0.074
| GOAL 1999 | Brief, multicontact | 0.617 | 0.333 | 1.142 | 0.124
| Kypri 2004 | Brief | 0.581 | 0.318 | 1.063 | 0.078
| Wallace 1998 | Brief, multicontact | 0.523 | 0.286 | 0.958 | 0.036
| Wutzke 2002 | Mixed | 0.516 | 0.218 | 1.224 | 0.133
Random | | | 0.571 | 0.315 | 1.033 | 0.064

### All-cause mortality in person-years: adults (excluding older and young adults)

Comparison of behavioral counseling interventions vs. control in adults: all-cause mortality in person-years

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the rate ratio for all-cause mortality in person-years among adults, behavioral counseling interventions versus control. Numbers less than 1 favor behavioral counseling interventions. Data for this figure are presented in Appendix C. This figure depicts that there was no significant difference in mortality between adults who received brief counseling interventions and those who were in the control arms (rate ratio, 0.639; 95% CI, 0.239 to 1.709). Overall I-squared = 0.0%.

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Overall | 3.183 | 4 | 0.528 | 0.000

Model | Study name | Intensity | Statistics with study removed
| | | RR | Lower limit | Upper limit | p-Value
| TrEAT 1997 | Brief, multicontact | 1.030 | 0.246 | 4.312 | 0.967
| Noknoy 2010 | Brief, multicontact | 0.557 | 0.198 | 1.565 | 0.267
| SIP 2008 (Bischof)-FC | Extended, multicontact | 0.710 | 0.251 | 2.006 | 0.518
| SIP 2008 (Bischof)-SC | Extended, multicontact | 0.686 | 0.218 | 2.156 | 0.519
| Wallace 1998 | Brief, multicontact | 0.501 | 0.177 | 1.417 | 0.193
Random | | | 0.639 | 0.239 | 1.709 | 0.373

## Health care utilization

### Change in number of practitioner visits: adults, 12 months

Comparison of behavioral counseling interventions vs. control in adults: 12 month change in number of practitioner visits

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials. The figure shows the difference in means of practitioner visits among adults at 12 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adults who received brief counseling interventions did not have significantly more or fewer visits at 12-month followup compared with those who were in the control arms (difference in means, -0.140; 95% CI, -0.500 to 0.219). Overall I-squared = 0.0%.

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Overall | 3.698 | 4 | 0.448 | 0.000

### Change in number of practitioner visits: adults, 12 months; without Lock, 2006

Comparison of behavioral counseling interventions vs. control in adults: 12 month change in number of practitioner visits

The figure contains one row for the results of each study and a pooled result from meta-analysis of all relevant trials minus one (Locke). The figure shows the difference in means of practitioner visits among adults at 12 months, behavioral counseling interventions versus control. Data for this figure are presented in Appendix C. This figure depicts that adults who received brief counseling interventions did not have significantly more or fewer visits at 12-month followup compared with those who were in the control arms (difference in means, -0.352; 95% CI, -1.481 to 0.776). Overall I-squared = 45.0.0%.

Heterogeneity Statistics
Intensity | Q-value | df (Q) | P-value | I-squared
Overall | 3.638 | 2 | 0.162 | 45.018