# Quality Criteria

In general terms, a “good” study has the least risk of bias and its results are considered to be valid. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. A “poor” study has significant risk of bias (e.g., stemming from serious errors in design or analysis) that may invalidate its results.

Two independent reviewers assigned quality ratings for each study. For each article, one of the two reviewers was always an experienced/senior investigator (DJ or RH). Disagreements between the two reviewers were resolved by discussion and consensus or by consulting a third member of the team. We gave good quality ratings to studies that met all, or all but one, criteria. We gave poor quality ratings to studies that had a fatal flaw (defined as a methodological shortcoming that leads to a very high risk of bias) in one or more categories, and we excluded them from our analyses.

Systematic Reviews Criteria
- Is the review based on a focused question of interest?
- Did the search strategy employ a comprehensive, systematic literature search?
- Are eligibility criteria for studies clearly described?
- Did at least 2 people independently review studies?
- Did authors use a standard method of critical appraisal before including studies?
- Was publication bias assessed?
- Was heterogeneity assessed and addressed?
- Was the approach used to synthesize the information adequate and appropriate?

Randomized Controlled Trials Criteria
- Were randomization and allocation concealment adequate?
- Were groups similar at baseline?
- Were outcome assessors masked?
- Were care providers masked?
- Were patients masked?
- Was overall attrition 20 percent or higher?
- Was differential attrition 15 percent or higher?
- Did the study use intention-to-treat analysis?
- Were outcome measures equal, valid, and reliable?

Table D-1 Quality ratings for efficacy/effectiveness trials

First Author, Year Trial Name | Randomization Adequate | Allocation Concealment Adequate | Groups Similar at Baseline | Outcome Assessors Masked | Care Providers Masked | Patients Masked | Overall Attrition ≥20% | Differential Attrition ≥15% | Study Used ITT Analyses | Outcome Measures Equal, Valid. and Reliable | Efficacy/ Effectiveness Quality Rating
Anderson & Scott, 1992^1^ NA | No | No | Yes | Yes | No | No | Yes | No | Yes | Yes | Fair
Babor, 1996^2^ WHO Brief Intervention | Yes | Yes | Unclear/ NR | Unclear/ NR | No | Yes | Yes | Unclear/ NR | Yes | Yes | Fair
Bischof et al., 2008^3^ Grothues et al., 2008^4^ Reinhardt et al., 2008^5^ SIP | Yes | Yes | Yes | Yes | No | No | No | No | Yes | Yes | Fair
Chang et al., 1999^6^ NA | Yes | Unclear/NR | No | Yes | Unclear/ NR | No | No | No | Unclear/ NR | Yes | Fair
Curry et al., 2003^7^ NA | Unclear/NR | Unclear/NR | Yes | Yes | No | No | Yes | No | Modified ITT | Yes | Fair
Fleming et al., 1997^8^ Fleming et al., 2000^9^ Fleming et al., 2002^10^ Grossberg et al., 2000^11^ Manwell et al., 2004^12^ Project TrEAT | Yes | Unclear/NR | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Good
Fleming et al., 1999^13^ Mundt et al., 2005^14^ GOAL | Unclear/NR | Unclear/NR | Yes | Unclear/NR | Yes | Yes | No | No | No | Yes | Fair
Fleming, et al., 2008^15^ Wilton, et al., 2009^16^ Healthy Moms | Yes | Unclear/NR | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Good
Fleming et al., 2010^17^ CHIPs | Yes | Unclear/NR | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Good
Kypri et al., 2004^18^ NA | Yes | Yes | Yes | No | Yes | No | No | No | No | Yes | Fair
Kypri et al., 2007^19^ Kypri et al., 2008^20^ NA | Yes | Yes | Yes | Yes | Unclear/NR | Yes | No | No | No | Yes | Good
Lin et al., 2010^21^ Moore et al., 2010^22^ HLAYA | Yes | Yes | Yes | Yes | No | No | No | Yes | Modified ITT | Yes | Fair
Lock et al., 2006^23^ NA | Unclear/NR | Unclear/NR | No | Yes | Yes | Yes | Yes | No | Yes | Yes | Fair
Maisto et al., 2001a24 Maisto et al., 2001b25 Gordon et al., 2003^26^ ELM | Yes | No | Yes | Yes | Unclear/NR | No | Yes | Yes | No | Yes | Fair
Noknoy et al., 2010^27^ NA | Yes | Yes | Yes | Yes | Unclear/NR | Yes | No | No | No | Yes | Fair
Ockene et al., 1999^28^ Ockene et al., 2009^29^ Reiff-Hekking et al., 2005^30^ Project Health | Yes | Unclear/NR | No | Yes | No | Yes | No | No | No | Yes | Fair
Richmond et al., 1995^31^ NA | Yes | Unclear/NR | Yes | Yes | No | Yes | Yes | No | Yes | Yes | Fair
Rubio et al., 2010^32^ NA | Yes | Unclear/NR | Yes | Yes | No | Unclear/NR | No | No | Yes | Yes | Fair
Saitz et al., 2003^33^ SIP | Yes | Yes | Yes | Yes | No | No | No | No | No | Yes | Fair
Schaus et al., 2009^34^ NA | Yes | Yes | Yes | No | No | No | Yes | No | No | Yes | Fair
Scott & Anderson, 1990^35^ NA | No | No | Yes | Yes | No | No | Yes | No | Yes | Yes | Fair
Senft et al., 1997^36^ Freeborn et al., 2000^37^ NA | Unclear/NR | Unclear/NR | Yes | Yes | Unclear/NR | No | No | Unclear/NR | Yes | Yes | Fair
Wallace et al., 1998^38^ NA | Unclear/NR | Unclear/NR | Yes | Yes | No | No | No | Unclear/NR | Modified ITT | Yes | Fair

Abbreviations: ELM = Early Lifestyle Modification; GOAL = Guiding Older Adults Lifestyles; HLAYA = Healthy Living As You Age; ITT = intent-to-treat; NA = not applicable; NR = not reported; SIP (Bischof, et al) = Stepped Intervention for Problem Drinkers; SIP (Saitz, et al.) = Screening and Intervention in Primary Care; TrEAT = Trial for Early Alcohol Treatment.

Comments on efficacy/effectiveness trials rated “poor” (high risk of bias):

- Aalto et al., 2000^39^:
  - 34% overall loss to followup, with large differences between groups (that could affect results), possibly because of small sample sizes;
  - No approach to handling missing data in analyses;
  - Unclear blinding of participants or outcome assessors
  - Unclear intervention delivery.
  - Inadequate allocation concealment, with intervening physician “drawing a card” to assign randomization condition to patients during intervention
- Aalto et al., 2001^40^:
  - 32% overall loss to followup, with large differences between groups (that could affect results), possibly because of small sample sizes;
  - No approach to handling missing data in analyses;
  - Unclear blinding of participants or outcome assessors
  - Unclear intervention delivery;
  - Inadequate allocation concealment, with intervening physician “drawing a card” to assign randomization condition to patients during intervention.
- Babor et al., 2006^41^:
  - High risk of selection bias and confounding due to attrition;
  - 65% or more of those eligible for 3 month followup did not complete 3-month followup, and less than half of those intended to be sampled for 3-month followup completed 3-month followup;
  - The study was randomized by clinic/practice, but analyzed at the individual level;
  - Unable to determine if groups were similar at baseline for important potential confounders;
  - Unable to separate results for zone 1 vs. zone 2 vs. zone 3;
  - By design, only some of those enrolled were actually contacted for followup.
- Beich et al., 2007^42^:
  - High risk of bias due to attrition;
  - High risk of selection bias due to inability to maintain comparable groups;
  - Over 50% of subjects in the intervention group and over 23% of subjects in the control group did not complete the secondary baseline questionnaire with recall of drinking behavior information;
  - The endpoint (1 year followup) was completed by only 53.8% of the intervention group and 64.4% of the control group.
- Cordoba et al., 1998^43^:
  - 270/546 excluded from analysis (49%) because of loss to followup or nonadherence to protocol (60/270). Therefore, not intention-to-treat analysis (completers analysis);
  - Unit of randomization was the primary care practice; unit of analysis was the patient;
- Drummond et al., 2009^44^:
  - Differential attrition: 10.3% for minimal intervention group vs. 28% for stepped care;
  - Data analysis states that it was ITT, but from the results tables it appears that they only analyzed the completers and did not do anything to address missing data/imputation;
  - As described by the authors sample size calculations, this is an underpowered pilot study.
- Heather et al, 1987^45^:
  - Media-recruited problem drinkers received 2 levels of self-help intervention;
  - Attrition rate 55% with differences between groups;
  - No replacement of missing values in analysis.
  - Also, perhaps should be excluded for wrong setting/population because of media, rather than primary care, recruitment of subjects
- McIntosh et al., 1997^46^:
  - Inadequate power for analyses, including all participants at baseline; thus, results reported by sex subgroups must be underpowered. They determined 50 patients would be needed in each group to detect a 10% effect; they didn't have 50 subjects in each group---just 40 in the “physician intervention” group; and the study found no difference, but they didn't have an adequate number of subjects in each group to detect a small difference.
  - Unclear allocation concealment
  - Baseline differences between groups, including differences in alcohol quantity and frequency measures, particularly among women;
- Romelsjo et al., 1989^47^:
  - Masking of general practitioner not assured;
  - Significant postrandomization exclusion (151/258 participants);
  - Inclusion criteria not adequately applied, resulting in missing most eligible persons based on drinking (and not laboratory levels);
  - Noncomparable groups assembled at baseline with respect to alcohol consumption and problems, and no adjustment for differences;
  - Does not appear to be intention-to-treat analysis because some cases followed up were not included in reported analyses;
  - No statistical testing of results reported.
- Vinson et al., 2000^48^:
  - High risk of selection bias and difficult to assess risk of selection bias with no data reported for comparability of groups at baseline;
  - Data analysis unclear, unable to determine what was done for the missing data/attrition and whether ITT or completers analysis;
  - Very little data reported overall;
  - Significant changes to protocol during the study and between those enrolled in 1992 and 1993;
  - Randomization in 1992 not described enough to determine if appropriate;
  - Group Ns not reported;
  - Only half of eligible patients enrolled.

Table D-2 Quality ratings for Harms trials

Author, Year Trial Name | Harms Pre-specified and Defined | Ascertainment Techniques for Harms Adequately Described | Ascertainment Techniques for Harms Equal, Valid, and Reliable | Duration of Followup Adequate for Harms Assessment? | Harms Assessment Quality Rating
Anderson & Scott, 1992^1^ NA | Mixed | No | Mixed | Yes | Fair
Fleming et al., 1997^8^ Fleming et al., 2000^9^ Fleming et al., 2002^10^ Grossberg et al., 2000^11^ Manwell et al., 2004^12^ Project TrEAT | No | No | NR | Yes | Fair
Fleming et al., 1999^13^ Mundt et al., 2005^14^ United States GOAL | Yes | No | Yes | Yes | Fair
Scott & Anderson, 1990^35^ United Kingdom NA | Mixed | No | Mixed | Yes | Fair
Wallace et al., 1998^38^ United Kingdom NA | Yes | No | No | Yes | Fair

Abbreviations: GOAL = Guiding Older Adults Lifestyles; NA = not applicable; TrEAT = Trial for Early Alcohol Treatment.

Table D-3 Quality ratings for systematic reviews (KQ 2)

First Author, Year | Review Based on a Focused Question of Interest | Search Strategy Employed a Comprehensive, Systematic, Literature Search | Eligibility Criteria for Studies Clearly Described | At Least 2 People Independently Reviewed Studies | Authors Used a Standard Method of Critical Appraisal Before Including Studies | Publication Bias Assessed | Heterogeneity Assessed and Addressed | Approach Used to Synthesize Information Adequate and Appropriate | Quality Rating
Berks, 2008^49^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Fair
Berner, 2007^50^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Bradley, 1998^51^ | Yes | Yes | Yes | Yes | Yes | No | CND | Yes | Fair
Burns, 2010^52^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Fair
Fiellin, 2000^53^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Fair

Abbreviations: CND = cannot determine.

Table D-4 Quality ratings for systematic reviews (all other KQs)

First author, year | Review based on a focused question of interest | Search strategy employed a comprehensive, systematic, literature search | Eligibility criteria for studies clearly described | At least 2 people independently review studies | Authors used a standard method of critical appraisal before including studies | Publication bias assessed | Heterogeneity assessed and addressed | Approach used to synthesize information adequate and appropriate | Quality Rating
Kaner, 2007^54^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good