# Evidence Tables

Evidence Table 1 Characteristics of included randomized controlled trials

Evidence Table 2 Characteristics of samples from included randomized controlled trials

Evidence Table 3 Intervention and control components from randomized controlled trials

Evidence Table 4 Outcomes by study

Evidence Table 5 Data for KQ 2 from systematic reviews

Evidence Table 6 Data for KQ 1 through 7 from systematic review

## References

1 Anderson P, Scott E. The effect of general practitioners' advice to heavy drinking men. Br J Addict. 1992;6:891-900. [pmid: 1525531].
2 World Health Organization Brief Interventions Study Group. A cross-national trial of brief interventions with heavy drinkers. WHO Brief Intervention Study Group. Am J Public Health. Jul. 1996;86(7):948-55. [pmid: 8669518].
3 Bischof G, Grothues JM, Reinhardt S, et al. Evaluation of a telephone-based stepped care intervention for alcohol-related disorders: a randomized controlled trial. Drug Alcohol Depend. Mar. 1. 2008;93(3):244-51. [pmid: 18054443].
4 Grothues JM, Bischof G, Reinhardt S, et al. Effectiveness of brief alcohol interventions for general practice patients with problematic drinking behavior and comorbid anxiety or depressive disorders. Drug Alcohol Depend. Apr. 1. 2008;94(1-3):214-20. [pmid: 18207336].
5 Reinhardt S, Bischof G, Grothues J, et al. Gender differences in the efficacy of brief interventions with a stepped care approach in general practice patients with alcohol-related disorders. Alcohol Alcohol. May-Jun. 2008;43(3):334-40. [pmid: 18263901].
6 Chang G, Wilkins-Haug L, Berman S, et al. Brief intervention for alcohol use in pregnancy: a randomized trial. Addiction. Oct. 1999;94(10):1499-508. [pmid: 10790902].
7 Curry SJ, Ludman EJ, Grothaus LC, et al. A randomized trial of a brief primary-care-based intervention for reducing at-risk drinking practices. Health Psychol. Mar. 2003;22(2):156-65. [pmid: 12683736].
8 Fleming MF, Barry KL, Manwell LB, et al. Brief physician advice for problem alcohol drinkers. A randomized controlled trial in community-based primary care practices. JAMA. Apr. 2. 1997;277(13):1039-45. [pmid: 9091691].
9 Fleming MF, Mundt MP, French MT, et al. Benefit-cost analysis of brief physician advice with problem drinkers in primary care settings. Med Care. Jan. 2000;38(1):7-18. [pmid: 10630716].
10 Fleming MF, Mundt MP, French MT, et al. Brief physician advice for problem drinkers: long-term efficacy and benefit-cost analysis. Alcohol Clin Exp Res. Jan. 2002;26(1):36-43. [pmid: 11821652].
11 Manwell LB, Fleming MF, Mundt MP, et al. Treatment of problem alcohol use in women of childbearing age: results of a brief intervention trial. Alcohol Clin Exp Res. Oct. 2000;24(10):1517-24. [pmid: 11045860].
12 Grossberg PM, Brown DD, Fleming MF. Brief physician advice for high-risk drinking among young adults. Ann Fam Med. Sep-Oct. 2004;2(5):474-80. [pmid: 15506584].
13 Fleming MF, Manwell LB, Barry KL, et al. Brief physician advice for alcohol problems in older adults: a randomized community-based trial. J Fam Pract. May. 1999;48(5):378-84. [pmid: 10334615].
14 Mundt MP, French MT, Roebuck MC, et al. Brief physician advice for problem drinking among older adults: an economic analysis of costs and benefits. J Stud Alcohol. May. 2005;66(3):389-94. [pmid: 16047528].
15 Fleming MF, Lund MR, Wilton G, et al. The Healthy Moms Study: the efficacy of brief alcohol intervention in postpartum women. Alcohol Clin Exp Res. Sep. 2008;32(9):1600-6. [pmid: 18627361].
16 Wilton G, Moberg DP, Fleming MF. The effect of brief alcohol intervention on postpartum depression. MCN Am J Matern Child Nurs. Sep-Oct. 2009;34(5):297-302. [pmid: 19713798].
17 Fleming MF, Balousek SL, Grossberg PM, et al. Brief physician advice for heavy drinking college students: a randomized controlled trial in college health clinics. J Stud Alcohol Drugs. Jan. 2010;71(1):23-31. [pmid: 20105410].
18 Kypri K, Saunders JB, Williams SM, et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. Nov. 2004;99(11):1410-7. [pmid: 15500594].
19 Kypri K, Langley JD, Saunders JB, et al. Assessment may conceal therapeutic benefit: findings from a randomized controlled trial for hazardous drinking. Addiction. Jan. 2007;102(1):62-70. [pmid: 17207124].
20 Kypri K, Langley JD, Saunders JB, et al. Randomized controlled trial of web-based alcohol screening and brief intervention in primary care. Arch Intern Med. Mar. 10. 2008;168(5):530-6. [pmid: 18332300].
21 Lin JC, Karno MP, Tang L, et al. Do health educator telephone calls reduce at-risk drinking among older adults in primary care?. J Gen Intern Med. 2010;25(4):334-9. [pmid: 20101471].
22 Moore AA, Blow FC, Hoffing M, et al. Primary care-based intervention to reduce at-risk drinking in older adults: a randomized controlled trial. Addiction. Jan. 2011;106(1):111-20. [pmid: 21143686].
23 Lock CA, Kaner E, Heather N, et al. Effectiveness of nurse-led brief alcohol intervention: a cluster randomized controlled trial. J Adv Nurs. May. 2006;54(4):426-39. [pmid: 16671972].
24 Maisto SA, Conigliaro J, McNeil M, et al. Effects of two types of brief intervention and readiness to change on alcohol use in hazardous drinkers. J Stud Alcohol. Sep. 2001;62(5):605-14. [pmid: 11702799].
25 Maisto SA, Conigliaro J, McNeil M, et al. The relationship between eligibility criteria for participation in alcohol brief intervention trials and other alcohol and health-related variables. Am J Addict. Summer. 2001;10(3):218-31. [pmid: 11579620].
26 Gordon AJ, Conigliaro J, Maisto SA, et al. Comparison of consumption effects of brief interventions for hazardous drinking elderly. Subst Use Misuse. Jun. 2003;38(8):1017-35. [pmid: 12901447].
27 Noknoy S, Rangsin R, Saengcharnchai P, et al. RCT of effectiveness of motivational enhancement therapy delivered by nurses for hazardous drinkers in primary care units in Thailand. Alcohol Alcohol. May-Jun. 2010;45(3):263-70. [pmid: 20236990].
28 Ockene JK, Adams A, Hurley TG, et al. Brief physician- and nurse practitioner-delivered counseling for high-risk drinkers: does it work?. Arch Intern Med. Oct. 11. 1999;159(18):2198-205. [pmid: 10527297].
29 Ockene JK, Reed GW, Reiff-Hekking S. Brief patient-centered clinician-delivered counseling for high-risk drinking: 4-year results. Ann Behav Med. Jun. 2009;37(3):335-42. [pmid: 19707840].
30 Reiff-Hekking S, Ockene JK, Hurley TG, et al. Brief physician and nurse practitioner-delivered counseling for high-risk drinking. Results at 12-month follow-up. J Gen Intern Med. Jan. 2005;20(1):7-13. [pmid: 15693921].
31 Richmond R, Heather N, Wodak A, et al. Controlled evaluation of a general practice-based brief intervention for excessive drinking. Addiction. Jan. 1995;90(1):119-32. [pmid: 7888970].
32 Rubio G, Jimenez-Arriero MA, Martinez I, et al. Efficacy of physician-delivered brief counseling intervention for binge drinkers. Am J Med. Jan. 2010;123(1):72-8. [pmid: 20102995].
33 Saitz R, Horton NJ, Sullivan LM, et al. Addressing alcohol problems in primary care: a cluster randomized, controlled trial of a systems intervention. The screening and intervention in primary care (SIP) study. Ann Intern Med. Mar. 4. 2003;138(5):372-82. [pmid: 12614089].
34 Schaus JF, Sole ML, McCoy TP, et al. Alcohol screening and brief intervention in a college student health center: a randomized controlled trial. J Stud Alcohol Drugs Suppl. Jul. 2009;(16):131-41. [pmid: 19538921].
35 Scott E, Anderson P. Randomized controlled trial of general practitioner intervention in women with excessive alcohol consumption. Drug Alcohol Rev. 1990;10(4):313-21. [pmid: 16818295].
36 Senft RA, Polen MR, Freeborn DK, et al. Brief intervention in a primary care setting for hazardous drinkers. Am J Prev Med. Nov-Dec. 1997;13(6):464-70. [pmid: 9415794].
37 Freeborn DK, Polen MR, Hollis JF, et al. Screening and brief intervention for hazardous drinking in an HMO: effects on medical care utilization. J Behav Health Serv Res. Nov. 2000;27(4):446-53. [pmid: 11070638].
38 Wallace P, Cutler S, Haines A. Randomised controlled trial of general practitioner intervention in patients with excessive alcohol consumption. BMJ. Sep. 10. 1988;297(6649):663-8. [pmid: 3052668].
39 Berks J, McCormick R. Screening for alcohol misuse in elderly primary care patients: a systematic literature review. Int Psychogeriatr. Dec. 2008;20(6):1090-103. [pmid: 18538045].
40 Berner MM, Kriston L, Bentele M, et al. The alcohol use disorders identification test for detecting at-risk drinking: a systematic review and meta-analysis. J Stud Alcohol Drugs. May. 2007;68(3):461-73. [pmid: 17446987].
41 Bradley KA, Boyd-Wickizer J, Powell SH, et al. Alcohol screening questionnaires in women: a critical review. JAMA. Jul. 8. 1998;280(2):166-71. [pmid: 9669791].
42 Burns E, Gray R, Smith LA. Brief screening questionnaires to identify problem drinking during pregnancy: a systematic review. Addiction. Apr. 2010;105(4):601-14. [pmid: 20403013].
43 Fiellin DA, Reid MC, O'Connor PG. Screening for alcohol problems in primary care: a systematic review. Arch Intern Med. Jul. 10. 2000;160(13):1977-89. [pmid: 10888972].
44 Kaner EF, Beyer F, Dickinson HO, et al. Effectiveness of brief alcohol interventions in primary care populations. Cochrane Database Syst Rev. 2007;(2):CD004148. [pmid: 17443541].