# Search Strategy

MEDLINE^®^

Search | Most Recent Queries | Result
#1 | Search “Alcohol-Related Disorders”[Mesh] | 86771
#2 | Search “Alcohol Drinking”[Mesh] | 41573
#3 | Search “Alcoholism”[Mesh] | 61181
#4 | Search “drinking behavior”[MeSH Terms] | 46604
#5 | Search problem drink* | 2021
#6 | Search heavy drink* | 3931
#7 | Search alcohol problem* | 2639
#8 | Search risk drink* | 563
#9 | Search at-risk drink* | 234
#10 | Search alcohol depend* | 6983
#11 | Search excessive drink* | 610
#12 | Search excessive alcohol* | 1501
#13 | Search “alcohol consumption”[All Fields] | 21680
#14 | Search alcohol addiction* | 596
#15 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 | 132104
#17 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 437318
#18 | Search #15 AND #17 | 4529
#19 | Search “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 45475
#20 | Search #15 AND #19 | 583
#21 | Search “Comparative Study”[Publication Type] | 1498440
#22 | Search #15 AND #21 | 13766
#23 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 38090
#24 | Search #15 AND #23 | 417
#25 | Search #18 OR #20 OR #22 OR #24 | 17884
#27 | Search “alcohol reduction” | 67
#28 | Search brief intervention* | 1393
#29 | Search early intervention* | 8437
#30 | Search minimal intervention* | 506
#31 | Search alcohol therap* | 33
#32 | Search alcohol treatment* | 1444
#33 | Search harm reduc* | 2065
#34 | Search “screening”[All Fields] AND alcohol | 9987
#35 | Search “counseling”[All Fields] AND alcohol | 1912
#36 | Search controlled drink* | 189
#37 | Search “intervention”[All Fields] | 248640
#38 | Search secondary prevention* | 9795
#39 | Search “general practitioner's advice”[All Fields] | 2
#40 | Search “Mass Screening”[MeSH] | 83521
#41 | Search “Counseling”[MeSH] | 27836
#42 | Search “Psychotherapy”[MeSH] | 130426
#43 | Search “Evidence-Based Practice”[Mesh] | 42726
#44 | Search naltrexone | 7002
#45 | Search revia | 7003
#46 | Search vivitrol | 8
#47 | Search acamprosate | 398
#48 | Search campral | 398
#49 | Search disulfiram | 3524
#50 | Search antabuse | 3594
#51 | Search (“health education”[MeSH Terms] OR “health education”[All Fields]) AND (“pamphlets”[MeSH Terms] OR “pamphlets”[All Fields]) | 1948
#52 | Search “counseling”[All Fields] AND drink* | 947
#53 | Search “screening”[All Fields] AND drink* | 3181
#54 | Search #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 OR #49 OR #50 OR #51 OR #52 OR #53 | 533938
#60 | Search #15 Limits: Clinical Trial, Meta-Analysis, Randomized Controlled Trial, Clinical Trial, Phase I, Clinical Trial, Phase II, Clinical Trial, Phase III, Clinical Trial, Phase IV, Comparative Study, Controlled Clinical Trial, Multicenter Study | 19163
#61 | Search #25 OR #60 | 20264
#62 | Search #61 AND #54 | 3749
#63 | Search ((#62) AND “1985/01/01”[Publication Date] : “3000”[Publication Date]) AND “0”[Publication Date] : “3000”[Publication Date] | 3483
#64 | Search #63 Limits: Humans, English Sort by: Author | 3178

Search | PubMed Search for Additional Articles 2.2.2011 | Result
#1 | Search SBIRT[tiab] | 29
#2 | “drinking”[tiab] OR “drinkers”[tiab] | 65791
#3 | “alcohol”[tiab] | 144585
#4 | “counseling”[tiab] | 14185
#5 | (#2 AND #3 AND #4) AND “1985/0101”[Publication Date] : “3000”[Publication Date]) AND “0”[Publication Date] : “3000”[Publication Date] Sort by: Author | 107
#6 | “randomized controlled trial”[tiab] | 17092
#7 | (#2 AND #3 AND #6) AND “1985/01/01”[Publication Date] : “3000”[Publication Date]) AND “0”[Publication Date] : “3000”[Publication Date] | 150
#8 | #1 OR #5 OR #7 | 281

Note: On February 25, 2011, we added the search term “Alcohol Deterrents”[MeSH], which resulted in 28 (all non-duplicate) abstracts.

Note: On March 7, 2011, per a TEP member's suggestion, we added the terms risky alcohol*, risky drink*, alcohol misuse, alcohol abuse, hazardous alcohol*, hazardous drink*, harmful alcohol*, and harmful drink* which resulted in 428 (77 nonduplicate) abstracts.

Note: On April 28, 2011, we amended the protocol to exclude studies of pharmacotherapy for alcohol dependence. However, because our scope included pharmacotherapy at the time of the searches, the pharmaceutical-related terms remain in the search strategy above.

A search with analogous terms was performed in the following databases:

- IPA, CINAHL^®^, and PsycINFO^®^ (2/1/2011) = 468 (164 after duplicates removed)
- Embase^®^ (2/1/2011) = 1,753 (1,060 after duplicates removed)
- Cochrane (1/31/2011) = 2,570 (1,257 after duplicates removed)

Total references identified by the main searches = 8,706

The following update searches were performed on August 29, 2011

MEDLINE^®^

Search | Most Recent Queries | Result
#1 | Search “Alcohol-Related Disorders”[Mesh] OR “Alcohol Drinking”[Mesh] OR “Alcoholism”[Mesh] OR “drinking behavior”[MeSH Terms] OR problem drink* OR heavy drink* OR alcohol problem* OR risk drink* OR at-risk drink* OR alcohol depend* OR excessive drink* OR excessive alcohol* OR “alcohol consumption”[All Fields] OR alcohol addiction* OR risky alcohol* OR risky drink* OR “alcohol misuse”[tiab] OR “alcohol abuse”[tiab] OR hazardous alcohol* OR hazardous drink* OR harmful alcohol* OR harmful drink* OR “SBIRT”[tiab] OR ((“drinking”[tiab] OR “drinkers”[tiab]) AND “alcohol”[tiab]) | 141968
#2 | Search “alcohol reduction” OR brief intervention* OR early intervention* OR minimal intervention* OR alcohol therap* OR alcohol treatment* OR harm reduc* OR (“screening”[All Fields] AND alcohol) OR (“counseling”[All Fields] AND alcohol) OR controlled drink* OR “intervention”[All Fields] OR secondary prevention* OR “general practitioner's advice”[All Fields] OR “Mass Screening”[MeSH] OR “Counseling”[MeSH] OR “Psychotherapy”[MeSH] OR “Evidence-Based Practice”[Mesh] OR ((“health education”[MeSH Terms] OR “health education”[All Fields]) AND (“pamphlets”[MeSH Terms] OR “pamphlets”[All Fields])) OR “Alcohol Deterrents”[MeSH] OR (“screening”[All Fields] AND drink*) OR (“counseling”[All Fields] AND drink*) | 549311
#3 | Search #1 AND #2 | 16041
#4 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 453968
#5 | Search “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 49653
#6 | Search “Comparative Study”[Publication Type] | 1526061
#7 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 42341
#8 | Search ((#3 AND (#4 OR #5 OR #6 OR #7)) AND “2011/01/01”[Entrez Date] : “3000”[Entrez Date]) AND “0”[Entrez Date] : “3000”[Entrez Date] | 69
#9 | Search #3 Limits: Clinical Trial, Meta-Analysis, Randomized Controlled Trial, Clinical Trial, Phase I, Clinical Trial, Phase II, Clinical Trial, Phase III, Clinical Trial, Phase IV, Comparative Study, Controlled Clinical Trial, Multicenter Study | 3494
#10 | Search ((#9) AND “2011/01/01”[Entrez Date] : “3000”[Entrez Date]) AND “0”[Entrez Date] : “3000”[Entrez Date] | 51
#11 | Search #8 OR #10 | 72
#12 | Search #11 Limits: Humans, English | 59

Searches with analogous terms and publication dates in the year 2011 were performed on August 29, 2011 in the following databases:

- IPA, CINAHL^®^, and PsycINFO^®^ = 4
- Embase^®^ = 84
- Cochrane = 173

Total additional references identified by the update searches = 320; 275 remained after duplicates were removed.

## Handsearches of the following references yielded 227 articles

A search of clinicaltrials.gov yielded 282 trials that resulted in 216 publications

Total references from main and update searches, handsearches, and the clinicaltrials.gov search, minus duplicates = 6,265

Ballesteros J, Duffy JC, Querejeta I, et al. Efficacy of brief interventions for hazardous drinkers in primary care: systematic review and meta-analyses. Alcohol Clin Exp Res. Apr. 2004;28(4):608-18. [pmid: 15100612].
Beich A, Thorsen T, Rollnick S. Screening in brief intervention trials targeting excessive drinkers in general practice: systematic review and meta-analysis. BMJ. Sep. 6. 2003;327(7414):536-42. [pmid: 12958114].
Bertholet N, Daeppen JB, Wietlisbach V, et al. Reduction of alcohol consumption by brief alcohol intervention in primary care: systematic review and meta-analysis. Arch Intern Med. May. 9. 2005;165(9):986-95. [pmid: 15883236].
Cuijpers P, Riper H, Lemmers L. The effects on mortality of brief interventions for problem drinking: a meta-analysis. Addiction. Jul. 2004;99(7):839-45. [pmid: 15200579].
Drummond C, Coulton S, James D, et al. Effectiveness and cost-effectiveness of a stepped care intervention for alcohol use disorders in primary care: pilot study. Br J Psychiatry. Nov. 2009;195(5):448-56. [pmid: 19880936].
Fleming MF, Balousek SL, Grossberg PM, et al. Brief physician advice for heavy drinking college students: a randomized controlled trial in college health clinics. J Stud Alcohol Drugs. Jan. 2010;71(1):23-31. [pmid: 20105410].
Kaner EF, Beyer F, Dickinson HO, et al. Effectiveness of brief alcohol interventions in primary care populations. Cochrane Database Syst Rev. 2007;(2):CD004148. [pmid: 17443541].
Lin JC, Karno MP, Tang L, et al. Do health educator telephone calls reduce at-risk drinking among older adults in primary care?. Journal of General Internal Medicine. 2010;25(4):334-9. First Author & Affiliation: Lin, James C. [pmid: 20101471].
Moore AA, Blow FC, Hoffing M, et al. Primary care-based intervention to reduce at-risk drinking in older adults: a randomized controlled trial. Addiction. Jan. 2011;106(1):111-20. [pmid: 21143686].
Stade BC, Bailey C, Dzendoletas D, et al. Psychological and/or educational interventions for reducing alcohol consumption in pregnant women and women planning pregnancy. Cochrane Database Syst Rev. 2009;(2):CD004228. [pmid: 19370597].