# Acknowledgments

We gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Jennifer M. Croswell, M.D., M.P.H., and the support of our former AHRQ Task Order Officer, Sonia Tyutyulkova, M.D., Ph.D. We extend our appreciation to our Key Informants and members of our Technical Expert Panel, all of whom provided thoughtful advice and input during our research process.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina at Chapel Hill. We express our gratitude to the following individuals for their contributions to this project: Carol Woodell, B.S.P.H., our Project Manager; Meera Viswanathan, Ph.D., Director of the RTI-UNC EPC; Timothy S. Carey, M.D., M.P.H, Director of the Cecil G. Sheps Center for Health Services Research at UNC; Megan Van Noord, M.S.L.S., our EPC Librarian; Carol Offen, editor, and Loraine Monroe, our EPC publications specialist.