# Results

This chapter reports on the results of our literature review and synthesis. First, we describe the results of our literature search and selection process. Description of the characteristics and methodological quality of the studies follow. For Key Questions (KQs) 1, 2, 4, and 5, we present the results of our analysis separately for schizophrenia and bipolar disorder and then by comparison. The findings for KQ3 are presented at the end of this section and are organized by comparison across both conditions. The results of all meta-analyses, including sample sizes, effect estimates, 95% confidence intervals (CI), and I-squared (I^2^) statistics, are available in evidence tables for each comparison.

Several appendixes provide supporting information to the findings presented in this section. A list of citations for the excluded and unobtained studies and for companion studies are provided in Appendix C and D, respectively. Risk of bias assessments for trials are available in Appendix E and F, and quality assessments for cohort studies are available in Appendix G. A description of the general characteristics of the included studies and patient flow through the studies are provided in Appendix H and I, respectively. Forest plots for adverse events (AEs) (KQ3) and funnel plots for all comparisons and outcomes for which there were 10 or more studies are available in Appendix J and K, respectively. Appendix L contains evidence tables for core illness symptom subscales, composite outcomes, and measures of functional capacity (e.g., memory, recall, and motor skills). Appendix M contains evidence tables for subgroup and sensitivity analyses. Appendix N contains evidence tables for AEs.

## Literature Search

All citations identified through electronic or hand searching and expert nomination were combined into a single database (Figure 2).42 Of the 11,576 citations identified, 2,165 were duplicates and 9,411 were unique study reports.

Figure 2 Flow diagram for study retrieval and selection

Figure 2 is a flow diagram that outlines the study retrieval and selection process. It consists of boxes with text that describes the study selection process from the total number of citations retrieved from the literature searches to the number of studies that satisfied the inclusion criteria of the report. This figure is described further in page 17 of the results section as follows: “All citations identified through electronic or hand searching and expert nomination were combined into a single database. Of the 11,576 citations identified, 2,165 were duplicates and 9,411 were unique study reports. Following level 1 screening, 8,219 were excluded, and 1,192 were further evaluated for inclusion. Of these, 125 primary publications passed level 2 screening and were included in this comparative effectiveness review (CER). An additional 146 companion publications passed level 2 screening and are also included. The main reasons for exclusion were publication type (e.g., case-control study, observational study with followup <2 years, or review article), population characteristics (e.g., patient age and other psychiatric condition), use of antipsychotic medications that are not Food and Drug Administration (FDA)-approved or medications no longer available in the U.S., and no extractable data related to the outcomes of interest (e.g., ongoing studies).”

Following level 1 screening, 8,219 were excluded, and 1,192 were further evaluated for inclusion. Of these, 125 primary publications23,31–33,43–163 passed level 2 screening and were included in this comparative effectiveness review (CER). An additional 146 companion publications passed level 2 screening and are also included. The characteristics of the publications excluded at level 2 screening are presented in Figure 2 and Appendix C. The main reasons for exclusion were publication type (e.g., case-control study, observational study with followup <2 years, or review article), population characteristics (e.g., patient age and other psychiatric condition), use of antipsychotic medications that are not Food and Drug Administration (FDA)-approved or medications no longer available in the U.S., and no extractable data related to the outcomes of interest (e.g., ongoing studies).

## Description of Included Studies

The 125 unique studies23,31–33,43–163 included in this review are described in detail in the evidence tables found in Appendixes H and I. An overview is provided in Table 4, Table 5, and Table 6. The 146 companion articles that met our inclusion criteria were used for data that were not provided in the primary report. The primary studies were published between 1974 and 2010 (median = 2002 [interquartile range (IQR), 1998 to 2006]). The majority of the studies were randomized controlled trials (RCTs) (97 percent) and were conducted in multicenter settings (56 percent). Studies were most frequently conducted in North America (46 percent). The number of enrolled participants ranged from 10 to 95,632 (median = 86 [IQR, 36 to 300]). The mean age of study participants ranged from 21 to 50 years (median = 37 years [IQR, 33 to 41]). The length of followup ranged from <1 day to 22 years (median = 8 weeks [IQR, 6 to 26 weeks]). Seventy percent of studies (n = 88) had some form of support from the pharmaceutical industry.

Table 4 Characteristics of included studies

Category | Characteristic | Number of studies (%)
Study design | RCT | 121 (96.8%)
Study design | nRCT | 2 (1.6%)
Study design | Retrospective cohort study | 2 (1.6%)
Number of centers | Multicenter | 70 (56.0%)
Number of centers | Single center | 52 (41.6%)
Number of centers | Two centers | 3 (2.4%)
Setting | Inpatient | 62 (49.6%)
Setting | Outpatient | 19 (15.2%)
Setting | Mixed | 26 (20.8%)
Setting | Unclear or not reported | 18 (14.4%)
Country | Africa | 2 (1.6%)
Country | Asia | 18 (14.4%)
Country | Australia | 1 (0.8%)
Country | Europe | 23 (18.4%)
Country | Middle East | 1 (0.8%)
Country | North America | 51 (40.8%)
Country | South America | 5 (4.0%)
Country | International (including North America) | 6 (4.8%)
Country | International (not including North America) | 18 (14.4%)

nRCT = nonrandomized controlled trial; RCT = randomized controlled trial

Table 5 Drug comparisons available and number of studies for each comparison

| Aripiprazole | Asenapine | Clozapine | Olanzapine | Quetiapine | Risperidone | Ziprasidone
Chlorpromazine | | | 13 | 1 | 1 | | 1
Fluphenazine | | | | 2 | 1 | 1
Haloperidol | 10 | 1 | 11 | 37 | 12 | 43 | 10
Perphenazine | 1 | | | 2 | 1 | 2 | 1
Trifluoperazine | | | 1
Thioridazine | | | 1 | | | 1

Table 6 Comparisons in the included studies by condition

Comparison | Schizophrenia (n) | Bipolar disorder (n)
Chlorpromazine vs. Clozapine | 12 | 1
Chlorpromazine vs. Olanzapine | 1 | 0
Chlorpromazine vs. Quetiapine | 1 | 0
Chlorpromazine vs. Ziprasidone | 1 | 0
Fluphenazine vs. Olanzapine | 2 | 0
Fluphenazine vs. Quetiapine | 1 | 0
Fluphenazine vs. Risperidone | 1 | 0
Haloperidol vs. Aripiprazole | 8 | 2
Haloperidol vs. Asenapine | 1 | 0
Haloperidol vs. Clozapine | 11 | 0
Haloperidol vs. Olanzapine | 35 | 2
Haloperidol vs. Quetiapine | 11 | 1
Haloperidol vs. Risperidone | 39 | 5
Haloperidol vs. Ziprasidone | 9 | 1
Perphenazine vs. Aripiprazole | 1 | 0
Perphenazine vs. Olanzapine | 2 | 0
Perphenazine vs. Quetiapine | 1 | 0
Perphenazine vs. Risperidone | 2 | 0
Perphenazine vs. Ziprasidone | 1 | 0
Trifluoperazine vs. Clozapine | 1 | 0
Thioridazine versus Clozapine | 1 | 0
Thioridazine versus Risperidone | 1 | 0

N = number; Vs. = versus

A total of 113 studies examined adults with schizophrenia or related psychoses, 11 studies examined adults with bipolar disorder, and 1 study examined adults with either diagnosis. Overall, the studies examined 22 comparisons of individual first-generation antipsychotics (FGAs) and individual second-generation antipsychotics (SGAs) (Table 5 and Table 6).

## Methodological Quality of Included Studies

Two independent reviewers assessed the risk of bias of RCTs and nonrandomized trials (nRCTs) using the Risk of Bias tool and the methodological quality of cohort studies using the Newcastle-Ottawa Scale. Consensus ratings are presented in Appendix E through G. A summary of the overall quality by study design is presented below.

### Randomized and Nonrandomized Controlled Trials

None of the 123 included trials23,31–33,43–161 were rated as having a low risk of bias. The majority of the trials (n = 78)23,31–33,43,44,46,47,49–56,59–61,64,66,67,70,72,74,78–81,84,85,87–89,93,94,96,97,99,101–110,112,113,115,117–127,131–134,138,143,145–147,150,153–155,158,160 were rated as having an unclear risk of bias due to under-reporting in the articles. The key potential biases in these studies were related to selection bias (i.e., random sequence generation and allocation concealment) and performance bias (i.e., proper blinding of participants and study personnel) (Appendix E and F). The remaining trials (n = 45)45,48,57,58,62,63,65,68,69,71,73,75–77,82,83,86,90–92,95,98,100,111,114,116,128–130,135–137,139–142,144,148,149,151,152,156,157,159,161 were considered to have a high risk of bias. The key potential biases in these studies were related to attrition bias (i.e., incomplete outcome data) and performance bias (i.e., proper blinding of participants and study personnel) (Appendix E and F). A summary of the distribution of scores across the risk of bias domains is presented in Table 7.

Table 7 Distribution of risk of bias scores by domain for trials

Domain | High | Unclear | Low
Adequate sequence generation | 3 (2.4%) | 105 (85.4%) | 15 (12.2%)
Allocation concealment | 1 (0.8%) | 116 (94.3%) | 6 (4.9%)
Blinding | 21 (17.1%) | 83 (67.5%) | 19 (15.4%)
Incomplete outcome data addressed | 24 (19.5%) | 32 (26.0%) | 67 (54.5%)
Free of selective reporting | 1 (0.8%) | 3 (2.4%) | 119 (96.7%)
Free of other bias | 0 (0.0%) | 20 (16.3%) | 103 (83.7%)

### Cohort Studies

Two cohort studies162,163 met the inclusion criteria. The methodological quality of the cohort studies was good (8 of a possible 9 stars for both studies). Both of the studies received only 1 of a possible 2 points for measures taken to ensure the comparability of cohorts.

## Schizophrenia (Key Questions 1, 2, 4, 5)

For schizophrenia, we included 113 studies that enrolled a total of 118,503 patients. The individual studies are described in Appendixes H and I. The results from the studies and pooled analyses are presented in Table 8 through Table 65. Within the forest plots, the studies are presented by year of publication. The following sections are organized by comparison and provide an overview of results according to the KQ: 1) core illness symptoms; 2) functional outcomes and health care system utilization; 4) other outcomes; and 5) subgroup analyses. For comparisons with more than one study, we highlight key points summarizing the overall findings prior to reporting detailed analyses.

Table 8 Characteristics of RCTs comparing chlorpromazine versus clozapine in the treatment of schizophrenia and related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout/Run-in Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Claghorn et al. 1987^63^ RCT (8 wks) | G1: CHL (50–1800mg/d); (76) G2: CLO (25–900mg/d); (75) Run-in phase: 2 wks | Sz w/neurological reactions (either TD or EPS) induced by ≥2 prior AP | High, NR
Ekblom et al. 1974^153^ RCT (5 wks) | G1: CHL (65–700mg/d); (21) G2: CLO (65–600mg/d); (20) Washout period: 2 wks | Male w/acute Sz; relapsed or exacerbated chronic Sz cases of the paranoid/hallucinatory or catatonic type | Unclear, NR
Gelenberg et al. 1979^154^ RCT (8 wks) | G1: CHL (50–1800mg/d); (8) G2: CLO (25–900mg/d); (7) Washout period: 48 hrs | Sz not further defined | Unclear, Industry
Hong et al. 1997^87^ RCT (12 wks) | G1: CHL (50–1800mg/d); (19) G2: CLO (25–900mg/d); (21) Run-in phase: 6 wks | Tx refractory Sz; symptom hx ≥6 mo | Unclear, Academic
Kane et al. 1988^94^ RCT (6 wks) | G1: CHL (1000–1800mg/d); (142) G2: CLO (500–900mg/d); (126) Run-in phase: 6 wks | Hx of tx resistance; ≥3 periods of tx in ≤5 yrs w/AP from 2 different classes; 6 wks w/doses equivalent to 1000mg/d CHL without relief; no period of functioning ≤5 yrs; | Unclear, Multiple sources including industry
Lieberman et al. 2003^109^ RCT (52 wks) | G1: CHL (≤600mg/d); (83) G2: CLO (≤400mg/d); (81) | Sz or schizophreniform disorder; symptoms <60 mo; no prior AP tx | Unclear, Industry
Rinieris et al. 1980^157^ RCT (6 wks) | G1: CHL (50–100mg/d); (16) G2: CLO (50–100mg/d); (5) Run-in phase: 1 wk | Sz not further defined | High, NR
Shopsin et al. 1979^158^ RCT (5 wks) | G1: CHL (50–1600mg/d); (12) G2: CLO (25–900mg/d); (13) Washout period: ≥1 wks | Chronic Sz; recent acute exacerbation necessitating involuntary hospitalization; no spontaneous remission | Unclear, NR
Singer et al. 1974^161^ RCT (40 d) | G1: CHL (50–600mg/d); (20) G2: CLO (50–600mg/d); (20) Washout period: 2 wks | Acute Sz | Unclear, NR

AP(s) = antipsychotic(s); CHL = chlorpromazine; CLO = clozapine; D = days; EPS = extrapyramidal symptoms; G = group; Hr(s) = hour(s); Hx = history; Mg = milligrams; Mo = month; No. = number; NR = not reported; RCT = randomized controlled trial; Sz = schizophrenia; TD = tardive dyskinesia; Tx = treatment; W/= with; Wk(s) = week(s); Yr(s) = year(s)

Table 9 Evidence summary table: chlorpromazine versus clozapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive Symptoms
PANSS87 | 1 | 40 | 2.00 (−0.79, 4.79) | NE | ND
Negative Symptoms
SANS109 | 1 | 164 | 2.00 (−2.66, 6.66) | NE | ND
General Psychopathology
PANSS87 | 1 | 40 | 5.00 (−3.68, 13.7) | NE | ND
Global Ratings and Total Scores
BPRS (On treatment)63,87,94,154,157,161 | 6 | 535 | 8.40 (5.92, 10.90) | 20% | clozapine
BPRS (Treatment naïve)109 | 1 | 164 | −0.20 (−1.38, 0.98) | NE | ND
CGI–I109 | 1 | 164 | −0.20 (−0.63, 0.23) | NE | ND
CGI–S94 | 1 | 268 | 0.90 (0.67, 1.13) | NE | clozapine
GAF109 | 1 | 164 | −1.00 (−12.1, 10.1) | NE | ND
PANSS (total)87 | 1 | 40 | 12.00 (−4.48, 28.5) | NE | ND
Health Care System Utilization
Rates of hospitalization/rehospitalization109 | 1 | 164 | 0.70 (0.23, 2.11)^*^ | NE | ND
Other Outcomes
Response rates87,94,154 | 3 | 323 | 0.13 (0.06, 0.28)^*^ | 0% | clozapine
Remission rates109,158 | 2 | 189 | 0.66 (0.25, 1.74)^*^ | 72% | ND

Note: bolded results are statistically significant;

* binary outcome;

BPRS = Brief Psychiatric Rating Scale; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; GAF = Global Assessment of Functioning; I^2^ = I-squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale; SANS = Scale for the Assessment of Negative Symptoms

Table 10 Strength of evidence (GRADE): chlorpromazine versus clozapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Positive Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Negative Symptoms
SANS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
General Psychopathology
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
Global Ratings and Total Scores
BPRS (on treatment) | 6 RCT | Medium | Consistent | Direct | Precise | Moderate (favoring clozapine)
CGI–I | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
CGI–S | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
GAF | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
SANS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

BPRS = Brief Psychiatric Rating Scale; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; GAF = Global Assessment of Functioning; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SANS = Scale for the Assessment of Negative Symptoms; SoE = Strength of Evidence

Table 11 Characteristics of RCT comparing chlorpromazine versus olanzapine in the treatment of schizophrenia

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Run-in period | Main Inclusion Criteria | Risk of Bias, Financial Support
Conley et al. 1998^66^ RCT (6 wks) | G1: CHL (600–1200mg/d); (42) G2: OLA (12.5–25mg/d); (42) Run-in phase: 6 wks | Tx resistant Sz; ≥2 periods of tx in ≤5 yrs with AP (≥2 classes, excluding HAL), at dosages ≥1000mg/d of CHL equivalents, for 6 wks | Unclear, Multiple sources

AP(s) = antipsychotic(s); CHL = chlorpromazine; D = days; G = group; HAL = haloperidol; Mg = milligrams; OLA = olanzapine; RCT = randomized controlled trial; Sz = schizophrenia; Tx = treatment; Wk(s) = week(s); Yr(s) = year(s)

Table 12 Evidence summary table: chlorpromazine versus olanzapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Negative Symptoms
SANS66 | 1 | 84 | 0.90 (−2.90, 4.70) | NE | ND
Global Ratings
BPRS66 | 1 | 84 | 2.80 (−2.74, 8.34) | NE | ND
CGI–S66 | 1 | 84 | 0.10 (−0.29, 0.49) | NE | ND
Other Outcomes
Response rates66 | 1 | 84 | 0.14 (0.01, 2.68)^*^ | NE | ND

* binary outcome;

BPRS = Brief Psychiatric Rating Scale; CGI–S = Clinical Global Impression–Severity; I^2^ = I-squared; ND = no difference; NE = not estimable; SANS = Scale for the Assessment of Negative Symptoms

Table 13 Strength of evidence (GRADE): chlorpromazine versus olanzapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Negative Symptoms
SANS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Global Ratings
BPRS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
CGI–S | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

BPRS = Brief Psychiatric Rating Scale; CGI–S = Clinical Global Impression–Severity; RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence

Table 14 Characteristics of RCT comparing chlorpromazine versus quetiapine in the treatment of schizophrenia and related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Peuskens et al. 1997^121^ RCT (8 wks) | G1: CHL (75–750mg/d); (100) G2: QUE (75–750mg/d); (101) Washout period: 24 hrs | Acute exacerbation of chronic/subchronic Sz, or schizophreniform disorder; not on depot AP | Unclear, Industry

AP(s) = antipsychotic(s); CHL = chlorpromazine; D = days; G = group; Hr(s) = hour(s); Mg = milligrams QUE = quetiapine; RCT = randomized controlled trial; Sz = schizophrenia; Wk(s) = week(s)

Table 15 Evidence summary table: chlorpromazine versus quetiapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Other Outcomes
Response rates121 | 1 | 201 | 0.81 (0.64, 1.02)^*^ | NE | ND

* binary outcome;

I^2^ = I-squared; ND = no difference; NE = not estimable

Table 16 Characteristics of RCT comparing chlorpromazine versus ziprasidone in the treatment of schizophrenia and related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Run-in Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Kane et al. 2006^96^ RCT (12 wks) | G1: CHL (100–1200mg/d); (154) G2: ZIP (40–160mg/d); (152) Run-in phase: 6 wks | Chronic/subchronic Sz; tx resistant; HAL nonresponders with no response to HAL during run-in phase | Unclear, Industry

AP(s) = antipsychotic(s); CHL = chlorpromazine; HAL = Haloperidol; G = group; Mg = milligrams; RCT = randomized controlled trial; Sz = schizophrenia; Tx = treatment; Wk(s) = week(s); ZIP = ziprasidone

Table 17 Evidence summary table: chlorpromazine versus ziprasidone

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Other Outcomes
Response rates96 | 1 | 306 | 0.95 (0.78, 1.16)^*^ | NE | ND

* binary outcome;

I^2^ = I-squared; ND = no difference; NE = not estimable

Table 18 Characteristics of RCT comparing fluphenazine versus olanzapine in the treatment of schizophrenia and related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Jakovljevic et al. 1999^89^ RCT (22 wks) | G1: FLU (6–21mg/d); (30) G2: OLA (5–20mg/d); (30) Washout period: 1–1.5 wks | SZ; no unstable illness hx or intolerance to OLA or FLU w/depot AP; no previous trial with OLA | Unclear, Industry

AP(s) = antipsychotic(s); D = day; FLU = fluphenazine; G = group; Hx = history; Mg = milligrams; OLA = olanzapine; RCT = randomized controlled trial; Sz = schizophrenia; W/= with; Wks = weeks

Table 19 Evidence summary table: fluphenazine versus olanzapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive Symptoms
PANSS89 | 1 | 60 | 5.10 (0.57, 9.63) | NE | olanzapine
Negative Symptoms
PANSS89 | 1 | 60 | 3.00 (−1.00, 7.00) | NE | ND
General Psychopathology
HAM–A89 | 1 | 60 | 4.00 (0.28, 7.72) | NE | olanzapine
PANSS89 | 1 | 60 | 8.20 (0.83, 15.57) | NE | olanzapine
Global Ratings and Total Scores
BPRS89 | 1 | 60 | 9.30 (0.57, 18.03) | NE | olanzapine
-CGI–S89 | 1 | 60 | 0.90 (0.17, 1.63) | NE | olanzapine
PANSS89 | 1 | 60 | 16.20 (1.22, 31.18) | NE | olanzapine
Other Outcomes
Response rates89 | 1 | 60 | 0.74 (0.51, 1.07)^*^ | NE | ND

Note: bolded outcomes are statistically significant;

* binary outcome;

BPRS = Brief Psychiatric Rating Scale; CGI–S = Clinical Global Impression–Severity; HAM–A = Hamilton Rating Scale for Anxiety; I^2^ = I-squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale

Table 20 Strength of evidence (GRADE): fluphenazine versus olanzapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Positive Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
Negative Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
General Psychopathology
HAM–A | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
Global Ratings and Total Scores
BPRS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
CGI–S | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient

BPRS = Brief Psychiatric Rating Scale; CGI–S = Clinical Global Impression–Severity; HAM–A = Hamilton Rating Scale for Anxiety; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence

Table 21 Characteristics of RCT comparing fluphenazine versus quetiapine in the treatment of schizophrenia and related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Run-in Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Conley et al. 2005^67^ RCT (12 wks) | G1: FLU (10–15mg/d); (13) G2: QUE (300–500mg/d); (12) Run-in phase: 4–6 wks | Tx resistant Sz; persistent positive psychotic symptoms; failed tx trials with 2 different APs | Unclear, Multiple sources

AP(s) = antipsychotic(s); D = day; FLU = fluphenazine; G = group; Mg = milligrams; QUE = quetiapine; RCT = randomized controlled trial; Sz = schizophrenia; Tx = Treatment; Wk(s) = week(s)

Table 22 Evidence summary table: fluphenazine versus quetiapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Global Ratings
BPRS67 | 1 | 25 | −1.98 (−12.96, 9.00) | NE | ND
CGI–S67 | 1 | 25 | −0.03 (−0.92, 0.86) | NE | ND
Sexual Dysfunction
Dysfunction67 | 1 | 25 | 2.15 (0.72, 6.48)^*^ | NE | ND
Improvement on treatment67 | 1 | 25 | 0.46 (0.05, 4.46)^*^ | NE | ND
Other Outcomes
Response rates67 | 1 | 25 | 0.62 (0.12, 3.07)^*^ | NE | ND

* binary outcome;

BPRS = Brief Psychiatric Rating Scale; CGI–S = Clinical Global Impression–Severity; I^2^ = I-squared; ND = no difference; NE = not estimable

Table 23 Strength of evidence (GRADE): fluphenazine versus quetiapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Global Ratings
BPRS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
CGI–S | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

BPRS = Brief Psychiatric Rating Scale; CGI–S = Clinical Global Impression–Severity; RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence

Table 24 Characteristics of RCT comparing fluphenazine versus risperidone in the treatment of schizophrenia and related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Run-in Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Conley et al. 2005^67^ RCT (12 wks) | G1: FLU (10–15mg/d); (13) G2: RIS (3–5mg/d); (13) Run-in phase: 4–6 wks | Tx resistant Sz; persistent positive psychotic symptoms; failed tx trials with 2 different APs | Unclear, Multiple sources

AP(s) = antipsychotic(s); D = day; FLU = fluphenazine; G = group; Mg = milligrams; RCT = randomized controlled trial; RIS = risperidone; Sz = schizophrenia; Tx = treatment; Wk(s) = week(s)

Table 25 Evidence summary table: fluphenazine versus risperidone

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Global Ratings
BPRS67 | 1 | 26 | −0.30 (−10.80, 10.20) | NE | ND
CGI–S67 | 1 | 26 | 0.07 (−0.77, 0.91) | NE | ND
Sexual dysfunction
Sexual dysfunction67 | 1 | 26 | 1.40 (0.60, 3.28)^*^ | NE | ND
Improvement on treatment67 | 1 | 26 | 0.17 (0.02, 1.20)^*^ | NE | ND
Other outcomes
Response rates67 | 1 | 26 | 0.67 (0.13, 3.35)^*^ | NE | ND

* binary outcome;

BPRS = Brief Psychiatric Rating Scale; CGI–S = Clinical Global Impression–Severity; I^2^ = I-squared; ND = no difference; NE = not estimable

Table 26 Strength of evidence (GRADE): fluphenazine versus risperidone

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Global Ratings
BPRS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
CGI–S | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

BPRS = Brief Psychiatric Rating Scale; CGI–S = Clinical Global Impression–Severity; RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence

Table 27 Characteristics of RCTs comparing haloperidol versus aripiprazole in the treatment of schizophrenia and other related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Andrezina et al. 2006^44^ RCT (24 hrs) | G1: HAL (6.5mg/2 hrs; max 3/d); (185) G2: ARI (9.75mg/2 hrs; max 3/d); (175) | Sz or schizoaffective with agitation and no use of benzodiazepines or anticholinergics ≤4 hr; lack of response to previous AP | Unclear, Industry
Daniel et al. 2007^74^ RCT (5 d) | G1: HAL (6.5mg/d); (151) G2: ARI (9.75mg/d); (153) | Acutely agitated Sz or schizoaffective disorder | Unclear, Industry
de Oliveira et al. 2009^76^ RCT (8 wks) | G1: HAL (10–15mg/d); (33) G2: ARI (15–30mg/d); (66) | Sz/schizoaffective disorder | High, Industry
Kane et al. 2002^92^ RCT (4 wks) | G1: HAL (10mg/d); (104) G2: ARI (15mg/d); (102) G3: ARI (30mg/d); (102) Washout period: <1 wks | Sz/schizoaffective disorder not refractory to antipsychotics; improvement with AP besides CLO; OP >1 3–month period <1 yr | High, Industry
Kasper et al. 2003^98^ RCT (52 wks) | G1: HAL (5–10mg/d); (433) G2: ARI (20–30mg/d); (861) Washout period: ≥5 d | Acute relapse of Sz; response to AP (except CLO); no hx tx resistance; ≥3 mo OP AP use in last yr; PANSS total ≥60 | Unclear, Industry
Kim et al. 2010^102^ RCT (8 wks) | G1: HAL (15.9±7.1mg/d); (35) G2: ARI (21.7±5.5 mg/d); (31) Washout period: >4wks | Sz not further defined | Unclear, Foundation
McCue et al. 2006^73^ RCT (3 wks) | G1: HAL (4–30mg); (61) G2: ARI (10–45mg); (63) | Sz, schizoaffective disorder or schizophreniform disorder; no hx of response or lack of response to AP, BP, major depression, or substance-induced psychotic disorder | High, No external funding
Tran-Johnson et al. 2007^31^ RCT (24 hrs) | G1: HAL (7.5mg/d); (60) G2: ARI (1mg/d); (57) G3: ARI (5.25mg/d); (63) G4: ARI (9.75mg/d); (57) G5: ARI (15mg/d); (58) | Sz, schizoaffective, or schizophreniform disorder; acute agitation | Unclear, Industry

AP(s) = antipsychotic(s); ARI = aripiprazole; BP = bipolar disorder; CLO = clozapine; D = day; G = group; HAL = haloperidol; Hr(s) = hour(s); Hx = history; Max = maximum; Mg = milligram; OP = outpatient; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; Sz = schizophrenia; Tx = treatment; Wk(s) = week(s); Yr(s) = year(s)

Table 28 Evidence summary table: haloperidol versus aripiprazole

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive Symptoms
PANSS76,92 | 2 | 407 | −0.99 (−2.64, 0.67) | 32% | ND
SAPS102 | 1 | 66 | −3.10 (−11.08, 4.88) | NE | ND
Negative Symptoms
PANSS76,92,98 | 3 | 1701 | 0.80 (0.14, 1.46) | 0% | aripiprazole
SANS102 | 1 | 66 | −1.10 (−5.24, 3.04) | NE | ND
General Psychopathology
ACES31 | 1 | 295 | 0.46 (−0.03, 0.95) | NE | ND
CABS31 | 1 | 295 | −1.82 (−3.83, 0.18) | NE | ND
PANSS76 | 1 | 99 | −1.60 (−5.28, 2.08) | NE | ND
Global Ratings
BPRS31,44,73 | 3 | 779 | −0.01 (−2.82, 2.81) | 59% | ND
CGI–I31 | 1 | 295 | −0.08 (−0.40, 0.25) | NE | ND
CGI–S31,44,74,76,92 | 5 | 1366 | −0.03 (−0.20, 0.14) | 0% | ND
Other Outcomes
Response rates44,73,76,92,98 | 5 | 2185 | 1.01 (0.76, 1.34)^*^ | 83% | ND
Low medication adherence76 | 1 | 99 | 0.66 (0.03, 15.70)^*^ | NE | ND
Caregiver satisfaction76 | 1 | 99 | 0.32 (0.15, 0.67)^*^ | NE | aripiprazole
Patient satisfaction76 | 1 | 99 | 0.33 (0.17, 0.66)^*^ | NE | aripiprazole

Note: bolded results are statistically significant;

* binary outcome;

ACES = Agitation-Calmness Evaluation Scale; BPRS = Brief Psychiatric Rating Scale; CABS = Corrigan Agitated Behavior Scale; CGI–I = Clinical Global Impression–Intensity; CGI–S = Clinical Global Impression–Severity; I^2^ = I-squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale; SANS = Scale for the Assessment of Negative Symptoms; SAPS = Scale for the Assessment of Positive Symptoms

Table 29 Strength of evidence (GRADE): haloperidol versus aripiprazole

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Positive Symptoms
PANSS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
SAPS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Negative Symptoms
PANSS | 3 RCT | Medium | Consistent | Direct | Imprecise | Moderate (favoring aripiprazole)
SANS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
General Psychopathology
ACES | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
CABS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Global Ratings and Total Scores
BPRS | 3 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
CGI–I | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
CGI–S | 5 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)

ACES = Agitation-Calmness Evaluation Scale; BPRS = Brief Psychiatric Rating Scale; CABS = Corrigan Agitated Behavior Scale; CGI–S = Clinical Global Impression–Severity; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SANS = Scale for the Assessment of Negative Symptoms; SAPS = Scale for the Assessment of Positive Symptoms; SoE = Strength of Evidence; ND = no difference

Table 30 Characteristics of RCTs comparing haloperidol versus asenapine in the treatment of schizophrenia

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Kane et al. 2010^97^ RCT (6 wks) | G1: HAL (4mg/d); (115) G2: ASE (5mg/d); (114) G3: ASE (10mg/d); (106) Washout period: 1–3 d | Sz with acute exacerbation of psychotic symptoms | Unclear, Industry

ASE = Asenapine; D = day; G = group; HAL = haloperidol; Mg = milligrams; RCT = randomized controlled trial; Sz = schizophrenia; Wk = week

Table 31 Evidence summary table: haloperidol versus asenapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive Symptoms
PANSS97 | 1 | 335 | 0.16 (−1.22, 1.54) | NE | ND
Negative Symptoms
PANSS97 | 1 | 335 | 0.39 (−0.72, 1.51) | NE | ND
General Psychopathology
CDS–S97 | 1 | 335 | 0.56 (−0.20, 1.32) | NE | ND
PANSS97 | 1 | 335 | 0.26 (−1.59, 2.10) | NE | ND
Global Ratings and Total Scores
CGI–S97 | 1 | 335 | 0.01 (−0.24, 0.25) | NE | ND
PANSS97 | 1 | 335 | 0.23 (−2.50, 2.95) | NE | ND
Other Outcomes
Response rates97 | 1 | 335 | 0.82 (0.64, 1.04)^*^ | NE | ND

* binary outcome;

CDS–S = Calgary Depression Scale for Schizophrenia; CGI–S = Clinical Global Impression–Severity; I^2^ = I-squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale

Table 32 Strength of evidence (GRADE): haloperidol versus asenapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Positive Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Negative Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
General Psychopathology
CDS–S | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Global Ratings and Total Scores
CGI–S | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

CDS–S = Calgary Depression Scale for Schizophrenia; CGI–S = Clinical Global Impression–Severity; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence

Table 33 Characteristics of RCTs comparing haloperidol versus clozapine in the treatment of schizophrenia and related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Run-in Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Breier et al. 1994^55^ RCT (10 wks) | G1: HAL (10–30mg/d); (37) G2: CLO (200–600mg/d); (38) Run-in phase: 6 wks | Chronic Sz not responding to 6 wks of FLU | Unclear, Government
Citrome et al. 2001^62^ RCT (14 wks) | G1: HAL (10–30mg/d); (37) G2: CLO (200–800mg/d); (40) Run-in phase: 1 wk | Sz w/suboptimal tx response; no depot AP <1 mo | High, Industry
Covington et al. 2000^70^ RCT (24 mo) | G1: HAL (NR); (42) G2: CLO (NR); (40) | Sz or schizoaffective disorder | Unclear, Government
Itoh et al. 1977^155^ RCT (12 wks)Kane et al. 2001^95^ RCT (29 wks) | G1: HAL (5–16mg/d); (34) G2: CLO (12.5–800mg/d); (37) | Sz/schizoaffective disorder, poor response (tx failure in >2 trials of conventional AP) | High, Industry
Klieser et al. 1994^103^ RCT (4 wks) | G1: HAL (16mg/d); (17) G2: CLO (350mg/d); (17) | Acute paranoid Sz; no previous AP tx | Unclear, NR
Krakowski et al. 2006^105^ RCT (12 wks) | G1: HAL (10–30mg/d); (36) G2: CLO (200–800mg/d); (37) Run-in phase: 1–2 wks | Schizophrenia or schizoaffective disorder; not hospitalized >1 yr or hx of nonresponse to CLO, OLA, or HAL | Unclear, Multiple sources including industry
Rosenheck et al. 1997^126^ RCT (12 mo) | G1: HAL (5–30mg/d); (218) G2: CLO (10–900mg/d); (205) | Tx refractory Sz; hx of high level of use of inpatient services | Unclear, Multiple sources including industry
Volavka et al. 2002^145^ RCT (14 wks) | G1: HAL (10–30mg/d); (37) G2: CLO (200–800mg/d); (40) | Chronic Sz or schizoaffective disorder and suboptimal response to previous tx | Unclear, Multiple sources

AP(s) = antipsychotic(s); CLO = clozapine; D = days; FLU = fluphenazine; G = group; HAL = haloperidol; Hr(s) = hour(s); Hx = history; Mg = milligrams; Mo = month; NR = not reported; OLA = olanzapine; RCT = randomized controlled trial; Sz = schizophrenia; Tx = treatment; W/ = with; Wk(s) = week(s); Yr(s) = year(s)

Table 34 Evidence summary table: haloperidol versus clozapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive Symptoms
PANSS105,145 | 2 | 147 | −1.51 (−3.39, 0.37) | 0% | ND
Negative Symptoms
PANSS105,145 | 2 | 150 | 0.11 (−1.75, 1.96) | 26% | ND
SANS55,70 | 2 | 157 | 0.94 (−2.60, 4.48) | 0% | ND
General Psychopathology
MOAS105 | 1 | 73 | 17.60 (−2.25, 37.45) | NE | ND
PANSS105,145 | 2 | 150 | −0.64 (−3.11, 1.82) | 0% | ND
Global Ratings and Total Scores
BPRS55,95,103,155 | 4 | 268 | 2.16 (−0.56, 4.87) | 0% | ND
CGI–I95 | 1 | 71 | 0.80 (0.26, 1.34) | NE | clozapine
CGI–S95 | 1 | 71 | 0.60 (0.13, 1.07) | NE | clozapine
PANSS105,126,145 | 3 | 573 | 1.04 (−3.91, 5.98) | 58% | ND
Health Care System Utilization
Mean hospital bed days126 | 1 | 423 | −7.10 (−19.02, 4.82) | NE | ND
Other Outcomes
Relapse rates55 | 1 | 75 | 0.68 (0.12, 3.87)^*^ | NE | ND
Response rates95,105 | 2 | 144 | 0.64 (0.28, 1.47)^*^ | 72% | ND
Remission rates95 | 1 | 71 | 0.16 (0.02, 1.20)^*^ | NE | ND
Patient satisfaction103 | 1 | 34 | 0.82 (0.46, 1.45)^*^ | NE | ND

Note: bolded results are statistically significant;

* binary outcome;

BPRS = Brief Psychiatric Rating Scale; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; I^2^ = I-squared; MOAS = Modified Overt Aggression Scale; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale; SANS = Scale for the Assessment of Negative Symptoms

Table 35 Strength of evidence (GRADE): haloperidol versus clozapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Positive Symptoms
PANSS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
Negative Symptoms
PANSS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
SANS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
General Psychopathology
MOAS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
Global Ratings and Total Scores
BPRS | 4 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
CGI–I | 1 RCT | Medium | Consistent | Direct | Precise | Insufficient
CGI–S | 1 RCT | Medium | Consistent | Direct | Precise | Insufficient
PANSS | 3 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)

BPRS = Brief Psychiatric Rating Scale; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; MOAS = Modified Overt Aggression Scale; PANSS = Positive and Negative Symptom Scale; ND = No difference; RCT = randomized controlled trial; RoB = risk of bias; SANS = Scale for the Assessment of Negative Symptoms; SoE = Strength of Evidence

Table 36 Characteristics of RCTs comparing haloperidol versus olanzapine in the treatment of schizophrenia and related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout/Run-in Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Altamura et al. 2002^43^ RCT (14 wks) | G1: HAL (10–20mg/d); (15) G2: OLA (10–20mg/d); (13) Washout period: 1 wk | Paranoid Sz with partial response to AP after ≥6 wks of different classes | Unclear, Industry
Avasthi et al. 2001^159^ RCT (12 wks) | G1: HAL (5–20mg/d); (10) G2: OLA (5–20mg/d); (17) | Sz; CGI–S score >3 | Unclear, Industry
Beasley et al. 1996^49^ RCT (1 yr) | G1: HAL (10–20mg/d); (69) G2: OLA (2.5–7.5mg/d); (65) G3: OLA (7.5–12.5mg/d); (64) G4: OLA (12.5–17.5mg/d); (69) Washout period: variable depending on medication Run-in phase: <1 wk | Sz with acute exacerbation | Unclear, Industry
Beasley et al. 1997^50^ RCT (1 yr) | G1: HAL (15±5mg/d); (81) G2: OLA (1.0mg/d); (88) G3: OLA (5±2.5mg/d); (87) G4: OLA (10±2.5mg/d); (86) G5: OLA (15±2.5mg/d); (89) Washout period: oral: >2 d; depot: >2 wks Run-in phase: 4–7 d | Sz with acute exacerbation | Unclear, Industry
Bernardo et al. 2001^51^ RCT (4 wks) | G1: HAL (10mg/d); (13) G2: OLA (10mg/d); (14) Washout period: 1 wk | Sz/schizophreniform disorder; no depot AP <6 mo | Unclear, Industry
Boulay et al. 2007^54^ RCT (56 d) | G1: HAL (2.5–20mg/d); (11) G2: OLA (2.5–20mg/d); (14) Washout period: 3 d | Sz not further identified; no depot AP <6 mo | Unclear, Industry
Breier et al. 2002^56^ RCT (24 hrs) | G1: HAL (7.5mg); (40) G2: OLA (2.5mg); (48) G3: OLA (5.0mg); (45) G4: OLA (7.5mg); (46) G5: OLA (10mg); (46) Washout period: 2–24 hrs | Hospitalized; Sz, schizophreniform disorder, schizoaffective disorder | Unclear, Industry
Buchanan et al. 2005^58^ RCT (16 wks) | G1: HAL (10–30mg/d); (34) G2: OLA (10–30mg/d); (29) Run-in phase: 4 wks | Sz/schizoaffective disorder with partial response to conventional APs, demonstrated >30% improvement on FLU, relapsed, or were intolerant of FLU during run-in phase | High, Multiple sources including industry
Crespo-Facorro et al. 2006^71^ RCT (6 wks) | G1: HAL (3–9mg/d); (56) G2: OLA (5–20mg/d); (55) Washout period: 3–5 d | Sz with no AP <6 wks | High, Multiple sources
Davidson et al. 2009^75^ RCT (6 mo) | G1: HAL (1–4mg/d); (103) G2: OLA (5–20mg/d); (105) | <2 yrs since onset of positive symptoms; <2 wks exposure to AP <1 yr; <6 wks lifetime exposure to AP | High, Industry
de Haan et al. 2003^78^ RCT (6 wks) | G1: HAL (2.5mg/d); (12) G2: OLA (7.5mg/d); (12) | Sz; hx of unresponsiveness to HAL or OLA; no IM AP <1 yr | Unclear, Government
Ishigooka et al. 2001^88^ RCT (8 wks) | G1: HAL (4–12mg/d); (89) G2: OLA (5–15mg/d); (93) Washout period: 2–4 wks | Sz; no tx with HAL, OLA or other investigational AP <3 mo; study AP contraindications | Unclear, NR
Keefe et al. 2006^101^ RCT (52 wks) | G1: HAL (2–19mg/d); (97) G2: OLA (5–20mg/d); (159) | Sz/schizoaffective disorder; no previous AP ≤1 mo | Unclear, Industry
Kim et al. 2010^102^ RCT (8 wks) | G1: HAL (15.9±7.1mg/d); (35) G2: OLA (15.9±4.3mg/d); (32) Washout period: >4wks | Sz not further defined | Unclear, Foundation
Kongsakon et al. 2006^104^ RCT (24 wks) | G1: HAL (5–20 mg); (132) G2: OLA (5–20 mg); (144) Washout period: 2–9 d | Sz not further defined | Unclear, Industry
Krakowski et al. 2006^105^ RCT (12 wks) | G1: HAL (10–30mg/d); (36) G2: OLA (10–35mg/d); (37) Run-in phase: 1–2 wks | Sz or schizoaffective disorder; not hospitalized >1 yr or hx of nonresponse to CLO, OLA, or HAL | Unclear, Multiple sources including industry
Lahti et al. 2009^106^ RCT (6 wks) | G1: HAL (10–20mg/d); (14) G2: OLA (12.5–25mg/d); (18) Washout period: 2 wks | Sz defined by DSM–III–R | Unclear, Government
Lieberman et al. 2003^108^ RCT (104 wks) | G1: HAL (2–20mg/d); (132) G2: OLA (5–20mg/d); (131) Washout period: <2 wks | Sz, schizophreniform, or schizoaffective disorder; onset <35 yrs; no AP drug tx >16 wks, previous CLO tx, or depot AP <3 dosing intervals | Unclear, Industry
Lindenmayer et al. 2007^110^ RCT (12 wks) | G1: HAL (5–20mg/d); (19) G2: OLA (5–20mg/d); (16) Washout period: 1 wk cross-titration from previous AP | Sz defined by DSM–IV–TR | Unclear, Industry
McCue et al. 2006^73^ RCT (3 wks) | G1: HAL (4–30mg); (61) G2: OLA (5–40 mg); (58) | Sz, schizoaffective disorder, or schizophreniform disorder; no hx of response or lack of response to AP, BP, major depression, or substance-induced psychotic disorder | High, No external funding
Purdon et al. 2000^124^ RCT (54 wks) | G1: HAL (5–20mg/d); (23) G2: OLA (5–20mg/d); (21) Washout period: 2–9 d Run-in phase: 1 mo | Sz <5 yrs of 1st exposure to AP; mild symptom severity | Unclear, Industry
Rosenheck et al. 2003^127^ RCT (12 mo) | G1: HAL (5–20mg/d); (150) G2: OLA (5–20mg/d); (159) | Sz/schizoaffective disorder; OP w/hx of psychiatric hospitalization <2 yrs | Unclear, Industry
Saddichha et al. 2008^129^ NRCT (6 wks) | G1: HAL (13.4±3.6mg/d); (31) G2: OLA (16.5±4.6mg/d); (35) | 1st episode Sz; AP drug-naïve | High, NR
Sayers et al. 2005^130^ RCT (26 wks) | G1: HAL (10–20mg/d); (12) G2: OLA (10–20mg/d); (12) | Sz and current cocaine abuse <6 mo; no depot AP <6 mo | High, Government
Smelson et al. 2006^136^ RCT (6 wks) | G1: HAL (5–20mg/d); (15) G2: OLA (5–20mg/d); (16) | Sz; cocaine dependent; no DSM–IV criteria for other Axis I disorder | High, Industry
Tollefson et al. 1997^141^ RCT (14 mo) | G1: HAL (5–20mg/d); (660) G2: OLA (5–20mg/d); (1336) | Sz; intolerant of current AP therapy (excluding HAL) | High, Industry
Volavka et al. 2002^145^ RCT (14 wks) | G1: HAL (10–30mg/d); (37) G2: OLA (10–40mg/d); (39) | Chronic Sz or schizoaffective disorder and suboptimal response to previous tx | Unclear, Multiple sources
Wright et al. 2001^147^ RCT (24 hrs) | G1: HAL (7.5 mg); (126) G2: OLA (10 mg); (131) | Sz, schizophreniform disorder, or schizoaffective disorder | Unclear, Industry

AP(s) = antipsychotic(s); BP = bipolar; CGI–S = Clinical Global Impression Severity Scale; CLO = clozapine; D = day; DSM–IV = Diagnostic and Statistical Manual of Mental Disorders – IV; FLU = fluphenazine; G = group; HAL = haloperidol; Hr(s) = hour(s); Hx = history; IM = intramuscular; Mg = milligrams; Mo = month; NR = not reported; OLA = olanzapine; OP = outpatient; RCT = randomized controlled trial; Sz = schizophrenia; Tx = treatment; Wk(s) = week(s); Yr(s) = year(s)

Table 37 Evidence summary table: haloperidol versus olanzapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive Symptoms
PANSS50,51,54,88,101,104,105,108,110,124,136,141,145,159 | 14 | 3742 | 0.43 (−0.22, 1.08) | 36% | ND
SAPS71,102 | 2 | 178 | 0.10 (−0.09, 0.28) | 0% | ND
Negative Symptoms
PANSS50,51,54,88,101,104,105,108,110,124,136,141,145,159 | 14 | 3742 | 1.06 (0.46, 1.67) | 27% | olanzapine
SANS49,58,71,102,159 | 5 | 535 | 1.79 (1.57, 2.02) | 0% | olanzapine
General Psychopathology
ABS56,147 | 2 | 482 | 0.80 (−1.22, 2.83) | 74% | ND
ACES56,147 | 2 | 482 | 0.06 (−0.40, 0.53) | 85% | ND
CDS–S54,71,91 | 3 | 344 | 0.60 (−0.08, 1.29) | 73% | ND
HAM–A101,159 | 2 | 283 | 0.90 (−0.43, 2.23) | 0% | ND
HAM–D58,71,110 | 3 | 209 | 1.69 (1.41, 1.96) | 0% | olanzapine
MADRS78,101,105,108,141,159 | 6 | 2639 | 2.46 (1.78, 3.14) | 0% | olanzapine
PANSS50,54,88,105,108,110,124,136,145,159 | 10 | 1187 | 0.53 (−1.20, 2.25) | 52% | ND
YMRS71 | 1 | 111 | 0.40 (0.21, 0.59) | NE | olanzapine
Global Ratings and Total Scores
BPRS43,49–51,56,58,71,73,88,104,106,141,147 | 13 | 4014 | 0.59 (−1.10, 2.28) | 82% | ND
CGI–I78,147 | 2 | 281 | 0.11 (−0.30, 0.51) | 36% | ND
CGI–S,49,50,56,58,91,108,141 omit outlier | 7 | 3453 | 0.20 (0.07, 0.32) | 33% | olanzapine
GAF91 | 1 | 208 | −4.00 (−13.70, 5.70) | NE | ND
PANSS43,50,51,54,78,88,91,101,104,105,108,110,127,141,145 | 15 | 4209 | 2.31 (0.44, 4.18) | 37% | olanzapine
Subjective Well-Being under Neuroleptics Scale78 | 1 | 24 | 7.00 (−3.55, 17.55) | NE | ND
Encounters With the Legal System
Positive urine toxicology136 | 1 | 31 | 3.20 (0.76, 13.46)^*^ | NE | ND
Sexual dysfunction
Sexual dysfunction (UKU)91 | 1 | 208 | 0.80 (0.52, 1.24) | NE | ND
Health Care System Utilization
Rates of hospitalization/rehospitalization91 | 1 | 208 | 0.79 (0.42, 1.51)^*^ | NE | ND
Mean hospital bed days127 | 1 | 309 | −7.10 (−20.95, 6.75) | NE | ND
Other Outcomes
Response rates49,71,73,88,91,101,104–106,108,110,130,141,147 | 14 | 4099 | 0.86 (0.78, 0.96)^*^ | 55% | olanzapine
Remission rates71,91,108 | 3 | 582 | 0.65 (0.45, 0.94)^*^ | 54% | olanzapine
Medication adherence101 | 1 | 256 | 1.00 (0.81, 1.22)^*^ | NE | ND
Patient insight into illness108 | 1 | 263 | −1.10 (−3.95, 1.75) | NE | ND
Health-Related Quality of Life
Health-related quality of life159 | 1 | 27 | −2.05 (−25.81, 21.71) | NE | ND
MANSA91 | 1 | 208 | 0.00 (−1.38, 1.38) | NE | ND
QLS49,58 | 2 | 330 | −2.62 (−6.39, 1.15) | 0% | ND
Schizophrenia-specific QLS104 | 1 | 276 | −3.62 (−8.94, 1.70) | NE | ND

Note: bolded results are statistically significant;

* binary outcome;

ABS = Agitated Behavior Scale; ACES = Agitation-Calmness Evaluation Scale; BPRS = Brief Psychiatric Rating Scale; CDS–S = Calgary Depression Scale for Schizophrenia; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; GAF = Global Assessment of Functioning; HAM–A = Hamilton Rating Scale for Anxiety; HAM–D = Hamilton Rating Scale for Depression; I^2^ = I-squared; MADRS = Montgomery-Asberg Depression Rating Scale; MANSA = Manchester Short Assessment of Quality of Life; ND = no difference; NE = not estimable; NR = not reported; PANSS = Positive and Negative Symptom Scale; QLS = Quality of Life Scale; SANS = Scale for the Assessment of Negative Symptoms; SAPS = Scale for the Assessment of Positive Symptoms; YMRS = Young Mania Rating Scale

Table 38 Strength of evidence (GRADE): haloperidol versus olanzapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Positive Symptoms
PANSS | 14 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
SAPS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
Negative Symptoms
PANSS | 14 RCT | Medium | Consistent | Direct | Precise | Moderate (favors OLA)
SANS | 5 RCT | Medium | Consistent | Direct | Precise | Moderate (favors OLA)
General Psychopathology
ABS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
ACES | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
CDS–S | 3 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
HAM–A | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
HAM–D | 3 RCT | Medium | Consistent | Direct | Precise | Moderate (favors OLA)
MADRS | 6 RCT | Medium | Consistent | Direct | Precise | Moderate (favors OLA)
PANSS | 10 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
YMRS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
Outcome
BPRS | 13 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
CGI–I | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
CGI–S, omit outliers | 7 RCT | Medium | Consistent | Direct | Precise | Moderate (favors OLA)
GAF | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS | 15 RCT | Medium | Consistent | Direct | Precise | Moderate (favors OLA)
SWBUN | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

ABS = Agitated Behavior Scale; ACES = Agitation-Calmness Evaluation Scale; BPRS = Brief Psychiatric Rating Scale; CDS–S = Calgary Depression Scale for Schizophrenia; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; GAF = Global Assessment of Functioning; HAM–A = Hamilton Rating Scale for Anxiety; HAM–D = Hamilton Rating Scale for Depression; MADRS = Montgomery-Asberg Depression Rating Scale; ND = no difference; OLA = olanzapine; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SANS = Scale for the Assessment of Negative Symptoms; SAPS = Scale for the Assessment of Positive Symptoms; SoE = Strength of Evidence; SWBUNS = Subjective Well-being Under Neuroleptics Scale; YMRS = Young Mania Rating Scale

Table 39 Characteristics of RCTs comparing haloperidol versus quetiapine in the treatment of schizophrenia and related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout/Run-in Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Arvanitis et al. 1997^46^ RCT (6 wks) | G1: HAL (12mg/d); (52) G2: QUE (75mg/d); (53) G3: QUE (150mg/d); (48) G4: QUE (300mg/d); (52) G5: QUE (600mg/d); (51) G6: QUE (750mg/d); (54) Washout period: 1 wk | Sz (chronic or subchronic) with no use of depot AP within one dosing interval | Unclear, Industry
Atmaca et al. 2002^47^ RCT (6 wks) | G1: HAL (10mg/d); (17) G2: QUE (600mg/d); (18) Washout period: 2 wks | Sz defined by DSM–IV | Unclear, NR
Copolov et al. 2000^68^ RCT (6 wks) | G1: HAL (1–16mg/d); (227) G2: QUE (50–800mg/d); (221) Washout period: 48 hrs | Acute exacerbation of chronic or subchronic Sz; no tx with a depot AP <1 dosing period | High, Industry
Emsley et al. 2000^79^ RCT (12 wks) | G1: HAL (5–20mg/d); (145) G2: QUE (600mg/d); (143) Run-in phase: 4 wks | Sz; hx of partial response to conventional APs; persistent positive symptoms while previously taking AP; partial or no response to 1 mo FLU tx | Unclear, Industry
Emsley et al. 2005^80^ RCT (2 yrs) | G1: HAL (5–20mg); (23) G2: QUE (100–800mg); (22) | Clinically stable Sz or schizoaffective disorder (DSM–IV); on stable dose of AP; had TD | Unclear, Multiple sources including industry
Glick et al. 2005^65^ RCT (48 wks) | G1: HAL (200mg/wk); (14) G2: QUE (500mg/d); (21) | Sz requiring long-term therapy | High, Multiple sources including industry
Kahn et al. 2008^91^ RCT (12 mo) | G1: HAL (1–4mg/d); (103) G2: QUE (200–750mg/d); (104) | Sz/schizophreniform or schizoaffective disorder; <2 yrs since onset of positive symptoms; no AP > 2 wks in last 1 yr, or >6 wks at any time | High, Industry
McCue et al. 2006^73^ RCT (3 wks) | G1: HAL (4–30mg); (61) G2: QUE (50–1200 mg); (62) | Sz, schizoaffective disorder, or schizophreniform disorder; no hx of response or lack of response to AP, BP, major depression, or substance-induced psychotic disorder | High, No external funding
Purdon et al. 2001^123^ RCT (6 mo) | G1: HAL (10–20mg/d); (12) G2: QUE (300–600mg/d); (13) Washout period: 48 hrs | Sz defined by DSM–IV | Unclear, Industry

AP(s) = antipsychotic(s); BP = bipolar disorder; D = day; DSM–IV = Diagnostic and Statistical Manual of Mental Disorders – IV; FLU = fluphenazine; G = group; HAL = haloperidol; Hr(s) = hour(s); Hx = history; Mg = milligrams; Mo = month; NR = not reported; QUE = quetiapine; RCT = randomized controlled trial; Sz = schizophrenia; TD = tardive dyskinesia; Tx = treatment; Wk(s) = week(s); Yr(s) = year(s)

Table 40 Evidence summary table: haloperidol versus quetiapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive Symptoms
PANSS65,79,80,123 | 4 | 393 | 0.68 (−0.14, 1.50) | 0% | ND
Negative Symptoms
PANSS65,79,80,123 | 4 | 393 | 1.36 (−0.41, 3.13) | 76% | ND
SANS46 | 1 | 310 | −0.94 (−2.04, 0.15) | NE | ND
General Psychopathology
BDI123 | 1 | 25 | 5.30 (−2.79, 13.39) | NE | ND
CDS–S91,123 | 2 | 232 | 0.03 (−0.52, 0.58) | 0% | ND
PANSS65,79,80,123 | 4 | 393 | 0.46 (−0.87, 1.78) | 9% | ND
Global Ratings and Total Scores
BPRS46,47,73,79 | 4 | 756 | 1.23 (−0.50, 2.96) | 0% | ND
CGI–I46,79,123 | 3 | 623 | 0.02 (−0.24, 0.27) | 0% | ND
CGI–S46,68,79,91 | 4 | 1253 | −0.23 (−0.42, −0.04) | 0% | haloperidol
GAF91 | 1 | 207 | 0.10 (−9.60, 9.80) | NE | ND
PANSS65,68,79,80,91,123 | 6 | 1048 | 1.18 (−0.94, 3.31) | 16% | ND
Sexual Dysfunction
Sexual dysfunction (UKU)91 | 1 | 207 | 1.01 (0.63, 1.62) | NE | ND
Health Care System Utilization
Rates of hospitalization/rehospitalization91 | 1 | 207 | 1.01 (0.51, 2.01)^*^ | NE | ND
Health-Related Quality of Life
MANSA91 | 1 | 207 | 0.00 (−1.38, 1.38) | NE | ND
Other Outcomes
Response rates46,68,73,79,80,91 | 6 | 1421 | 0.99 (0.76, 1.30)^*^ | 77% | ND
Remission rates91 | 1 | 207 | 0.72 (0.41, 1.25)^*^ | NE | ND

Note: bolded results are statistically significant;

* binary outcome;

BDI = Beck Depression Inventory; BPRS = Brief Psychiatric Rating Scale; CDS–S = Calgary Depression Scale for Schizophrenia; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; GAF = Global Assessment of Functioning; I2 = I-squared; MANSA = Manchester Short Assessment of Quality of Life; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale; SANS = Scale for the Assessment of Negative Symptoms

Table 41 Strength of evidence (GRADE): haloperidol versus quetiapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Positive Symptoms
PANSS | 4 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
Negative Symptoms
PANSS | 4 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
SANS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
General Psychopathology
BDI | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
CDS–S | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
PANSS | 4 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
Global Ratings and Total Scores
BPRS | 4 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
CGI–I | 3 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
CGI–S | 4 RCT | Medium | Consistent | Direct | Precise | Moderate (favoring haloperidol)
GAF | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS | 6 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)

BDI = Beck Depression Inventory; BPRS = Brief Psychiatric Rating Scale; CDS–S = Calgary Depression Scale for Schizophrenia; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; GAF = Global Assessment of Functioning; ND = no difference; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SANS = Scale for the Assessment of Negative Symptoms; SoE = Strength of Evidence.

Table 42 Characteristics of RCTs comparing haloperidol versus risperidone in the treatment of schizophrenia

Study, Design (Followup) | Interventions, Dosages; No. randomized, Washout/Run-in Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Apiquian et al. 2008^45^ RCT (4 wks) | G1: HAL (2mg/d); (10) G2: RIS (1mg/d); (10) | Sz with psychosis | High, NR
Blin et al. 1996^52^ RCT (4 wks) | G1: HAL (4–12mg/d); (20) G2: RIS (4–12mg/d); (21) | Sz with acute exacerbation and anxiety symptoms; no depot AP <1 mo or short–acting AP <2 d | Unclear, NR
Borison et al. 1992^53^ RCT (6 wks) | G1: HAL (4–20mg/d); (12) G2: RIS (2–10mg/d); (12) Run-in phase: 1 wk | Sz with acute exacerbation defined by DSM–III–R | Unclear, Industry
Cavallaro et al. 2001^59^ RCT (6 wks) | G1: HAL (2.5–10mg/d); (16) G2: RIS (2.5–10mg/d); (17) Run-in phase: <=1 wk | Subchronic Sz; no AP <1 wk or depot APs in <1 mo | Unclear, Industry
Ceskova et al. 1993^60^ RCT (8 wks) | G1: HAL (2–20mg/d); (31) G2: RIS (2–20mg/d); (31) | Acute Sz pts defined by ICD–9 | Unclear, NR
Chouinard et al. 1993^61^ RCT (8 wks) | G1: HAL (20mg/d); (21) G2: RIS (2mg/d); (24) G3: RIS (6mg/d); (22) G4: RIS (10mg/d); (22) G5: RIS (16mg/d); (24) Washout period: 2 d – 2 wks | Sz; no depot AP for one tx cycle | Unclear, Industry
Claus et al. 1992^64^ RCT (12 wks) | G1: HAL (1–10mg/d); (21) G2: RIS (1–10mg/d); (21) Washout period: 1 wk Run-in phase: 2 wks | Chronic Sz | Unclear, Industry
Crespo-Facorro et al. 2006^71^ RCT (6 wks) | G1: HAL (3–9mg/d); (56) G3: RIS (3–6mg/d); (61) Washout period: 3–5 d | Sz with no AP <6 wks | High, Multiple sources
Csernansky et al. 2002 72 RCT (12 mo) | G1: HAL (5–20mg/d); (188) G2: RIS (2–8mg/d); (177) Washout period: <1 wks | Sz or schizoaffective disorder; no hx of AP refractoriness or depot AP for one tx cycle; clinically stable >30 d | Unclear, Industry
de Sena et al. 2003^77^ RCT (12 mo) | G1: HAL (5–17mg/d); (13) G2: RIS (1–6mg/d); (20) Washout period: 3–7d | Sz pts defined by DSM–III–R | High, Industry
Emsley et al. 1999^81^ RCT (6 wks) | G1: HAL (2–10mg/d); (84) G2: RIS (2–10mg/d); (99) | Sz/schizophreniform disorder without prior tx; psychotic symptoms requiring tx | Unclear, NR
Fakra et al. 2008^82^ RCT (50 wks) | G1: HAL (NR); (15) G2: RIS (NR); (15) Washout period: 1 wk | Sz defined by DSM–IV | High, Multiple sources including industry
Heck et al. 2000^85^ RCT (NR) | G1: HAL (3–24mg/d); (37) G2: RIS (2–16mg/d); (40) | Clinically stable Sz on AP; >5 on ESRS or antiparkinson drug use | Unclear, Industry
Kee et al. 1998^99^ RCT (NR) | G1: HAL (15mg/d); (9) G2: RIS (6mg/d); (9) Washout period: <1 wks Run-in phase: 3 wks | Sz; tx resistant defined by DSM–III–R | Unclear, Multiple sources
Keefe et al. 2006^101^ RCT (52 wks) | G1: HAL (2–19mg/d); (97) G2: RIS (2–10mg/d); (158) | Sz/schizoaffective disorder; no previous AP <1 mo | Unclear, Industry
Kim et al. 2010^102^ RCT (8 wks) | G1: HAL (15.9±7.1mg/d); (35) G2: RIS (4.8±2.9mg/d); (41) Washout period: >4wks | Sz not further defined | Unclear, Foundation
Lee et al. 2007^107^ RCT (8 wks) | G1: HAL (7.6±2.6mg/d); (10) G2: RIS (4.1±0.8mg/d); (10) | Sz defined by DSM–IV | High, Government
Liu 2000^111^ | G1: HAL (7.6±2.6mg/d); (28) G2: RIS (4.1±0.8mg/d); (28) | PANSS (total) >65; no pts with hx of physical illness or substance abuse | High, NR
Marder et al. 1994^114^ RCT (8 wks) | G1: HAL (20mg/d); (66) G2: RIS (2mg/d); (63) G3: RIS (6mg/d); (64) G4: RIS (10mg/d); (65) G5: RIS (16mg/d); (64) Washout period: 1 wk | Sz; no schizoaffective disorder | High, Industry
Marder et al. 2003^113^ RCT (2 yrs) | G1: HAL (2 mg t.i.d. for 1 wk then 6 mg h.s.); (30) G2: RIS (2 mg t.i.d. for 1 wk then 6 mg h.s.); (33) Run-in phase: 2 wk | >2 Sz episodes <2 yrs w/continuing psychotic symptoms; OP >1 mo | Unclear, Multiple sources
McCue et al. 2006^73^ RCT (3 wks) | G1: HAL (4–30mg); (61) G2: RIS (2–9 mg); (65) | Sz, schizoaffective disorder, or schizophreniform disorder; no hx of response or lack of response to AP, BP, major depression, or substance-induced psychotic disorder | High, No external funding
Min et al. 1993^117^ RCT (8 wks) | G1: HAL (2.5–5mg/d); (19) G2: RIS (2.5–5mg); (16) Washout period:1 wk | Chronic Sz defined by DSM–III–R | Unclear, NR
Moller et al. 2008^118^ RCT (2 yrs) | G1: HAL (2–8mg/d); (146) G2: RIS (2–8mg/d); (143) Washout period: 1 wk | Sz recovered from a 1st episode (1st inpatient tx of psychotic symptoms) | Unclear, Multiple sources
Peuskens et al. 1995^120^ RCT (8 wks) | G1: HAL (10mg/d); (226) G2: RIS (1mg/d); (229) G3: RIS (4mg/d); (227) G4: RIS (8mg/d); (230) G5: RIS (12mg/d); (226) G6: RIS (16mg/d); (224) Washout period: 3–7 d | Chronic Sz defined by DSM–III–R | Unclear, NR
Purdon et al. 2000^124^ RCT (54 wks) | G1: HAL (5–20mg/d); (23) G2: RIS (2–6mg/d); (21) Washout period: 2–9 d Run-in phase: 1 mo | Sz <5 yrs of 1st exposure to AP; mild symptom severity | Unclear, Industry
Remillard et al. 2008^125^ RCT (12 mo) | G1: HAL (2–40mg/d); (14) G2: RIS (2–6mg/d); (14) | Sz defined DSM–III–R | Unclear, Industry
Schooler et al. 2005^132^ RCT (2 yrs) | G1: HAL (1–8mg/d); (277) G2: RIS (1–8mg/d); (278) Washout period: 3–7 d | Sz, schizophreniform, or schizoaffective disorder <1 yr; <2 hospitalizations for psychosis; <12 wks of cumulative exposure to AP; required AP tx upon enrollment | Unclear, Industry
Shrivastava et al. 2000^135^ RCT (12 mo) | G1: HAL (5–15mg/d); (50) G2: RIS (2mg/d); (50) Run-in phase: 2–4 wks | Hospitalized; acute Sz exacerbation | High, NR
Tamrakar et al. 2006^139^ RCT (6 wks) | G1: HAL (10–20mg/d); (18) G2: RIS (4–6mg/d); (18) Washout period: 1 wk for oral; 4 wks for depot | Sz not further defined | High, NR
Volavka et al. 2002^145^ RCT (14 wks) | G1: HAL (10–30mg/d); (37) G2: RIS (4–16mg/d); (41) | Chronic Sz or schizoaffective disorder and suboptimal response to previous tx | Unclear, Multiple sources
Wirshing et al. 1999^146^ RCT (8 wks) | G1: HAL (15mg/d); (33) G2: RIS (6mg/d); (34) Washout period: 3–7 d Run-in phase: 3 wks | Tx resistant Sz; no functioning within last 5 yrs | Unclear, Multiple sources
Yen et al. 2004^149^ RCT (12 wks) | G1: HAL (4–20mg/d); (20) G2: RIS (2–12mg/d); (21) Washout period: 7 d for oral AP; 4 wks for depot AP | Sz defined by DSM–III–R | High, Government
Zhang et al. 2001^150^ RCT (12 wks) | G1: HAL (6mg/d); (37) G2: RIS (20mg/d); (41) Run-in phase: 2 wks | Sz; full dose conventional AP >3 mo; duration of illness >5 yrs | Unclear, NR

AP(s) = antipsychotic(s); BP = bipolar; D = day; DSM = Diagnostic and Statistical Manual of Mental Disorders; ESRS = Extrapyramidal Syndrome Rating Scale; G = group; HAL = haloperidol; Hx = history; ICD–9 = International Classification of Diseases, 9th edition; Mg = milligrams; Mo = month; NR = not reported; OP = outpatient; Pts = patients; RCT = randomized controlled trial; RIS = risperidone; Sz = schizophrenia; T.i.d. = twice daily; Tx = treatment; W/= with; Wk(s) = week(s); Yr(s) = years(s)

Table 43 Evidence summary table: haloperidol versus risperidone

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive Symptoms
PANSS52,61,64,72,81,101,107,111,114,117,118,120,124,125,132,135,139,145,149,150 | 20 | 4043 | 0.64 (−0.06, 1.34) | 53% | ND
SAPS71,102 | 2 | 193 | −0.14 (−2.01, 1.73) | 35% | ND
Negative Symptoms
PANSS52,61,64,72,81,101,107,111,114,117,118,120,124,125,132,135,139,145,149,150 | 20 | 4043 | 0.60 (0.01,1.20) | 30% | risperidone
SANS53,71,102,118 | 4 | 506 | 0.58 (0.37, 0.80) | 0% | risperidone
General Psychopathology
CDS–S71,85,118 | 3 | 483 | 0.47 (−0.19, 1.13) | 53% | ND
HAM–A101 | 1 | 255 | 0.10 (−1.44, 1.64) | NE | ND
HAM–D71,118 | 2 | 406 | 0.49 (−0.83, 1.81) | 71% | ND
MADRS101 | 1 | 255 | 0.50 (−1.58, 2.58) | NE | ND
PANSS (general psychopathology),52,61,64,81,107,111,117,120,124,132,145,149,150 omit outliers | 13 | 2648 | 0.90 (−0.10, 1.90) | 0% | ND
YMRS71,118 | 2 | 406 | 0.10 (−0.07, 0.26) | 0% | ND
Global Ratings and Total Scores
BPRS52,53,60,61,71,73,81,85,113,114,117,120,146 | 13 | 2592 | 0.51 (−0.17, 1.20) | 44% | ND
CGI–I117,132,146 | 3 | 657 | −0.02 (−0.39, 0.36) | 48% | ND
CGI–S61,71,114,117,118,120,146 | 8 | 1667 | 0.03 (−0.18, 0.23) | 61% | ND
NOSIE–30^64^ | 1 | 42 | −5.30 (−21.61, 11.01) | NE | ND
PANSS45,52,61,64,72,81,82,101,107,111,114,117,118,120,132,135,139,145,149,150 | 20 | 4021 | 2.23 (−0.37, 4.83) | 75% | ND
SADS–C64 | 1 | 42 | −0.40 (−10.12, 9.32) | NE | ND
SCL–90–R114 | 1 | 63 | 0.31 (0.12, 0.50) | NE | risperidone
Subjective Well–being Under Neuroleptic Scale118 | 1 | 289 | 1.80 (−2.39, 5.99) | NE | ND
Employment or Personal Earnings
Economic independence135 | 1 | 100 | 0.94 (0.68, 1.29)^*^ | NE | ND
Encounters with legal system
Attitude regarding drugs118 | 1 | 289 | −0.80 (−2.12, 0.52) | NE | ND
Health care system utilization
Other Outcomes
Relapse rates72,77,113,118,132,135 | 6 | 1405 | 1.35 (1.17, 1.57)^*^ | 0% | risperidone
Remission rates60,71 | 2 | 179 | 0.84 (0.56, 1.24) | 0% | ND
Response rates52,53,59,61,64,73,81,101,114,117,120,132,135,145,146,150 | 16 | 3453 | 0.94 (0.87, 1.02) | 29% | ND
Medication adherence72,101,149 | 3 | 661 | 0.99 (0.95, 1.02)^*^ | 0% | ND
Patient satisfaction146 | 1 | 67 | 0.67 (0.37, 1.20)^*^ | NE | ND
Health-Related Quality of Life
QLS: Total113 | 1 | 63 | 0.10 (−0.17, 0.37) | NE | ND
LQLP: total score118 | 1 | 289 | 0.10 (−0.20, 0.40) | NE | ND
LQLP: general health118 | 1 | 289 | −0.10 (−0.43, 0.23) | NE | ND
QoL: common objects113 | 1 | 63 | 0.04 (−0.25, 0.33) | NE | ND
QoL: Intrapsychic113 | 1 | 63 | 0.09 (−0.14, 0.32) | NE | ND
QoL: role functioning113 | 1 | 63 | 0.05 (−0.69, 0.79) | NE | ND

Note: bold = statistically significant;

* binary outcome;

BPRS = Brief Psychiatric Rating Scale; CDS–S = Calgary Depression Scale for Schizophrenia; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; HAM–A = Hamilton Rating Scale for Anxiety; HAM–D = Hamilton Rating Scale for Depression; I^2^ = I-squared; LQLP = Lancashire Quality of Life Profile; MADRS = Montgomery–Asberg Depression Rating Scale; ND = no difference; NE = not estimable; NOSIE = Nurses’ Observation Scale for Inpatient Evaluation; PANSS = Positive and Negative Symptom Scale; QLS = Quality of Life Scale; QoL = quality of life; SADS–C = Schedule for Affective Disorders and Schizophrenia–Change; SANS = Scale for the Assessment of Negative Symptoms; SAPS = Scale for the Assessment of Positive Symptoms; SCL–90–R = Symptom Checklist–90–R; SWBUN = Subjective Well-Being Under Neuroleptics Scale; YMRS = Young Mania Rating Scale

Table 44 Strength of evidence (GRADE): haloperidol versus risperidone

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Positive Symptoms
PANSS | 20 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
SAPS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
Negative Symptoms
PANSS | 20 RCT | Medium | Consistent | Direct | Precise | Moderate (favoring risperidone)
SANS | 4 RCT | Medium | Consistent | Direct | Precise | Moderate (favoring risperidone)
General Psychopathology
CDS–S | 3 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
HAM–A | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
HAM–D | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
MADRS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS | 13 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
YMRS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
Global Ratings and Total Scores
BPRS | 13 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
CGI–I | 3 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
CGI–S | 8 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
NOSIE–30 | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS | 20 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
SADS–C | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
SCL–90–R | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
SWBUN | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

BPRS = Brief Psychiatric Rating Scale; CDS–S = Calgary Depression Scale for Schizophrenia; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; HAM–A = Hamilton Rating Scale for Anxiety; HAM–D = Hamilton Rating Scale for Depression; MADRS = Montgomery–Asberg Depression Rating Scale; ND = no difference; NOSIE = Nurses’ Observation Scale for Inpatient Evaluation; RoB = risk of bias; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; SADS–C = Schedule for Affective Disorders and Schizophrenia–Change; SANS = Scale for the Assessment of Negative Symptoms; SAPS = Scale for the Assessment of Positive Symptoms; SCL–90–R = Symptom Checklist–90–R; SoE = strength of evidence; YMRS = Young Mania Rating Scale

Table 45 Characteristics of RCTs comparing haloperidol versus ziprasidone in the treatment of schizophrenia and related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout/Run-in Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Brook et al. 2005^57^ RCT (6 wks) | G1: HAL IM (2.5–10mg/d; Oral: 5–20mg/d); (138) G2: ZIP IM (10–40mg/d; Oral: 40–80mg/d); (429) | Acute exacerbation of Sz or schizoaffective disorder | High, Industry
Corripio et al. 2005^69^ RCT (2 wks) | G1: HAL (5–20mg/d); (10) G2: ZIP (10–40mg/d); (10) Washout period: 2 wks | Sz manifesting acute psychotic exacerbation | High, Multiple sources
Davidson et al. 2009^75^ RCT (6 mo) | G1: HAL (1–4mg/d); (103) G2: ZIP (40–160mg/d); (82) | <2 yrs since onset of positive symptoms; <2 wks exposure to AP <1 yr; <6 wks lifetime exposure to AP | High, Industry
Goff et al. 1998^83^ RCT (4 wks) | G1: HAL (15mg/d); (17) G2: ZIP (4mg/d); (19) G3: ZIP (10mg/d); (17) G4: ZIP (40mg/d); (17) G5: ZIP (160mg/d); (20) Washout period: ≥1 wks | Hospitalized ≤2 wks for acute exacerbation; hospitalized or resided in an intermediate tx center ≥3 mo; partially responded to AP tx; no depot AP ≤2 mo or recent illicit drug | High, NR
Hirsch et al. 2002^86^ NRCT (28 wks) | G1: HAL (5–15mg/d); (153) G2: ZIP (80–160mg/d); (148) Washout period: 2 wks Run-in phase: ≤2 wks | Chronic/subchronic Sz; required AP maintenance tx; ≤2 AP tx failures ≤2 yrs; received investigational AP ≤4 wks or FLU ≤5 wks | High, Industry
Kahn et al. 2008^91^ RCT (12 mo) | G1: HAL (1–4mg/d); (103) G2: ZIP (40–160mg/d); (82) | Sz/schizophreniform or schizoaffective disorder; ≤2 yrs since onset of positive symptoms; no AP ≥2 wks in last 1 yr, or ≥6 wks at any time | High, Industry
McCue et al. 2006^73^ RCT (3 wks) | G1: HAL (4–30mg); (61) G2: ZIP (40–240 mg); (59) | Sz, schizoaffective disorder, or schizophreniform disorder; no hx of response or lack of response to AP, BP, major depression, or substance-induced psychotic disorder | High, No external funding
Potkin et al. 2009^122^ RCT (3.75 yrs) | G1: HAL (5–20mg/d); (151) G2: ZIP (80–120mg/d); (448) G3: ZIP (80–160mg/d) Washout period: 4 wks | Chronic/subchronic Sz or schizoaffective disorder | Unclear, Industry

AP(s) = antipsychotic(s); BP = bipolar disorder; D = day; FLU = fluphenazine; G = group; HAL = haloperidol; Hx = history; IM = intramuscular; Mg = milligrams; Mo = month; NR = not reported; RCT = randomized controlled trial; Sz = schizophrenia; Tx = treatment; Wks = weeks; Yr(s) = year(s); ZIP = ziprasidone

Table 46 Evidence summary table: haloperidol versus ziprasidone

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Negative Symptoms
PANSS86,122 | 2 | 900 | 0.56 (−0.30, 1.42) | 0% | ND
General Psychopathology
CDS–S91 | 1 | 185 | 0.00 (−0.71, 0.71) | NE | ND
Covi anxiety57 | 1 | 567 | 0.63 (−1.23, 2.49) | NE | ND
MADRS86 | 1 | 301 | 0.10 (−1.85, 2.05) | NE | ND
Global Ratings and Total Scores
BPRS57,73,83,86 | 4 | 1078 | 0.24 (−0.57, 1.06) | 0% | ND
CGI–S57,83,86,91 | 4 | 1143 | −0.00 (−0.26, 0.26) | 28% | ND
GAF86,91,122 | 3 | 1085 | 0.30 (−1.58, 2.19) | 0% | ND
PANSS69,86,91,122 | 4 | 1105 | 1.22 (−0.62, 3.07) | 0% | ND
Sexual Dysfunction
Sexual dysfunction (UKU)91 | 1 | 185 | 0.69 (0.45, 1.07)^*^ | NE | ND
Health Care System Utilization
Rates of hospitalization/re–hospitalization86,91 | 2 | 486 | 2.62 (0.99, 6.97)^*^ | 0% | ND
Other Outcomes
Response rates57,69,73,83,86,91 | 6 | 1283 | 0.98 (0.74, 1.30)^*^ | 80% | ND
Remission rates86,91,122 | 3 | 1085 | 0.89 (0.71, 1.12)^*^ | 12% | ND
Health-Related Quality of Life
MANSA scale91 | 1 | 185 | −0.10 (−1.48, 1.28) | NE | ND
QLS122 | 1 | 599 | −12.12 (−22.06, −2.17) | NE | ziprasidone

BPRS = Brief Psychiatric Rating Scale; CDS–S = Calgary Depression Scale for Schizophrenia; CGI–S = Clinical Global Impression–Severity; GAF = Global Assessment of Functioning; I^2^ = I-squared; MADRS = Montgomery-Asberg Depression Scale; MANSA = Manchester Short Assessment of Quality of Life; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale; QLS = Quality of Life scale; UKU = Udvalg for Kliniske Undersogelser

Note: bold = statistically significant.

* Binary outcome.

Table 47 Strength of evidence (GRADE): haloperidol versus ziprasidone

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Negative Symptoms
PANSS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
General Psychopathology
CDS–S | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Covi nxiety | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
MADRS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Global Ratings and Total Scores
BPRS | 4 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
CGI–S | 4 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
GAF | 3 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
PANSS | 4 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)

BPRS = Brief Psychiatric Rating Scale; CDS–S = Calgary Depression Scale for Schizophrenia; CGI–S = Clinical Global Impression–Severity; GAF = Global Assessment of Functioning; I^2^ = I-squared; MADRS = Montgomery-Asberg Depression Scale; ND = no difference; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SoE = strength of evidence

Table 48 Characteristics of RCT comparing perphenazine versus aripiprazole in the treatment of schizophrenia and related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout/Run-in Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Kane et al. 2007^93^ RCT (6 wks) | G1: PER (8–64mg/d); (146) G2: ARI (15–30mg/d); (154) Washout period: 2–14 d Run–in phase: 4–6 wks | Tx resistant Sz with OLA or RIS; no schizoaffective disorder, residual schizophrenia, BP, refractory response to prior CLO or PER | Unclear, Industry

AP(s) = antipsychotic(s); ARI = aripiprazole; BP = bipolar disorder; CLO = clozapine; D = day; G = group; Mg = milligrams; No. = number; OLA = olanzapine; PER = perphenazine; RCT = randomized controlled trial; RIS = risperidone; Sz = schizophrenia; Tx = treatment; Wk(s) = week(s)

Table 49 Evidence summary table: perphenazine versus aripiprazole

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Global Ratings and Total Scores
CGI–I93 | 1 | 300 | −0.20 (−0.52, 0.12) | NE | ND
CGI–S93 | 1 | 300 | 0.00 (−0.25, 0.25) | NE | ND
PANSS scale93 | 1 | 300 | −0.70 (−5.61,4.21) | NE | ND
PANSS–derived BPRS93 | 1 | 300 | 0.00 (−0.99,0.99) | NE | ND
Other Outcomes
Response rates93 | 1 | 300 | 0.95 (0.64, 1.40)^*^ | NE | ND
Health-Related Quality of Life
Health-related quality of life (20% improvement)93 | 1 | 300 | 4.74 (2.58, 8.69) | NE | perphenazine

Note: bold = statistically significant;

* binary outcome;

BPRS = Brief Psychiatric Rating Scale; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; I2 = I-squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale

Table 50 Strength of evidence (GRADE): perphenazine versus aripiprazole

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Global Ratings and Total Scores
CGI–I | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
CGI–S | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS–derived BPRS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

BPRS = Brief Psychiatric Rating Scale; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence

Table 51 Characteristics of RCTs comparing perphenazine versus olanzapine in the treatment of schizophrenia

Study, Design (Followup) | Interventions, Dosages; No. Randomized | Main Inclusion Criteria | Risk of Bias, Financial Support
Ascher-Svanum et al. 2008^131^ RCT (1 yr) | G1: PER (NR); (48) G2: OLA (NR); (229) | Sz, schizoaffective or schizophreniform disorders; BPRS ≥18 | Unclear, Industry
Lieberman et al. 2005^23^ RCT (18 mo) | G1: PER (8–32mg/d); (261) G2: OLA (7.5–30mg/d); (336) | Sz defined by DSM–IV | Unclear, Multiple sources including industry

BPRS = Brief Psychiatric Rating Scale; D = day; DSM–IV = Diagnostic and Statistical Manual, 4^th^ edition; G = group; Mg = milligrams; Mo = month(s); No. = number; NR = not reported; OLA = olanzapine; PER = perphenazine; RCT = randomized controlled trial; Sz = schizophrenia; Yr(s) = year(s)

Table 52 Evidence summary table: perphenazine versus olanzapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive Symptoms
PANSS23 | 1 | 597 | 1.47 (0.55, 2.40) | NE | olanzapine
Negative Symptoms
PANSS23 | 1 | 597 | 0.43 (−0.55, 1.41) | NE | ND
General Psychopathology
PANSS23 | 1 | 597 | 2.17 (0.66, 3.68) | NE | olanzapine
Global Ratings and Total Scores
CGI–S23 | 1 | 597 | 0.25 (0.06, 0.43) | NE | olanzapine
PANSS23 | 1 | 597 | −4.59 (−7.42, −1.77) | NE | perphenazine
Employment/Personal Earnings
Paid employment in past month23 | 1 | 597 | 1.29 (0.70, 2.38)^*^ | NE | ND
Health Care System Utilization
Rates of hospitalization/rehospitalization23 | 1 | 597 | 1.39 (0.92, 2.09)^*^ | NE | ND
Health-Related Quality of Life
QLS Total score23 | 1 | 597 | 0.00 (−0.16, 0.16) | NE | ND
Medication Adherence
Time to all-cause medication discontinuation (days)131 | 1 | 277 | −78.70 (−119.34, −38.06) | NE | olanzapine

Note: bold = statistically significant;

* binary outcome;

CGI–S = Clinical Global Impression–Severity; I^2^ = I-squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale; QLS = Quality of Life Scale

Table 53 Strength of evidence (GRADE): perphenazine versus olanzapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Positive Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
Negative Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
General Psychopathology
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
Global Ratings and Total Scores
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
CGI–S | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

CGI–S = Clinical Global Impression–Severity; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence

Table 54 Characteristics of RCT comparing perphenazine versus quetiapine in the treatment of schizophrenia

Study, Design (Followup) | Interventions, Dosages; No. Randomized | Main Inclusion Criteria | Risk of Bias, Financial Support
Lieberman et al. 2005^23^ RCT (18 mo) | G1: PER (8–32mg/d); (261) G2: QUE (200–800mg/d); (337) | Sz defined by DSM–IV | Unclear, Multiple sources including industry

D = day; DSM–IV = Diagnostic and Statistical Manual, 4^th^ edition; G = group; Mg = milligrams; Mo = month(s); PER = perphenazine; QUE = quetiapine; RCT = randomized controlled trial; Sz = schizophrenia

Table 55 Evidence summary table: perphenazine versus quetiapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive Symptoms
PANSS23 | 1 | 586 | −0.93 (−1.93, 0.06) | NE | ND
Negative Symptoms
PANSS23 | 1 | 586 | −0.70 (−1.66, 0.26) | NE | ND
General Psychopathology
PANSS23 | 1 | 586 | −0.54 (−2.10, 1.02) | NE | ND
Global ratings and Total Scores
CGI23 | 1 | 586 | −0.17(−0.36, 0.01) | NE | ND
PANSS23 | 1 | 586 | 1.52 (−1.39, 4.43) | NE | ND
Employment/Personal Earnings
Paid employment in past month23 | 1 | 598 | 1.75 (0.90, 3.43)^*^ | NE | ND
Health Care System Utilization
Rates of hospitalization/rehospitalization23 | 1 | 598 | 0.78 (0.55, 1.11)^*^ | NE | ND
Health-related Quality of Life
Quality of Life Scale Total score23 | 1 | 598 | 0.10 (−0.07, 0.27) | NE | ND

* binary outcome;

CGI = Clinical Global Impression; I^2^ = I-squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale

Table 56 Strength of evidence (GRADE): perphenazine versus quetiapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Positive Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
Negative Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
General Psychopathology
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
General Psychopathology
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
CGI | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

CGI = Clinical Global Impression; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence

Table 57 Characteristics of RCTs comparing perphenazine versus risperidone in the treatment of schizophrenia

Study, Design (Followup) | Interventions, Dosages; No. Randomized | Main Inclusion Criteria | Risk of Bias, Financial Support
Ascher-Svanum et al. 2008^131^ RCT (1 yr) | G1: PER (NR); (48) G2: RIS (NR); (221) | Sz, schizoaffective or schizophreniform disorders; BPRS >18 | Unclear, Industry
Lieberman et al. 2005^23^ RCT (18 mo) | G1: PER (8–32mg/d); (261) G2: RIS (1.5–6.0mg/d); (341) | Sz defined by DSM–IV | Unclear, Multiple sources including industry

BPRS = Brief Psychiatric Rating Scale; D = day; DSM–IV = Diagnostic and Statistical Manual, 4th edition; G = group; Mg = milligrams; Mo = month(s); NR = not reported; PER = perphenazine; RCT = randomized controlled trial; RIS = risperidone; Sz = schizophrenia; Yr(s) = year(s)

Table 58 Evidence summary table: perphenazine versus risperidone

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive Symptoms
PANSS23 | 1 | 590 | −0.06 (−1.04, 0.94) | NE | ND
Negative Symptoms
PANSS23 | 1 | 590 | −0.87 (−1.86, 0.12) | NE | ND
General Psychopathology
PANSS23 | 1 | 590 | 0.24 (−1.39, 1.87) | NE | ND
Global Ratings and Total Scores
CGI23 | 1 | 590 | −0.06 (−0.25, 0.13) | NE | ND
PANSS23 | 1 | 590 | 0.17 (−2.84, 3.22) | NE | ND
Employment/Personal Earnings
Paid employment in past month23 | 1 | 602 | 1.38 (0.74, 2.57)^*^ | NE | ND
Health Care System Utilization
Rates of hospitalization/rehospitalization23 | 1 | 602 | 1.05 (0.72, 1.53)^*^ | NE | ND
Health-Related Quality of Life
Quality of Life Scale Total score23 | 1 | 602 | −0.07 (−0.24, 0.10) | NE | ND
Medication Adherence
Time to all-cause medication discontinuation (days)131 | 1 | 269 | −33.40 (−75.18, 8.38) | NE | ND

CGI = Clinical Global Impression; I^2^ = I-squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale; QLS = Quality of Life Scale

* Binary outcome.

Table 59 Strength of evidence (GRADE): perphenazine versus risperidone

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Positive Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
Negative Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
General Psychopathology
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
Global Ratings and Total Scores
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
CGI | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

CGI = Clinical Global Impression; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence

Table 60 Characteristics of RCT comparing perphenazine versus ziprasidone in the treatment of schizophrenia

Study, Design (Followup) | Interventions, Dosages; No. Randomized | Main Inclusion Criteria | Risk of Bias, Financial Support
Lieberman et al. 2005^23^ RCT (18 mo) | G1: PER (8–32mg/d); (261) G2: ZIP (40–160mg/d); (185) | Sz defined by DSM–IV | Unclear, Multiple sources including industry

d = Day; DSM–IV = Diagnostic and Statistical Manual, 4th edition; G = group; Mg = milligrams; Mo = month(s); PER = perphenazine; RCT = randomized controlled trial; Sz = schizophrenia; ZIP = ziprasidone

Table 61 Evidence summary table: perphenazine versus ziprasidone

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive Symptoms
PANSS23 | 1 | 440 | −0.85 (−2.06, 0.35) | NE | ND
Negative Symptoms
PANSS23 | 1 | 440 | −0.97 (−2.05, 0.11) | NE | ND
General Psychopathology
PANSS23 | 1 | 440 | −1.92 (−3.71, −0.14) | NE | perphenazine
Global Ratings and Total Scores
CGI23 | 1 | 440 | −0.12 (−0.34, 0.10) | NE | ND
PANSS23 | 1 | 440 | 2.23 (−1.18, 5.63) | NE | ND
Employment or Personal Earnings
Paid employment in past month23 | 1 | 446 | 1.22 (0.60, 2.51)^*^ | NE | ND
Health Care System Utilization
Rates of hospitalization or rehospitalization23 | 1 | 446 | 0.88 (0.58, 1.34)^*^ | NE | ND
Health-Related Quality of Life
Quality of Life Scale Total score23 | 1 | 446 | −0.07 (−0.27, 0.13) | NE | ND

Note: bold = statistically significant;

* point estimate reflex relative risk;

CGI = Clinical Global Impression; I^2^ = I-squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale; QLS = Quality of Life Scale

Table 62 Strength of evidence (GRADE): perphenazine versus ziprasidone

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Positive Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
Negative Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
General Psychopathology
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
Global Ratings and Total Scores
PANSS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient
CGI | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

CGI = Clinical Global Impression; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence

Table 63 Characteristics of RCTs comparing trifluoperazine versus clozapine in the treatment of schizophrenia and related psychoses

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Run-in Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Rinieris et al. 1980^157^ RCT (6 wks) | G1: TRI (7.5–15mg/d); (20) G2: CLO (50–100mg/d); (5) Run-in phase: 1 wk | Sz not further defined | High, NR

CLO = clozapine; D = days; G = group; Mg = milligrams; No. = number; NR = not reported; RCT = randomized controlled trial; Sz = schizophrenia; TRI = Trifluoperazine; Wk(s) = week(s)

Table 64 Evidence summary table: trifluoperazine versus clozapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Global Ratings
BPRS157 | 1 | 25 | 2.50 (−4.19, 9.19) | NE | ND

BPRS = Brief Psychiatric Rating Scale; I^2^ = I-squared; ND = no difference; NE = not estimable

Table 65 Strength of evidence (GRADE): trifluoperazine versus clozapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Global Ratings and Total Scores
BPRS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

BPRS = Brief Psychiatric Rating Scale; RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence

For KQ1, the outcomes are grouped as follows: positive symptoms, negative symptoms, general psychopathology, global ratings, and total scores. Additionally, scores on subscales or composite scores, and functional capacity outcomes are presented in Appendix L. KQs 2 and 4 were grouped and are reported together throughout the results section. Within all KQs, comparisons are presented in alphabetic order by drug name.

### Chlorpromazine Versus Clozapine

#### Key Points

- Nine RCTs comparing chlorpromazine with clozapine in patients with a range of illness severity were included; few studies examined the same outcomes.
- The most commonly reported outcome was total symptom score using the Brief Psychiatric Rating Scale (BPRS). Pooled results from six studies showed greater efficacy for clozapine, and the difference was considered clinically important (moderate strength of evidence (SoE)).
- Three trials assessed response rates and showed a significant difference favoring clozapine; two trials included treatment-resistant patients with followup between 6 and 12 weeks.
- Two trials assessed remission rates and found no significant difference; length of followup was 5 weeks (chronic schizophrenia) and 1 year (first-episode schizophrenia).
- The remaining outcomes were assessed in single trials; the majority showed no significant differences between antipsychotic effect.

Nine RCTs63,87,94,109,153,154,157,158,161 (n = 765) compared chlorpromazine versus clozapine. The doses varied across the studies ranging from 50 to 1800 mg/d for chlorpromazine and 25 to 900 mg/d for clozapine. Key characteristics of the included trials and summary of results are presented in Table 8 and Table 9. All the trials included patients with schizophrenia. One trial109 also included patients with schizophreniform disorder. Another trial153 only included males with paranoid/hallucinatory or catatonic type schizophrenia. Two trials87,94 were in patients considered to be treatment resistant; both studies assessed treatment resistance historically, whereas one of the studies94 also confirmed treatment resistance with a run-in period. One study109 focused on participants with first-episode schizophrenia. Three trials87,109,161 included only Asian participants. Two trials87,158 specifically excluded participants with drug or alcohol dependence.

The risk of bias was unclear for seven studies87,94,109,153,154,158,161 and high for two studies.63,157 Three studies had financial support from industry: in two studies94,154 the industry sponsors were producers of both drugs being compared, whereas the third study109 was sponsored by a company that produces clozapine. Duration of followup was ≤6 weeks for five studies,94,153,154,157,158 between 6 weeks and 6 months for three studies,63,87,161 and >6 months for two studies.109,156

Publication bias was not formally tested for any of the outcomes due the small number of included trials. The SoE for the majority of the evaluated outcomes was insufficient due to the small number of included trials (Table 10).

#### Key Question 1 Improving Core Illness Symptoms

##### Positive Symptoms

One trial87 (n = 40) of patients with treatment-refractory schizophrenia and symptoms for greater than 6 months compared chlorpromazine (50–1800 mg/d) with clozapine (25–900 mg/d); there was no significant difference in positive symptoms based on the Positive and Negative Symptom Scale (PANSS) (Table 9). The SoE was graded insufficient (Table 10).

##### Negative Symptoms

One trial109 (n = 164) of treatment-naïve patients with schizophrenia or schizophreniform disorder compared chlorpromazine (≤600 mg/d) with clozapine (≤400 mg/d) and reported no significant difference for negative symptoms using the Scale for the Assessment of Negative Symptoms (SANS) (Table 9). The SoE was graded as insufficient (Table 10).

##### General Psychopathology

One trial87 (n = 40) of patients with treatment-refractory schizophrenia and symptoms for greater than 6 months compared chlorpromazine (50–1800 mg/d) with clozapine (25–900 mg/d) and found no significant difference for PANSS (general psychopathology) (Table 9). The SoE was graded as insufficient (Table 10).

##### Global Ratings and Total Scores

Seven trials63,87,94,109,154,157,161 (n = 699) reported total scores using five unique scales (Table 9). All seven trials reported total scores based on the BPRS. Two trials87,94 were in patients with treatment resistance. The dosages of chlorpromazine ranged from 50–1800 mg/d and clozapine from 25–900 mg/d.

Pooled results are not reported due to considerable heterogeneity among the included trials (I^2^ = 90 percent) (Appendix M, Table 94). One trial109 showed an effect in the opposite direction to the other studies: the point estimate favored chlorpromazine, although the difference between groups was not statistically significant. This trial was distinct from the other trials in that it specifically included patients with schizophreniform disorder and only those with a first episode, used relatively lower doses of both the FGA and SGA, and followed patients for 12 months. Removing this trial from the analysis reduced the heterogeneity to 20 percent.

Pooling of the remaining six trials showed a significant difference favoring clozapine (MD [mean difference] = 8.40; 95% CI, 5.92 to 10.88) (Table 9; Figure 3). This difference was considered to be clinically significant. The results of subgroup and sensitivity analyses showed some variation in the magnitude of effect based on population and study characteristics. A larger effect was observed for patients with treatment resistance and previous episodes, for trials with shorter followup periods, and for industry-funded trials. The effect in favor of clozapine was larger when higher doses of chlorpromazine were used (up to 1800 mg/d vs. 100 and 600 mg/day). Sensitivity analyses showed a larger effect when studies with imputed data were excluded, whereas no notable difference in effect was found based on risk of bias. Overall, the SoE for this outcome was graded as moderate (Table 10).

Figure 3 Chlorpromazine versus clozapine – core symptoms (Sz) – Total score

BPRS = Brief Psychiatric Rating Scale; CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; SD = standard deviation; Sz = schizophrenia

Figure 3 is a metagraph depicting the effect of chlorpromazine versus clozapine for total score on the BPRS for patients with Sz. Seven studies contributed data from 699 patients. Pooled results are displayed for patients with previous schizophrenic episodes and those with their first episode. For the six studies (n=535) comparing patients with previous episodes, the pooled estimates showed clozapine to be superior to chlorpromazine on BPRS scores (MD=8.40, 95 percent CI, 5.92, 10.88). For the one study (n=164) comparing treatment naïve patients, chlorpromazine was favored, although the difference was not significant (MD=−0.20, 95 percent CI, −1.38, 0.98).

One trial,94 (n = 268) in patients with a history of treatment resistance compared chlorpromazine (1000–1800 mg/d) with clozapine (500–900 mg/d) and reported Clinical Global Impression–Severity (CGI–S). The study found a significant difference favoring clozapine (Table 9). This difference was considered clinically significant; however, the SoE was graded as insufficient (Table 10).

One trial109 (n = 164) in treatment-naïve patients comparing chlorpromazine (≤600 mg/d) with clozapine (≤400 mg) reported no significant difference based on the Clinical Global Impression–Improvement (CGI–I) and Global Assessment of Functioning (GAF) (Table 9). The SoE for these outcome measures was graded as insufficient (Table 10).

One trial87 (n = 40) of patients with treatment-refractory schizophrenia and symptoms for greater than 6 months compared chlorpromazine (50–1800 mg/d) with clozapine (25–900 mg/d) and reported no significant difference in PANSS (total) (Table 9). The SoE was graded as insufficient (Table 10).

#### Key Questions 2 and 4 Improvement in Functional Outcomes, Decreasing Health Care System Utilization, and Other Outcomes

##### Health Care System Utilization

One trial109 (n = 164) of treatment-naïve patients compared chlorpromazine (≤600 mg/d) with clozapine (≤400 mg) and found no significant differences in rates of hospitalization or rehospitalization (Table 9).

Other Outcomes. Three trials87,94,154 (n = 323) in patients with schizophrenia, including those with treatment resistance,87,94 compared chlorpromazine (50–1800 mg/d) with clozapine (25–900 mg/d) and reported a significant difference favoring clozapine for response rates (Table 9).

Two trials109,158 (n = 189) in treatment-naïve patients with schizophrenia or schizophreniform disorder109 and chronic schizophrenics with an acute exacerbation necessitating involuntary hospitalization158 compared chlorpromazine (50–1600 mg/d) with clozapine (25–900 mg/d). No significant differences were found in remission rates (Table 9).

#### Key Question 5 Subgroups

##### Race

Three trials87,109,161 (n = 244) were performed exclusively in Asian patients with schizophrenia and compared chlorpromazine (50–1800 mg/d) with clozapine (25–900 mg/d). There was no significant difference for the PANSS (positive),87 SANS,109 PANSS (general psychopathology),87 or global ratings and global ratings and total scores (BPRS,87,109,161 CGI–I,109 GAF,109 and PANSS (total)).87

##### Sex

One trial153 (n = 41) examined males with acute schizophrenia or relapsed or exacerbated chronic schizophrenia of the paranoid/hallucinatory or catatonic types. The trial compared chlorpromazine (65–700 mg/d) with clozapine (65–600 mg/d); however, there was no extractable data for KQs 1, 2, or 4.

##### Treatment Naïve and Treatment of First Episode

One trial109 (n = 164) in treatment-naïve patients compared chlorpromazine (≤600 mg/d) with clozapine (≤400 mg). No significant differences were reported for negative symptoms using SANS and global rating scores based on BPRS and CGI–I.

Treatment Resistance. Two trials87,94 (n = 308) in patients with treatment resistance compared chlorpromazine (50–1800 mg/d) with clozapine (25–900 mg/d) and reported a significant difference favoring clozapine for BPRS (MD = 10.22; 95% CI, 7.12 to 13.33) and CGI–S (MD = 0.90; 95% CI, 0.67 to 1.13). The differences were considered to be clinically significant. The differences on the PANSS (positive), PANSS (general psychopathology), and PANSS (total) were not significantly different between groups.

### Chlorpromazine Versus Olanzapine

One RCT66 (n = 84) compared chlorpromazine (600–1200 mg/d) with olanzapine (12.5–25 mg/d) in patients with treatment-resistant schizophrenia (Table 11). There was no reported difference in core illness symptoms (negative symptoms, global ratings) and response rates between groups (Table 12). No other relevant outcomes were reported. The SoE for all reported outcomes was insufficient (Table 13).

### Chlorpromazine Versus Quetiapine

One RCT121 (n = 201) compared chlorpromazine (75–750 mg/d) with quetiapine (75–750 mg/d) in patients with chronic or subchronic schizophrenia with an acute exacerbation or patients with schizophreniform disorder (Table 14). There was no reported difference in response rates between groups (Table 15). No other relevant outcomes were reported.

### Chlorpromazine Versus Ziprasidone

One RCT96 (n = 306) compared chlorpromazine (100–1200 mg/d) with ziprasidone (40–160 mg/d) in Asian patients with chronic or subchronic treatment-resistant schizophrenia (Table 16). There were no reported results for core illness symptoms. There was no difference in response rates between groups (Table 17). No other relevant outcomes were reported.

### Fluphenazine Versus Olanzapine

One RCT89 (n = 60) compared fluphenazine (6–21 mg/d) with olanzapine (5–20 mg/d) in Caucasian patients with stable schizophrenia (Table 18). For positive symptoms, a significant difference favored olanzapine based on PANSS (positive) (Table 19). For general psychopathology, significant differences favoring olanzapine based on the Hamilton Rating Scale for Anxiety (HAM–A) and the PANSS (general psychopathology) were reported (Table 19). Global Ratings and Total Scores reported significant benefits favoring olanzapine for the BPRS, CGI–S, and PANSS (total) scales (Table 19). The results for the core illness symptoms were not considered to be clinically significant, and the SoE for all the evaluated outcomes was insufficient due to the inclusion of only a single trial (Table 20). No significant differences were found for negative symptoms based on PANSS (negative) and response rates (Table 19).

### Fluphenazine Versus Quetiapine

One RCT67 (n = 25) compared fluphenazine (10–15 mg/d) versus quetiapine (300–500 mg/d) in patients with treatment-resistant schizophrenia (Table 21). No significant differences were reported between groups for core illness symptoms (global ratings), sexual dysfunction, and response rates (Table 22). The SoE for all the evaluated outcomes was insufficient due to the inclusion of only a single trial (Table 23).

### Fluphenazine Versus Risperidone

One RCT67 (n = 26) compared fluphenazine (10–15 mg/d) with risperidone (3–5 mg/d) in patients with treatment-resistant schizophrenia (Table 24). No differences were found between groups for any of the core illness symptom assessments (global ratings), sexual dysfunction, and response rates (Table 25). The SoE for all the evaluated outcomes was insufficient due to the inclusion of only a single trial (Table 26).

### Haloperidol Versus Aripiprazole

#### Key Points

- Eight RCTs compared haloperidol with aripiprazole among patients with varying disease severity.
- Six studies assessing global ratings using three different tools (BPRS, CGI–I, and CGI–S) found no differences between study groups. The SoE was graded as low or insufficient depending on the scale used.
- A significant difference in favor of aripiprazole was found for negative symptoms based on three studies that used the PANSS (negative) scale (moderate SoE). This finding was not considered to be clinically significant.
- No difference was found for positive symptoms based on two studies that used the PANSS (positive) scale (low SoE).
- Five studies assessed response rates and showed no differences between groups.
- The remaining outcomes were assessed in single trials, and the majority showed no significant differences.

Eight RCTs31,44,73,74,76,92,98,102 (n = 2,850) compared haloperidol with aripiprazole. Key characteristics of the included trials and summary of findings are presented in Table 27 and Table 28, respectively. Five trials31,73,74,76,92 specifically included patients with schizoaffective disorder, whereas one trial44 specifically excluded patients with schizoaffective disorder. Five studies31,44,74,76,92 specifically excluded patients with drug and/or alcohol dependence. Two studies98,102 included only patients with multiple episodes, whereas the remaining studies included patients with both first and multiple episodes. Five studies31,44,73,74,98 included only patients with no treatment resistance; the remaining three studies included mixed populations with both treatment resistance and no treatment resistance. One trial102 included only Asian patients. In the majority of studies, the maximum dose of haloperidol was 10 mg/d; in two studies the maximum dose was 15 mg/d76 and 30 mg/d.73 The dosage for aripiprazole varied across studies ranging from 1 mg/d31 to 45 mg/d.73

Risk of bias was unclear for five studies31,44,74,98,102 and high for three studies.73,76,92 The duration of followup was <6 weeks in five studies,31,44,73,74,92 between 6 weeks and 6 months in two studies,76,102 and >6 months in one study.98 Six studies31,44,74,76,92,98 were funded by industry; in all cases the industry manufactured aripiprazole.

Publication bias was not formally tested for any of the outcomes due the small number of included trials. The SoE for the majority of the evaluated outcomes was insufficient due to the small number of trials (Table 29).

#### Key Question 1 Improving Core Illness Symptoms

##### Positive Symptoms

Three trials76,92,102 (n = 473) assessed positive symptoms using two different scales. Two of the studies76,92 included only patients with schizoaffective disorders and no alcohol and/or drug use; the third study102 only included Asians and a mixed population in terms of disorder subtypes and comorbid drug or alcohol use. Studies were consistent in the dosages of study drugs. Duration of followup was <6 weeks for one study92 and 8 weeks for two studies.76,102 Risk of bias was high for two studies76,92 and unclear for one study.102 Two of the studies were industry-funded.76,102

No significant differences were found based on the PANSS (positive; two studies)76,92 and Scale for the Assessment of Positive Symptoms (SAPS; 1 study)102 (Table 28; Figure 4). There was moderate statistical heterogeneity between the two studies that reported PANSS scores; the only notable differences between these studies were duration of followup of 4 weeks92 versus 8 weeks76 and risk of bias (high92 vs. unclear76). The SoE was graded as low for PANSS (positive) and insufficient for SAPS (Table 29).

Figure 4 Haloperidol versus aripiprazole – Positive symptoms

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 4 is a metagraph depicting the effect of haloperidol versus aripiprazole on positive symptoms in patients with Sz. Two studies contributed data from 407 participants. The pooled estimate shows no difference between haloperidol and aripiprazole on the PANSS (MD=−0.99, 95 percent CI, −2.64, 0.67). Moderate statistical heterogeneity was present (p=0.23, I2=32 percent).

Negative Symptoms. Four trials76,92,98,102 (n = 1767) reported on negative symptoms. Two trials76,92 specifically included patients with schizoaffective disorders and no comorbid drug or alcohol use; two trials98,102 included mixed populations in terms of disorder subtype and cormorbid drug or alcohol use. Two trials98,102 included only patients with multiple episodes, whereas two trials76,92 included mixed first and multiple episodes. One trial98 specifically excluded treatment-resistant patients, and one study102 included only Asians. One trial102 included a higher range of haloperidol dose; the doses of aripiprazole were consistent across studies. Risk of bias was high for two studies76,92 and unclear for two studies.98,102 All studies were industry-funded except one.102

There was a significant difference favoring aripiprazole based on PANSS (negative), with no evidence of statistical heterogeneity (Table 28; Figure 5).76,92,98 This difference was not considered to be clinically significant. There was no difference in the SANS102 based on one small study (Table 28). The SoE was graded as moderate for PANSS (negative) and insufficient for SANS (Table 29).

Figure 5 Haloperidol versus aripiprazole – Negative symptoms

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 5 is a metagraph depicting the effect of haloperidol versus aripiprazole on negative symptoms in patient with Sz. This metagraph pooled three studies with a total of 1,701 patients contributing data. There was a significant difference favoring aripiprazole based on PANSS (negative) (MD=0.80, 95 percent CI, 0.14, 1.46).

##### General Psychopathology

One trial comparing 7.5 mg/d haloperidol with 1 mg/d aripiprazole reported results for the Agitation-Calmness Evaluation Scale (ACES) and Corrigan Agitated Behavior Scale (CABS),31 and showed no differences between study groups. The study specifically included patients with schizoaffective disorders and no comorbid alcohol or drug use. The study excluded patients with treatment resistance and included both first and multiple episodes. Length of followup was only 24 hours. Risk of bias was unclear, and the study was industry-funded.

One trial76 (n = 99) reported PANSS (general psychopathology) and found no differences between groups over the 8-week study period (Table 28). The trial included only patients with schizoaffective disorders and no comorbid alcohol or drug use; the trial included a mix of first and multiple episodes, as well as treatment-resistant and nonresistant patients. Risk of bias was high, and the trial was industry-funded.

The SoE for PANSS (negative), ACES, and CABS was graded as insufficient (Table 29).

##### Global Ratings and Total Scores

Six trials31,44,73,74,76,92 (n = 1,490) presented global rating scores. No differences were found for BPRS (3 studies),31,44,73 CGI–I (1 study),31 or CGI–S (5 studies)31,44,74,76,92 (Table 28; Figure 6). The SoE was graded as low for BPRS and CGI–S and insufficient for CGI–I (Table 29).

Figure 6 Haloperidol versus aripiprazole – Global ratings and total scores

BPRS = Brief Psychiatric Rating Scale; CGI–S = Clinical Global Impression–Severity; CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; SD = standard deviation

Figure 6 is a metagraph depicting the effect of haloperidol versus aripiprazole on global ratings and total scores for patients with Sz. Three studies (n=779) used the BPRS to evaluate patients. One study favored aripiprazole, while the other two favored haloperidol (MD=−0.01, 95 percent CI, −2.82, 2.81). The studies were statistically heterogeneous (p=0.09, I2=59%). Five studies (n=1,366) presented global ratings scores using the CGI scale. Pooled analysis of the five studies found no difference between treatments (MD=−0.03, 95 percent CI, −0.20, 0.14).

The three trials31,44,73 that reported BPRS were statistically heterogeneous: one trial had an effect estimate favoring aripiprazole, and the other two favored haloperidol (although 95% CIs in all cases included the null). All three trials specifically included patients with schizoaffective disorders and no treatment resistance, and included mixed first and multiple episodes. The one trial differed in that it did not specifically exclude patients with comorbid drug or alcohol use, and it used relatively higher doses of both haloperidol (4–30 mg/d vs. 6.5 and 7.5 mg/d) and aripiprazole (10–45 mg/d vs. 1 and 9.75 mg/d). Further, the duration of followup was longer for the one trial (3 weeks vs. 24 hours). The trial73 that differed had high risk of bias and was not industry-funded, while the other two trials had an unclear risk of bias and were industry-funded.

The five trials31,44,74,76,92 that reported CGI–S showed no evidence of statistical heterogeneity, but varied on several clinical and study characteristics. All studies specifically included patients with schizoaffective disorders except one44 in which patients with schizoaffective disorders were excluded. Three studies31,44,74 specifically excluded treatment-resistant patients, whereas two studies76,92 had both treatment-resistant and nonresistant patients. All studies specifically excluded patients with comorbid drug or alcohol use. The range of dose for haloperidol was relatively consistent across studies; however, the dose for aripiprazole ranged from 1 mg/d31 to 15–30 mg/d.76,92 The duration of followup ranged from 24 hours31,44 to 8 weeks.76 Risk of bias was unclear for all but one trial, which was high;92 all trials were industry-funded.

#### Key Questions 2 and 4 Improvement in Functional Outcomes, Decreasing Health Care System Utilization, and Other Outcomes

##### Other Outcomes

Five trials44,73,76,92,98 (n = 2,185) assessed treatment response rates and found no significant difference between groups (Table 28; Figure 7); however, there was considerable statistical heterogeneity (Appendix M, Table 95). The trials varied on characteristics of the patient populations: schizoaffective disorder included,73,76,92 schizoaffective disorder excluded,44 mixed;98 treatment-resistant patients excluded.44,73,98 All but one trial98 excluded patients with comorbid drug or alcohol use and included mixed first and multiple episodes. Doses ranged across studies from 6.5 to 4–30 mg/d for haloperidol and from 1 mg to 10–45 mg/d for aripiprazole. Duration of followup also varied across studies from 24 hours44 to 52 weeks.98 All but one study73 were assessed as unclear risk of bias and were industry-funded. None of these variables explained the statistical heterogeneity in the pooled estimate of effect.

Figure 7 Haloperidol versus aripiprazole – Response rates

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; M-H = Mantel-Haenszel

Figure 7 is a metagraph depicting the effect of haloperidol versus aripiprazole on response rates in patients with Sz. A total of five studies contributed data from 2,185 patients. No significant difference was found between haloperidol and aripiprazole (MD=1.01, 95 percent CI, 0.76, 1.34); however considerable statistical heterogeneity was present between studies (p<0.0001, I2=83%).

One trial76 (n = 99) comparing 10–15 mg/d haloperidol with 15–30 mg/d aripiprazole examined medication adherence, caregiver satisfaction, and patient satisfaction. The study reported a significant difference for caregiver and patient satisfaction favoring aripiprazole. There was no significant difference between groups for compliance rates (Table 28). This study specifically included patients with schizoaffective disorder, no comorbid drug or alcohol use, and mixed first and multiple episodes. Length of followup was 8 weeks. Risk of bias was unclear, and the study was industry-funded.

#### Key Question 5 Subgroups

##### Race

One trial102 (n = 66) involving Korean patients with schizophrenia compared haloperidol (15.9±7.1 mg/d) with aripiprazole (21.7±5.5 mg/d) and reported no significant difference for positive (SAPS) or negative (SANS) core illness symptoms.

### Haloperidol Versus Asenapine

One RCT97 (n = 335) compared haloperidol (4 mg/d) with asenapine (5–10 mg/d) in patients with schizophrenia with acute exacerbation of psychotic symptoms (Table 30). This study did not find any significant differences between groups for core illness symptoms (positive, negative, or general psychopathology symptoms and global ratings and total scores) or for response rates (Table 31). The SoE for all the evaluated outcomes was insufficient due to the inclusion of only a single trial (Table 32).

### Haloperidol Versus Clozapine

#### Key Points

- Nine studies compared haloperidol with clozapine and involved patients with varying disease severity.
- Four studies assessed total scores using BPRS and three studies using PANSS. No differences were found between groups for either scale. Results were statistically heterogeneous for the PANSS total score, with one trial showing a significant difference favoring clozapine. This trial included patients with treatment-refractory schizophrenia and a history of high use of inpatient services; further, the study had a longer duration of followup (12 months vs. 12–14 weeks). The SoE was low for both BPRS and PANSS.
- The remaining outcomes were assessed in only one to two trials each; all showed no significant differences between study groups, except for CGI–I and CGI–S in a single study.

Nine RCTs55,62,70,95,103,105,126,145,155 (n = 1,000) compared haloperidol with clozapine. Key characteristics of the included trials and summary of findings are presented in Table 33 and Table 34, respectively. All trials included various disorder subtypes, except for one study103 that included only patients with paranoid schizophrenia; four studies70,95,105,145 specifically included patients with schizoaffective disorders. Five trials55,62,95,126,145 included patients with treatment-resistant schizophrenia, and one study105 specifically excluded treatment-resistant patients. Five trials55,62,95,126,145 included only patients with multiple episodes. Two trials55,95 specifically excluded patients with comorbid drug or alcohol use. The dosages varied across studies, ranging from 2.25 to 30 mg/d for haloperidol and 12.5 to 900 mg/d for clozapine.

Risk of bias was unclear for all but two studies,62,95 which were high. Five studies were funded; by producers of clozapine,62,95 both haloperidol and clozapine,126,145 or makers of other antipsychotics.105 Duration of followup varied: <6weeks for one study;103 between 6 weeks and 6 months for five studies;55,62,105,145,155 and >6 months for three studies.70,95,126

Publication bias was not formally tested for any of the outcomes due to the small number of included trials. The SoE for the majority of the evaluated outcomes was insufficient to low due to the small number of trials in individual outcomes assessments (Table 35).

#### Key Question 1 Improving Core Illness Symptoms

##### Positive Symptoms

Two trials105,145 (n = 150) assessed positive symptoms using PANSS (positive) and found no significant differences between groups (Table 34; Figure 8). The studies specifically included schizoaffective patients. One study145 specifically included patients with multiple episodes with treatment resistance whereas the other study105 excluded patients with treatment resistance. The doses of haloperidol (10–30 mg/d) and clozapine (200–800 mg/d) were consistent across studies. Duration of followup was relatively consistent, ranging from 12 to 14 weeks. Risk of bias was unclear for both studies, and both were industry-funded. The SoE was low for PANSS (positive) (Table 35).

Figure 8 Haloperidol versus clozapine – Positive symptoms

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 8 is a metagraph depicting the effect of haloperidol versus clozapine on positive symptoms in patients with Sz. Two studies provided data from 150 participants. The pooled estimate showed no significant difference between groups when assessing positive symptoms using the PANSS (MD=−1.50, 95 percent CI, −3.36, 0.37)

##### Negative Symptoms

Four trials55,70,105,145 (n = 307) compared haloperidol (10–30 mg/d) with clozapine (200–800 mg/d). Three70,105,145 of the four trials specifically included patients with schizoaffective disorders. Two studies included only patients with multiple episodes,55,145 whereas the other two trials included mixed first and multiple episodes. Two studies included only treatment-resistant patients assessed by history145 and run-in;55 one study105 specifically excluded treatment-resistant patients. One trial55 specifically excluded patients with comorbid drug or alcohol use. The drug doses were consistent in three studies, but not reported in one.70 Duration of followup was 10 to 14 weeks for three studies and 24 months for the fourth.70 Risk of bias was unclear for all studies; two studies were industry-funded105,145 and two55,70 were government-funded.

No significant differences between groups were found based on PANSS (negative)55,70 and SANS55,70 (Table 34; Figure 9). The SoE for both scales was graded as low (Table 35).

Figure 9 Haloperidol versus clozapine – Negative symptoms

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SANS = Scale for the Assessment of Negative Symptoms; SD = standard deviation

Figure 9 is a metagraph depicting the effect of haloperidol versus clozapine on negative symptoms in patients with Sz and schizoaffective disorders (3 studies only). Two studies measured negative symptoms using the PANSS scale (n=150) and found no difference between treatments (MD=0.11, 95 percent CI, −1.75, 1.96). Two studies measured negative symptoms using the SANS scale (n=157) and found no difference between groups (MD=0.94, 95 percent CI, −2.60, 4.48).

##### General Psychopathology

Two trials105,145 (n = 150) used the PANSS (general psychopathology). Both trials specifically included patients with schizoaffective disorders. One trial145 included only patients with multiple episodes, whereas the other study included patients with both first and multiple episodes. Treatment-resistant patients were included in one study145 and excluded in the other. Both trials used the same doses of study drugs. Duration of followup was also consistent (12 and 14 weeks, respectively). Both studies had unclear risk of bias and were industry-funded.

The studies were consistent in their treatment estimates, and pooled results showed no significant difference between groups for general psychopathology (Table 34; Figure 10). The SoE was graded as low (Table 35).

Figure 10 Haloperidol versus clozapine – General psychopathology

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 10 is a metagraph depicting the effect of haloperidol versus clozapine on general psychopathology as measured by the PANSS scale in patients with Sz. Two studies (n=150) were pooled. The studies were consistent in their treatment estimates and pooled results showed no significant difference between groups (MD=−0.64, 95 percent CI, −3.11, 1.82).

One105 of the above studies also reported results of the Modified Overt Aggression Scale (MOAS) and found no difference between groups (insufficient SoE).

##### Global Ratings and Total Score

Seven trials55,95,103,105,126,145,155 (n = 841) reported global ratings and total scores using four different scales. Four studies55,95,103,155 used BPRS and reported consistent findings, with a pooled estimate showing no significant difference between groups (Table 34; Figure 11). These studies included varied disorder subtypes: paranoid schizophrenia,103 schizoaffective disorders,95 and mixed.55,155 Two studies55,95 included only patients with multiple episodes and treatment resistance and specifically excluded patients with comorbid alcohol or drug use. Duration of followup ranged from 4 weeks103 to 29 weeks.95 Risk of bias was unclear in all but one study,95 which was high. Source of funding was not reported in two studies;103,155 one study95 was industry-funded and one was government-funded.55

Figure 11 Haloperidol versus clozapine – Global ratings and total scores

BPRS = Brief Psychiatric Rating Scale; CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 11 is a metagraph depicting the effect of haloperidol versus clozapine on global ratings and total scores in patients with Sz. Four studies with 268 patients used the BPRS scale to evaluate total scores were pooled. All four studies showed consistent findings and the pooled estimate showed no significant difference between the groups (MD=2.16, 95 percent CI, −0.56, 4.87). Three studies involving 573 patients used the PANSS scale to evaluate global ratings. The pooled estimate showed no significant difference between groups (MD=1.04, 95 percent CI, −3.91, 5.98); however statistical heterogeneity was substantial (p=0.09, I2=58%).

Three studies used PANSS (total score).105,126,145 The pooled estimate showed no significant difference between groups (Table 34; Figure 11); however, the statistical heterogeneity was substantial. Moreover, one of the studies126 showed a significant difference in favor of clozapine, whereas the other two studies showed no significant difference. Removing this one study from the analysis reduced the heterogeneity to 0 percent, and the result remained nonstatistically significant. The trial differed from the other two with respect to several clinical and study characteristics. The two studies with similar estimates specifically included patients with schizoaffective disorders. The study that differed had a greater range of dosing: 5–30 mg/d versus 10–30 mg/d for haloperidol and 100–900 mg/d versus 200–800 mg/d for clozapine. Duration of followup differed substantially: 12 to 14 weeks for the two similar studies105,145 versus 12 months.126 All studies had unclear risk of bias and were funded by industry.

One study95 assessed global rating scores using CGI–I and CGI–S (Table 34). The study included patients with schizoaffective disorder, multiple episodes, and treatment resistance. Patients with comorbid drug or alcohol use were specifically excluded. The doses were 5–16 mg/d for haloperidol and 12.5–800 mg/d for clozapine. Duration of followup was 29 weeks. The risk of bias was high, and the study was industry-funded. The results for both scales were statistically significant in favor of clozapine.

The SoE for BPRS and PANSS was graded as low; CGI–I and CGI–S were graded as insufficient (Table 35).

#### Key Questions 2 and 4 Improvement in Functional Outcomes, Decreasing Health Care System Utilization, and Other Outcomes

##### Health Care System Utilization

One trial126 (n = 423) in patients with treatment-refractory schizophrenia compared haloperidol (5–30 mg/d) with clozapine (10–900 mg/d) and reported no significant differences in duration of hospital stay between groups (Table 34).

##### Other Outcomes

One trial examining treatment-resistant patients with mixed disorder subtypes, multiple episodes, and no cormorbid alcohol or drug use reported no significant difference in relapse rates (Table 34).55 The study compared 5–16 mg/d haloperidol with 12.5–800 mg/d clozapine and followed patients for 29 weeks. Risk of bias was unclear, and the trial was government-funded.

Two studies assessed treatment response95,105 and found no significant difference overall; however, there was substantial statistical heterogeneity. One study95 showing a positive effect in favor of clozapine included patients with schizoaffective disorders, multiple episodes, treatment resistance, and no comorbid drug or alcohol use. The study compared 5–16 mg/d haloperidol with 12.5–800 mg/d clozapine. Duration of followup was 29 weeks. The study had high risk of bias and was industry-funded. This study also examined remission rates and found no significant difference between groups. The second study105 showed no significant difference between groups. It also included patients with schizoaffective disorders and multiple episodes; however, it included patients with both first and multiple episodes and excluded treatment-resistant patients. The risk of bias was unclear, and the trial was industry-funded.

Finally, one study103 assessed patient satisfaction and found no significant difference between groups. The study included mixed disorder subtypes and patients with multiple episodes, treatment resistance, and no comorbid alcohol or drug use. The study compared 10–30 mg/d haloperidol with 200–600 mg/d clozapine and followed patients for 10 weeks. The risk of bias was unclear, and the study was government-funded.103

#### Key Question 5 Subgroups

##### Disorder Subtypes and Treatment Naïve

One trial103 (n = 34) in treatment-naïve patients with paranoid schizophrenia compared 16 mg/d haloperidol with 12.5–800 mg/d clozapine and found no significant difference on BPRS.

##### Treatment Resistance

Five trials55,62,95,126,145 (n = 88) in patients with treatment-refractory schizophrenia compared 5–30 mg/d haloperidol with 12.5–900 mg/d clozapine and found no significant differences for positive symptoms (PANSS (positive)145), negative symptoms (PANSS (negative),145 SANS55), general psychopathology (PANSS (general psychopathology)145), or general ratings and total scores (BPRS,55,95 PANSS (total)126,145). There were significant differences in favor of clozapine in one trial95 for the general rating scale CGI–I (MD = 0.80; 95% CI, 0.26 to 1.34) and CGI–S (MD = 0.60; 95% CI, 0.13 to 1.07). This was not clinically significant.

### Haloperidol Versus Olanzapine

#### Key Points

- Twenty-nine studies compared haloperidol with olanzapine in patients with a range of illness severity.
- Sixteen studies reported positive symptoms using two different scales: PANSS (14 studies) and SAPS (2 studies). For both scales, the pooled results showed no differences between groups, and the SoE was low.
- Eighteen studies assessed negative symptoms using two scales: PANSS (14 studies) and SANS (5 studies). For both scales, results significantly favored olanzapine and in both cases the differences between groups were considered to be clinically important. The SoE was moderate for both scales.
- Eighteen studies reported general psychopathology using eight scales. Ten studies used the PANSS and found no differences between groups. Six studies used the Montgomery-Asberg Depression Rating Scale (MADRS) and found results significantly favored olanzapine, which was considered to be clinically relevant. Three studies used the Hamilton Rating Scale for Depression (HAM–D) and Calgary Depression Scale for Schizophrenia (CDS–S); only the HAM–D was found to significantly favor olanzapine. This difference was considered to be clinically significant. Two studies used the Agitated Behavior Scale (ABS), ACES, and HAM–A and found no differences. A single study used the Young Mania Rating Scale (YMRS) and showed no difference between groups. The SoE ranged from low to moderate.
- Twenty-two studies assessed global ratings and total scores using six scales: PANSS (15 studies), BPRS (13 studies), CGI–S (8 studies), CGI–I (2 studies), GAF (1 study), and Subjective Well-Being Under Neuroleptics scale (1 study). In all cases no significant differences were found except for the PANSS (total score), which showed a significant difference favoring olanzapine. This was considered to be clinically significant. Results for BPRS and CGI–S showed substantial statistical heterogeneity which may be partially explained by treatment resistance: when studies that included only patients with treatment resistance were removed from the analysis for BPRS, the results were homogeneous and favored olanzapine. Removing one trial with first episode patients (not treatment resistant) from the analysis for CGI–S reduced the heterogeneity and results favored olanzapine. The SoE was moderate for PANSS and CGI–S, low for BPRS and CGI–I, and insufficient for the remaining scales.
- Response rates were assessed in 14 studies and showed a significant benefit for olanzapine. The statistical heterogeneity was substantial. As above, when studies that included only patients with treatment resistance were removed from the analysis, the results were homogeneous and favored olanzapine.
- Remission rates were assessed in three studies and showed a significant benefit for olanzapine.
- Five studies assessed health-related quality of life and showed no significant differences between groups.
- Other outcomes were assessed in single trials and showed no differences between groups.

Twenty-nine RCTs43,49–51,54,56,58,71,73,75,78,88,91,101,102,104–106,108,110,124,127,129,130,136,141,145,147,159 (n = 5,750) compared haloperidol with olanzapine. Key characteristics of the included trials and summary of findings are presented in Table 36 and Table 37, respectively. One trial43 included patients with paranoid schizophrenia, five studies58,73,91,127,145 specifically included patients with schizoaffective disorder, and the remaining studies included mixed disorder subtypes. All studies included patients with both first and multiple episodes. Nine studies51,58,73,78,105,110,130,141,145 included only patients with treatment resistance, which was ascertained from history in all cases. Three studies91,124,129 specifically excluded patients with treatment resistance. Two studies130,136 specifically included patients with comorbid alcohol or drug use, whereas nine studies49–51,54,56,58,71,124,129 excluded patients with drug or alcohol use. Drug doses varied substantially across studies: from 1–4 mg/d75 to 10–30 mg/d58,105 for haloperidol and from 1–17.5mg/d49 to 5–40 mg/d73 for olanzapine. All studies included adults ranging in age from 18 to 64, except one study78 that included only patients 17 to 28 years of age. Two studies102,104 only included Asian patients.

Risk of bias was unclear for 19 studies43,49–51,54,56,78,88,101,102,104–106,108,110,124,127,145,147 and high for 10 studies.58,71,73,75,91,129,130,136,141,159 Duration of followup varied across studies: ≤6 weeks for 9 studies;51,56,71,73,78,106,129,136,147 between 6 weeks and 6 months for 11 studies;43,54,58,88,102,104,105,110,130,145,159 and ≥6 months for 9 studies.49,50,75,91,101,108,124,127,141 Source of funding included: government (3 studies);78,106,130 company that produces olanzapine (18 studies);43,49–51,54,56,58,101,104,105,108,110,124,127,136,141,147,159 multiple companies, including producer of haloperidol (2 studies);75,91 and multiple companies including producers of both drugs (1 studies).145

Publication bias was assessed for outcomes with at least 10 studies, and results are reported in the sections that follow. The SoE for the evaluated outcomes varied from insufficient to moderate mainly depending on the number of included trials and heterogeneity among the included trials (Table 38).

For each outcome, we examined whether differences existed for the various clinical characteristics (disorder subtypes, inclusion or exclusion of patients with schizoaffective disorder, sex, age group, race, comorbidities, previous exposure to antipsychotics, and treatment resistance), study characteristics (drug dose, followup period, and study sponsorship), and analytic methods (risk of bias and imputed data). When pooled estimates showed evidence of statistical heterogeneity, we report on any subgroups that had an effect on heterogeneity. All other subgroups showed no effect. Appendix M (Tables 96–102) provides detailed tables on all subgroup analyses.

#### Key Question 1 Improving Core Illness Symptoms

##### Positive Symptoms

Sixteen trials50,51,54,71,88,101,102,104,105,108,110,124,136,141,145,159 (n = 3,920) reported no difference in positive symptoms using two scales (Table 37; Figure 12). The SoE for both scales was graded as low (Table 38).

Figure 12 Haloperidol versus olanzapine – Positive symptoms

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; SD = standard deviation

Figure 12 is a metagraph depicting the effect of haloperidol versus olanzapine on positive symptoms in patients with Sz. Sixteen trials contributing 3,920 patients reported no difference in positive symptoms between groups. Fourteen trials used PANSS (positive) (n=3,742) and found no statistical difference between treatments (MD=0.43, 95 percent CI, −0.22, 1.08); however moderate statistical heterogeneity was present (p=0.09, I2=36%). Two studies (n=178) evaluated positive symptoms using the SAPS and also found no difference between groups (MD=0.10, 95 percent CI, −0.09, 0.28).

Fourteen trials50,51,54,88,101,104,105,108,110,124,136,141,145,159 (n = 3,742) used PANSS (positive). Pooled results showed no significant difference between groups; however, there was moderate statistical heterogeneity (I^2^ = 36 percent). Restricting the analyses to the following subgroups reduced the heterogeneity:

- Mixed populations regarding comorbid drug or alcohol use: significantly favored olanzapine (I^2^ = 17 percent);
- Olanzapine doses of ≤20 mg and haloperidol doses of ≤20 mg: significantly favored olanzapine (I^2^ = 23 percent);
- Duration of followup >6 months: significantly favored olanzapine (I^2^ = 0 percent);
- No imputed data: significantly favored olanzapine (I^2^ = 17 percent).

The tests for publication bias were not significant, although the funnel plot appeared slightly asymmetrical, with studies showing larger effects for haloperidol (Appendix K, Funnel plot 1).

Two trials71,102 (n = 178) showed no significant difference between groups based on SAPS. There was no evidence of statistical heterogeneity between the studies (I^2^ = 0 percent).

##### Negative Symptoms

Eighteen trials,49–51,54,58,71,88,101,102,104,105,108,110,124,136,141,145,159 (n = 4,250) reported significant differences in favor of olanzapine on negative symptoms using two scales (Table 37; Figure 13). The SoE for these scales was graded as moderate (Table 38).

Figure 13 Haloperidol versus olanzapine – Negative symptoms

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SANS = Scale for the Assessment of Negative Symptoms; SD = standard deviation

Figure 13 is a metagraph depicting the effect of haloperidol versus olanzapine on negative symptoms in patients with Sz. Eighteen trials involving 4,250 patients contributed data for this comparison. Fourteen studies (n=3,742) used the PANSS (negative) to assess patients. Pooled estimates were significantly different between groups in favor of olanzapine (MD=1.06, 95 percent CI, 0.46, 1.67); however moderate statistical heterogeneity was present between studies (p=0.16, I2=27%). Five trials (n=535) used the SANS scale to evaluate negative symptoms and reported significant results favoring olanzapine (MD=1.79, 95 percent CI, 1.57, 2.02).

Fourteen studies (n = 3,742) used PANSS (negative).50,51,54,88,101,104,105,108,110,124,136,141,145,159 Pooled estimates were significantly different between groups in favor of olanzapine, which was considered to be clinically significant. The results showed moderate statistical heterogeneity (I^2^ = 27 percent). Restricting the analyses to the following subgroups reduced the heterogeneity:

- Mixed populations regarding comorbid drug or alcohol use: significantly favored olanzapine (I^2^ = 2 percent);
- Followup greater than 6 months (5 studies): significantly favored olanzapine (I^2^ = 0 percent);
- Unclear risk of bias (11 studies): significantly favored olanzapine (I^2^ = 0 percent).

There was no indication of publication bias based on statistical tests or visual examination of the funnel plot (Appendix K, Funnel plot 2).

Five trials49,58,71,102,159 (n = 535) used SANS and reported significant results favoring olanzapine, which was considered to be clinically significant. There was no evidence of statistical heterogeneity across trials (I^2^ = 0 percent).

##### General Psychopathology

Eighteen studies50,54,56,58,71,78,88,91,101,105,108,110,124,136,141,145,147,159 (n = 4,327) assessed a range of other symptoms using eight scales (Table 37; Figure 14).

Figure 14 Haloperidol versus olanzapine – General psychopathology

ABS = Agitated Behavior Scale; ACES = Agitation-Calmness Evaluation Scale; CDS–S = Calgary Depression Scale for Schizophrenia; CI = confidence intervals; df = degrees of freedom; HAM–A = Hamilton Rating Scale for Anxiety; HAM–D = Hamilton Rating Scale for Depression; I^2^ = I-squared; IV = inverse variance; MADRS = Montgomery-Asberg Depression Rating Scale; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 14 is a metagraph depicting the effect of haloperidol versus olanzapine on general psychopathology. Eighteen studies (n=4,327) used a variety of scales to assess symptoms. Two trials (n=482) found no statistical difference between groups when using both the ABS (MD=0.80, 95 percent CI, −1.22, 2.83) and the ACES (MD=0.06, 95 percent IC, −0.40, 0.53); however statistical heterogeneity was significant for both (p=0.05, I2=74% and p=0.009, I2=85% respectively). Three studies used the CDS-S (n=344) and found no statistically significant difference between groups (MD=0.60, 95 percent CI, −0.08, 1.29); however statistical heterogeneity was substantial (p=0.02, I2=73%). Two studies (n=283) used the HAM-A, and found no significant difference between groups (MD=0.90, 95 percent CI, −0.43, 2.23). Three studies (n=209) used the HAM-D and the pooled results showed a significant difference in favor of olanzapine (MD=1.69, 95 percent CI, 1.41, 1.96). Ten trials (n=1,187) showed no difference between groups on the PANSS (MD=0.53, 95 percent CI, −1.20, 2.25); however statistical heterogeneity was substantial (p=0.03, I2=52%).

Ten trials50,54,88,105,108,110,124,136,145,159 (n = 1,187) showed no difference based on PANSS (general psychopathology); however, the statistical heterogeneity was substantial (I^2^ = 52 percent). Restricting the analyses to the following subgroups reduced the heterogeneity:

- Mixed populations regarding comorbid drug or alcohol use: no difference between groups (I^2^ = 25 percent);
- Studies that excluded cormorbid drug or alcohol use: no difference between groups (I^2^ = 25 percent);
- Followup >6 months (4 studies): significantly favored olanzapine (I^2^ = 0 percent);
- Unclear risk of bias (8 studies): no difference between groups (I^2^ = 33).

There was no suggestion of publication bias based on statistical tests or visual inspection of the funnel plot (Appendix K, Funnel plot 3).

Three trials58,71,110 (n = 209) used the HAM–D; the pooled results were significant in favor of olanzapine and showed no statistical heterogeneity (I^2^ = 0 percent). This was considered to be clinically significant.

Six trials78,101,105,108,141,159 (n = 2,639) used the MADRS. The pooled estimate showed significant results favoring olanzapine; there was no statistical heterogeneity across the studies (I^2^ = 0 percent). This was considered to be clinically significant.

Three trials54,71,91 (n = 344) reported CDS–S; the pooled result was not statistically significant, however the statistical heterogeneity was substantial (I^2^ = 73 percent). One study71 showed a significant benefit of olanzapine, whereas the other studies54,91 showed no significant difference between groups. One study91 specifically included schizoaffective disorder. Two studies54,71 excluded patients with comorbid drug or alcohol use. All studies included both treatment resistant and nonresistant patients. The dose of haloperidol varied across studies: 2.5–20 mg/d,54 3–9 mg/d,71 and 1–4 mg/d.91 The dose of olanzapine was more consistent with upper limits of 20 mg/d for all studies. Duration of followup varied from 6 weeks71 to 1 year.91 Risk of bias was high for two studies71,91 and unclear for one.54 Two trials54,91 were industry-funded; the other71 did not report a funding source.

Two trials101,159 (n = 283) showed no significant difference between groups based on the HAM–A (Table 37; Figure 14). There was no statistical heterogeneity across the studies (I^2^ = 0 percent).

Two trials56,147 (n = 482) found no significant difference based on the ABS and ACES. Statistical heterogeneity across studies was substantial (I^2^ = 74 percent and 85 percent, respectively). Both studies included mixed populations in terms of disorder subtypes and treatment resistance. One study56 specifically excluded patients with comorbid drug or alcohol use. Both studies used 7.5 mg/d of haloperidol and maximum 10 mg/d of olanzapine. Duration of followup was 24 hours for both studies. Both trials had unclear risk of bias and were funded by industry.

One study reported significant results favoring olanzapine based on the YMRS71 (n = 111); these results were considered not to be clinically important.

The SoE was graded as moderate for the HAM–D and MADRS, whereas the HAM–A, PANSS (general psychopathology), ABS, ACES, and CDS–S were graded as low SoE. The SoE for YMRS was graded as insufficient (Table 38).

##### Global Ratings and Total Scores

Twenty-two trials,43,49–51,54,56,58,71,73,78,88,91,101,104–106,108,110,127,141,145,147 (n = 5,283) reported global ratings and total scores using six different scales (Table 37; Figure 15).

Figure 15 Haloperidol versus olanzapine – Global ratings and total scores

BPRS = Brief Psychiatric Rating Scale; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; CI = confidence intervals; df = degrees of freedom; GAF = Global Assessment of Functioning; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 15 is a metagraph depicting the effect of haloperidol versus olanzapine on global ratings and total scores in patients with Sz. Twenty-two trials (n=5,283) reported global ratings and total scores using six different scales. Thirteen studies (n=4,014) reported no significant difference between groups on the BPRS (MD=0.59, 95 percent CI, −1.10, 2.28); however heterogeneity was substantial (p<0.00001, I2=82%). Two studies (n=281) used the CGI-I and pooled analysis showed no difference between groups (MD=0.11, 95 percent CI, −0.30, 0.51); however moderate heterogeneity existed between studies (p=0.21, I2=36%). Eight studies (n=3,564) used the CGI-S to evaluate global ratings; however on the metagraph one outlier study was omitted to show ratings favoring olanzapine (MD=0.20, 95 percent CI, 0.07, 0.32). Statistical heterogeneity was moderate (p=0.17, I2=33%). Fifteen trials (n=4,209) using the PANSS (total) reported a statistically significant difference between groups in favor of olanzapine (MD=2.31, 95 percent CI, 0.44, 4.18). Moderate heterogeneity existed between the studies (p=0.07, I2=37%).

Fifteen trials43,50,51,54,78,88,91,101,104,105,108,110,127,141,145 (n = 4,209) reported a statistically significant difference in favor of olanzapine based on PANSS (total). The difference was considered to be clinically important; however, there was moderate statistical heterogeneity (I^2^ = 37 percent). Restricting the analyses to the following subgroups reduced the heterogeneity:

- Specifically included schizoaffective disorder (3 studies): no difference between groups (I^2^ = 0 percent);
- Specifically excluded patients with comorbid drug or alcohol use (3 studies): no difference between groups (I^2^ = 0 percent);
- Included both treatment resistant and nonresistant patients (8 studies): no difference between groups (I^2^ = 23 percent);
- Followed patients for less than 6 weeks (2 studies): no difference between groups (I^2^ = 0 percent);
- Followed patients for longer than 6 months (6 studies): significantly favored olanzapine (I^2^ = 0 percent);
- Maximum doses of haloperidol and olanzapine of 20 mg/d (13 studies): significantly favored olanzapine (I^2^ = 23 percent);
- No industry funding (2 studies): no difference between groups (I^2^ = 0 percent);
- Imputed data for the meta-analysis (3 studies): no difference between groups (I^2^ = 0 percent); no imputed data (12 studies): significantly favored olanzapine (I^2^ = 5 percent).

There was no suggestion of publication bias based on statistical tests and visual inspection of the funnel plot (Appendix K, Funnel plot 4).

Thirteen trials43,49–51,56,58,71,73,88,104,106,141,147 (n = 4,014) reported no significant difference between groups based on BPRS; however, the statistical heterogeneity was substantial (I^2^ = 82 percent). Restricting the analyses to the following subgroups reduced the heterogeneity:

- Included patients with and without comorbid alcohol or drug use (7 studies): significantly favored olanzapine (I^2^ = 36 percent);
- Included treatment resistant and non-treatment-resistant patients (9 studies) (i.e., removed studies with only treatment resistant patients): significantly favored olanzapine (I^2^ = 0 percent);
- Followed patients for >6 weeks and up to 6 months (4 studies): significantly favored olanzapine (I^2^ = 0 percent);
- Did not report funding or had funding from sources other than industry (4 studies): significantly favored olanzapine (I^2^ = 0 percent).

There was no suggestion of publication bias based on statistical tests (Appendix K, Funnel plot 5).

Eight trials49,50,56,58,71,91,108,141 (n = 3,564) used the CGI–S, but pooled results are not presented due to substantial heterogeneity (I^2^ = 82 percent) among the included trials. Restricting the analyses to the following subgroups reduced the heterogeneity:

- Patients with schizoaffective disorder (2 studies): no difference between groups (I^2^ = 34 percent);
- Patients with and without comorbid drug or alcohol use (3 studies): significantly favored olanzapine (I^2^ = 0 percent);
- Treatment-resistant patients (2 studies): significantly favored olanzapine (I^2^ = 32 percent);
- Followed patients for >6 months (5 studies): significantly favored olanzapine (I^2^ = 7 percent);
- Industry funding (7 studies): significantly favored olanzapine (I^2^ = 33 percent);
- Unclear risk of bias (4 studies): no difference between groups (I^2^ = 11 percent).

Further, one study appeared to be an outlier as it was the only study that significantly favored haloperidol. Removing this study reduced the heterogeneity to 33 percent and results significantly favored olanzapine. This study included only patients with first episode and no treatment resistance.

Two studies78,147 used the CGI–I and pooled results showed no difference between groups. Statistical heterogeneity was moderate (I^2^ = 36 percent). One study78 specifically included patients with schizoaffective disorder, treatment resistant by history, and young adults (17–28 years). Both studies included patients with and without comorbid drug or alcohol use. One study78 compared 2.5 mg/d haloperidol with 7.5 mg/d olanzapine, whereas the other study 147 examined doses of 7.5 mg/d and 10 mg/d, respectively. Duration of followup was 6 weeks78 and 8 weeks. 147 Risk of bias was unclear for both studies; one was funded by government78 and the other by industry. 147

One study comparing 1–4 mg/d haloperidol with 5–20 mg/d olanzapine used the GAF and found no difference between groups.91

The Subjective Well–Being under Neuroleptics Scale was used in one study,78 and no differences were found between groups.

The SoE for PANSS and CGI–S was graded as moderate; BPRS and CGI–I were graded as low; GAF and the Subjective Well-Being under Neuroleptics Scale were graded as insufficient (Table 38).

#### Key Questions 2 and 4 Improvement in Functional Outcomes, Decreasing Health Care System Utilization, and Other Outcomes

##### Functional Outcomes

###### Encounters With Legal System

One trial136 (n = 31) that enrolled cocaine dependent patients compared 5–20 mg/d haloperidol with 5–20 mg/d olanzapine and found no difference between the groups for positive urine cocaine toxicology (Table 37). Duration of followup was 6 weeks. Risk of bias was high and the trial was industry-funded.

###### Sexual Dysfunction

One trial91 (n = 208) in patients with schizoaffective or schizophreniform disorder without treatment resistance compared 1–4 mg/d haloperidol with 5–20 mg/d olanzapine. The trial followed patients for one year and found no significant difference between groups regarding the incidence of sexual dysfunction (Table 37). The trial was considered high risk of bias and was industry-funded.

##### Health Care System Utilization

The same trial described above91 found no significant difference between groups in terms of rates of hospitalization or rehospitalization (Table 37). One trial127 found no difference in mean hospital bed days (Table 37).

##### Other Outcomes

Pooled results from 14 trials49,71,73,88,91,101,104–106,108,110,130,141,147 (n = 4,099) showed a significant difference favoring olanzapine on response rates; however, statistical heterogeneity was substantial (I^2^ = 55 percent) (Table 37; Figure 16). Restricting the analyses to the following subgroups reduced the heterogeneity:

- Mix of disorder subtypes (12 studies): significantly favored olanzapine (I^2^ = 26 percent);
- Specifically excluded patients with comorbid drug or alcohol use (2 studies): no difference between groups (I^2^ = 29 percent);
- Included treatment-resistant and nonresistant patients (8 studies): significantly favored olanzapine (I^2^ = 0 percent);
- Followed patients for <6 weeks (4 studies): no difference between groups (I^2^ = 0 percent);
- Followed patients for >6 weeks but <6 months (5 studies): no difference between groups (I^2^ = 22 percent);
- No industry funding reported (5 studies): no difference between groups (I^2^ = 0 percent);
- Unclear risk of bias (9 studies): significantly favored olanzapine (I^2^ = 7 percent);
- Imputed data (3 studies): no difference between groups (I^2^ = 0 percent).

Figure 16 Haloperidol versus olanzapine – Response rates

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; M-H = Mantel-Haenszel

Figure 16 is a metagraph depicting the effect of haloperidol versus olanzapine on the response rates of patients with Sz. Fourteen trials (n=4,099) showed a significant difference between groups, favoring olanzapine (MD=0.86, 95 percent CI, 0.78, 0.96); however, statistical heterogeneity was substantial (p=0.006, I2=55%).

There was no indication of publication bias based on statistical tests and visual inspection of the funnel plot (Appendix K, Funnel plot 6).

Three trials71,91,108 (n = 582) assessed remission rates (Table 37). The pooled result was significant favoring olanzapine; however, there was substantial statistical heterogeneity. Removing one trial91 from the analysis reduced the heterogeneity to 0 percent, and the result remained statistically significant. The trial differed from the other two in that it specifically included patients with schizoaffective disorder.

Single trials examined medication adherence101 (n = 256) and patient insight into illness108 (n = 263) and reported no differences between groups (Table 37). Characteristics of these studies are described in Table 36.

Five trials49,58,91,104,159 examined health-related quality of life (HRQoL) using different scales; no differences were found between groups, and there was minimal statistical heterogeneity across the trials (Table 37). Two of the trials58,91 specifically included patients with schizoaffective disorders. Two trials49,58 specifically excluded patients with comorbid drug or alcohol use. One trial104 included only patients of Asian descent. One study58 used up to 30 mg/d of both haloperidol and olanzapine and included only patients with treatment resistance. All studies followed patients for longer than 6 months. Risk of bias was unclear for two studies49,104 and high for three;58,91,159 all trials were industry-funded.

#### Key Question 5 Subgroups

##### Age

One trial78 (n = 24) in patients with schizophrenia aged 17–28 years found no differences between groups for general psychopathology (MADRS) or global ratings and total scores (CGI–I, PANSS (total), Subjective Well-Being under Neuroleptics Scale).

##### Comorbidities

Two trials130,136 (n = 55) in patients with comorbid cocaine use reported no significant difference on the PANSS (positive), but a significant difference in favor of haloperidol on the PANSS (negative) (MD = −3.20; 95% CI, −6.03 to −0.37) and the PANSS (general psychopathology) (MD = −6.10; 95% CI, −10.90 to −1.30). The results for PANSS negative and general psychopathology were considered to be clinically significant.

##### Disease Subgroup

One trial43 (n = 28) in patients with paranoid schizophrenia reported no significant difference on global ratings using the BPRS scale.

##### Race

Three trials,88,102,104 (n = 525) in Asian patients reported no significant difference on PANSS (positive), SAPS, PANSS (negative), SANS, or PANSS (general psychopathology), but a significant difference in favor of olanzapine on BPRS (MD = 3.36; 95% CI, 0.63 to 6.09) and PANSS (total) (MD = 5.53; 95% CI, 1.10 to 9.96). The difference on BPRS and PANSS (total) were considered to be clinically significant.

##### Treatment of a First Episode

Four trials71,75,108,129 (n = 928) included patients undergoing treatment for their first schizophrenic episode. There was no significant difference on PANSS (positive), SAPS, PANSS (general psychopathology), and CDS–S. However, there was a significant difference in favor of olanzapine on the YMRS (MD = 0.40; 95% CI, 0.21 to 0.59), PANSS (negative) (MD = 1.49; 95% CI, 0.05 to 2.93), SANS (MD = 1.80; 95% CI, 1.58 to 2.02), HAM–D (MD = 1.70; 95% CI, 1.42 to 1.98), and BPRS (MD = 1.10; 95% CI, 0.58 to 1.62). There was a significant difference favoring haloperidol on the CGI–S scale (MD = 0.80; 95% CI, 0.69 to 0.91).

##### Treatment Resistance

Nine trials51,58,73,78,105,110,130,141,145 (n = 2,804) in treatment-resistant patients reported no difference in positive symptoms (PANSS [positive]),51,105,110,141,145 negative symptoms (SANS),58 general psychopathology (HAM–D,58 PANSS (general psychopathology),105,110,145 or global ratings and total scores (BPRS,51,58,73,141 CGI–I,78 PANSS,51,78,105,110,141,145 and Subjective Well-Being under Neuroleptics Scale).78 There was a significant difference favoring olanzapine for two scales: one measure general psychopathology (MADRS)78,105,141 and the other a global rating scale (CGI–S).58,141

### Haloperidol Versus Quetiapine

#### Key Points

- Nine studies compared haloperidol versus quetiapine in patients with a range of disease severity.
- Positive symptoms assessed using PANSS (4 trials) was not significantly different between groups (low SoE).
- Negative symptoms assessed using PANSS (4 trials) and SANS (1 trial) were not significantly different between groups. The results for PANSS were statistically heterogeneous with one of the trials (which was high risk of bias vs. unclear for the other three) showing a significant difference in favor of quetiapine. The SoE was low for PANSS and insufficient for SANS.
- General psychopathology was assessed using PANSS (general psychopathology) (4 trials), CDS–S (2 trials), and Beck Depression Inventory (BDI) (1 trial), and was not significantly different between groups. The SoE was low for PANSS and CDS–S and insufficient for BDI.
- Global ratings and total scores were assessed using PANSS (total) (6 trials), CGI–S (4 trials), BPRS (4 trials), CGI–I (3 trials), and GAF (1 trial). No differences were found for any scales except for CGI–S, which showed a significant benefit for haloperidol, which was not considered to be clinically significant. The SoE was low or insufficient for all scales except for CGI–S, which was moderate.
- Response rates were assessed in six studies and showed no difference between groups overall. One study was an outlier and showed a significant difference favoring haloperidol. This study of treatment-resistant patients used relatively higher doses of haloperidol (4–30 mg/d) and quetiapine (50–1200 mg/d) and followed patients for only 3 weeks.
- Other outcomes were assessed in a single trial and showed no differences between groups.

Nine RCTs,46,47,65,68,73,79,80,91,123 (n = 1,516) compared haloperidol (1–200 mg/d) with quetiapine (50–1200 mg/d). Key characteristics of the included trials and summary of findings are presented in Table 39 and Table 40. All studies included mixed populations in terms of first versus repeat episodes. One study80 specifically included patients with schizoaffective disorder, whereas the others included mixed populations in terms of disorder subtypes. Three studies47,73,123 specifically excluded patients with comorbid drug or alcohol use; the others included patients with and without comorbid drug or alcohol use. Two studies73,79 included only treatment-resistant patients based on history; the other studies included mixed populations with respect to treatment resistance. One study47 included only female patients, whereas the others included mixed male and female populations. The doses for haloperidol ranged from 1–4 mg/d91 to 4–30 mg/d.73 Likewise the doses for quetiapine varied with maximum doses ranging from 500 mg/d65 to 1200 mg/d.73

Duration of followup was ≤6 weeks for four studies,46,47,68,73 between four weeks and 6 months for two studies,65,79 and ≥6 months for three studies.80,91,123 Risk of bias was unclear in five studies46,47,79,80,123 and high in four.65,68,73,91 All studies reported having industry support except for two47,73 that did not report their source of funding.

Publication bias was not formally tested for any of the outcomes due to the small number of included trials. The SoE for the majority of the evaluated outcomes was insufficient or low, largely due to the small number of trials (Table 41).

#### Key Question 1 Improving Core Illness Symptoms

##### Positive Symptoms

Four trials65,79,80,123 (n = 393) reported on positive symptoms using the PANSS (positive), and pooled results showed no significant difference between groups (Table 40; Figure 17); the trials were statistically homogenous. One of the studies80 specifically included patients with schizoaffective disorder and treatment resistance based on history, whereas the others included mixed populations in terms of disorder subtypes and treatment resistance. One study123 specifically excluded patients with comorbid drug or alcohol use. The dose of haloperidol was relatively consistent across studies except one65 that gave 200 mg/wk. The dose of quetiapine ranged from 100–800 mg/d. Duration of followup was <6 months for two studies65,79 and ≥6 months for two studies.80,123 Risk of bias was high for one study65 and unclear for the other three; all studies were industry-funded. The SoE for PANSS (positive) was graded as low (Table 41).

Figure 17 Haloperidol versus quetiapine – Positive symptoms

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 17 is a metagraph depicting the effect of haloperidol versus quetiapine on positive symptoms in patients with Sz. Four trials (n=393) reported on positive symptoms using the PANSS (positive). Pooled results showed no significant difference between groups (MD=0.68, 95 percent CI, −0.14, 1.50).

##### Negative Symptoms

Five trials,46,65,79,80,123 (n = 703) reported negative symptoms using two scales (Table 40; Figure 18). Four trials,65,79,80,123 (n = 393) reported no significant difference between groups using PANSS (negative); however, there was substantial statistical heterogeneity. We examined predefined subgroup and sensitivity analyses to explain the heterogeneity (Appendix M, Table 103). There was no change in heterogeneity based on disorder subtype, comorbid drug or alcohol use, treatment resistance, or duration of followup. Three studies had unclear risk of bias and had minimal statistical heterogeneity (I^2^ = 10 percent); the pooled estimate showed no difference between groups. One study65 with high risk of bias showed an important significant difference favoring quetiapine.

Figure 18 Haloperidol versus quetiapine – Negative symptoms

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 18 is a metagraph depicting the effect of haloperidol versus quetiapine on negative symptoms in patients with Sz. Four trials with a total of 393 patients contributing data reported no significant difference between groups on the PANSS (negative) (MD=1.36, 95 percent CI, −0.41, 3.13); however substantial heterogeneity existed (p=0.006, I2=76%). One trial with 310 participants found no significant difference between groups on the SANS (MD=−0.94, 95 percent CI, −2.04, 0.15).

One trial46 (n = 310) compared 12 mg/d haloperidol with 75–750 mg/d quetiapine and found no significant difference between groups using SANS (Table 40; Figure 18). This trial included mixed populations in terms of disorder subtypes, comorbid drug or alcohol use, and treatment resistance. Duration of followup was 6 weeks. Risk of bias was unclear, and the trial was industry-funded.

The SoE was low for PANSS (negative) and insufficient for SANS (Table 41).

##### General Psychopathology

Four trials65,79,80,123 (n = 393) reported no significant difference between groups using PANSS (general psychopathology) (Table 40; Figure 19); there was minimal statistical heterogeneity across the studies. One of the studies80 specifically included patients with schizoaffective disorder and treatment resistance based on history, whereas the others included mixed populations in terms of disorder subtypes and treatment resistance. One study123 specifically excluded patients with comorbid drug or alcohol use. The dose of haloperidol was relatively consistent across studies except one65 that gave 200 mg/d. The dose of quetiapine ranged from 100–800 mg/d. Duration of followup was <6 months for two studies65,79 and ≥6 months for two studies.80,123 Risk of bias was high for one study65 and unclear for the other three; all studies were industry-funded.

Figure 19 Haloperidol versus quetiapine – General psychopathology

CDS–S = Calgary Depression Scale for Schizophrenia; CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 19 is a metagraph depicting the effect of haloperidol versus quetiapine on general psychopathology in patients with Sz. Two trials (n=232) reported no significant difference between groups using the CDS-S (MD=0.03, 95 percent CI, −0.52, 0.58). Four trials (n=393) reported no significant difference between groups using PANSS scale (MD=0.46, 95 percent CI, −0.87, 1.78). Minimal heterogeneity existed between studies (p=0.35, I2=9%).

Two trials91,123 (n = 232) reported no significant difference between groups using CDS–S (Table 40; Figure 19). There was no statistical heterogeneity across these two studies. Both studies included mixed populations with respect to disorder subtype and treatment resistance. One trial123 specifically excluded patients with comorbid drug or alcohol use. Doses of haloperidol varied from 1–4 mg/d91 to 10–20 mg/d;123 doses of quetiapine ranged from 200–750 mg/d91 and 300–600 mg/d.123 Duration of followup was ≥6 months in both studies. Risk of bias was high91 and unclear;123 both studies were industry-funded.

One of the trials described immediately above123 (n = 25) reported results for the Beck Depression Inventory and found no significant difference between groups (Table 40).

The SoE for PANSS (general psychopathology) and CDS–S was graded as low, while the SoE for BDI was insufficient (Table 41).

##### Global Ratings and Total Scores

Nine studies46,47,65,68,73,79,80,91,123 (n = 1,516) examined total scores using five scales (Table 40; Figure 20). Six trials65,68,79,80,91,123 (n = 1,048) reported no significant difference using PANSS (total) (Table 40; Figure 20); there was minimal statistical heterogeneity. One study80 specifically included patients with schizoaffective disorders. One study79 included only patients with treatment resistance based on history. One study123 specifically excluded patients with comorbid drug or alcohol use. Doses of haloperidol ranged from 1–4 mg/d91 to 10–20 mg/d;123 doses of quetiapine ranged from 50–800 mg/d across studies. Duration of followup was 6 weeks,68 between 6 weeks and 6 months,65,79 and >6 months.80,91,123 Risk of bias was unclear for three studies79,80,123 and high for three;65,68,91 all were industry-funded.

Figure 20 Haloperidol versus quetiapine – Global ratings and total scores

BPRS = Brief Psychiatric Rating Scale; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 20 is a metagraph depicting the effect of haloperidol versus quetiapine on global ratings and total scores in patients with Sz. Four trials (n=756) reported no difference on the BPRS (MD=1.23, 95 percent CI, −0.50, 2.96). Three trials (n=623) showed no significant difference using the CGI-I (MD=0.02, 95 percent CI −0.24, 0.27). Four trials (n=1,253) demonstrated a significant difference favoring haloperidol when the results were pooled for the CGI-S score (MD=−0.23, 95 percent CI, −0.42, −0.04). Six trials (n=1,048) used the PANSS scale to evaluate the total scores and reported no significant difference between groups (MD=1.18, 95 percent CI, −0.94, 3.31).

Four trials46,68,79,91 reported a significant difference favoring haloperidol using CGI–S; the results were statistically homogeneous. All studies included mixed populations in terms of disorder subtype and comorbid drug or alcohol use. One study79 only included treatment-resistant patients. Dose of haloperidol ranged from 1–20 mg/d with varying ranges across studies. Likewise, quetiapine ranged from 75–800 mg/d. Duration of followup was 6 weeks,46,68, 12 weeks,79 and 1 year.91 Risk of bias was unclear for two trials46,79 and high for two trials;68,91 all trials were industry-funded.

Four trials46,47,73,79 reported no difference using BPRS (Table 40; Figure 20); the results were statistically homogeneous. All studies included mixed populations in terms of disorder subtypes. Two studies47,73 excluded patients with comorbid drug or alcohol use. Two studies73,79 included only patients with treatment resistance. One study47 included only women. Doses of haloperidol and quetiapine were relatively consistent, although ranged from 4–30 mg/d and 50–1200 mg/d, respectively, in one study.73 Duration of followup was ≤6 weeks in three studies46,47,73 and 12 weeks in one study.79 Risk of bias was unclear for three trials and high for one.73 Two trials46,79 were industry-funded; two47,73 did not report source of funding.

Three trials46,79,123 (n = 623) showed no significant difference using CGI–I (Table 40; Figure 20); results were homogeneous across trials. All trials included mixed populations in terms of disorder subtypes. One study123 excluded patients with comorbid drug or alcohol use. One study79 included only patients with treatment resistance by history. Doses of haloperidol ranged from 5–20 mg/d; doses of quetiapine ranged from 75–750 mg/d. Risk of bias was unclear in all studies; all were industry-funded.

A single trial91 (n = 207) compared 1–4 mg/d haloperidol with 200–750 mg/d quetiapine and found no significant difference between groups using GAF (Table 40; Figure 20). The trial included mixed populations in terms of disorder subtypes, treatment resistance, and comorbid drug or alcohol use. Duration of followup was 1 year. Risk of bias was high, and the trial was industry-funded.

The SoE for CGI–S was graded as moderate (favoring haloperidol), for BPRS, CGI–I, and PANSS was graded as low (no difference), and for GAF was graded as insufficient (Table 41).

#### Key Questions 2 and 4 Improvement in Functional Outcomes, Decreasing Health Care System Utilization, and Other Outcomes

##### Functional Outcomes

###### Sexual Dysfunction

One trial91 (n = 207) comparing 1–4 mg/d haloperidol with 200–750 mg/d quetiapine found no significant difference between groups with respect to sexual dysfunction (Table 40). The trial included mixed populations in terms of disorder subtypes, treatment resistance, and comorbid drug or alcohol use. Duration of followup was 1 year. Risk of bias was high, and the trial was industry-funded.

##### Health Care System Utilization

The same trial91 described immediately above found no significant difference between groups for rates of hospitalization or rehospitalization (Table 40).

##### Other Outcomes

Pooled results for six trials46,68,73,79,80,91 (n = 1,421) showed no significant difference in response rates (Table 40; Figure 21); however, the statistical heterogeneity was substantial (I^2^ = 77 percent). We conducted predefined subgroup and sensitivity analyses to identify reasons for heterogeneous results across studies (Appendix M, Table 104). Heterogeneity was not explained by disorder subtypes or risk of bias. Three studies that followed patients for ≥6 months were homogeneous (I^2^ = 0 percent), and pooled results favored quetiapine. Four studies that included both treatment-resistant and nonresistant patients showed reduced heterogeneity (I^2^ = 6 percent), but no difference between groups. We examined one study73 that was an outlier in that it showed a statistically significant benefit favoring haloperidol. This study was distinct from the others as it included doses of haloperidol ranging to 30 mg/d and it specifically excluded patients with comorbid drug or alcohol use. Further, the study did not report its source of funding, whereas the others declared industry support.

Figure 21 Haloperidol versus quetiapine – Response rates

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; M-H = Mantel-Haenszel

Figure 21 depicts the effect of haloperidol versus quetiapine on the response rates of patients with Sz. Six trials involving 1,421 patients contributed data. Pooled results found no significant difference in response rates (MD=0.99, 95 percent CI, 0.76, 1.30); however statistical heterogeneity was substantial (p=0.0005, I2=77%).

One trial91 (n = 207) comparing 1–4 mg/d haloperidol with 200–750 mg/d quetiapine found no significant difference in remission rates (Table 40) or health-related quality of life. The trial included mixed populations in terms of disorder subtypes, treatment resistance, and comorbid drug or alcohol use. Duration of followup was 1 year. Risk of bias was high, and the trial was industry-funded.

#### Key Question 5 Subgroups

##### Sex

One trial47 (n = 35) in female schizophrenic patients showed no significant difference for the global rating scale BPRS.

##### Treatment Resistance

One trial79 (n = 288) in patients with treatment-resistant schizophrenia showed no significant difference on PANSS (positive), PANSS (negative), PANSS (general psychopathology), and general ratings and total scores (BPRS,79 CGI–I,79 CGI–S,79 PANSS (total)).

### Haloperidol Versus Risperidone

#### Key Points

- Thirty-three studies compared haloperidol with risperidone in patients with a range of illness severity.
- Twenty-two studies reported positive symptoms using two different scales: PANSS (20 studies) and SAPS (2 studies). Pooled results showed no differences between groups, and the SoE was considered low.
- Twenty-three studies assessed negative symptoms using two different scales: PANSS (20 studies) and SANS (4 studies). Pooled results of findings from each scale showed significant benefits for risperidone. The SoE was moderate for both scales.
- Sixteen studies reported general psychopathology using PANSS (general psychopathology; 16 studies), CDS–S (3 studies), HAM–D (2 studies), YMRS (2 studies), HAM–A (1 study), and MADRS (1 study). For PANSS, pooled results for all 16 studies are not presented due to substantial heterogeneity. Three studies were outliers in that they favored haloperidol; pooling the remaining 13 trials showed no difference between groups. Results for HAM–D and CDS–S showed no significant differences; however, heterogeneity was substantial. No differences were found for YMRS, MADRS, and HAM–A. The SoE was low for PANSS, CDS–S, HAM–D, and YMRS; insufficient for MADRS and HAM–A.
- Twenty-seven studies assessed global ratings and total scores using eight scales: PANSS (total; 20 studies), BPRS (13 studies), CGI–S (8 studies), CGI–I (3 studies), Nurses Observation Scale for Inpatient Evaluation (NOISIE) (1 study), Schedule for Affective Disorders and Schizophrenia–Change (SADS–C) (1 study), SCL–90–R (1 study), and Subjective Well–being Under Neuroleptic Scale (1 study). In all cases where there were multiple studies, pooled results showed no significant differences between groups. The SoE was low for all scales except those with only one trial, which were considered insufficient.
- Response rates were assessed in 16 studies and showed no difference between groups.
- Relapse rates were assessed in six studies and showed a significant benefit for risperidone.
- Remission rates were assessed in two studies and showed no difference between groups.
- Two studies assessed health-related quality of life (HRQoL) and showed no significant differences between groups.
- Other outcomes were assessed in few trials and showed no differences between groups.

Thirty-three RCTs,45,52,53,59–61,64,71–73,77,81,82,85,99,101,102,107,111,113,114,117,118,120,124,125,132,135,139,145, 146,149,150 (n = 4,789) compared haloperidol with risperidone. Key characteristics of the included trials and summary findings are presented in Table 42 and Table 43. All studies included populations with mixed disorder subtypes. Five studies72,73,81,132,145 specifically included patients with schizoaffective disorder, whereas two studies52,114 excluded patients with schizoaffective disorder. One study81 included only patients with first episodes, 13 studies59,64,85,99,102,113,117,118, 120,135,145,146,150 included only patients with multiple episodes, and the remaining studies included all patients. Five studies73,99,145,146,150 included only patients with treatment resistance, which was ascertained by history in all but one study,146 which conducted a run-in period to the trial. Four studies72,81,118,124 included only patients with no treatment resistance. The remaining studies included all patients regardless of treatment resistance. Twenty studies45,52,53,59,61,71,72,77,81,82,107,111, 117,118,120,124,125,132,149,150 specifically excluded patients with comorbid drug or alcohol use; the remaining studies included patients both with and without comorbid drug or alcohol use. Six studies102,107,111,117,149,150 included only patients of Asian descent. Doses of haloperidol ranged from 1 to 40 mg/d; doses ranged greater than 20 mg/d in two studies.73,145 Doses of risperidone ranged from 1 to 16 mg/d.

Duration of followup was ≤6 weeks in 8 studies,45,52,53,59,71,73,81,139 between 6 weeks and 6 months in 13 studies,60,61,64,102,107,111,114,117,120,145,146,149,150 and >6 months in 10 studies;72,77,82,101,113,118,124,125,132,135 2 studies85,99 did not report length of followup. Risk of bias was high in 10 studies45,71,73,77,82,111,114,135,139,149 and unclear in the others. Eighteen studies53,59,61,64,77,82,85,99,101,113,114,118,124,125,132,145,146 were industry-funded, two107,149 were funded by government, one102 received institutional funding, and the others did not report funding source.

Publication bias was assessed for outcomes with at least 10 studies, and results are reported in the sections that follow. The SoE for the evaluated outcomes varied from insufficient to moderate mainly depending on the number of included trials (Table 44).

For each outcome, we examined whether differences existed for clinical characteristics (disorder subtypes, inclusion or exclusion of patients with schizoaffective disorder, sex, age group, race, comorbidities, previous exposure to antipsychotics, and treatment resistance), study characteristics (drug dose, followup period, and study sponsorship), and analytic methods (risk of bias and imputed data). When pooled estimates showed evidence of statistical heterogeneity, we report on any subgroups that had an effect on heterogeneity. All other subgroups showed no effect. Appendix M Tables 105 to 111 provides detailed tables on all subgroup analyses.

#### Key Question 1 Improving Core Illness Symptoms

##### Positive Symptoms

Twenty-two trials52,61,64,71,72,81,101,102,107,111,114,117,118,120,124,125,132,135,139,145,149,150 (n = 4,266) reported on positive symptoms using two scales (Table 43). Across 20 trials,52,61,64,72,81,101,107, 111,114,117,118,120,124,125,132,135,139,145,149,150 (n = 4,043) there was no significant difference between groups on the PANSS (positive) (Table 43; Figure 22); however, there was substantial statistical heterogeneity among the studies (I^2^ = 53 percent). Restricting the analyses to the following subgroups reduced the heterogeneity:

- Mixed populations with respect to comorbid drug use (6 studies): significantly favored risperidone (I^2^ = 0 percent);
- Mixed populations with respect to first versus multiple episodes (11 studies): significantly favored risperidone (I^2^ = 34 percent);
- Followed patients for >6 weeks and <6 months (10 studies); no difference between groups (I^2^ = 0 percent);
- Asian patients only (5 studies): no difference between groups (I^2^ = 0 percent);
- No industry funding or no funding source reported (12 studies): significantly favored risperidone (I^2^ = 28 percent);
- High risk of bias (5 studies): significantly favored risperidone (I^2^ = 0 percent).

Figure 22 Haloperidol versus risperidone – Positive symptoms

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SAPS = Scale for the Assessment of Positive Symptoms; SD = standard deviation

Figure 22 is a metagraph depicting the effect of haloperidol versus risperidone on positive symptoms in patients with Sz. Twenty studies (n=4,043) evaluated patients for positive symptoms on the PANSS scale. When data was pooled no significant difference was found between groups (MD=0.64, 95 percent CI, −0.06, 1.34); however there was substantial statistical heterogeneity between studies (p=0.003, I2=53%). Two trials (n=193) reported positive symptoms using the SAPS scale and pooled results showed no significant difference between groups (MD=−0.14, 95 percent CI, −2.01, 1.73). Heterogeneity was moderate (p=0.22, I2=35%)

Tests for publication bias were not significant, although the funnel plot showed some asymmetry due to the two small studies that showed large effects for risperidone (Appendix K, Funnel plot 7).

Two trials71,102 (n = 193) reported on the SAPS, (Table 43; Figure 22) and pooled results showed no significant difference between groups. Statistical heterogeneity was moderate (I^2^ = 35 percent). Crespo-Facorro et al.71 compared 3–9 mg/d haloperidol with 3–6 mg/d risperidone and showed a significant difference favoring risperidone. This study included mixed populations in terms of disorder subtypes, first and multiple episodes, and treatment resistance. The study excluded patients with comorbid drug or alcohol use. Duration of followup was 6 weeks; the study had high risk of bias and did not report on funding source. Kim et al.102 compared 15.9±7.1 mg/d haloperidol with 4.8±2.9mg/d risperidone and found no significant difference between groups. This study included mixed populations in terms of disorder subtypes, comorbid drug or alcohol use, and treatment resistance. The study included only patients of Asian descent with multiple episodes. Duration of followup was 8 weeks; risk of bias was unclear, and the study received institutional support.

The SoE for PANSS (positive) and SAPS was graded as low (Table 44).

##### Negative Symptoms

Twenty-three trials52,53,61,64,71,72,81,101,102,107,111,114,117,118,120,124,125,132,135,139,145,149,150 (n = 4,260) reported on negative symptoms using two scales (Table 43; Figure 23).

Figure 23 Haloperidol versus risperidone – Negative symptoms

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SANS = Scale for the Assessment of Negative Symptoms; SD = standard deviation

Figure 23 is a metagraph depicting the effect of haloperidol versus risperidone on negative symptoms in patients with Sz. Twenty studies (n=4,043) were pooled to show a significant difference favoring risperidone (MD=0.60, 95 percent CI, 0.01, 1.20). Statistical heterogeneity was moderate (p=0.10, I2=30). Pooled results from four trials (n=506) showed a significant difference on the SANS scale favoring risperidone (MD=0.58, 95 percent CI, 0.37, 0.80).

Twenty trials52,61,64,72,81,101,107,111,114,117,118,120,124,125,132,135,139,145,149,150 (n = 4,043) reported PANSS (negative). Pooled results showed a significant difference favoring risperidone; statistical heterogeneity was moderate (I^2^ = 30 percent). This was considered not to be clinically significant. Restricting the analyses to the following subgroups reduced the heterogeneity:

- Specifically included patients with schizoaffective disorder (4 studies): significantly favored risperidone (I^2^ = 0 percent);
- Specifically excluded patients with schizoaffective disorder (2 studies): significantly favored risperidone (I^2^ = 0 percent);
- Included patients with both first and multiple episodes (13 studies): significantly favored risperidone (I^2^ = 0 percent);
- Mixed populations with respect to treatment resistance (14 studies): significantly favored risperidone (I^2^ = 3 percent);
- Followed patients for <6 weeks (3 studies): no difference between groups (I^2^ = 0 percent);
- Followed patients for >6 weeks and <6 months (10 studies); no difference between groups (I^2^ = 0 percent);
- Received funding from sources other than industry or did not report source of funding (10 studies): significantly favored risperidone (I^2^ = 0 percent).
- High risk of bias (5 studies): significantly favored risperidone (I^2^ = 0 percent);
- Patient populations of Asian descent (5 studies): significantly favored risperidone (I^2^ = 0 percent);

There was no indication of publication bias based on statistical tests and visual inspection of the funnel plot (Appendix K, Funnel plot 8).

Pooled results from four trials53,71,102,118 (n = 506) showed a significant difference on the SANS scale favoring risperidone. This was considered to be clinically significant. There was no evidence of heterogeneity (I^2^ = 0 percent).

The SoE for PANSS (negative) and SANS was graded as moderate (Table 44).

##### General Psychopathology

Sixteen trials52,61,64,81,107,111,117,118,120,124,132,135,139,145,149,150 (n = 3,073) reported PANSS (general psychopathology) (Table 43; Figure 24). Pooled results are not reported due to marked heterogeneity among the included trials (I^2^ = 96 percent; 95% CI, 94 to 97). Thirteen of the trials (n = 2,648) showed no difference between groups; pooled results also showed no difference and had no statistical heterogeneity (MD = 0.90; 95% CI, −0.10 to 1.90; I^2^ = 0 percent). The three trials that were removed from the analysis all favored haloperidol. There was substantial statistical heterogeneity among these three trials. All three studies included mixed disorder subtypes. Two studies118,135 only included patients with multiple episodes. One study118 excluded patients with comorbid drug or alcohol use and treatment resistance; this study showed the most conservative estimate of the three favoring haloperidol. Doses of haloperidol were 2–8 mg/d,118 5–15 mg/d,135 and 10–20^139^ mg/d; doses of risperidone were 2–8 mg/d,118 2 mg/d,135 and 4–6 mg/d.139 Duration of followup was 6 weeks,139 1 year,135 and 2 years.118 Risk of bias was unclear for one study,118 which was industry-funded; the other two studies had high risk of bias and did not report source of funding. There was no indication of publication bias based on statistical tests (Appendix K, Funnel plot 9). The SoE was graded as low (Table 44).

Figure 24 Haloperidol versus risperidone – General psychopathology

CDS–S = Calgary Depression Scale for Schizophrenia; CI = confidence intervals; df = degrees of freedom; HAM–D = Hamilton Rating Scale for Depression; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation; YMRS = Young Mania Rating Scale

Figure 24 is a metagraph depicting the effect of haloperidol versus risperidone on general psychopathology in patients with Sz. Three studies (n=483) used the CDS-S and pooled results found no difference (MD=0.47, 95 percent CI, −0.19, 1.13); however heterogeneity was substantial (p=0.12, I2=53%). Two trials (n=408) used the HAM-D and found no difference between groups (MD=0.49, 95 percent CI −0.83, 1.81), although heterogeneity was substantial (p=0.06, I2=71%). Sixteen trials (n=3,073) used the PANSS to evaluate general psychopathology. Only 13 trials could be pooled (n=2,648) and found no difference between the groups (MD=0.90, 95 percent CI, −0.10, 1.90). Three outlier trials (n=425) using the PANSS favored haloperidol (MD=−17.61, 95 percent CI, −30.90, −4.32); however there was substantial heterogeneity between the studies (p<0.00001, I2=99%). Two studies (n=406) used the YMRS and showed no difference between groups (MD=0.10, 95 percent CI, −0.07, 0.26).

Three studies used CDS–S71,85,118 (n = 483); pooled results showed no difference; however, there was substantial statistical heterogeneity. Crespo-Facorro71 described immediately above showed a significant effect favoring risperidone. The other two studies showed no difference and were statistically homogeneous. Both studies included mixed disorder subtypes and only patients with multiple episodes. One study118 excluded patients with treatment resistance, whereas the other included both treatment-resistant and nonresistant patients. One118 excluded patients with comorbid drug or alcohol use, the other included a mixed population.85 One study118 used 2–8 mg/d of both drugs; the other compared 3–24 mg/d haloperidol with 2–16 mg/d risperidone. Duration of followup was 8 weeks in one study118 and not reported in the other.85 Both studies had unclear risk of bias and industry funding.

Two studies used HAM–D71,118 (n = 468); pooled results showed no difference, although heterogeneity was substantial (I^2^ = 71 percent). Crespo-Facorro et al.71 compared 3–9 mg/d haloperidol with 3–6 mg/d risperidone and showed a significant difference favoring risperidone. This study included mixed populations in terms of disorder subtypes, first and multiple episodes, and treatment resistance. The study excluded patients with comorbid drug or alcohol use. Duration of followup was 6 weeks; the study had high risk of bias and did not report funding source. Moller et al.118 compared 2–8 mg/d of both haloperidol and risperidone and found no difference between groups. The study included mixed populations in terms of disorder subtype. The study excluded patients with comorbid drug or alcohol use and treatment resistance; only patients with multiple episodes were included. Duration of followup was 2 years. Risk of bias was unclear, and the study was industry-funded.

Two studies used the YMRS; results were consistent across studies and showed no difference between groups.71,118 There was no evidence of heterogeneity between the studies (I^2^ = 0 percent).

One trial used HAM–A101 (n = 255) and found no difference between groups.

One study101 (n = 256) compared 2–19 mg/d haloperidol with 2–10 mg/d risperidone and reported no difference between groups based on the MADRS.

The SoE for the CDS–S, HAM–D, PANSS, and YMRS were graded as low and for the HAM–A and MADRS were graded as insufficient (Table 44).

##### Global Ratings and Total Scores

Global ratings and total scores were reported in 27 trials45,52,53,60,61,64,71–73,81,82,85,101,107,111,113, 114,117,118,120,132,135,139,145,146,149,150 (n = 4,557) using 8 different scales (Table 43; Figure 25).

Figure 25 Haloperidol versus risperidone – Global ratings and total scores

BPRS = Brief Psychiatric Rating Scale; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale

Figure 25 is a metagraph depicting the effect of haloperidol versus risperidone on global ratings and total scores. Thirteen trials (n=2,592) used the BPRS and found no difference between groups (MD=0.51, 95 percent CI, −0.17, 1.20); heterogeneity was moderate (p=0.04, I2=44%). Three studies (n=657) pooled results to find no difference between groups on the CGI-I (MD=−0.02, 95 percent CI, −0.39, 0.36); however heterogeneity was present (p=0.15, I2=48%). Eight studies (n=2,346) reported scores based on the CGI-S and found no difference (MD=0.03, 95 percent CI, −0.17, 0.23); however studies were substantially heterogeneous (p=0.009, I2=63%). Twenty studies (n=4,021) used the PANSS and found no significant difference between groups on total scores (MD=2.23, 95 percent CI −0.37, 4.83); however heterogeneity was substantial (p<0.00001, I2=75%).

Twenty studies (n = 4,021) used the PANSS (total).45,52,61,64,72,81,82,101,107,111,114,117,118,120,132,135, 139,145,149,150 There was no significant difference between groups; however, heterogeneity was substantial (I^2^ = 75 percent). All studies individually showed no difference or favored risperidone except for one study135 favoring haloperidol. When this study, was removed from the analysis, the heterogeneity was minimal (I^2^ = 12 percent). This study compared 5–15 mg/d haloperidol with 2 mg/d risperidone and included mixed populations with respect to disorder subtype, treatment resistance, and comorbid drug or alcohol use. The study only included patients with multiple episodes. Duration of followup was 1 year. Risk of bias was high, and source of funding was not reported. There was some suggestion of publication bias based on Egger’s test (p = 0.01) and visual inspection of the funnel plot, with one small study showing a large effect for risperidone (Appendix K, Funnel plot 10).

Thirteen studies (n = 2592) used the BPRS.52,53,60,61,71,73,81,85,113,114,117,120,146 There was no significant difference between groups; statistical heterogeneity was moderate (I^2^ = 44 percent). Restricting the analyses to the following subgroups reduced the heterogeneity:

- Excluded patients with comorbid drug or alcohol use (7 studies): significantly favored risperidone (I^2^ = 0 percent);
- Included patients with multiple episodes only (5 studies): no difference between groups (I^2^ = 0 percent);
- Duration of followup was ≤6 weeks (5 studies): significantly favored risperidone (I^2^ = 0 percent);
- Industry funding (6 studies): no difference between groups (I^2^ = 0 percent); Other sources of funding or source of funding not reported (7 studies): no difference between groups (I^2^ = 18 percent);
- Unclear risk of bias (10 studies): no difference between groups (I^2^ = 0 percent); High risk of bias (3 studies): significantly favored risperidone (I^2^ = 7% percent);
- Some subgroups showed negligible heterogeneity, but the subgroups included very few studies (e.g., schizoaffective disorder, treatment resistance, and haloperidol >20 mg/d).

There was no indication of publication bias based on statistical tests and visual inspection of the funnel plot (Appendix K, Funnel plot 11).

Eight studies reported scores based on CGI–S;52,61,71,114,117,118,120,146 there were no differences between groups, but the results were statistically heterogeneous (I^2^ = 63 percent). Most studies showed no difference between groups except for Crespo-Facorro et al.,71 which favored haloperidol and Blin et al.,52 which favored risperidone. Removing these two trials reduced the heterogeneity to 0 percent. Crespo-Facorro et al.71 compared 3–9 mg/d haloperidol with 3–6 mg/d risperidone and included mixed populations in terms of disorder subtypes, first and multiple episodes, and treatment resistance. The study excluded patients with comorbid drug or alcohol use. Duration of followup was 6 weeks; the study had high risk of bias and did not report funding source. Blin et al.52 compared similar doses of haloperidol and risperidone (4–12 mg/d). The study excluded patients with schizoaffective disorder and comorbid drug or alcohol use, and included mixed populations with respect to treatment resistance and first or multiple episodes. Duration of followup was 4 weeks. Risk of bias was unclear; funding source was not reported.

Three studies used the CGI–I;117,132,146 no difference between groups was found, but the studies were statistically heterogeneous (I^2^ = 48 percent). One study132 specifically included patients with schizoaffective disorder. Two studies117,146 only included patients with multiple episodes. One study146 only included patients with treatment resistance, ascertained by history and run-in to the trial. One study involved only Asian patients117 and excluded patients with comorbid drug or alcohol use. Doses of haloperidol were 2.5–5 mg/d,117 1–8 mg/d132 and 15 mg/d;146 doses of risperidone were 2.5–5 mg/d,^117^1–8 mg/d, 132 and 6 mg/d.146 Duration of followup was 8 weeks117,146 and 2 years.132 All studies had unclear risk of bias, and two declared industry funding.132,146

Single studies64 (n = 42) compared 1–10 mg/d of haloperidol with 1–10 mg/d of risperidone and found no differences between groups on the NOISIE or SADS–C.

One study114 (n = 322) compared 20 mg/d haloperidol with 2–16 mg/d risperidone and found a significant difference in favor of risperidone for the Symptom Checklist (SCL–90–R). The difference was considered not to be clinically important.

One study118 (n = 289) compared 2–8 mg/d of haloperidol with 2–8 mg/d of risperidone and found no differences between groups on the Subjective Well–being Under Neuroleptic Scale.

The SoE was graded low for BPRS, CGI–I, CGI–S, and PANSS (total) and insufficient for NOISIE, SADS–C, SCL–90–R, and Subjective Well-being Under Neuroleptics Scale (Table 44).

#### Key Questions 2 and 4 Improvement in Functional Outcomes, Decreasing Health Care System Utilization, and Other Outcomes

##### Functional Outcomes

###### Employment or Personal Earnings

One trial135 (n = 100) comparing 5–15 mg/d haloperidol with 2 mg/d risperidone reported economic independence in patients and found no significant difference between groups (Table 43).

###### Encounters with Legal System

One trial118 (n = 289) comparing 2–8 mg/d haloperidol with 2–8 mg/d risperidone reported attitudes regarding drugs and found no significant difference between groups (Table 43).

##### Health Care System Utilization

Pooled data from three trials77,118,135 (n = 422) showed no significant differences between groups for rates of hospitalization or rehospitalization (I^2^ = 24 percent) (Table 43). Two studies77,118 excluded patients with comorbid drug or alcohol use. Two studies118,135 only included patients with multiple episodes. One118 study excluded patients with treatment resistance. Doses of haloperidol varied: 5–17 mg/d,77 2–8 mg/d,118 and 5–15 mg/d;135 doses of risperidone were 1–6 mg/d77 2–8 mg/d,118 and 2 mg/d.135 Duration of followup was 1 year77,135 and 2 years.118 Risk of bias was high for two trials77,135 and unclear for one.118 Two studies were industry-funded,77,118 and one did not report funding source.

##### Other Outcomes

###### Relapse, Response, and Remission Rates

Pooled results from six trials72,77,113,118,132,135 (n = 1,405) showed a significantly lower relapse rate favoring risperidone (Table 43; Figure 26); the studies were statistically homogeneous (I^2^ = 0 percent).

Figure 26 Haloperidol versus risperidone – Relapse rates

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; M-H = Mantel-Haenszel

Figure 26 is a metagraph depicting the effect of haloperidol versus risperidone on relapse rates in patients with Sz. Pooled results from six trials (n=1,405) showed significantly lower relapse rates favoring risperidone (MD=1.35, 95 percent CI, 1.17, 1.57).

Two trials60,71 (n = 179) showed no significant difference between groups on treatment remission rates (Table 43); results were statistically homogeneous (I^2^ = 0 percent)

Pooled results from 16 trials52,53,59,61,64,73,81,101,114,117,120,132,135,145,146,150 (n = 3,453) showed no significant difference between groups for treatment response rates (Table 43; Figure 27) there was no important statistical heterogeneity (I^2^ = 29 percent). No important patterns were observed in the subgroup and sensitivity analyses; moreover, all subgroups showed no difference between groups (Appendix M, Table 111). All of the individual trials showed no differences except one study,114 which showed a significant benefit favoring risperidone. This trial compared 20 mg/d haloperidol with 2–16 mg/d risperidone, excluded patients with schizoaffective disorder, and included mixed populations with respect to comorbid drug or alcohol use, first or multiple episodes, and treatment resistance. Length of followup was 8 weeks. Risk of bias was high, and the study was industry-funded. There was suggestion of publication bias with more small trials favoring risperidone, based on Begg’s rank correlation (p = 0.03) and Egger’s (p = 0.006) tests, as well as visual inspection of the funnel plot (Appendix K, Funnel plot 12).

Figure 27 Haloperidol versus risperidone – Response rates

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; M-H = Mantel-Haenszel

Figure 27 is a metagraph depicting the effect of haloperidol versus risperidone on response rates in patients with Sz. Sixteen trials (n=3,453) were pooled and no significant difference between groups was found (MD=0.94, 95 percent CI 0.87, 1.02); heterogeneity was not statistically important (p=0.13, I2=29%).

###### Medication Adherence

Three trials72,101,149 (n = 661) assessed medication adherence (Table 43); pooled results were homogeneous (I^2^ = 0 percent) and showed no difference between groups.

###### Health-related Quality of Life

Two trials113,118 (n = 674) assessed health-related quality of life using a variety of measures and found no differences (Table 43).

###### Patient Satisfaction

One trial146 (n = 67) comparing 15 mg/d haloperidol with 6 mg/d risperidone found no significant differences between groups for patient satisfaction (Table 43).

#### Key Question 5 Subgroups

##### Race

Six trials102,107,111,117,149,150 (n = 369) in Asian patients showed no significant difference on PANSS (positive), SAPS, PANSS (negative), or SANS.

##### First Episode

Pooled results from four trials71,81,118,132 (n = 1,365) in patients undergoing treatment for their first psychotic episode showed a significant difference on the SAPS and SANS scales favoring risperidone ([MD = 0.30; 95% CI, 0.12 to 0.48] and [MD = 0.60; 95% CI, 0.38 to 0.62], respectively). No significant differences were found for the PANSS (positive), CDS–S, HAM–D, PANSS (negative), PANSS (general psychopathology), BPRS, CGI–I, CGI–S, PANSS (total), and YMRS.

### Haloperidol Versus Ziprasidone

#### Key Points

- Eight RCTs compared haloperidol versus ziprasidone in patients with a range of disease severity.
- The most commonly reported outcome was global rating or total symptom scores using four different scales: BPRS (4 trials), CGI–S (4 trials), PANSS (4 trials), and GAF (3 trials). No differences were found between groups for any of the scales. The SoE was low for all scales.
- Six studies reported response rates and overall showed no difference; however, results showed substantial statistical heterogeneity, which was not fully explained through the predefined subgroup and sensitivity analyses. Moreover, some subgroups showed no differences (3 studies excluding patients with comorbid drug or alcohol use), one favored haloperidol (2 studies with duration of followup >6 months), and others favored ziprasidone (3 studies of patients with treatment resistance or mixed populations; 2 studies in which funding source was not reported).
- Three studies assessed remission rates and found no differences between groups.
- Other outcomes were assessed in only one to two studies, and in all but one case showed no differences between groups.

Eight RCTs57,69,73,75,83,86,91,122 (n = 2,067) compared haloperidol with ziprasidone. Key characteristics of the included trials and summary findings are presented in Table 45 and Table 46. All trials included mixed populations in terms of disorder subtypes. Three studies57,69,83 excluded patients with comorbid drug or alcohol use. One study included only patients with treatment resistance ascertained by history.73 Three studies specifically excluded patients with treatment resistance.57,86,91 Doses of haloperidol ranged across studies and varied from 1–4 mg/d75,91 to 4–30 mg/day.73 Doses of ziprasidone also varied across studies, ranging from 4–160 mg/d83 to 40–240 mg/d.73

Duration of followup was ≤6 weeks in four studies57,69,73,83 and ≥6 months in four studies;75,86,91,122 one study122 followed patients for 3.75 years. Risk of bias was unclear for two studies73,122 and high for the others. Seven studies were industry-funded, whereas two studies73,83 did not report their source of funding.

Publication bias was not formally tested for any of the outcomes due the small number of included trials. The SoE for the majority of the evaluated outcomes was insufficient due to the small number of trials (Table 47).

#### Key Question 1 Improving Core Illness Symptoms

##### Positive Symptoms

None of the included trials reported positive symptoms.

##### Negative Symptoms

Two trials86,122 (n = 900) assessed negative symptoms using the PANSS (negative) and reported no significant difference between groups (Table 46; Figure 28); results showed no evidence of heterogeneity (I^2^ = 0 percent). Both studies included mixed populations with respect to disorder subtypes and comorbid drug or alcohol use. Both studies used consistent doses of haloperidol (5–15 mg/d and 5–20 mg/d) and ziprasidone (80–160 mg/d). One study86 excluded patients with treatment resistance. Duration of followup was 28 weeks86 and 3.75 years.122 Risk of bias was high86 and unclear;122 both were funded by industry. The SoE was low (Table 47).

Figure 28 Haloperidol versus ziprasidone – Negative symptoms

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 28 is a metagraph depicting the effect of haloperidol versus ziprasidone for negative symptoms in patients with Sz. Two trials (n=900) using the PANSS assessed patients for negative symptoms and reported no significant difference between groups (MD=0.56, 95 percent CI, −0.30, 1.42).

##### General Psychopathology

One trial57 (n = 567) compared 5–20 mg/d haloperidol with 10–40 mg/d ziprasidone and found no significant difference between groups using the Covi Anxiety Scale (Table 46). This trial included patients with mixed disorder subtypes. Patients with comorbid drug or alcohol use and those with treatment resistance were excluded. Duration of followup was 6 weeks. Risk of bias was high, and the trial was industry-funded.

One trial91 (n = 185) compared haloperidol (1–4 mg/d) with ziprasidone (40–60 mg/d) and found no significant difference between groups using the CDS–S (Table 46). The study included participants with mixed disorder subtypes and comorbid drug or alcohol use. Patients with treatment resistance were excluded. Duration of followup was 1 year. Risk of bias was high, and the study was industry-funded.

One trial86 (n = 301) compared haloperidol (5–15 mg/d) with ziprasidone (80–160 mg/d) and found no significant difference between groups on MADRS (Table 46). The trial included a mix of disorder subtypes and comorbid drug or alcohol use. Patients with treatment resistance were excluded. Duration of followup was 28 weeks. Risk of bias was high, and the trial was industry-funded.

The SoE was insufficient for three scales used to assess general psychopathology (Table 47).

##### Global Ratings and Total Scores

Seven trials assessed total scores using four different tools. Four trials57,73,83,86 (n = 1,078) found no significant difference between groups on BPRS (Table 46; Figure 29); there was no statistical heterogeneity. All studies included a mix of disorder subtypes. Two studies57,83 excluded patients with comorbid drug or alcohol use. One study73 included only patients with treatment resistance; two studies57,86 excluded patients with treatment resistance. Doses of haloperidol were relatively consistent, except for one study where the upper limit was 30 mg/d.73 Upper limits for ziprasidone varied: 40 mg/d,57 160 mg/d,83,86 and 240 mg/d.73 Duration of followup was ≤6 weeks in three studies and 28 weeks in the other.86 Risk of bias was high in three studies and unclear in one.73 Two studies57,86 reported industry funding; two studies73,83 did not report funding source.

Figure 29 Haloperidol versus ziprasidone – Global ratings and total scores

BPRS = Brief Psychiatric Rating Scale; CGI–S = Clinical Global Impression–Severity; CI = confidence intervals; df = degrees of freedom; GAF = Global Assessment of Functioning; I^2^ = I-squared; IV = inverse variance; PANSS = Positive and Negative Symptom Scale; SD = standard deviation

Figure 29 is a metagraph depicting the effect of haloperidol versus ziprasidone for global ratings and total scores in patients with Sz. Four trials (n=1,078) found no significant difference between groups on the BPRS (MD=0.24, 95 percent CI, −0.57, 1.06). Four trials (n=1,143) showed no significant difference between groups on the CGI-S (MD=0.00, 95 percent CI, −0.26, 0.26); however some statistical heterogeneity was present (p=0.24, I2=28%). Three trials (n=1,085) used the GAF and found no significant difference between groups (MD=0.30, 95 percent CI, −1.58, 2.19). Four trials (n=1,105) showed no difference between groups on the PANSS (MD=1.22, 95 percent CI, −0.62, 3.07).

Four trials57,83,86,91 (n = 1,275) showed no significant difference between groups on CGI–S (Table 46; Figure 29); there was some statistical heterogeneity between studies. All studies included a mix of disorder subtypes. Two studies57,83 excluded patients with comorbid drug or alcohol use. Three studies57,86,91 excluded patients with treatment resistance. One study91 used a relatively lower dose of haloperidol (1–4 mg/d). Ziprasidone doses were relatively consistent; however, one study57 had a lower maximum dose (40 vs. 160 mg/d). Duration of followup was ≤6 weeks in two studies,57,83 28 weeks in one study,86 and 1 year in one study.91 All studies were high risk of bias; three reported industry funding, and one did not report funding source.83

Four trials69,86,91,122 (n = 1,105) showed no significant difference between groups on PANSS (total) (Table 46; Figure 29); there was no statistical heterogeneity among studies. All studies included a mix of disorder subtypes. One study69 excluded patients with drug or alcohol use. Two studies86,91 excluded patients with treatment resistance. One study91 used a relatively lower dose of haloperidol (1–4 mg/d). Ziprasidone doses were relatively consistent; however, one study69 had a lower maximum dose (40 vs. 160 mg/d). Duration of followup ranged from 2 weeks69 to 3.75 years.122 Risk of bias was high for three studies and unclear for one;122 all studies were industry-funded.

Three trials86,91,122 (n = 1,085) showed no significant difference between groups on the GAF scale (Table 46; Figure 29); there was no statistical heterogeneity. All studies included patients with a mix of disorder subtypes and comorbid drug or alcohol use. Two studies86,91 excluded patients with treatment resistance. One study91 used a relatively lower dose of haloperidol (1–4 mg/d). Ziprasidone doses were consistent across studies. Followup ranged from 28 weeks86 to 3.75 years.122 Risk of bias was high for two studies86,91 and unclear for one;122 all were industry-funded.

The SoE was graded as low for BPRS, CGI–S, PANSS (total), and GAF (Table 47).

#### Key Questions 2 and 4 Improvement in Functional Outcomes, Decreasing Health Care System Utilization, and Other Outcomes

##### Functional Outcomes

###### Sexual Dysfunction

One trial91 (n = 185) compared haloperidol (1–4 mg/d) and ziprasidone (40–160 mg/d) and found no differences between groups for incidence of sexual dysfunction (Table 46). The study included participants with mixed disorder subtypes and comorbid drug or alcohol use. Patients with treatment resistance were excluded. Duration of followup was 1 year. Risk of bias was high, and the study was industry-funded.

##### Health Care System Utilization

Pooled results for two trials86,91 (n = 486) showed no significant difference between groups for rates of hospitalization or rehospitalization (Table 46). Both trials included patients with a mix of disorder subtypes and comorbid drug or alcohol use. Both excluded patients with treatment resistance. One trial91 used a relatively lower dose of haloperidol (1–4 mg/d); ziprasidone doses were consistent. Duration of followup was 28 weeks86 and 1 year.91 Risk of bias was high in both trials, and both were industry-funded.

##### Other Outcomes

###### Response and Remission Rates

Six trials57,69,73,83,86,91 (n = 1,283) showed no significant difference between groups for treatment response rates (Table 46; Figure 30). However, statistical heterogeneity was substantial; therefore, the overall estimate may not be meaningful. We conducted predefined subgroup and sensitivity analyses to explain heterogeneity (Appendix M, Table 112). Three studies that excluded patients with comorbid drug or alcohol use had no heterogeneity (I^2^ = 0 percent) and showed no difference. Two studies that followed patients for ≥6 months had no heterogeneity (I^2^ = 0 percent) and showed significant results favoring haloperidol. Three studies had mixed treatment-resistant and nonresistant patients (2 studies) or included only treatment-resistant patients (1 study); when combined, these studies had no heterogeneity (I^2^ = 0 percent) and showed significant results favoring ziprasidone. Two studies did not report their source of funding; these studies had no heterogeneity, and their pooled results favored ziprasidone. One study73 appeared as an outlier, as it showed a statistically significant benefit for ziprasidone. This study included relatively larger doses of haloperidol (up to 30 mg/d) and included only treatment-resistant patients; the study had unclear risk of bias.

Figure 30 Haloperidol versus ziprasidone – Response rates

CI = confidence intervals; df = degrees of freedom; I^2^ = I-squared; IV = inverse variance; M-H = Mantel-Haenszel

Figure 30 is a metagraph depicting the effect of haloperidol versus ziprasidone on response rates in patients with Sz. Six trials contributing 1,283 participants were pooled and found no significant difference between groups (MD=0.98, 95 percent CI, 0.74, 1.30); however statistical heterogeneity was substantial (p=0.0002, I2=80%).

Three trials86,91,122 (n = 1,085) found no significant difference between groups for remission rates (Table 46); the statistical heterogeneity was minimal. These studies included a mix of populations with respect to disorder subtypes and cormorbid drug or alcohol use. Two studies86,91 excluded patients with treatment resistance. One study91 used a relatively lower dose of haloperidol (1–4 mg/d); doses of ziprasidone were consistent across studies. All studies followed patients for >6 months, and one study122 followed patients for 3.75 years. Risk of bias was high for two studies and unclear for one;122 all studies declared industry support.

###### Health-related Quality of Life

A single trial91 (n = 185) comparing 1–4 mg/d haloperidol with 40–160 mg/d ziprasidone reported no significant difference between groups for health-related quality of life based on the Manchester Short Assessment of Quality of Life Scale. The study included participants with mixed disorder subtypes and comorbid drug or alcohol use. Patients with treatment resistance were excluded. Duration of followup was 1 year. Risk of bias was high, and the study was industry-funded. Another trial122 (n = 599) compared 5–20 mg/d haloperidol with 80–160 mg/d ziprasidone and found a significant difference favoring ziprasidone on the Quality of Life Scale (Table 46). This trial included a mix of patients with respect to disorder subtype, comorbid drug or alcohol use, and treatment resistance. Duration of followup was 3.75 years. The trial had unclear risk of bias and was industry-funded.

#### Key Question 5 Subgroups

None of the included studies addressed the prespecified subgroups for the key core illness symptoms.

### Perphenazine Versus Aripiprazole

One RCT93 (n = 300) compared perphenazine (8–64 mg/d) with aripiprazole (15–30 mg/d) in patients with treatment-resistant schizophrenia (Table 48). There were no significant differences in core illness symptoms (global ratings/total scores) or response rates (Table 49). The SoE for all the evaluated outcomes was insufficient due to the inclusion of only a single trial (Table 50). A significant difference favoring perphenazine was reported showing a 20 percent improvement for health-related quality of life.

### Perphenazine Versus Olanzapine

Two RCTs23,131 (n = 874) compared perphenazine with olanzapine. Key characteristics of the included trials and summary findings are presented in Table 51 and Table 52. Publication bias was not formally tested due to the inclusion of a small number of trials. The SoE for all evaluated outcomes was insufficient due to the inclusion of only two trials (Table 53).

#### Key Question 1 Improving Core Illness Symptoms

One trial23 (n = 597) including patients with schizophrenia compared perphenazine (8–32 mg/d) and olanzapine (7.5–30 mg/d) and reported on PANSS (positive), PANSS (negative), PANSS (general psychopathology), PANSS (total), and CGI–S scales. All the findings significantly favored olanzapine, except PANSS (total), which favored perphenazine, and PANSS (negative), which was not significantly different between groups (Table 52). The differences were not considered to be clinically relevant, and the SoE for all outcomes was graded as insufficient (Table 53).

#### Key Questions 2 and 4 Improvement in Functional Outcomes, Decreasing Health Care System Utilization, and Other Outcomes

##### Employment or Personal Earnings

One trial23 (n = 597) of patients with schizophrenia compared perphenazine (8–32 mg/d) with olanzapine (7.5–30 mg/d) and reported no significant difference between groups for the employment or personal earnings (Table 52).

##### Health Care System Utilization

One trial23 (n = 597) of patients with schizophrenia compared perphenazine (8–32 mg/d) with olanzapine (7.5–30 mg/d) and reported no significant difference between groups for the rates of hospitalization or rehospitalization (Table 52).

##### Other Outcomes

One trial23 (n = 597) of patients with schizophrenia compared perphenazine (8–32 mg/d) with olanzapine (7.5–30 mg/d) and reported no significant difference between groups for the Quality of Life Scale (total score) (Table 52). One trial131 of patients with schizophrenia, schizoaffective disorder, or schizophreniform disorder reported a significantly longer time to all-cause medication discontinuation (days) favoring olanzapine (Table 52).

#### Key Question 5 Subgroups

##### Comorbidities

One trial23 (n = 597) of patients with schizophrenia compared perphenazine (8–32 mg/d) with olanzapine (7.5–30 mg/d) and reported on a subgroup of patients with comorbid illicit substance use. There was a significant difference in favor of olanzapine on PANSS (positive) (MD = 1.91; 95% CI, 0.57 to 3.25), PANSS (negative) (MD = 1.67; 95% CI, 0.17 to 3.17), and CGI–S (MD = 0.43; 95% CI, 0.17 to 0.69). There was a significant difference in favor of perphenazine for PANSS (total) (MD = −5.11; 95% CI, −9.31 to −0.91). No difference between groups was found for the PANSS (general psychopathology). The differences were not considered to be clinically relevant.

### Perphenazine Versus Quetiapine

One RCT23 (n = 598) compared perphenazine (8–32 mg/d) with quetiapine (200–800 mg/d) in patients with schizophrenia (Table 54). No significant differences between groups were found for core illness symptoms (positive or negative symptoms, general psychopathology, or total scores), functional outcomes (paid employment in past month), health care system utilization, or quality of life scores (Table 55). The SoE for all the evaluated outcomes was insufficient due to the inclusion of only a single trial (Table 56). For subgroup analysis investigating comorbidities, no significant differences were found between groups on PANSS (positive, negative, general psychopathology, or total score) or CGI–S.

### Perphenazine Versus Risperidone

Two RCTs23,131 (n = 871) in patients with schizophrenia compared perphenazine (8–32 mg/d) with risperidone (1.5–6.0 mg/d). Key characteristics of the included trials and summary findings are presented in Table 57 and Table 58. Publication bias was not formally tested due to the inclusion of a small number of trials. The SoE for all evaluated outcomes was insufficient due to the inclusion of only a small number of trials (Table 59).

#### Key Question 1 Improving Core Illness Symptoms

One trial23 (n = 602) including patients with schizophrenia and comparing perphenazine (8–32 mg/d) with risperidone (1.5–6.0 mg/d) reported no significant difference between groups on PANSS (positive), PANSS (negative), PANSS (general psychopathology), PANSS (total), and CGI–S (Table 58). The SoE for the outcomes was graded as insufficient (Table 59).

#### Key Questions 2 and 4 Improvement in Functional Outcomes, Decreasing Health Care System Utilization, and Other Outcomes

##### Employment or Personal Earnings

One trial23 (n = 602) in patients with schizophrenia that compared perphenazine (8–32 mg/d) with risperidone (1.5–6.0 mg/d) reported no significant difference between groups for the employment or personal earnings (Table 58).

##### Health Care System Utilization

One trial23 (n = 602) in patients with schizophrenia that compared perphenazine (8–32 mg/d) with risperidone (1.5–6.0 mg/d) reported no significant difference between groups on rates of hospitalization or rehospitalization (Table 58).

##### Other Outcomes

One trial23 (n = 602) in patients with schizophrenia that compared perphenazine (8–32 mg/d) with risperidone (1.5–6.0 mg/d) reported no significant difference between groups on the Quality of Life Scale (total score) (Table 58). Another trial131 in patients with schizophrenia, schizoaffective disorder, or schizophreniform disorder reported no significant difference between groups for all-cause medication discontinuation (days) (Table 58).

#### Key Question 5 Subgroups

##### Comorbidities

One trial,23 including patients with schizophrenia and comparing perphenazine (8–32 mg/d) with risperidone (1.5–6.0 mg/d), reported on a subgroup of patients with comorbid illicit substance use. There was no significant difference between groups on PANSS (positive), PANSS (negative), PANSS (general psychopathology), PANSS (total), or CGI–S.

### Perphenazine Versus Ziprasidone

One RCT23 (n = 446) compared perphenazine (8–32 mg/d) with ziprasidone (40–160 mg/d) in patients with schizophrenia (Table 60). No significant differences were found between groups for core illness symptoms (positive, negative, and total scores); however, a significant difference favoring perphenaine for core illness symptoms (general psychopathology) was found, but was considered not clinically significant (Table 61). The SoE for all the evaluated outcomes was insufficient due to the inclusion of only a single trial (Table 62). No significant differences were found between groups for functional outcomes (paid employment in past month), health care system utilization (rates of hospitalization or rehospitalisation), quality of life scores, or for subgroup analysis investigating comorbid illicit substance use.

### Trifluoperazine Versus Clozapine

One RCT157 (n = 25) compared trifluoperazine (7.5–15 mg/d) with clozapine (50–100 mg/d) in patients schizophrenia (Table 63). There was no reported difference in core illness symptoms (BPRS) (Table 64). No other relevant outcomes were reported. The SoE for BPRS was insufficient (Table 65).

## Bipolar Disorder (Key Questions 1, 2, 4, 5)

For bipolar disorder, we included 11 trials that enrolled a total of 2,217 adult patients. The individual studies are described in Appendix H and I. The results from the studies and pooled analyses are presented in Table 66 to Table 82. Within the forest plots, the studies are presented by year of publication. The following sections provide an overview of results according to KQ: 1) core illness symptoms; 2) functional outcomes and health care system utilization; 4) other outcomes; and 5) subgroup analyses. For KQ1, the outcomes are grouped as follows: mood (mania), mood (depression), positive and negative symptoms, general psychopathology, and global ratings and total scores. KQs 2 and 4 were grouped and are reported together throughout the results section. Comparisons are presented in alphabetic order by drug name.

Table 66 Characteristics of RCT comparing chlorpromazine versus clozapine in the treatment of bipolar disorder with manic episodes

Study, Design (Followup) | Interventions, Dosages; No. Randomized | Main Inclusion Criteria | Risk of Bias, Financial Support
Barbini et al. 1997^48^ RCT (3 wks) | G1: CHL (2–5mg/kg/d); (12) G2: CLO (25–175mg/d); (15) | BP with manic episode; no depot AP <6 mo | High, NR

AP(s) = antipsychotic(s); BP = bipolar disorder; CHL = chlorpromazine; CLO = clozapine; D = days; G = group; Kg = kikograms; Mg = milligrams; Mo = month; NR = not reported; RCT = randomized controlled trial; Wk(s) = week(s);

Table 67 Evidence summary table: chlorpromazine versus clozapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Mood (Mania)
YMRS scale48 | 1 | 27 | 3.94 (−0.11, 7.99) | NE | ND

I^2^ = I-squared; ND = no difference; NE = not estimable; YMRS = Young Mania Rating Scale

Table 68 Strength of evidence (GRADE): chlorpromazine versus clozapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Mood (Mania)
YMRS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence; YMRS = Young Mania Rating Scale

Table 69 Characteristics of RCTs comparing haloperidol versus aripiprazole in the treatment of bipolar disorder

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Vieta et al. 2005^32^ RCT (12 wks) | G1: HAL (10–15mg/d); (172) G2: ARI (15–30mg/d); (175) Washout period: 1–3 d | BP; no rapid-cycling BP I, current manic episode >4 wks, substance abuse, or unresponsive to previous AP | Unclear, Industry
Young et al. 2009^33^ RCT (12 wks) | G1: HAL (5–15mg/d); (165) G2: ARI (15–30mg/d); (167) Washout period: 2–14 d | BP I manic or mixed type (with or without psychotic features) | Unclear, Industry

AP(s) = antipsychotic(s); ARI = aripiprazole; BP I = bipolar disorder type I; D = days; G = group; HAL = haloperidol; Hr(s) = hour(s); Mg = milligrams; Mo = month; RCT = randomized controlled trial; Wk(s) = week(s)

Table 70 Evidence summary table: haloperidol versus aripiprazole

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Mood (Mania)
YMRS32,33 | 2 | 679 | 0.90 (−0.77, 2.58) | 22% | ND
Mood (Depression)
MADRS32,33 | 2 | 679 | 0.22 (−1.73, 2.18) | 0% | ND
Positive/Negative Symptoms
PANSS (positive)33 | 1 | 332 | −0.50 (−1.61, 0.61) | NE | ND
PANSS (negative)33 | 1 | 332 | −0.10 (−0.65, 0.45) | NE | ND
Global Ratings and Total Scores
CGI–BP32,33 | 2 | 679 | 0.15 (−0.35, 0.65) | 81% | ND
PANSS33 | 1 | 332 | −1.90 (−4.95, 1.15) | NE | ND
Other Outcomes
Relapse rates32 | 1 | 347 | 0.53 (0.40, 0.71)^*^ | NE | haloperidol
Remission rates33 | 1 | 332 | 1.02 (0.89, 1.17)^*^ | NE | ND
Response rates32,33 | 2 | 679 | 0.77 (0.42, 1.42)^*^ | 94% | ND

Note: bolded results are statistically significant;

* binary outcome;

CGI–BP = Clinical Global Impression–Bipolar; I^2^ = I-squared; MADRS = Montgomery-Asberg Depression Rating; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale; YMRS = Young Mania Rating Scale

Table 71 Strength of evidence (GRADE): haloperidol versus aripiprazole

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Mood (Mania)
YMRS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
Mood (Depression)
MADRS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
Positive/Negative Symptoms
PANSS (positive) | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS (negative) | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Global Ratings and Total Scores
CGI–BP | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
PANSS (total) | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

CGI–BP = Clinical Global Impression–Bipolar; MADRS = Montgomery-Asberg Depression Rating; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SoE = Strength of Evidence; Total = total scores; YMRS = Young Mania Rating Scale; ND = no difference

Table 72 Characteristics of RCTs comparing haloperidol versus olanzapine in the treatment of bipolar disorder

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout Period | Main Inclusion criteria | Risk of Bias, Financial Support
Moreno et al. 2007^119^ RCT (6 wks) | G1: HAL (3–15mg/d); (5) G2: OLA (5–20mg/d); (7) Washout period: 4 d | BP; switched between depression and mania phase ≤1 mo before or after PSG procedure | Unclear, Foundation
Tohen et al. 2003^140^ RCT (12 wks) | G1: HAL (3–15mg/d); (219) G2: OLA (5–20mg/d); (234) | BP defined by DSM–IV | High, Industry

AP(s) = antipsychotic(s); BP = bipolar disorder; D = days; DSM-IV = diagnostic and statistical manual of mental disorders; G = group; HAL = haloperidol; Hr(s) = hour(s); Mg = milligrams; Mo = month; OLA = olanzapine; PSG = polysomnographic studies; RCT = randomized controlled trial; Wk(s) = week(s);

Table 73 Evidence summary table: haloperidol versus olanzapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Mood (Mania)
YMRS119,140 | 2 | 465 | −0.37 (−1.98, 1.24) | 0% | ND
Mood (Depression)
HAM–D140 | 1 | 453 | 0.90 (−0.64, 2.44) | NE | ND
Sleep
Number of awakenings119 | 1 | 12 | 11.40 (−10.44, 33.24) | NE | ND
Sleep efficiency (%)119 | 1 | 12 | −8.90 (−34.65, 16.85) | NE | ND
Stage REM (min)119 | 1 | 12 | −10.70 (−54.10, 32.70) | NE | ND
Total REM activity119 | 1 | 12 | −29.30 (−85.88, 27.28) | NE | ND
Total sleep time (min)119 | 1 | 12 | 18.60 (−107.21,144.41) | NE | ND
Global Ratings and Total Scores
CGI–BP119 | 1 | 12 | −1.80 (−5.66, 2.06) | NE | ND
Employment/Personal Earnings
Active workers: number working for pay140 | 1 | 453 | 0.50 (0.32, 0.79)^*^ | NE | olanzapine
SLICE/LIFE: household activities impairment score140 | 1 | 453 | 0.23 (−0.10, 0.56) | NE | ND
SLICE/LIFE: work activities impairment score140 | 1 | 453 | 0.00 (−0.33, 0.33) | NE | ND
Other Outcomes
Relapse rates140 | 1 | 453 | 0.80 (0.52, 1.24)^*^ | NE | ND
Remission rates140 | 1 | 453 | 0.85 (0.70, 1.03)^*^ | NE | ND
Response rates140 | 1 | 453 | 0.98 (0.94, 1.02)^*^ | NE | ND
Health-Related Quality of Life
SF–36 mental summary score140 | 1 | 453 | 17.30 (14.47, 20.13) | NE | haloperidol
SF–36 physical summary score140 | 1 | 453 | −3.74 (−5.46, −2.02) | NE | olanzapine

Note: bolded results are statistically significant;

* binary outcome;

CGI–BP = Clinical Global Impression–Bipolar; HAM–D = Hamilton Rating Scale for Depression; I^2^ = I-squared; ND = no difference; NE = not estimable; REM = rapid eye movement; SF = Short Form; SLICE/LIFE = Streamlined Longitudinal Interview Clinical Evaluation from the Longitudinal Interval Followup Evaluation; YMRS = Young Mania Rating Scale

Table 74 Strength of evidence (GRADE): haloperidol versus olanzapine

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Mood (Mania)
YMRS | 2 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
Mood (Depression)
HAM–D | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Sleep
Number of awakenings | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Sleep efficiency (%) | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Stage REM (min) | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Total REM activity | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Total sleep time (min) | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Global Ratings and Total Scores
CGI–BP | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

CGI–BP = Clinical Global Impression–Bipolar; HAM–D = Hamilton Rating Scale for Depression; Min = minute; ND = no difference; RCT = randomized controlled trial; REM = rapid eye movement; RoB = risk of bias; SoE = Strength of Evidence; YMRS = Young Mania Rating Scale

Table 75 Characteristics of RCT comparing haloperidol versus quetiapine in the treatment of bipolar disorder

Study, Design (Followup) | Interventions, Dosages; No. Randomized | Main Inclusion Criteria | Risk of Bias, Financial Support
McIntyre et al. 2005^115^ RCT (12 wks) | G1: HAL (2–8mg/d); (99) G2: QUE (100–800mg/d); (102) | BP I, current episode manic, with or without psychotic features; ≥1 manic or mixed episode; no tx with CLO ≤1 mo | Unclear, Industry

BP I = bipolar disorder type I; CLO = clozapine; D = days; DSM-IV = diagnostic and statistical manual of mental disorders; G = group; HAL = haloperidol; Hr(s) = hour(s); Mg = milligrams; Mo = month; QUE = quetiapine; RCT = randomized controlled trial; Wk(s) = week(s);

Table 76 Evidence summary table: haloperidol versus quetiapine

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Other Outcomes
Remission rates115 | 1 | 201 | 1.14 (0.94, 1.40)^*^ | NE | ND
Response rates115 | 1 | 201 | 1.03 (0.83, 1.28)^*^ | NE | ND

I^2^ = I-squared; ND = no difference; NE = not estimable

* Binary outcome.

Table 77 Characteristics of RCTs comparing haloperidol versus risperidone in the treatment of bipolar disorder

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Janicak et al. 2001^90^ RCT (6 wks) | G1: HAL (4–20mg); (32) G2: RIS (2–10mg); (30) Washout period: ~5 d | BP subtype, manic phase; no hypersensitivity hx to HAL or RIS | High, Industry
Sachs et al. 2002^128^ RCT (3 wks) | G1: HAL (4–12mg/d); (53) G2: RIS (2–6mg/d); (52) Washout period: ≤3 d | BP and ≥1 prior manic episode; no CLO ≤1 month or depot AP within one cycle | High, Industry
Segal et al. 1998^133^ RCT (28 d) | G1: HAL (10mg/d); (15) G2: RIS (6mg/d); (15) | BP with acute manic episode defined by DSM-IV | Unclear, Industry
Smulevich et al. 2005^138^ RCT (12 wks) | G1: HAL (4–12mg/d); (144) G2: RIS (2–6mg/d); (154) Washout period: ≥3 d | BP I with ≥1 manic or mixed episode; no schizoaffective disorder, rapid- cycling BP, borderline or antisocial personality disorders | Unclear, Industry

AP(s) = antipsychotic(s); BP = bipolar disorder; CLO = clozapine; D = days; DSM-IV = diagnostic and statistical manual of mental disorders; G = group; HAL = haloperidol; Hr(s) = hour(s); Hx = history; Mg = milligrams; Mo = month; No = number; NR = not reported; RIS = risperidone; RCT = randomized controlled trial; Wk(s) = week(s)

Table 78 Evidence summary table: haloperidol versus risperidone

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Mood (Mania)
CARS-M90 | 1 | 62 | 3.00 (−3.36, 9.36) | NE | ND
YMRS128,133,138 | 3 | 433 | 1.08 (−0.95, 3.12) | 0% | ND
Mood (Depression)
HAM-D90 | 1 | 62 | −5.00 (−10.86, 0.86) | NE | ND
Positive Symptoms
PANSS90 | 1 | 62 | −80 (−3.90, 2.30) | NE | ND
Negative Symptoms
PANSS90 | 1 | 62 | −1.30 (−4.33, 1.73) | NE | ND
Global Ratings and Total Scores
BPRS133 | 1 | 30 | −1.60 (−7.11, 3.91) | NE | ND
CGI-I90 | 1 | 62 | 0.00 (−0.42, 0.42) | NE | ND
PANSS90 | 1 | 62 | −2.00 (−13.10, 9.10) | NE | ND
Other Outcomes
Response rates90 | 1 | 62 | 1.07 (0.44, 2.59) | NE | ND

BPRS = Brief Psychiatric Rating Scale; CARS–M = Clinician-Administered Rating Scale for Mania; CGI–I = Clinical Global Impression–Improvement; HAM–D = Hamilton Rating Scale for Depression; I^2^ = I-squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale; YMRS = Young Mania Rating Scale

Table 79 Strength of evidence (GRADE): haloperidol versus risperidone

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Mood (Mania)
CARS-M | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
YMRS | 3 RCT | Medium | Consistent | Direct | Imprecise | Low (ND)
Mood (Depression)
HAM-D | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Positive Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Negative Symptoms
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
Global Ratings and Total Scores
BPRS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
CGI-I | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient
PANSS | 1 RCT | Medium | Unknown | Direct | Imprecise | Insufficient

BPRS = Brief Psychiatric Rating Scale; CARS–M = Clinician-Administered Rating Scale for Mania; CGI–I = Clinical Global Impression–Improvement; HAM–D = Hamilton Rating Scale for Depression; ND = no difference; PANSS = Positive and Negative Symptom Scale; RCT = randomized controlled trial; RoB = risk of bias; SoE = strength of evidence; YMRS = Young Mania Rating Scale

Table 80 Characteristics of RCT comparing haloperidol versus ziprasidone in the treatment of bipolar disorder

Study, Design (Followup) | Interventions, Dosages; No. Randomized, Washout Period | Main Inclusion Criteria | Risk of Bias, Financial Support
Vieta et al. 2010^144^ RCT (12 wks) | G1: HAL (8–30mg/d); (78) G2: ZIP (80–160mg/d); (73) Washout period: 2–10 d | BP I disorder, most recent episode manic or mixed | High, Industry

BP = bipolar; D = days; G = group; HAL = haloperidol; Hr(s) = hour(s); Mg = milligrams; RCT = randomized controlled trial; Wk(s) = week(s); ZIP = ziprasidone

Table 81 Evidence summary table: haloperidol versus ziprasidone

Outcome or Subgroup | Studies | Participants | Effect Estimate | I^2^ | Favors
Mood (Mania)
YMRS144 | 1 | 350 | −5.52 (−7.79, −3.25) | NE | haloperidol
Other Outcomes
Remission rates144 | 1 | 350 | 1.42 (1.00, 2.02)^*^ | NE | ND
Response rates144 | 1 | 350 | 1.09 (1.02, 1.16)^*^ | NE | haloperidol

Note: bolded results are statistically significant;

* binary outcome;

I^2^ = I-squared; ND = no difference; NE = not estimable; YMRS = Young Mania Rating Scale

Table 82 Strength of evidence (GRADE): haloperidol versus ziprasidone

Outcome | Source | RoB | Consistency | Directness | Precision | SoE
Mood (Mania)
YMRS | 1 RCT | Medium | Unknown | Direct | Precise | Insufficient

RCT = randomized controlled trial; RoB = risk of bias; SoE = strength of evidence; YMRS = Young Mania Rating Scale

### Chlorpromazine Versus Clozapine

One RCT48 (n = 27) compared chlorpromazine (2–5 mg/d) with clozapine (25–175 mg/d) in patients with bipolar disorder and manic episodes (Table 66). No significant differences were found between groups for mood (mania) (YMRS scale) (Table 67). The SoE was insufficient due to the inclusion of only a single trial (Table 68). Other reported AEs were not different between groups (Appendix N, Tables 113 and 114).

### Haloperidol Versus Aripiprazole

Two RCTs32,33 (n = 679) compared haloperidol with aripiprazole. Key characteristics of the included trials and findings are summarized in Table 69 and Table 70. Both studies included only patients with bipolar I disorder and no comorbid drug or alcohol use. Young et al.33 only included patients with multiple episodes and no treatment resistance, whereas Vieta et al.32 had no restrictions regarding first versus multiple episodes or treatment resistance. Doses were the same for both studies: 10–15 mg/d haloperidol and 15–30 mg/d aripiprazole. Duration of followup was 12 weeks in both studies. Both trials had unclear risk of bias was and were industry-funded.

Publication bias was not formally tested for any of the outcomes due the small number of included trials. The SoE for the evaluated outcomes was low or insufficient due to the small number of included trials (Table 71).

#### Key Question 1 Improving Core Illness Symptoms

##### Mood: Mania

Two trials32,33 (n = 679) assessed global ratings and total scores based on the YMRS; however, there was moderate heterogeneity for the YMRS. The study characteristics are described above which may explain some of the heterogeneity observed in effect estimates. Nevertheless, none of the studies individually showed significant effects. The SoE was graded as low for YMRS (Table 71).

##### Mood: Depression

Pooled results from the two included trials32,33 (n = 679) showed no significant difference in total scores based on the MADRS (Table 70); however, statistical heterogeneity was substantial across studies. The SoE was graded as low (Table 71).

##### Positive and Negative Symptoms

Young et al.33 (n = 332) found no significant difference in positive symptoms based on the PANSS (positive) or negative symptoms on the PANSS (negative) (Table 70). The SoE was graded as insufficient for both scales (Table 71).

##### Global Ratings and Total Scores

Two trials32,33 (n = 679) assessed global ratings on the Clinical Global Impression–Bipolar (CGI–BP) version, with one study33 also assessing PANSS (total) (Table 70). No significant differences were found on either scale; however there was substantial heterogeneity for the CGI–BP. The study characteristics are described above which may explain some of the heterogeneity observed in effect estimates. Nevertheless, none of the studies individually showed significant effects. The SoE was graded as low for CGI–BP and insufficient for PANSS (total) (Table 71).

#### Key Questions 2 and 4 Improvement in Functional Outcomes, Decreasing Health Care System Utilization, and Other Outcomes

Other Outcomes. The two relevant trials32,33 reported no significant difference in response rates overall; however, statistical heterogeneity was substantial (Table 70). Vieta et al.32 had no restrictions regarding first versus multiple episodes or treatment resistance and showed a significant difference favoring haloperidol. In contrast, Young et al.33 only included patients with multiple episodes and no treatment resistance and showed no difference between groups.

Vieta et al.32 (n = 347) found a significant difference in relapse rates favoring haloperidol (Table 70). Young et al.33 (n = 332) found no significant difference in remission rates (Table 70).

#### Key Question 5 Subgroups

Neither study addressed the prespecified subgroups.

### Haloperidol Versus Olanzapine

Two trials119,140 (n = 463) compared haloperidol with olanzapine. Key trial characteristics and findings are summarized in Table 72 and Table 73. Moreno et al.119 included only patients with bipolar II disorder, whereas Tohen et al.140 included only patients with bipolar I disorder. Both studies included only patients with no comorbid drug or alcohol use and included mixed populations with respect to first versus multiple episodes and treatment resistance. Drug doses were consistent across studies: 3–15 mg/d haloperidol versus 5–20 mg/d olanzapine.

Moreno et al.119 and Tohen et al.140 followed patients for 6 and 12 weeks, respectively. Moreno et al.119 had unclear risk of bias and was supported through foundation funding; Tohen et al.140 had high risk of bias and was industry-funded.

Publication bias was not formally tested for any of the outcomes due the small number of included trials. The SoE for all the evaluated outcomes was insufficient due to the small number of included trials (Table 74).

#### Key Question 1 Improving Core Illness Symptoms

##### Mood: Mania

Both trials119,140 (n = 465) assessed total score using YMRS and found no differences between groups; results were statistically homogeneous across studies (Table 73). The SoE for YMRS was graded as low.

##### Mood: Depression

Tohen et al.140 (n = 453) found no significant differences based on HAM–D (Table 73). The SoE was graded as insufficient (Table 74).

##### Sleep

Moreno et al.119 (n = 12) found no significant differences in number of awakenings, sleep efficiency, stage rapid eye movement, total rapid eye movement, or total sleep time (Table 73). The SoE was graded as insufficient (Table 74).

##### Global Ratings and Total Scores

Moreno et al.119 (n = 12) assessed total score with CGI–BP and showed no difference between groups. The SoE for CGI–BP was graded as insufficient (Table 74).

#### Key Questions 2 and 4 Improvement in Functional Outcomes, Decreasing Health Care System Utilization, and Other Outcomes

##### Functional Outcomes

Tohen et al.140 (n = 453) examined patients with bipolar I and found a significant difference on the number of days worked for pay favoring olanzapine, but not for the Streamlined Longitudinal Interview Clinical Evaluation from the Longitudinal Interval Followup Evaluation household or work activities impairment scores (Table 73).

##### Other Outcomes

Tohen et al.140 (n = 453) reported on relapse, response, and remission rates; no significant difference was found between groups for any of the outcomes (Table 73). The same trial140 assessed health-related quality of life using the Short Form–36 (Table 73). Results showed a significant difference on the mental summary score favoring haloperidol and a significant difference on the physical summary score favoring olanzapine (Table 73).

#### Key Question 5 Subgroups

##### Disorder Subtype

Tohen et al.140 included only patients with bipolar I disorder and found no significant difference on HAM–D or YMRS.

Moreno et al.119 included only patients with bipolar II disorder and found no significant difference on number of awakenings, sleep efficiency, rapid eye movement, rapid eye movement activity, total sleep time (minutes), the CGI–BP, or the YMRS.

### Haloperidol Versus Quetiapine

One trial115 (n = 201) compared haloperidol (2–8 mg/d) with quetiapine (100–800 mg/d) in patients with bipolar disorder in a current manic episode with or without psychotic features (Table 75). This trial did not report core illness symptoms, or investigate subgroups (Table 76). No significant differences between groups were found for response rates or remission rates.

### Haloperidol Versus Risperidone

#### Key Points

- Four RCTs compared haloperidol with risperidone; three of the studies included both bipolar I and bipolar II patients, whereas one trial included only bipolar I disorder.
- The most commonly reported outcome was mood (mania) using the YMRS. Pooled results from three studies showed no differences between groups. The SoE was low.
- Other outcomes were assessed in single studies and no significant differences were reported.

Four trials90,128,133,138 involving 463 adults with bipolar disorder compared haloperidol with risperidone. Key characteristics of the included trials and summary findings are presented in Table 77 and Table 78. Three studies included mixed bipolar I and bipolar II disorder, whereas one study138 included only patients with bipolar I disorder. All studies restricted inclusion to patients with no comorbid drug or alcohol use. Two studies128,138 only included patients with multiple episodes; two studies90,133 included both patients with first and multiple episodes. One study138 specifically excluded patients with treatment resistance. Dosages for haloperidol ranged from 4–20 mg/d and for risperidone ranged from 2–10 mg/d.

Duration of followup was ≤6 weeks in three studies90,128,133 and 12 weeks in the fourth.138 Risk of bias was high for two studies90,128 and unclear for two studies.133,138 All studies were funded by industry.

Publication bias was not formally tested for any of the outcomes due the small number of included trials. The SoE for all the evaluated outcomes was insufficient or low due to the small number of included trials (Table 79).

#### Key Question 1 Improving Core Illness Symptoms

##### Mood: Mania

All four trials90,128,133,138 presented results for mood (mania) using two scales. One trial90 (n = 62) assessed mania symptoms using the Clinician-Administered Rating Scale for Mania; no differences between groups were found. The study compared 4–20 mg/d haloperidol with 2–10 mg/d risperidone. The trial included mixed populations with respect to type of bipolar disorder (I and II), first and previous episodes, and treatment resistance. Patients with comorbid drug or alcohol use were excluded. Duration of followup was 6 weeks. Risk of bias was high, and the trial was industry-funded.

Three trials128,133,138 (n = 433) showed no differences based on the YMRS; the pooled results showed no statistical heterogeneity. Two of the studies included patients with both bipolar I and II disorders, whereas the third study138 included only bipolar I disorder. Two studies128,138 included only patients with multiple episodes. One study138 included patients with no treatment resistance. None of the studies included patients with comorbid drug or alcohol use. Dose ranged from 4–20mg/d for haloperidol and 2–6mg/d for risperidone. Duration of followup ranged from 3 weeks128 to 12 weeks.138 Risk of bias was high in one study128 and unclear in two studies;133,138 all studies were industry-funded.

##### Mood: Depression

One trial90 as above assessed depressive symptoms using the HAM–D; no differences between groups were found.

##### Positive and Negative Symptoms

One trial90 described above assessed positive and negative symptoms. No significant difference was found using the PANSS.

##### Global Ratings and Total Scores

Two trials90,133 presented results for global ratings and total symptom scores using two scales. One trial133 (n = 30) comparing 10 mg/d haloperidol with 6 mg/d risperidone reported BPRS and found no difference between groups. The study included patients with both bipolar I and II disorders and excluded patients with comorbid alcohol or drug use. The study population was mixed with respect to first and previous episodes as well as treatment resistance. Duration of followup was 12 weeks. Risk of bias was unclear, and the trial was industry-funded.

One trial90 comparing 4–20 mg/d haloperidol with 2–10 mg/d risperidone found no differences on the CGI–I or PANSS (total) scale. This trial included mixed populations with respect to type of bipolar disorder (I and II), first and previous episodes, and treatment resistance. The trial excluded patients with comorbid drug or alcohol use. Duration of followup was 6 weeks. Risk of bias was high, and the trial was industry-funded.

#### Key Questions 2 and 4 Improvement in Functional Outcomes, Decreasing Health Care System Utilization, and Other Outcomes

##### Other Outcomes

One trial90 comparing 4–20 mg/d haloperidol with 2–10 mg/d risperidone assessed response rates and and found no difference between groups. This trial included mixed populations with respect to type of disorder (bipolar I and II), first and previous episodes, and treatment resistance. Patients with comorbid drug or alcohol use were excluded. Duration of followup was 6 weeks. Risk of bias was high, and the trial was industry-funded.

#### Key Question 5 Subgroups

Disorder Subtype. One trial138 in 298 patients with bipolar disorder with acute mania compared haloperidol (4–12 mg/d) with risperidone (2–6 mg/d) and found no significant difference on the YMRS.

### Haloperidol Versus Ziprasidone

One trial144 (n = 350) compared haloperidol (8–30 mg/d) with ziprasidone (80–160 mg/d) in patients with bipolar I disorder and mixed or manic subtypes (Table 80). A significant difference favoring haloperidol was found for the improvement of core illness symptoms, response rates, and for subgroup analysis of disorder subtype (Table 81). The SoE for all the evaluated outcomes was insufficient due to the inclusion of only a single trial (Table 82). No difference between groups was found for remission rates.

## Adverse Events (Key Question 3)

This section reviews the evidence on the comparative harms of individual FGAs and SGAs. The results are organized in alphabetical order by drug comparison (Appendix N). For each comparison, we report data on general and specific AEs. We categorized the outcomes by systems. As detailed in the methods section, we extracted only binary data for AEs (i.e., the number of patients who experienced a given event in each group), not continuous data (e.g., mean change in laboratory values). In addition, we counted each event as if it corresponded to a unique individual. Because an individual patient may have experienced more than one event during the course of the study, this assumption may have overestimated the number of patients that experienced an AE.

A priori, we identified four AEs to be the most clinically important: diabetes mellitus, tardive dyskinesia, metabolic syndrome, and mortality. Table 83 summarizes the results of studies that provided data for these AEs and the SoE for each comparison. For metabolic syndrome, two RCTs comparing haloperidol with olanzapine found no difference in incidence of metabolic syndrome (low SoE). For mortality, two RCTs comparing chlorpromazine with clozapine and two RCTs comparing haloperidol with aripiprazole showed no difference between the groups (low SoE), although the length of followup of the trials for the latter comparison was only 24 hours. The evidence was insufficient to allow conclusions for the remaining comparisons, primarily because only single studies provided data. The only significant differences in the remaining comparisons showed less incidence with the SGAs with the exception of a higher incidence of patients developing metabolic syndrome with clozapine compared with haloperidol.

Table 83 Summary of the strength of evidence for AEs

Comparison (Number of Studies) | RR (95% CI) | Summary | SoE
Diabetes Mellitus
Haloperidol vs. olanzapine (1 RCT) | 0.85 (0.21 to 3.49) | No significant difference. | Insufficient
Perphenazine vs. olanzapine (1 RCT) | 0.81 (0.45 to 1.45) | No significant difference. | Insufficient
Perphenazine vs. quetiapine (1 RCT) | 1.57 (0.79 to 3.12) | No significant difference. | Insufficient
Perphenazine vs. risperidone (1 RCT) | 1.06 (0.57 to 1.96) | No significant difference. | Insufficient
Perphenazine vs. ziprasidone (1 RCT) | 1.00 (0.49 to 2.05) | No significant difference. | Insufficient
Tardive Dyskinesia
Chlorpromazine vs. clozapine (1 RCT) | 3.30 (0.14 to 76.46) | No significant difference. | Insufficient
Chlorpromazine vs. ziprasidone (1 RCT) | 1.21 (0.61 to 2.44) | No significant difference. | Insufficient
Haloperidol vs. clozapine (1 cohort) | 34.50 (2.07 to 573.55) | Significant difference, with more events for haloperidol. | Insufficient
Haloperidol vs. olanzapine (1 RCT) | 11.75 (0.65 to 211.26) | No significant difference. | Insufficient
Haloperidol vs. quetiapine (1 RCT) | NE | Zero events in both groups. | Insufficient
Haloperidol vs. ziprasidone (1 RCT) | 4.84 (0.23 to 99.93) | No significant difference. | Insufficient
Metabolic Syndrome
Haloperidol vs. clozapine (1 RCT) | 0.27 (0.10 to 0.75) | Significant difference, with more events for clozapine. | Insufficient
Haloperidol vs. olanzapine (2 RCTs) | 0.38 (0.06 to 2.51) | No significant difference. | Low
Perphenazine vs. olanzapine (1 RCT) | 0.88 (0.63 to 1.21) | No significant difference. | Insufficient
Perphenazine vs. quetiapine (1 RCT) | 1.19 (0.84 to 1.70) | No significant difference. | Insufficient
Perphenazine vs. risperidone (1 RCT) | 1.42 (0.98 to 2.06) | No significant difference. | Insufficient
Perphenazine vs. ziprasidone (1 RCT) | 1.51 (0.96 to 2.39) | No significant difference. | Insufficient
Mortality
Chlorpromazine vs. clozapine (2 RCTs) | 0.98 (0.10 to 9.19) | No significant difference. | Low
Chlorpromazine vs. clozapine (1 Cohort) | 1.98 (1.30 to 3.00) | Significant difference, with more events for chlorpromazine. | Insufficient
Chlorpromazine vs. ziprasidone (1 RCT) | NE | Zero events in both groups. | Insufficient
Haloperidol vs. aripiprazole (2 RCT) | 0.77 (0.04 to 15.91) | No significant difference. | Low
Haloperidol vs. risperidone (1 Cohort) | 1.70 (1.31 to 2.20) | Significant difference, with more events for haloperidol. | Insufficient
Thioridazine vs. clozapine (1 Cohort) | 2.12 (1.38 to 3.26) | Significant difference, with more events for thioridazine. | Insufficient
Thioridazine vs. risperidone (1 Cohort) | 1.82 (1.37 to 2.40) | Significant difference, with more events for thioridazine. | Insufficient

CI = confidence interval; NE = not estimable; RCT = randomized controlled trial; RR = relative risk; SoE = strength of evidence

### Chlorpromazine Versus Clozapine

Twelve trials48,63,87,94,109,152–154,156,158,160,161 reported on the incidence of AEs in patients receiving chlorpromazine compared with patients receiving clozapine (Table 84).

Table 84 Evidence summary table: chlorpromazine versus clozapine – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Cardiovascular
Hypertension94,160 | 2 | 312 | 0.39 (0.17, 0.90) | 0% | chlorpromazine
Cholinergic and Anticholinergic
Dry mouth63,87,94,152,161 | 5 | 563 | 3.00 (1.67, 5.40) | 11% | clozapine
Hypersalivation48,63,87,94,152,154,158,160,161 | 9 | 674 | 0.25 (0.14, 0.45) | 13% | chlorpromazine
CNS
Drowsiness94,152,153,160,161 | 5 | 457 | 0.75 (0.58, 0.97) | 0% | chlorpromazine
EPS
EPS48,63,87,109,158,160 | 6 | 451 | 2.75 (1.48, 5.12) | 0% | clozapine
Systemic AE
Fever or chills94,160 | 2 | 312 | 0.35 (0.15, 0.83) | 0% | chlorpromazine

AE = adverse event; CNS = central nervous system; EPS = extrapyramidal symptoms or syndrome; I^2^ = I–squared; KQ = Key Question

#### General Measures

The rates of mortality (2 trials)109,156 and withdrawals due to AEs (5 trials)63,87,109,152,160 were not different between groups.

#### Specific Measures

##### Behavior and Psychosis

No differences were found in single trials reporting the incidence of agitation,153 depression,152 and increasing paranoia and excitement.154

##### Body Mass Index (BMI) and Weight

A single trial87 reported no differences in incidence of weight gain (>5 percent) and weight loss.

##### Cardiovascular

Hypertension occurred less frequently with chlorpromazine (2 trials).94,160 No difference between groups was found for abnormal electrocardiogram (ECG) (2 trials),154,160 cardiotoxic effects (1 trial),153 hypotension (5 trials),48,87,94,109,160 orthostatic hypotension (3 trials),153,158,160 and tachycardia (2 trials).87,94

##### Cholinergic and Anticholinergic

Dry mouth was reported less frequently with clozapine (5 trials),63,87,94,152,161 whereas hypersalivation was reported less frequently with chlorpromazine (9 trials).48,63,87,94,152,154,158,160,161 There was no difference in the incidence of ileus in one trial.109

##### Central Nervous System (CNS)

Drowsiness was less frequent with chlorpromazine (5 trials).94,152,153,160,161 Dizziness (3 trials),94,160,161 sedation (3 trials),48,63,87 seizure (3 trials),63,87,153 and slurred speech (1 trial)160 did not differ between groups.

##### Dermatology

There was no difference between groups in the incidence of dermatologic reactions (3 trials).87,109,153

##### Endocrine (Prolactin and Thyroid)

One trial reported no difference in the incidence hyperprolactinemia.63

##### Extrapyramidal Symptoms or Syndrome (EPS)

EPS were less frequent with clozapine (6 trials).48,63,87,109,158,160 There was no difference in the incidence of the following AEs: akathisia (3 trials),63,87,154 dystonia (2 trials),63,154 oculogyric crisis (1 trial),154 parkinsonism (2 trials),153,154 rigidity (3 trials),63,152,160 staggering (1 trial),160 deterioration of tardive dyskinesia (1 trial),87 and tremor (3 trials).152,160,161

##### Genitourinary

In a single trial63 there was no difference in the incidence of impotence.

##### Gastrointestinal

No differences were found in the incidence of abdominal cramps (1 trial),160 constipation (4 trials),63,94,109,152 diarrhea (1 trial),160 heartburn (1 trial),160 and nausea or vomiting (3 trials).87,94,160

##### Hematology

No differences were found in the incidence of agranulocytosis (2 trials),63,94 abnormal blood cell count (1 trial),154 neutropenia (1 trial),109 elevated platelet count (1 trial),154 and leukocytopenia (4 trials).48,63,87,94

##### Hepatobiliary

No differences in the incidence of elevated hepatic enzymes (2 trials)87,94 or jaundice (1 trial)87 were reported.

##### Sleep

No differences in the incidence of deep sleep or sleep disturbances were reported in a single trial.153

##### Respiratory and Airway

No difference in the incidence of coughing was reported in one trial.160

##### Systemic AEs

Fever or chills were reported less frequently with chlorpromazine (2 trials).94,160 There were no differences between groups in the incidence of accidental falls (1 trial),87 headaches (2 trials),94,160 hyperthermia (3 trials),109,154,160 and tension (1 trial).160

### Chlorpromazine Versus Olanzapine

A single trial66 reported on the incidence of AEs in patients receiving chlorpromazine compared with patients receiving olanzapine (Table 85). The incidence of orthostatic hypotension, dry mouth, unsteady gait, and constipation was less frequent with olanzapine. Other reported AEs were not different between groups (Appendix N, Tables 115 and 116).

Table 85 Evidence summary table: chlorpromazine versus olanzapine – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Cardiovascular
Orthostatic hypotension66 | 1 | 84 | 7.50 (2.90, 19.42) | NE | olanzapine
Cholinergic and Anticholinergic
Dry mouth66 | 1 | 84 | 1.94 (1.27, 2.97) | NE | olanzapine
CNS
Unsteady gait66 | 1 | 84 | 15.00 (2.07, 108.48) | NE | olanzapine
GI
Constipation66 | 1 | 84 | 2.60 (1.02, 6.65) | NE | olanzapine

AE = adverse event; CNS = Central Nervous System; GI = gastrointestinal; I^2^ = I-squared; KQ = Key Question; NE = not estimable

### Chlorpromazine Versus Quetiapine

A single trial121 reported on the incidence of AEs in patients receiving chlorpromazine compared with patients receiving quetiapine (Table 86). The incidence of orthostatic hypotension was less frequent with quetiapine. Other reported AEs did not differ between groups (Appendix N, Tables 117 and 118).

Table 86 Evidence summary table: chlorpromazine versus quetiapine – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Cardiovascular
Orthostatic hypotension121 | 1 | 201 | 3.64 (1.40, 9.42) | NE | quetiapine

AE = adverse event; I^2^ = I-squared; KQ = Key Question; NE = not estimable

### Chlorpromazine Versus Ziprasidone

A single trial96 reported on the incidence of AEs in patients receiving chlorpromazine compared with patients receiving ziprasidone (Table 87). The incidence of orthostatic hypotension was less frequent with chlorpromazine. Other reported AEs did not differ between groups (Appendix N, Tables 119 and 120).

Table 87 Evidence summary table: chlorpromazine versus ziprasidone – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
BMI and Weight
Weight loss96 | 1 | 306 | 0.19 (0.06, 0.62) | NE | chlorpromazine

AE = adverse event; I^2^ = I-squared; KQ = Key Question; NE = not estimable

### Fluphenazine Versus Olanzapine

A single trial89 comparing the incidence of AEs in patients receiving fluphenazine compared with patients receiving olanzapine showed no difference between groups (Appendix N, Tables 121 and 122).

### Fluphenazine Versus Quetiapine

A single trial67 reported on the incidence of AEs in patients receiving fluphenazine compared with patients receiving quetiapine; no difference in reported AEs or persistence and reversibility of AEs were found (Appendix N, Tables 123, 124, and 125).

### Fluphenazine Versus Risperidone

A single trial67 reported on the incidence of AEs in patients receiving fluphenazine compared with patients receiving quetiapine; no difference in reported AEs or persistence and reversibility of AEs were found (Appendix N, Tables 126, 127, and 128).

### Haloperidol Versus Aripiprazole

Nine trials31–33,44,73,74,76,92,98 reported on the incidence of AEs in patients receiving haloperidol compared with patients receiving aripiprazole (Table 88). The statistically significant findings are presented in Table 89. Other reported AEs did not differ between groups (Appendix N, Tables 129 and 130).

Table 88 Evidence summary table: haloperidol versus aripiprazole – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Incidence of patients with AEs31,73,98 | 3 | 1713 | 1.11 (1.06, 1.17) | 0% | aripiprazole
Withdrawals due to AEs31–33,44,76,92,98 | 7 | 3035 | 1.25 (1.06, 1.47) | 0% | aripiprazole

AE = adverse events; CI = confidence intervals; I^2^ = I–squared

Table 89 Evidence summary table: haloperidol versus aripiprazole – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Behavior and Psychosis
Mania33 | 1 | 332 | 0.20 (0.05, 0.91) | NE | haloperidol
CNS
Dizziness31,44,92 | 3 | 963 | 0.53 (0.31, 0.90) | 0% | haloperidol
Somnolence31,33,44,74,92,98 | 6 | 2893 | 1.39 (1.03, 1.87) | 0% | aripiprazole
Endocrine (Prolactin and Thyroid)
Hyperprolactinemia32,33 | 2 | 679 | 3.67 (2.16, 6.24) | 70% | aripiprazole
EPS
Akathisia31–33,74,76,92,98 | 7 | 2979 | 2.04 (1.70, 2.44) | 0% | aripiprazole
Dystonia31 | 1 | 295 | 7.83 (1.47, 41.76) | NE | aripiprazole
EPS32,33,44,74,92,98 | 6 | 2945 | 2.22 (1.37, 3.59) | 83% | aripiprazole
Rigidity33 | 1 | 332 | 8.10 (1.89, 34.66) | NE | aripiprazole
Tremor32,33,76,92,98 | 5 | 2380 | 1.99 (1.42, 2.78) | 4% | aripiprazole
GI
Dyspepsia74 | 1 | 304 | 9.12 (1.17, 71.10) | NE | aripiprazole
Nausea or vomiting31,44,74,92 | 4 | 1267 | 0.49 (0.28, 0.85) | 0% | haloperidol
Ophthalmology
Blurred vision92 | 1 | 308 | 5.23 (1.42, 19.30) | NE | aripiprazole

AE = adverse events; CNS = central nervous system; EPS = extrapyramidal symptoms or syndrome; GI = gastrointestinal; I^2^ = I-squared; KQ = Key Question; NE = not estimable

#### General Measures

The incidence of patients with AEs (3 trials)31,73,98 and withdrawals due to AEs (7 trials)31–33,44,76,92,98 were less frequent with aripiprazole. Rates of mortality (2 trials)31,44 and serious adverse events (SAEs) (6 trials)31–33,44,76,92 were not different between groups.

#### Specific Measures

##### Behavior and Psychosis

The incidence of mania in a single trial33 was less frequent with haloperidol. No differences between groups were found for agitation (4 trials),31,44,74,98 anxiety (4 trials),33,74,92,98 depression (2 trials),32,33 clinical deterioration (1 trial),73 and psychosis (1 trial).98

##### BMI and Weight

No difference between groups was found for weight gain (3 trials).33,92,98

##### Cardiovascular

The incidence of ECG abnormalities (3 trials),31,32,92 orthostatic hypotension (1 trial),92 and tachycardia (1 trial)31 were not different between groups.

##### CNS

Dizziness (3 trials)31,44,92 was less frequent with haloperidol, and somnolence (6 trials)31,33,44,74,92,98 was less frequent with aripiprazole. No difference was reported for the incidence of seizures in a single trial.31

##### Dermatology

Two trials found no difference between groups in injection site reactions.31,44

##### Endocrine (Prolactin and Thyroid)

Hyperprolactinemia (2 trials)32,33 was less frequent with aripiprazole.

##### EPS

Akathisia (7 trials),31–33,74,76,92,98 dystonia (1 trial),31 EPS (6 trials),32,33,44,74,92,98 rigidity (1 trial),33 and tremor (5 trials)32,33,76,92,98 were less frequent with aripiprazole. No difference was found between groups for asthenia (1 trial)92 and hypertonia (1 trial).92

##### Gastrointestinal

Dyspepsia (1 trial)74 was less frequent with aripiprazole; nausea or vomiting (4 trials)31,44,74,92 was less frequent with haloperidol. There was no difference between groups in the incidence of abdominal pain (1 trial)92 and diarrhea (1 trial).74

##### Hepatobiliary

A single trial found no difference in the incidence of liver damage.32

##### Ophthalmology

A single trial found the incidence of blurred vision less frequent with aripiprazole.92

##### Sleep

There was no difference between groups in the incidence of insomnia (7 trials).32,33,44,74,76,92,98

##### Systemic AEs

There was no difference in the incidence of headache (7 trials).31–33,44,74,92,98

### Haloperidol Versus Asenapine

A single trial67 reported on the incidence of AEs in patients receiving haloperidol compared with patients receiving asenapine. Oral hypoesthesia and somnolence were less frequent with haloperidol. Hyperprolactinemia, dystonia, and EPS were less frequent with asenapine (Table 90). There were no differences in the other reported AEs (Appendix N, Tables 131 and 132).

Table 90 Evidence summary table: haloperidol versus asenapine – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
CNS
Oral hypoesthesia97 | 1 | 335 | 0.04 (0.00, 0.69) | NE | haloperidol
Somnolence97 | 1 | 335 | 0.21 (0.05, 0.90) | NE | haloperidol
Endocrine (Prolactin and Thyroid)
Hyperprolactinemia97 | 1 | 335 | 2.30 (1.02, 5.15) | NE | asenapine
EPS
Dystonia97 | 1 | 335 | 3.51 (1.33, 9.24) | NE | asenapine
EPS97 | 1 | 335 | 2.07 (1.40, 3.07) | NE | asenapine

AE = adverse event; CNS = central nervous system; EPS = extrapyramidal symptoms or syndrome; I^2^ = I-squared; KQ = Key Question; NE = not estimable

### Haloperidol Versus Clozapine

Six trials55,95,105,126,145,155 and two cohort studies162,163 reported on the incidence of AEs in patients receiving haloperidol compared with patients receiving clozapine (Table 91). The statistically significant findings are presented in Table 92. Other reported AEs did not differ between groups (Appendix N, Tables 133 and 134).

Table 91 Evidence summary table: haloperidol versus clozapine – general AEs (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Mortality (Cohort)163 | 1 | 49625 | 1.98 (1.30, 3.00) | NE | clozapine

AE = adverse events; I^2^ = I–squared; KQ = Key Question; NE = not estimable

Table 92 Evidence summary table: haloperidol versus clozapine – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Behavior and Psychosis
Irritability155 | 1 | 88 | 3.21 (1.26, 8.15) | NE | clozapine
Overt aggression145 | 1 | 77 | 1.66 (1.03, 2.66) | NE | clozapine
Cholinergic and Anticholinergic
Dry mouth55,155 | 2 | 163 | 2.81 (1.61, 4.92) | 0% | clozapine
Hypersalivation55 | 1 | 75 | 0.23 (0.12, 0.46) | NE | haloperidol
EPS
Hyperkinesia155 | 1 | 88 | 2.01 (1.13, 3.56) | NE | clozapine
Tardive Dyskinesia (Cohort)162 | 1 | 333 | 34.50 (2.07, 573.55) | NE | clozapine
GI
Nausea or vomiting55,155 | 2 | 163 | 0.44 (0.21, 0.93) | 17% | haloperidol
Metabolic
Abnormal Glucose levels105 | 1 | 73 | 0.05 (0.00, 0.80) | NE | haloperidol
Metabolic syndrome (emergent)105 | 1 | 73 | 0.27 (0.10, 0.75) | NE | haloperidol
Sleep
Insomnia155 | 1 | 88 | 3.44 (1.51, 7.84) | NE | clozapine

AE = adverse event; EPS = extrapyramidal symptoms or syndrome; GI = gastrointestinal; I^2^ = I-squared; KQ = Key Question; NE = not estimable

#### General Measures

A single cohort study found less incidence of mortality with clozapine.163 The incidence of patients with AEs (1 trial)126 and withdrawals due to AEs (5 trials),55,95,105,126,145 was not different between groups.

#### Specific Measures

##### Behavior and Psychosis

Single trials reported less frequent incidence of irritability155 and overt aggression145 with clozapine. One trial found no difference between groups in clinical deterioration conducive to termination.145

##### BMI and Weight

No difference between groups was reported for weight gain (2 trials).105,145

##### Cardiovascular

Single trials found no differences in incidence of hypertension,55 hypertensive episodes,145 intrathoracic oppression,155 orthostatic hypotension,155 and palpitation.155

##### Cholinergic and Anticholinergic

Dry mouth (2 trials)55,155 was less frequent with clozapine. Hypersalivation (1 trial)55 was less frequent with haloperidol.

##### CNS

No differences between groups were found for the incidence of CNS abnormalities, including dizziness (2 trials),55,155 drowsiness (1 trial),155 dysarthria (1 trial),155 sedation (1 trial),55 seizures (1 trial),145 and seizures conducive to termination (1 trial).145

##### Dermatology

Single trials reported no difference in the incidence of pruritus155 and rash.155

##### Endocrine (Prolactin and Thyroid)

A single trial155 reported no difference in the incidence of abnormal menstruation.

##### EPS

A single trial155 found less frequent incidence of hyperkinesia with clozapine and no difference between groups in the incidence of hypertonia. One cohort study162 reported less frequent incidence of tardive dyskinesia with clozapine.

##### Gastrointestinal

The incidence of nausea or vomiting (2 trials)55,155 was less frequent with haloperidol. There was no difference in the incidence of constipation (2 trials),55,155 diarrhea (2 trials),55,155 loss of appetite (1 trial),155 and other gastrointestinal abnormalities (1 trial).155

##### Genital, Urinary, and Breast

A single trial55 reported no difference in the incidence of enuresis.

##### Hematology

There were no differences between groups in the incidence of agranulocytosis (2 trials),126,145 bruising (1 trial),55 hematological problems conducive to termination (1 trial),145 leukopenia (1 trial),126 and neutropenia (2 trials).126,145

##### Metabolic

A single trial105 reported less frequent incidence of abnormal glucose levels and emergent metabolic syndrome with haloperidol. The trial found no difference in hypercholesterolemia and hypertriglyceridemia.

##### Ophthalmology

A single trial155 reported no difference in ophthalmic disturbances.

##### Respiratory and Airway

Two trials55,155 reported no difference in upper respiratory disturbances.

##### Sleep

A single trial155 reported less frequent incidence of insomnia with clozapine.

##### Systemic AEs

The incidence of the following AEs was not different between groups: headache (1 trial),155 fever (2 trials),55,155 intercurrent illnesses conducive to termination (1 trial),145 malaise (1 trial),55 sweating (1 trial),155 and weakness (1 trial).155

### Haloperidol Versus Olanzapine

Twenty-seven trials43,49–51,54,56,71,73,78,84,88,91,101,104–106,108,110,124,127,129,140–142,145,147,159 and two cohort studies162,163 reported on the incidence of AEs in patients receiving haloperidol compared with patients receiving olanzapine (Table 93). The statistically significant findings are presented in Table 94. Other reported AEs did not differ between groups (Appendix N, Tables 135 and 136).

Table 93 Evidence summary table: haloperidol versus olanzapine – general measures with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Withdrawals due to adverse events43,49,50,54,71,78,84,88,91,101,104,105,108,110,124,127,140,141,145,147,159 | 21 | 5351 | 1.87 (1.55, 2.27) | 0% | olanzapine

I^2^ = I-squared; KQ = Key Question

Table 94 Evidence summary table: haloperidol versus olanzapine – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Behavior and Psychosis
Anorexia88 | 1 | 182 | 3.66 (1.25, 10.69) | NE | olanzapine
Appetite (decreased)141 | 1 | 1996 | 1.56 (1.25, 1.96) | NE | olanzapine
Appetite (excessive) 141 | 1 | 1996 | 0.51 (0.41, 0.64) | NE | haloperidol
Conversion symptoms141 | 1 | 1996 | 2.34 (1.12, 4.88) | NE | olanzapine
BMI and Weight
Overweight or obese91,129 | 2 | 274 | 0.35 (0.21, 0.58) | 0% | haloperidol
Weight gain49,71,88,91,101,104,105,108,127,129,140–142,145,159 | 15 | 4600 | 0.47 (0.37, 0.61) | 75% | haloperidol
Cardiovascular
Palpitations141 | 1 | 1996 | 1.48 (1.09, 2.02) | NE | olanzapine
Cholinergic and Anticholinergic
Dry mouth49,71,101,141,159 | 5 | 2657 | 0.75 (0.62, 0.91) | 0% | haloperidol
Hypersalivation50,71,88,140,141,159 | 6 | 3200 | 3.38 (1.79, 6.38) | 49% | olanzapine
CNS
Drowsiness141 | 1 | 1996 | 1.19 (1.02, 1.38) | NE | olanzapine
Gait abnormalities88 | 1 | 182 | 8.36 (1.98, 35.32) | NE | olanzapine
Heaviness in extremities141 | 1 | 1996 | 1.40 (1.11, 1.77) | NE | olanzapine
Hypokinesia71,140,141,159 | 4 | 2587 | 3.01 (1.88, 4.82) | 7% | olanzapine
Hypotonia141 | 1 | 1996 | 1.68 (1.03, 2.72) | NE | olanzapine
Endocrine (Prolactin and Thyroid)
Hot flashes141 | 1 | 1996 | 1.62 (1.06, 2.49) | NE | olanzapine
EPS
Akathisia49–51,56,71,88,91,101,104,108,127,140,141,159 | 14 | 5031 | 3.11 (2.43, 3.98) | 38% | olanzapine
Ataxia141 | 1 | 1996 | 1.84 (1.01, 3.35) | NE | olanzapine
Bradykinesia88 | 1 | 182 | 8.36 (1.98, 35.32) | NE | olanzapine
Dyskinesia50,91,140,141 | 4 | 3088 | 3.55 (2.01, 6.27) | 10% | olanzapine
Dystonia49,50,56,91,104,140,147,159 | 8 | 2144 | 5.01 (2.70, 9.28) | 0% | olanzapine
EPS50,104,106,140,141,147 | 6 | 3445 | 3.88 (2.19, 6.85) | 69% | olanzapine
Hypertonia49,50,140,141 | 4 | 3147 | 2.54 (1.65, 3.91) | 55% | olanzapine
Parkinsonism51,56,71,84,88,91,108,147 | 8 | 1283 | 4.28 (2.49, 7.35) | 50% | olanzapine
Rigidity71,159 | 2 | 138 | 10.65 (2.08, 54.50) | 0% | olanzapine
Tremor49,50,71,88,101,104,140,141,159 | 9 | 3999 | 2.30 (1.59, 3.34) | 58% | olanzapine
Genital, Urinary, and Breast
Difficult micturition141 | 1 | 1996 | 1.68 (1.11, 2.54) | NE | olanzapine
GI
Nausea or vomiting49,88,101,141,141 | 5 | 4697 | 1.43 (1.06, 1.92) | 34% | olanzapine
Hepatobiliary
SGOT abnormality108 | 1 | 263 | 0.41 (0.28, 0.58) | NE | haloperidol
SGPT abnormality49,108 | 2 | 530 | 0.46 (0.35, 0.62) | 0% | haloperidol
Metabolic
Hypercholesterolemia91,105 | 2 | 281 | 0.43 (0.26, 0.72) | 0% | haloperidol
Hyperglycemia91,105 | 2 | 281 | 0.28 (0.12, 0.66) | 0% | haloperidol
Hypertriglyceridemia91,105 | 2 | 281 | 0.53 (0.30, 0.92) | 0% | haloperidol
HDL (low)91 | 1 | 208 | 0.38 (0.16, 0.94) | NE | haloperidol
Ophthalmology
Blurred vision141 | 1 | 1996 | 1.40 (1.10, 1.78) | NE | olanzapine
Sleep
Early awakening141 | 1 | 1996 | 1.49 (1.24, 1.79) | NE | olanzapine
Increased dreams/nightmares141 | 1 | 1996 | 1.31 (1.05, 1.63) | NE | olanzapine
Insomnia49,50,88,101,104,127,141 | 7 | 3717 | 1.36 (1.03, 1.80) | 49% | olanzapine
Systemic AE
Chills141 | 1 | 1996 | 1.74 (1.19, 2.52) | NE | olanzapine
Fever140 | 1 | 453 | 0.05 (0.00, 0.86) | NE | haloperidol
Infection140 | 1 | 453 | 0.27 (0.08, 0.93) | NE | haloperidol
Increased perspiration141 | 1 | 1996 | 1.91 (1.44, 2.54) | NE | olanzapine

AE = adverse event; BMI = body mass index; CNS = central nervous system; EPS = extrapyramidal symptoms or syndrome; GI = gastrointestinal; HDL = high-density lipoprotein; I^2^ = I-squared; KQ = Key Question; NE = not estimable; SGOT = serum glutamic oxaloacetic transaminase; SGPT = serum glutamic pyruvic transaminase

#### General Measures

The incidence of withdrawals due to AEs (21 trials)43,49,50,54,71,78,84,88,91,101,104,105,108,110,124,127,140,141,145,147,159 was reported less frequently with olanzapine. There was some suggestion of publication bias based on Egger’s test (p = 0.02) and some funnel plot asymmetry (Appendix K, Funnel plot 13). No difference was found for patients with AEs (1 trial),73 persistence and reversibility of AE (1 trial),88 and SAEs (3 trials).91,104,147

#### Specific Measures

##### Behavior and Psychosis

In single trials, the incidence of anorexia,88 decreased appetite,141 and conversion symptoms141 were less frequent with olanzapine, whereas the incidence of excessive appetite (1 trial)141 was less frequent with haloperidol. Other behavioral and psychotic-related AEs were not different between groups: abnormal thinking (1 trial),101 accommodation disturbance (1 trial),159 agitation (2 trials),49,101 anxiety (4 trials),49,88,101,147 behavioral deterioration (2 trials),73,84 depression (1 trial),101 excitement (1 trial),88 hallucinations (2 trials),84,101 nervousness (2 trials),49,101 overt aggression or violent behavior (3 trials),49,110,145 paranoia (1 trial),101 personality disorder (1 trial),49 suicidal ideation (1 trial),110 and suicide (1 trial),88 suicide attempt (1 trial).88

##### BMI and Weight

The incidence of patients categorized as overweight or obese (2 trials)91,129 and weight gain (15 trials)49,71,88,91,101,104,105,108,127,129,140–142,145,159 was less frequent with haloperidol. There was no difference between groups in patients with weight loss (2 trials).88,141

##### Cardiovascular

A single trial found fewer palpitations with olanzapine.141 No difference between groups was found for ECG abnormalities (2 trials),56,91 hypertensive episodes (1 trial),145 and hypotension (1 trial).56

##### Cholinergic and Anticholinergic

AEs. The incidence of dry mouth (5 trials)49,71,101,141,159 was less frequent with haloperidol. The incidence of hypersalivation (6 trials)50,71,88,140,141,159 was less frequent with olanzapine.

##### CNS

The incidence of drowsiness (1 trial),141 gait abnormalities (1 trial),88 heaviness in the extremities (1 trial),141 hypokinesia (4 trials),71,140,141,159 and hypotonia (1 trial)141 was less frequent with olanzapine. There were no differences between groups for asthenia (3 trials),49,71,159 concentration difficulty (1 trial),71 dizziness (3 trials),49,101,140 seizures (1 trial),145 and somnolence (6 trials).49,71,88,101,140,159

##### Dermatology

A single trial147 reported no difference in the incidence of maculopapular rash.

##### Endocrine (Prolactin and Thyroid)

In a single trial,141 the incidence of hot flashes was less frequent with olanzapine. There was no difference in the incidence of amenorrhea (1 trial).71 The pooled results for hyperprolactinemia (3 trials)50,91,108 were not reported because there was marked heterogeneity between the trials (I^2^ = 97 percent).

##### EPS

The incidence of the following EPS-related AEs were less frequent with olanzapine: akathisia (14 trials),49–51,56,71,88,91,101,104,108,127,140,141,159 ataxia (1 trial),141 bradykinesia (1 trial),88 dyskinesia (4 trials),50,91,140,141 dystonia (8 trials),49,50,56,91,104,140,147,159 EPS (6 trials),50,104,106,140,141,147 hypertonia (4 trials),49,50,140,141 parkinsonism (8 trials),51,56,71,84,88,91,108,147 rigidity (2 trials),71,159 and tremor (9 trials).49,50,71,88,101,104,140,141,159 Single trials found no difference in the incidence of neuroleptic malignant syndrome147 and tardive dyskinesia.140

##### Gastrointestinal

The incidence of nausea or vomiting (5 trials)49,88,101,141,141 was less frequent with olanzapine. There was no difference in the incidence of constipation (3 trials),49,101,159 diarrhea (1 trial),101 and dyspepsia (1 trial).49

##### Genital, Urinary, and Breast

In single trials, difficult micturition141 was less frequent with olanzapine. No differences were found between groups for ejaculatory dysfunction,71 erectile dysfunction,71 and micturition disturbances.159

##### Hematology

The incidence of the following hematological disorders were not different between groups: agranulocytosis (2 trials),141,145 eosinophilia (1 trial),50 hematological problems conducive to termination (1 trial),145 and neutropenia (1 trial).145

##### Hepatobiliary

The incidence of abnormalities of serum glutamic oxaloacetic transaminase (1 trial)108 and serum glutamic pyruvic transaminase (2 trials)49,108 were less frequent with haloperidol. In single trials, there was no difference in the incidence of elevated alanine aminotransferase50 or increased gamma-glutamyl transpeptidase.50

##### Metabolic

The incidence of the following metabolic disorders was less frequent with haloperidol: hypercholesterolemia (2 trials),91,105 hyperglycemia (2 trials),91,105 hypertriglyceridemia (2 trials),91,105 and low levels of high-density lipoprotein (1 trial).91 There were no differences between groups in the incidence of diabetes (1 trial)129 or metabolic syndrome (2 trials).105,129

##### Ophthalmology

A single trial141 reported less blurred vision with olanzapine.

##### Respiratory and Airway

The incidence of rhinitis was not different between groups (2 trials).49,101

##### Sleep

The incidence of sleep disturbances, including early awakening (1 trial),141 increased dreams or nightmares (1 trial),141 and insomnia (7 trials),49,50,88,101,104,127,141 were less frequent with olanzapine.

##### Systemic AEs

In single trials, chills141 and increased perspiration141 were less frequent with olanzapine. In contrast, fever140 and infection140 were less frequent with haloperidol. No differences were found between groups for the following other systemic AEs: headache (3 trials),49,50,101 injury (1 trial),49 intercurrent illnesses conducive to termination (1 trial),145 malaise (1 trial),88 pain (2 trials),49,101 and tension (1 trial).159

### Haloperidol Versus Quetiapine

Ten trials46,47,65,68,73,79,80,91,115,123 reported on the incidence of AEs in patients receiving haloperidol compared with patients receiving quetiapine. The statistically significant findings are presented in Table 95. Other reported AEs did not differ between groups (Appendix N, Tables 137 and 138).

Table 95 Evidence summary table: haloperidol versus quetiapine – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Behavior and Psychosis
Asthenia68 | 1 | 448 | 0.29 (0.12, 0.71) | NE | haloperidol
BMI and Weight
Weight gain46,91,123 | 3 | 542 | 0.59 (0.39, 0.89) | 0% | haloperidol
Cardiovascular
Orthostatic hypotension46,68,115 | 3 | 959 | 0.49 (0.25, 0.94) | 0% | haloperidol
Cholinergic and Anticholinergic
Dry mouth68,115,123 | 3 | 674 | 0.32 (0.15, 0.65) | 0% | haloperidol
CNS
Somnolence46,68,115,123 | 4 | 984 | 0.57 (0.39, 0.84) | 0% | haloperidol
Endocrine (Prolactin and Thyroid)
Hyperprolactinemia68,79,91 | 3 | 943 | 2.24 (1.04, 4.80) | 89% | quetiapine
Thyroid function test abnormalities68 | 1 | 448 | 0.05 (0.00, 0.79) | NE | haloperidol
EPS
Akathisia46,68,79,91,115 | 5 | 1454 | 3.51 (1.84, 6.72) | 68% | quetiapine
Parkinsonism46,91 | 2 | 517 | 4.04 (1.97, 8.26) | 53% | quetiapine
Tremor68,115 | 2 | 649 | 3.80 (2.12, 6.81) | 0% | quetiapine
GI
Constipation46,68 | 2 | 758 | 0.45 (0.22, 0.93) | 0% | haloperidol

AE = adverse events; CNS = central nervous system; EPS = extrapyramidal symptoms or syndrome; GI = gastrointestinal; I^2^ = I-squared; KQ = Key Question; NE = not estimable

#### General Measures

The incidences of patients with AEs (3 trials),68,73,79 SAEs (1 trial),91 and withdrawals due to AEs (8 trials)46,47,68,79,80,91,115,123 were not different between groups.

#### Specific Measures

##### Behavior and Psychosis

A single trial68 reported less frequent asthenia with haloperidol. The following other AEs related to behavior and psychosis were not different between groups: agitation (4 trials),46,68,115,123 anxiety (1 trial),68 depression (1 trial),115 deterioration (1 trial),73 fatigue (1 trial),123 and irritability (1 trial).123

##### BMI and Weight

Weight gain (3 trials)46,91,123 was less frequent with haloperidol. A single trial91 reported no difference between groups in the incidence of overweight patients.

##### Cardiovascular

Orthostatic hypotension (3 trials),46,68,115 was less frequent with haloperidol. The incidence of ECG abnormalities (2 trials)46,91 was not different between groups.

##### Cholinergic and Anticholinergic

Dry mouth (3 trials)68,115,123 was less frequent with haloperidol; hypersalivation (2 trials)68,123 did not differ between groups.

##### CNS

Somnolence (4 trials)46,68,115,123 was less frequent with haloperidol. The incidence of other CNS abnormalities, including dizziness (2 trials),46,68 drowsiness (1 trial),123 sedation (1 trial)123 did not differ between groups.

##### Dermatology

A single trial123 reported no difference in the incidence of dry skin or rash.

##### Endocrine (Prolactin and Thyroid)

Hyperprolactinemia (3 trials)68,79,91 was less frequent with quetiapine. A single trial found less frequent thyroid function test abnormalities with haloperidol.68 Single trials reported no difference for the following endocrine abnormalities: amenorrhea or menstrual cycle irregularities,123 cold flashes,123 and galactorrhea.47

##### EPS

Akathisia (5 trials),46,68,79,91,115 parkinsonism (2 trials),46,91 and tremors (2 trials)68,115 were less frequent with quetiapine. The following EPS-related AEs showed no difference between groups: akinesia (1 trial),68 cogwheel rigidity (1 trial),68 dyskinesia (1 trial),91 dystonia (3 trials),46,68,91 fine tremors (1 trial),123 hypertonia (2 trials),68,79 involuntary movement of the jaw (1 trial),123 neck rigidity (1 trial),68 oculogyric crisis (1 trial),68 stiffness (1 trial),123 tardive dyskinesia (1 trial),65 and twitching of the extremities (1 trial).123 Pooled results for EPS (5 trials)46,68,79,80,115 were not reported because of marked heterogeneity between the trials (I^2^ = 90 percent).

##### Gastrointestinal

Constipation (2 trials)46,68 was less frequent with haloperidol. A single trial46 reported no difference in the rate of dyspepsia.

##### Hematology

Single trials found no differences in the incidence of agranulocytosis46 or leucopenia.68

##### Hepatobiliary

A single trial68 reported no difference between groups in elevated liver transaminases.

##### Metabolic

Single trials reported no differences between groups in the incidence of low levels of high-density lipoprotein,91 hypercholesterolemia,91 hyperglycemia,91 and hypertriglyceridemia.91

##### Ophthalmology

A single trial123 reported no difference in the incidence of blurred vision.

##### Sleep

The incidence of insomnia (4 trials)46,68,115,123 did not differ between groups.

##### Systemic AEs

The incidence of headaches (4 trials)46,68,115,123 did not differ between groups.

### Haloperidol Versus Risperidone

Twenty-eight trials52,53,59–61,64,71–73,81,82,85,90,101,117,118,120,124,128,132,136,138,139,145,146,149–151 and one cohort study163 reported on the incidence of AEs in patients receiving haloperidol compared with patients receiving risperidone (Table 96). The statistically significant findings are presented in Table 97. Other reported AEs did not differ between groups (Appendix N, Tables 139 and 140).

Table 96 Evidence summary table: haloperidol versus risperidone – general measures of AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Incidence of patients with adverse events72,73,81,85,117,128,136,151 | 8 | 1313 | 1.20 (1.01, 1.42) | 84% | risperidone
Mortality (Cohort)163 | 1 | 63352 | 1.70 (1.31, 2.20) | NE | risperidone
Withdrawals due to adverse events52,59–61,64,71,72,81,82,85,90,101,118,120,124,128,132,138,145,146,149–151 | 23 | 4421 | 1.27 (1.04, 1.55) | 0% | risperidone

AE = adverse events; I^2^ = I-squared; KQ = Key Question; NE = not estimable

Table 97 Evidence summary table: haloperidol versus risperidone – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Behavior and Psychosis
Asthenia52,71,117,120,149 | 5 | 1596 | 1.20 (1.02, 1.41) | 0% | risperidone
BMI and Weight
Weight gain101 | 1 | 255 | 0.19 (0.05, 0.81) | NE | haloperidol
EPS
Akathisia52,60,71,101,139,146,149 | 7 | 619 | 1.79 (1.31, 2.44) | 0% | risperidone
EPS61,117,128,138,151 | 5 | 675 | 1.86 (1.46, 2.36) | 0% | risperidone
Tremor52,85,101,128 | 4 | 478 | 2.09 (1.23, 3.53) | 0% | risperidone

AE = adverse event; BMI = body mass index; EPS = extrapyramidal symptoms or syndrome; I^2^ = I-squared; KQ = Key Question; NE = not estimable

#### General Measures

The incidences of patients with AEs (8 trials),72,73,81,85,117,128,136,151 mortality (1 cohort study),163 and withdrawals due to AEs (23 trials),52,59–61,64,71,72,81,82,85,90,101,118,120,124,128,132,138,145,146,149–151 were less frequent with risperidone. There was no indication of publication bias for withdrawals due to AEs based on statistical tests and visual inspection of the funnel plot (Appendix K, Funnel plot 14). Single trials showed no difference for the incidence of AEs resolved spontaneously by 24 hours151 and SAEs.52

#### Specific Measures

##### Behavior and Psychosis

Asthenia (5 trials),52,71,117,120,149 was less frequent with risperidone. No differences between groups were found for the following AEs: abnormal thinking (1 trial),101 accommodation disturbances (2 trials),120,149 agitation (4 trials),61,72,81,101 anxiety (3 trials),61,81,101 concentration difficulty (4 trials),64,71,117,120 decreased appetite (1 trial),64 depression (2 trials),101,118 deterioration (1 trial),73 drug overdose (1 trial),118 decreased sexual desire (2 trials),120,149 fatigue (2 trials),60,64 hallucination (1 trial),101 increased appetite (1 trial),64 manic reaction (1 trial),128 nervousness (1 trial),101 paranoia (1 trial),101 and sexual disturbances (1 trial).52

##### BMI and Weight

A single trial101 reported less incidence of weight gain with haloperidol.

##### Cardiovascular

The groups did not differ in the incidence of the following cardiovascular abnormalities: ECG abnormalities (1 trial),128 hypotension (1 trial),61 orthostatic tachycardia (1 trial),61 orthostatic hypotension (3 trials),52,61,64 and palpitations (2 trials).52,64

##### Cholinergic and Anticholinergic

The incidence of decreased salivation (1 trial),71 dry mouth (4 trials),52,60,64,101 and hypersalivation (1 trial)85 did not differ between groups.

##### CNS

No differences were found between groups for dizziness (3 trials),101,128,151 sedation (1 trial),64 somnolence (5 trials),52,53,101,128,151 and vertigo (2 trials).52,64

##### Endocrine (Prolactin and Thyroid)

The incidence of amenorrhea (4 trials)64,71,120,149 and galactorrhea (1 trial)132 did not differ between groups.

##### EPS

Akathisia (7 trials),52,60,71,101,139,146,149 EPS (5 trials),61,117,128,138,151 and tremor (4 trials)52,85,101,128 were less frequent with risperidone. There was no difference between groups for dystonia (3 trials)60,139,149 or oculogyric crisis (1 trial).85

##### Gastrointestinal

The incidence of constipation (7 trials),52,53,64,101,120,128,149 diarrhea (1 trial),101 dyspepsia (1 trial),128 nausea or vomiting (5 trials)53,61,64,85,101 did not differ between groups.

##### Genital, Urinary, and Breast

The incidence of breast tension (1 trial),64 dry vagina (1 trial),149 ejaculatory dysfunction (4 trials),64,71,120,149 erectile dysfunction (3 trials),64,71,120 gynecomastia (1 trial),132 and micturition disturbances (1 trial)52 did not differ between groups.

##### Hematology

A single trial145 reported no difference in the incidence of agranulocytosis.

##### Ophthalmology

Two trials60,64 reported no difference in the incidence of blurred vision.

##### Respiratory and Airway

A single trial101 reported no difference in the incidence of rhinitis.

##### Sleep

The incidence of insomnia (6 trials)52,61,81,101,120,151 and sleep disorders (2 trials)52,85 did not differ between groups.

##### Systemic AEs

No differences were found between groups in the incidence headaches (9 trials),52,53,61,64,81,85,101,128,151 increased sweating (2 trials),52,64 infection (1 trial),53 and pain (1 trial).101

### Haloperidol Versus Ziprasidone

Nine trials 57,69,73,83,86,91,116,122,144 reported on the incidence of AEs in patients receiving haloperidol compared with patients receiving ziprasidone (Table 98). The statistically significant findings are presented in Table 99. Other reported AEs did not differ between groups (Appendix N, Tables 141, 142, and 143).

Table 98 Evidence summary table: haloperidol versus ziprasidone – general measures with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Incidence of patients with adverse events57,69,73,83,86,144 | 6 | 1448 | 1.13 (1.03, 1.23) | 31% | ziprasidone
Withdrawals due to adverse events57,83,86,91,116,144 | 6 | 1551 | 1.73 (1.30, 2.32) | 0% | ziprasidone

I^2^ = I-squared; KQ = Key Question

Table 99 Evidence summary table: haloperidol versus ziprasidone – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
CNS
Hypokinesia144 | 1 | 350 | 6.21 (1.41, 27.34) | NE | ziprasidone
Hypotonia144 | 1 | 350 | 5.86 (1.75, 19.65) | NE | ziprasidone
EPS
Dystonia57,91,144 | 3 | 1102 | 2.19 (1.34, 3.60) | 15% | ziprasidone
EPS57,69,116,122,144 | 5 | 1594 | 2.34 (1.56, 3.53) | 63% | ziprasidone
Hypertonia57,86,116 | 3 | 926 | 2.45 (1.52, 3.94) | 0% | ziprasidone
Movement disorder86 | 1 | 301 | 2.73 (1.77, 4.19) | NE | ziprasidone
Tremor57,86,116,122,144 | 5 | 1875 | 2.55 (1.79, 3.63) | 4% | ziprasidone

AE = adverse events; CNS = central nervous system; EPS = extrapyramidal symptoms or syndrome; GI = gastrointestinal; I^2^ = I-squared; KQ = Key Question; NE = not estimable

#### General Measures

The incidences of patients with AEs (6 trials)57,69,73,83,86,144 and withdrawals due to AEs (6 trials)57,83,86,91,116,144 were less frequent with ziprasidone. No difference between groups was found for mortality (2 trials)116,144 and SAEs (4 trials).57,86,91,144

#### Specific Measures

##### Behavior and Psychosis

The incidence of agitation (2 trials),86,116 anxiety (3 trials),86,116,144 asthenia (2 trials),86,116 depression (2 trials),86,144 clinical deterioration (1 trial),73 and hallucinations (1 trial)86 did not differ between groups.

##### BMI and Weight

The incidence of overweight patients (1 trial)91 and patients with weight gain (2 trials)91,144 or weight loss (1 trial)144 did not differ between groups.

##### Cardiovascular

The incidence of cardiovascular AEs (1 trial),116 ECG abnormalities (6 trials),57,86,91,116,122,144 hypertension (1 trial),116 hypotension (1 trial),116 and syncope (1 trial)116 did not differ between groups.

##### Cholinergic and Anticholinergic

Two studies found no difference in the incidence of dry mouth.86,116

##### CNS

A single trial144 found that hypokinesia and hypotonia were less frequent with ziprasidone. The incidence of dizziness (3 trials)86,116,144 and somnolence (5 trials),57,86,116,122,144 did not differ between groups.

##### Dermatology

A single trial116 reported no difference in the incidence of injection-site pain.

##### Endocrine (Prolactin and Thyroid)

Two trials57,91 reported no difference in the incidence of hyperprolactinemia.

##### EPS

Dystonia (3 trials),57,91,144 EPS (5 trials),57,69,116,122,144 hypertonia (3 trials),57,86,116 movement disorder (1 trial),86 and tremor (5 trials)57,86,116,122,144 were less frequent with ziprasidone. No differences between groups were found in the incidence of akathisia (6 trials),57,86,91,116,122,144 dyskinesia (1 trial),91 parkinsonism (1 trial),91 psychosis (1 trial),86 and tardive dyskinesia (1 trial).86

##### Gastrointestinal

The incidence of dyspepsia (1 trial)144 and nausea or vomiting (2 trials)86,116 did not differ between groups.

##### Metabolic

A single study found no difference between groups in the incidence of low levels of high-density lipoprotein, hypercholesterolemia, hyperglycemia, and hypertriglyceridemia.91

##### Ophthalmology

A single trial116 reported no difference in the incidence of abnormal vision.

##### Sleep

The incidence of insomnia (4 trials)57,86,116,122 did not differ between groups.

##### Systemic AEs

The incidence of headaches (3 trials),86,116,144 malaise (1 trial),116 and sweating (1 trial)116 did not differ between groups.

### Perphenazine Versus Aripiprazole

A single trial93 reported on the incidence of AEs in patients receiving perphenazine compared with patients receiving aripiprazole (Table 100). The incidence of dizziness, ECG abnormalities, hyperprolactinemia, and injury was less frequent with aripiprazole. Other reported AEs were not different between groups (Appendix N, Tables 144 and 145).

Table 100 Evidence summary table: perphenazine versus aripiprazole – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Behavior and Psychosis
Dizziness93 | 1 | 300 | 5.27 (1.18, 23.66) | NE | aripiprazole
Cardiovascular
ECG abnormalities93 | 1 | 300 | 15.82 (2.12, 118.27) | NE | aripiprazole
Endocrine (Prolactin and Thyroid)
Hyperprolactinemia93 | 1 | 300 | 13.89 (6.25, 30.86) | NE | aripiprazole
Systemic AE
Injury93 | 1 | 300 | 4.75 (1.04, 21.60) | NE | aripiprazole

AE = adverse event; ECG = electrocardiogram; I^2^ = I–squared; KQ = Key Question; NE = not estimable

### Perphenazine Versus Olanzapine

A single trial23 reported on the incidence of AEs in patients receiving perphenazine compared with patients receiving olanzapine (Table 101). Weight gain was less frequent with perphenazine. The incidence of patients with Abnormal Involuntary Movement Scale (AIMS) global severity score ≥2 and insomnia was less frequent with olanzapine. Other reported AEs were not different between groups (Appendix N, Tables 146 and 147).

Table 101 Evidence summary table: perphenazine versus olanzapine – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
BMI and Weight
Weight gain23 | 1 | 597 | 0.41 (0.28, 0.60) | NE | perphenazine
EPS
AIMS global severity score ≥2^23^ | 1 | 597 | 1.65 (1.07, 2.54) | NE | olanzapine
Sleep
Insomnia23 | 1 | 597 | 1.54 (1.12, 2.13) | NE | olanzapine

AE = adverse events; AIMS = Abnormal Involuntary Movement Scale; BMI = body mass index; EPS = extrapyramidal symptoms or syndrome; I^2^ = I-squared; KQ = Key Question; NE = not estimable

### Perphenazine Versus Quetiapine

A single trial23 reported on the incidence of AEs in patients receiving perphenazine compared with patients receiving quetiapine (Table 102). Anticholinergic AEs was less frequent with perphenazine. The incidence of patients with AIMS global severity score ≥2 was less frequent with quetiapine. Other reported AEs were not different between groups (Appendix N, Tables 148 and 149).

Table 102 Evidence summary table: perphenazine versus quetiapine – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Cholinergic and Anticholinergic
Anticholinergic side effects23 | 1 | 598 | 0.70 (0.53, 0.93) | NE | perphenazine
EPS
AIMS global severity score ≥2^23^ | 1 | 598 | 1.76 (1.13, 2.75) | NE | quetiapine

AE = adverse events; AIMS = Abnormal Involuntary Movement Scale; EPS = extrapyramidal symptoms or syndrome; I^2^ = I-squared; KQ = Key Question; NE = not estimable

### Perphenazine Versus Risperidone

A single trial23 reported on the incidence of AEs in patients receiving perphenazine compared with patients receiving risperidone (Table 103). Incontinence or nocturia was less frequent with perphenazine. Other reported AEs were not different between groups (Appendix N, Tables 150 and 151).

Table 103 Evidence summary table: perphenazine versus risperidone – specific AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Genital, Urinary, and Breast
Incontinence or nocturia23 | 1 | 602 | 0.31 (0.13, 0.75) | NE | perphenazine

AE = adverse events; I^2^ = I-squared; KQ = Key Question; NE = not estimable

### Perphenazine Versus Ziprasidone

A single trial23 found no differences between perphenazine and ziprasidone in the incidence of any AEs (Appendix N, Tables 152 and 153).

### Thioridazine Versus Clozapine

A single cohort study163 found lower incidence of mortality with clozapine compared with thiordazine (Table 104; Appendix N, Table 154).

Table 104 Evidence summary table: thioridazine versus clozapine – general AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Mortality (Cohort)163 | 1 | 32280 | 2.12 (1.38, 3.26) | NE | clozapine

AE = adverse events I^2^ = I-squared; KQ = Key Question; NE = not estimable

### Thioridazine Versus Risperidone

A single cohort study163 found lower incidence of mortality with risperidone compared with thiordazine (Table 105; Appendix N, Table 155).

Table 105 Evidence summary table: thioridazine versus risperidone – general AEs with significant differences (KQ3)

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less With
Mortality (Cohort)163 | 1 | 46007 | 1.82 (1.37, 2.40) | NE | risperidone

AE = adverse event; I^2^ = I-squared; KQ = Key Question; NE = not estimable