# Peer Reviewers

Jaime Hallak, M.D.

Department of Neurology, Psychiatry and Psychological Medicine

Ribeirão Preto Medical School

University of São Paulo

São Paulo, Brazil

Stephen Marder, M.D.

Professor

Psychiatry and Biobehavioral Sciences

University of California Los Angeles

Los Angeles, CA

David Osser, M.D.

Associate Professor

Department of Psychiatry

Harvard Medical School

Boston, MA

Scot E. Purdon, Ph.D.

Clinical Professor

Department of Psychiatry

University of Alberta

Edmonton, Canada

George Simpson, M.D.

Department of Psychiatry and the Behavioral Sciences

Keck School of Medicine

University of Southern California

Los Angeles, CA

Donald M. Steinwachs, Ph.D.

Professor, Health Policy and Management

School of Hygiene and Public Health

Johns Hopkins University

Baltimore, MD