# Technical Expert Panel

John Davis, M.D.

Research Professor, Gillman Professor

Department of Psychiatry

University of Illinois at Chicago

Chicago, IL

Lisa Dixon, M.D.

Division Head, Department of Psychiatry

University of Maryland School of Medicine

Baltimore, MD

Ken Duckworth, M.D.

Medical Director

National Alliance on Mental Illness

Arlington, VA

Peter Jones, M.D.

Head, Department of Psychiatry

University of Cambridge

Cambridge, UK

Julie A. Kreyenbuhl, Pharm.D., Ph.D.

Associate Professor

Department of Psychiatry

University of Maryland School of Medicine

Baltimore, MD

John H. Krystal, M.D.

Chair, Department of Psychiatry

Yale University School of Medicine

New Haven, CT