# Errata

On August 20, 2012, Appendix O was updated to clarify that the route of administration for INVEGA SUSTENNA is IM injection (dosage 39 mg – 234 mg) and the route of administration for RISPERIDOL CONSTA is IM injection (dosage 25 mg).