# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Ms. Annabritt Chisholm (article retrieval), Ms. Teodora Radisic (article retrieval), Mr. Ben Vandermeer (data analysis), and Ms. Andrea Milne (literature searching). We acknowledge Ms. Christine Ha, Ms. Elizabeth Sumamo Schellenberg, and Mr. Kai Wong for help in screening the gray literature.