# First-Generation and Second-Generation FDA-Approved and Available Antipsychotics

Table O-1 First-generation antipsychotics included in the CER

Generic name | Trade names(s) | Mode of administration | Recommended dose | Frequency
Chlorpromazine | Chlorpromazine hydrochloride Chlorpromazine hydrochloride | Oral IM/IV | 200–600 mg/day | 1–4 times
Droperidol | Inapsine | IM/IV | Initial 2.5 mg/dose | increase by 1.25 mg as needed
Fluphenazine | Fluphenazine decanoate | Oral | 2.5–10 mg/day | 3–4 times
Fluphenazine | Fluphenazine hydrochloride | IM | 2.5–10 mg/dose | every 6 to 8 hour
Haloperidol | Haloperidol | Oral | 4–12 mg/day | 1–2 times
Haloperidol | Haldol | Tablets | | 2–3 times
Haloperidol | Haloperidol decanoate | Solution IM (as lactate) | | Every hour if needed
Loxapine | Loxapine, Loxapine succinate | Oral | 60–100 mg/day | 2–4 times
Perphenazine | Perphenazine | Oral (non-hospitalized) | 12–18 mg/day; | 3 times
Perphenazine | | Oral (hospitalized) | 16–64 mg/day | 2–4 times
Pimozide | ORAP | Oral | 7–10 mg/day | 1–3 times
Prochlorperazine | Compro | Oral | 15–40 mg/day | 3–4 times
Prochlorperazine | Prochlorperazine
Prochlorperazine | Prochlorperazine edisylate | IM | 15–40 mg/day | 3–4 times
Prochlorperazine | Prochlorperazine maleate | IV | 7.5–40 mg/day | 3–4 times
Thioridazine | Thioridazine hydrochloride D/C: Thioridazine hydrochloride intensol, Mellaril, Mellaril-S | Oral | 150–300 mg/day | 2–3 times
Thiothixene | Navane Thiothixene D/C: Thiothixene hydrochloride, Thiothixene hydrochloride intensol | Oral | 6–30 mg/day | 2–3 times
Trifluoperazine | Trifluoperazine hydrochloride | Oral (non-hospitalized) | 1–2 mg | 2 times/day

D/C = discontinued according to FDA site; IM = intramuscular; IV = intravenous; mg = milligrams

Table O-2 Second-generation antipsychotics included in the CER

Generic name | Brand names(s) | Mode of administration | Recommended dose | Frequency
Aripiprazole | Abilify | Tablet | 10–15mg/day; | QD
Aripiprazole | Abilify | Solution
Aripiprazole | Abilify | Orally disintegrating tablet
Aripiprazole | Abilify | Injection | Max 30mg/day | ≥2 hour between doses
Asenapine | Saphouris | Orally disintegrating tablet | Schizophrenia 5mg; BD 10mg | 2 times/day 2 times/day
Clozapine | Clozapine Clozaril | Tablet Orally disintegrating tablet | 300–450 mg/day | 1–3 times/day
Iloperidone | Fanapt | Tablet | 12–24mg/day | 2 times/day
Olanzapine | Olanzapine | Tablet | Schizophrenia, 10mg/day; | QD
Olanzapine | Zyprexa, | Orally disintegrating tablet | BD I 10–15mg/day | QD
Olanzapine | Zyprexa Zydis | IM injection
Lurasidone | Latuda | Tablet | 40–80mg/day | 1–2 times/day
Paliperidone | Invega | Tablet extended release | 6mg/day | QD in the AM
Paliperidone | Invega sustenna | IM injection | 39–234 mg/day
Quetiapine | Quetiapine fumarate | Tablet | Schizophrenia, 150–750mg/day; | 2 times/day
Quetiapine | Seroquel | | BD (mania), 400–800mg/day; | 2 times/day
Quetiapine | Seroquel XR | Sustained release tablets | BD (depression), 300mg/day; | 2 times/day
Quetiapine | | | BD (maintenance), 400–800mg/day | 2 times/day
Quetiapine | | | | QD at bedtime
Quetiapine | | | | 2 times/day
Risperidone | Risperidone, | Tablet | Schizophrenia, 4–8mg/day; | 1–2 times/day
Risperidone | Risperdal, | Solution | BD (mania), 1–6mg/day
Risperidone | | Orally disintegrating tablet
Risperidone | Risperdal consta | IM injection | 25 mg/day
Ziprasidone | Ziprasidone hydrochloride Geodon | Capsules IM injection | Schizophrenia, up to 80mg; BD (manic/mixed, maintenance), 40–80mg; Agitation associated with Schizophrenia (IM), up to max 40mg/day | 2 times/day 2 times/day 10mg may be injected q2 hour

BD = bipolar disease; IM = intramuscular; mg = milligrams; QD = every day; q2 = every two hours

Table O-3 First-generation antipsychotics: FDA status

Drug | FDA status | Indications | Age group approved for | Black box Warnings
Chlorpromazine | Approved 1974 | Schizophrenia BP (mania) Hyperactivity Uncontrolled hiccups, nausea and vomiting | Adults Children (1–12 yrs) | Patients with cardiovascular disease or hx of seizures
Droperidol | Approved 1988 | Antiemetic Acute psychosis | Adults Children (2–12 yrs) as antiemetic, no data on pediatric psychosis | QT prolongation (dose related) Torsades de pointes
Fluphenazine | Approved 1960 | Schizophrenia BD (mania) | Adults Children >12yrss Not recommended for use in children under 12 yrs | Possible increased mortality in elderly with dementia-related psychosis Not approved for the treatment of dementia-related behavior problems.
Haloperidol | Approved 1986 | Schizophrenia Tourette’s Disorder | Adults Safety and effectiveness in pediatric patients <18 yrs have not been established | Increased mortality in elderly with dementia-related psychosis
Loxapine | Approved 1975 | Schizophrenia | Adults Safety and effectiveness in pediatric patients <16 have not been established | Increased mortality in elderly with dementia-related psychosis
Perphenazine | Approved 1965 | Schizophrenia | Adults Safety and effectiveness in pediatric patients have not been established | Increased mortality in elderly with dementia-related psychosis Children, adolescents, and young adults taking antidepressants are at increased risk of suicidal thinking
Pimozide | Approved 1984 | Tourette’s Disorder | Children and adults 8–53 yrs. Limited evidence in children <12 yrs Use and safety have not been evaluated in other childhood disorders, ORAP is not recommended for use in any condition other than Tourette’s Disorder | Use of pimozide in tx of Tourette’s Disorder involves different risk/benefit considerations than tx of other conditions. A decision to use ORAP should take into consideration Tardive Dyskinesia Neuroleptic Malignant Syndrome (NMS) Sudden, unexpected deaths in conditions other than Tourette’s Disorder. May have tumorigenic potential.
Thiothixene | Approved 1967 | Schizophrenia | Adults Safety and effectiveness in pediatric patients <12 years have not been established | Increased mortality in elderly with dementia-related psychosis
Trifluoperazine | Approved 1959 | Schizophrenia | Adults and children (6–12 yrs) | Increased mortality in elderly patients with dementia-related psychosis
Prochlorperazine | Approved 1956 | Schizophrenia Severe nausea and vomiting | Adults and children Children >2 yrs and >20 pounds | May cause tardive dyskinesia
Thioridazine | Approved 1962 | Schizophrenia | Adults and children | Life-threatening pro-arrhythmic effect

BD = bipolar disease; IM = intramuscular; tx = treatment; yrs = years

Table O-4 Second-generation antipsychotics: FDA status

Drug | FDA status | Indications | Age group approved for | Black box warnings
Aripiprazole | Approved 2002 | Schizophrenia | Adults & adolescents (13–17 yrs) | Increased mortality in elderly with dementia-related psychosis
Aripiprazole | Approved 2004 | BD(L) (manic/mixed) monotherapy or adjunctive to lithium or valproate | Adults & pediatrics (10–17 yrs) | Children, adolescents, and young adults taking antidepressants are at increased risk of suicidal thinking & behavior
Aripiprazole | Approved 2007 | Adjunctive tx of major depressive disorder | Adults Children (6–17 yrs) | Leukopenia, Neutropenia, Agranulocytosis
Aripiprazole | Approved 2009 | Autistic Disorder, Injection | Adults with agitation associated with Schizophrenia or BD(L) (manic/mixed) | Not approved for behavior problems in older adults with dementia.
Aripiprazole | Approved 2002 | Schizophrenia | Adults and adolescents (13–17 yrs) | Increased mortality in elderly with dementia-related psychosis
Aripiprazole | Approved 2004 | BD(L) (manic/mixed) monotherapy or adjunctive to lithium or valproate | Adults and pediatrics (10–17 yrs) | Children, adolescents, and young adults taking antidepressants are at increased risk of suicidal thinking and behavior
Aripiprazole | Approved 2007 | Adjunctive tx of major depressive disorder | Adults | Not approved for behavior problems in older adults with dementia.
Aripiprazole | | Injection | Adults with agitation associated with Schizophrenia or BD(L) (manic/mixed)
Asenapine | Approved 2009 | Acute Schizophrenia BD I (manic/mixed) | Adults Adults Pediatric use: safety & effectiveness not established in patients <18 yrs | Increased mortality in elderly with dementia-related psychosis
Clozapine, | Approved 1989 | Treatment resistant Schizophrenia | Adults Pediatric use: safety & effectiveness not established in patients <18 yrs | 1. agranulocytosis; 2. seizures; 3. myocarditis; 4. cardiovascular and respiratory effects, (respiratory and/or cardiac arrest).; 5. increased mortality in elderly patients with dementia-related psychosis
Clozapine, | Approved 2002 | Reduce the risk of suicidal behavior in younger schizophrenics. | Adults Pediatric use: safety & effectiveness not established in patients <18 yrs
Iloperidone | Approved 2009 | Acute Schizophrenia | Adults | Increased mortality in elderly with dementia-related psychosis Not approved for patients with dementia-related psychosis.
Lurasidone | Approved 2010 | Schizophrenia | Adults | Increased mortality in elderly with dementia-related psychosis
Olanzapine | Approved 1996 | Schizophrenia &BD(L) (manic/mixed) | Adults Adolescents (13–17 yrs), Schizophrenia & BD (manic/mixed) Pediatric use: safety & effectiveness not established in patients <13 yrs | Increased mortality in elderly with dementia-related psychosis Not approved for patients with dementia-related psychosis.
Olanzapine | Approved 2003: combined w fluoxetine | BD (depressive) | Adults Adolescents (13–17 yrs), Schizophrenia & BD (manic/mixed) Pediatric use: safety & effectiveness not established in patients <13 yrs | Increased mortality in elderly with dementia-related psychosis Not approved for patients with dementia-related psychosis.
Olanzapine | Approved 2004 | BD(L) long-term tx | Adults Adolescents (13–17 yrs), Schizophrenia & BD (manic/mixed) Pediatric use: safety & effectiveness not established in patients <13 yrs | Increased mortality in elderly with dementia-related psychosis Not approved for patients with dementia-related psychosis.
Olanzapine | Approved 2009: combined w fluoxetine | Tx resistant depression | Adults Adolescents (13–17 yrs), Schizophrenia & BD (manic/mixed) Pediatric use: safety & effectiveness not established in patients <13 yrs | Increased mortality in elderly with dementia-related psychosis Not approved for patients with dementia-related psychosis.
Paliperidone | Approved 2006 | Schizophrenia | Adult | Increased mortality in elderly with dementia-related psychosis
Paliperidone | Approved 2006 | Schizoaffective disorder | Pediatric use: safety & effectiveness not established in patients <18 yrs | Increased mortality in elderly with dementia-related psychosis
Quetiapine | Approved 1997 | Schizophrenia | Adults & adolescents (13–17 yrs) Adults, children & adolescents (10–17 yrs) Adults Adults | Increased mortality in elderly with dementia-related psychosis Increased risk of suicidal thinking and behavior Not approved for patients with dementia-related psychosis
Quetiapine | Approved 2004 | BD (acute manic) | Adults & adolescents (13–17 yrs) Adults, children & adolescents (10–17 yrs) Adults Adults | Increased mortality in elderly with dementia-related psychosis Increased risk of suicidal thinking and behavior Not approved for patients with dementia-related psychosis
Quetiapine | Approved 2008 | BD (depression) BD (maintenance) | Adults & adolescents (13–17 yrs) Adults, children & adolescents (10–17 yrs) Adults Adults | Increased mortality in elderly with dementia-related psychosis Increased risk of suicidal thinking and behavior Not approved for patients with dementia-related psychosis
Risperidone | Approved 1993 | Schizophrenia | Adults & adolescents (13–17 yrs) Adults & adolescents (10–17 years) Children (5–16 yrs) | Increased mortality in elderly with dementia-related psychosis
Risperidone | Approved 2007 | BD (manic/mixed) | Adults & adolescents (13–17 yrs) Adults & adolescents (10–17 years) Children (5–16 yrs) | Increased mortality in elderly with dementia-related psychosis
Risperidone | Approved 2003 | Irritability associated with autism | Adults & adolescents (13–17 yrs) Adults & adolescents (10–17 years) Children (5–16 yrs) | Increased mortality in elderly with dementia-related psychosis
Ziprasidone | Approved 2001 | Schizophrenia | Adults Adults Adults Pediatric use: safety & effectiveness not established in patients <18 yrs | Increased mortality in elderly with dementia-related psychosis
Ziprasidone | Approved 2001 | BD (manic/mixed) | Adults Adults Adults Pediatric use: safety & effectiveness not established in patients <18 yrs | Increased mortality in elderly with dementia-related psychosis
Ziprasidone | Approved 2001 | BD (maintenance) | Adults Adults Adults Pediatric use: safety & effectiveness not established in patients <18 yrs | Increased mortality in elderly with dementia-related psychosis

BD = bipolar disease; tx = treatment; yrs = years