# Summary Tables of Adverse Events

## Chlorpromazine Versus Clozapine

Table 113 Evidence summary table: chlorpromazine versus clozapine – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Mortality109,156 | 2 | 214 | 0.98 (0.10, 9.19) | 0% | ND
Withdrawals due to AE63,87,109,152,160 | 5 | 463 | 1.70 (0.65, 4.45) | 34% | ND

AE = adverse event; I^2^ = I–squared; ND = no difference

Table 114 Evidence summary table: chlorpromazine versus clozapine – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Agitation153 | 1 | 41 | 6.68 (0.37, 121.71) | NE | ND
Depression152 | 1 | 64 | 9.56 (0.54, 170.62) | NE | ND
Paranoia (increasing)154 | 1 | 15 | 0.30 (0.01, 6.29) | NE | ND
BMI and weight
Weight gain (>5%)87 | 1 | 40 | 2.21 (0.79, 6.18) | NE | ND
Weight loss87 | 1 | 40 | 2.21 (0.22, 22.47) | NE | ND
Cardiovascular
Abnormal ECG154,160 | 2 | 59 | 0.81 (0.39, 1.68) | 0% | ND
Cardiotoxics effects153 | 1 | 41 | NE | NE | ND
Hypertension94,160 | 2 | 312 | 0.39 (0.17, 0.90) | 0% | chlorpromazine
Hypotension48,87,94,109,160 | 5 | 543 | 1.94 (0.91, 4.13) | 49% | ND
Orthostatic hypotension153,158,160 | 3 | 110 | 0.61 (0.12, 3.09) | 0% | ND
Tachycardia87,94 | 2 | 308 | 0.66 (0.37, 1.20) | 0% | ND
Cholinergic and anticholinergic
Dry mouth63,87,94,152,161 | 5 | 563 | 3.00 (1.67, 5.40) | 11% | clozapine
Hypersalivation48,63,87,94,152,154,158,160,161 | 9 | 674 | 0.25 (0.14, 0.45) | 13% | chlorpromazine
Ileus109 | 1 | 164 | 2.93 (0.12, 70.85) | NE | ND
CNS
Dizziness94,160,161 | 3 | 352 | 0.62 (0.21, 1.87) | 50% | ND
Drowsiness94,152,153,160,161 | 5 | 457 | 0.75 (0.58, 0.97) | 0% | chlorpromazine
Sedation48,63,87 | 3 | 218 | 1.07 (0.69, 1.64) | 0% | ND
Seizure63,87,153 | 3 | 232 | 2.91 (0.31, 27.28) | 0% | ND
Slurred speech160 | 1 | 44 | 1.76 (0.08, 40.80) | NE | ND
Dermatology
Dermatitis109 | 1 | 164 | 2.93 (0.12, 70.85) | NE | ND
Dermatologic problem87 | 1 | 40 | 5.50 (0.28, 107.78) | NE | ND
Exanthema or eczema153 | 1 | 41 | 8.59 (0.49, 150.00) | NE | ND
Endocrine (prolactin - thyroid)
Hyperprolactinemia63 | 1 | 151 | 4.94 (0.24, 101.10) | NE | ND
EPS
Akathisia63,87,154 | 3 | 206 | 0.99 (0.37, 2.67) | 0% | ND
Dystonia63,154 | 2 | 166 | 3.64 (0.43, 31.19) | 0% | ND
EPS48,63,87,109,158,160 | 6 | 451 | 2.75 (1.48, 5.12) | 0% | clozapine
Oculogyric crisis154 | 1 | 15 | 2.67 (0.13, 56.63) | NE | ND
Parkinsonism153,154 | 2 | 56 | 2.67 (0.13, 56.63) | NE | ND
Rigidity63,152,160 | 3 | 259 | 0.76 (0.10, 6.07) | 58% | ND
Staggering160 | 1 | 44 | 0.57 (0.04, 8.53) | NE | ND
Tardive dyskinesia (deterioration)87 | 1 | 40 | 3.30 (0.14, 76.46) | NE | ND
Tremor152,160,161 | 3 | 148 | 0.74 (0.28, 1.94) | 7% | ND
Genito-urinary
Impotence63 | 1 | 151 | 2.96 (0.12, 71.55) | NE | ND
GI
Abdominal cramps160 | 1 | 44 | 1.76 (0.08, 40.80) | NE | ND
Constipation63,94,109,152 | 4 | 647 | 0.69 (0.44, 1.09) | 0% | ND
Diarrhea160 | 1 | 44 | 0.38 (0.07, 2.04) | NE | ND
Heartburn160 | 1 | 44 | 1.76 (0.08, 40.80) | NE | ND
Nausea/vomiting87,94,160 | 3 | 352 | 1.06 (0.55, 2.04) | 0% | ND
Hematology
Agranulocytosis63,94 | 2 | 419 | NE | NE | ND
Blood cell count (abnormal)154 | 1 | 15 | NE | NE | ND
Neutropenia109 | 1 | 164 | 2.93 (0.12, 70.85) | NE | ND
Platelet count (elevated)154 | 1 | 15 | 0.07 (0.00, 1.03) | NE | ND
Leukocytopenia48,63,87,94 | 4 | 486 | 0.71 (0.18, 2.76) | 55% | ND
Hepato-biliary
Hepatic enzymes (elevated)87,94 | 2 | 308 | 0.79 (0.11, 5.71) | 33% | ND
Jaundice87 | 1 | 40 | 3.30 (0.14, 76.46) | NE | ND
Sleep
Deep sleep153 | 1 | 41 | 0.32 (0.01, 7.38) | NE | ND
Sleep disturbances153 | 1 | 41 | 6.68 (0.37, 121.71) | NE | ND
Respiratory and airway
Cough160 | 1 | 44 | 0.20 (0.01, 4.53) | NE | ND
Systemic AE
Fall (accident)87 | 1 | 40 | 0.22 (0.01, 4.31) | NE | ND
Fever/Chills94,160 | 2 | 312 | 0.35 (0.15, 0.83) | 0% | chlorpromazine
Headache94,160 | 2 | 312 | 0.86 (0.43, 1.71) | 0% | ND
Hyperthermia109,154,160 | 3 | 223 | 0.23 (0.05, 1.20) | 0% | ND
Tension160 | 1 | 44 | 2.93 (0.15, 57.52) | NE | ND

Significant results are in bold; AE = adverse event; BMI = body mass index; CNS = central nervous system; ECG = electrocardiogram; EPS = extrapyramidal symptoms/syndrome; GI = gastrointestinal; I^2^ = I–squared; ND = no difference; NE = not estimable

## Chlorpromazine Versus Olanzapine

Table 115 Evidence summary table: chlorpromazine versus olanzapine – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Withdrawals due to adverse events66 | 1 | 84 | 6.00 (0.75, 47.71) | NE | ND

AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 116 Evidence summary table: chlorpromazine versus olanzapine – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Cardiovascular
Orthostatic hypotension66 | 1 | 84 | 7.50 (2.90, 19.42) | NE | olanzapine
Tachycardia66 | 1 | 84 | 7.00 (0.90, 54.44) | NE | ND
Cholinergic and anticholinergic
Dry mouth66 | 1 | 84 | 1.94 (1.27, 2.97) | NE | olanzapine
CNS
Dizziness66 | 1 | 84 | 1.17 (0.43, 3.18) | NE | ND
Drowsiness/lethargy66 | 1 | 84 | 1.47 (0.89, 2.41) | NE | ND
Slurred speech66 | 1 | 84 | 9.00 (0.50, 162.10) | NE | ND
Unsteady gait66 | 1 | 84 | 15.00 (2.07, 108.48) | NE | olanzapine
EPS
EPS66 | 1 | 84 | 1.75 (0.99, 3.08) | NE | ND
GI
Constipation66 | 1 | 84 | 2.60 (1.02, 6.65) | NE | olanzapine
Dyspepsia/heartburn66 | 1 | 84 | 2.25 (0.75, 6.74) | NE | ND
Nausea/vomiting66 | 1 | 84 | 1.00 (0.31, 3.20) | NE | ND
Gentio-urinary
Dysuria66 | 1 | 84 | 9.00 (0.50, 162.10) | NE | ND
Ophthalmology
Blurred vision66 | 1 | 84 | 1.25 (0.36, 4.33) | NE | ND
Sleep
Insomnia66 | 1 | 84 | 0.33 (0.07, 1.56) | NE | ND
Systemic AE
Headache66 | 1 | 84 | 0.67 (0.30, 1.46) | NE | ND

Note: Bold = statistically significant; AE = adverse event; EPS = extrapyramidal symptoms/syndrome; GI = gastrointestinal; I^2^ = I–squared; ND = no difference; NE = not estimable

## Chlorpromazine Versus Quetiapine

Table 117 Evidence summary table: chlorpromazine versus quetiapine – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Severe AEs121 | 1 | 201 | 1.31 (0.92, 1.86) | NE | ND
Withdrawals due to AEs121 | 1 | 201 | 2.27 (0.72, 7.14) | NE | ND

AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 118 Evidence summary table: chlorpromazine versus quetiapine – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Agitation121 | 1 | 201 | 2.02 (0.79, 5.17) | NE | ND
Anxiety121 | 1 | 201 | 1.35 (0.48, 3.74) | NE | ND
Nervousness121 | 1 | 201 | 2.53 (0.50, 12.71) | NE | ND
BMI and weight
Weight gain121 | 1 | 201 | 0.67 (0.40, 1.14) | NE | ND
Cardiovascular
Hypotension121 | 1 | 201 | 2.36 (0.63, 8.86) | NE | ND
Orthostatic hypotension121 | 1 | 201 | 3.64 (1.40, 9.42) | NE | quetiapine
Tachycardia121 | 1 | 201 | 1.01 (0.34, 3.03) | NE | ND
Cholinergic and anticholinergic
Dry mouth121 | 1 | 201 | 0.76 (0.27, 2.10) | NE | ND
CNS
Dizziness121 | 1 | 201 | 2.53 (0.50, 12.71) | NE | ND
Somnolence121 | 1 | 201 | 1.15 (0.60, 2.24) | NE | ND
EPS
Akathasia121 | 1 | 201 | 1.52 (0.44, 5.21) | NE | ND
Hypertonia121 | 1 | 201 | 0.51 (0.13, 1.96) | NE | ND
Tremor121 | 1 | 201 | 0.51 (0.13, 1.96) | NE | ND
GI
Constipation121 | 1 | 201 | 4.04 (0.88, 18.56) | NE | ND
Hepato-biliary
Elevated ALT121 | 1 | 201 | 1.01 (0.30, 3.38) | NE | ND
Sleep
Insomnia121 | 1 | 201 | 1.62 (0.77, 3.39) | NE | ND
Systemic AE
Headache121 | 1 | 201 | 1.62 (0.55, 4.77) | NE | ND

Significant results are in bold; AE = adverse event; ALT = alanine transaminase; BMI = body mass index; CNS = central nervous system; EPS = extrapyramidal symptoms/syndrome; GI = gastrointestinal; I^2^ = I–squared; ND = no difference; NE = not estimable

## Chlorpromazine Versus Ziprasidone

Table 119 Evidence summary table: chlorpromazine versus ziprasidone – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Mortality96 | 1 | 306 | NE | NE | ND
Withdrawals due to AEs96 | 1 | 306 | 1.32 (0.47, 3.70) | NE | ND

AE = adverse events; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 120 Evidence summary table: chlorpromazine versus ziprasidone – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
BMI and weight
Weight gain96 | 1 | 306 | 3.29 (0.92, 11.72) | NE | ND
Weight loss96 | 1 | 306 | 0.19 (0.06, 0.62) | NE | chlorpromazine
Cardiovascular
ECG abnormalities96 | 1 | 306 | NE | NE | ND
Orthostatic hypotension96 | 1 | 306 | 2.63 (0.71, 9.73) | NE | ND
CNS
Dizziness96 | 1 | 306 | 2.08 (0.97, 4.46) | NE | ND
Somnolence96 | 1 | 306 | 1.50 (0.99, 2.26) | NE | ND
Endocrine (prolactin - thyroid)
Amenorrhea96 | 1 | 306 | 3.95 (0.45, 34.92) | NE | ND
EPS
Akathisia96 | 1 | 306 | 1.43 (0.63, 3.24) | NE | ND
EPS96 | 1 | 306 | 1.09 (0.79, 1.49) | NE | ND
Tardive dyskinesia96 | 1 | 306 | 1.21 (0.61, 2.44) | NE | ND
Tremor96 | 1 | 306 | 0.42 (0.17, 1.07) | NE | ND
Genital, urinary, and breast
Male sexual dysfunction96 | 1 | 306 | 0.42 (0.11, 1.61) | NE | ND
GI
Vomiting96 | 1 | 306 | 0.74 (0.26, 2.08) | NE | ND

Significant results are in bold; BMI = body mass index; CNS = central nervous system; ECG = electrocardiogram EPS = extrapyramidal symptoms/syndrome; GI = gastrointestinal; I^2^ = I–squared; ND = no difference; NE = not estimable

## Fluphenazine Versus Olanzapine

Table 121 Evidence summary table: fluphenazine versus olanzapine – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Incidence of patients with AEs89 | 1 | 60 | 9.00 (0.51, 160.17) | NE | ND
Withdrawals due to AEs89 | 1 | 60 | 0.74 (0.51, 1.07) | NE | ND

AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 122 Evidence summary table: fluphenazine versus olanzapine – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
BMI and weight
Weight gain89 | 1 | 60 | 0.09 (0.01, 1.57) | NE | ND
CNS
Stupor89 | 1 | 60 | 3.00 (0.13, 70.83) | NE | ND
EPS
Akathisia89 | 1 | 60 | 0.33 (0.10, 1.11) | NE | ND
Dyskinesia89 | 1 | 60 | 0.25 (0.03, 2.11) | NE | ND
Dyskinetic symptoms89 | 1 | 60 | 2.00 (0.19, 20.90) | NE | ND
Hypertonia89 | 1 | 60 | 0.33 (0.04, 3.03) | NE | ND
Parkinsonism89 | 1 | 60 | 1.20 (0.41, 3.51) | NE | ND
Tremor89 | 1 | 60 | 1.50 (0.27, 8.34) | NE | ND
Sleep
Insomnia89 | 1 | 60 | 0.08 (0.00, 1.31) | NE | ND

AE = adverse event; BMI = body mass index; CNS = central nervous system; EPS = extrapyramidal symptoms/syndrome; I^2^ = I–squared; ND = no difference; NE = not estimable

## Fluphenazine Versus Quetiapine

Table 123 Evidence summary table: fluphenazine versus quetiapine – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Withdrawals due to adverse events67 | 1 | 25 | 0.19 (0.01, 3.52) | NE | ND

AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 124 Evidence summary table: fluphenazine versus quetiapine – persistence and reversibility of adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Amenorrhea resolved by end of study67 | 1 | 25 | NE | NE | ND
Gynecomastia resolved by end of study67 | 1 | 25 | 2.79 (0.12, 62.48) | NE | ND

I^2^ = I–squared; ND = no difference; NE = not estimable

Table 125 Evidence summary table: fluphenazine versus quetiapine – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Anxiety67 | 1 | 25 | 0.92 (0.06, 13.18) | NE | ND
Cardiovascular
ECG abnormalities67 | 1 | 25 | 0.31 (0.01, 6.94) | NE | ND
Orthostatic hypotension67 | 1 | 25 | 1.85 (0.19, 17.84) | NE | ND
Cholinergic and anticholinergic
Dry mouth67 | 1 | 25 | 0.46 (0.10, 2.08) | NE | ND
CNS
Dizziness67 | 1 | 25 | 0.92 (0.06, 13.18) | NE | ND
Lethargy67 | 1 | 25 | 1.38 (0.28, 6.91) | NE | ND
Somnolence67 | 1 | 25 | 1.23 (0.34, 4.40) | NE | ND
Endocrine (prolactin - thyroid)
Amenorrhea67 | 1 | 25 | NE | NE | ND
Galactorrhea67 | 1 | 25 | NE | NE | ND
EPS
Tremor67 | 1 | 25 | 0.31 (0.01, 6.94) | NE | ND
Genital, urinary, and breast
Gynecomastia67 | 1 | 25 | 2.79 (0.12, 62.48) | NE | ND
Urinary hesitancy67 | 1 | 25 | 0.92 (0.15, 5.56) | NE | ND
Urinary frequency67 | 1 | 25 | 0.31 (0.01, 6.94) | NE | ND
GI
Constipation67 | 1 | 25 | 0.92 (0.29, 2.89) | NE | ND
Diarrhea67 | 1 | 25 | 0.19 (0.01, 3.52) | NE | ND
Dyspepsia/heartburn67 | 1 | 25 | 2.77 (0.33, 23.14) | NE | ND
Increased appetite67 | 1 | 25 | 0.62 (0.12, 3.07) | NE | ND
Nausea/vomiting67 | 1 | 25 | 1.85 (0.19, 17.84) | NE | ND
Ophthalmology
Blurry vision67 | 1 | 25 | 0.92 (0.15, 5.56) | NE | ND
Sleep
Insomnia67 | 1 | 25 | 1.54 (0.46, 5.09) | NE | ND
Systemic AE
Headache67 | 1 | 25 | 0.92 (0.35, 2.41) | NE | ND

AE = adverse event; CNS = central nervous system; EPS = extrapyramidal symptoms/syndrome; GI = gastrointestinal; I^2^ = I–squared; ND = no difference; NE = not estimable

## Fluphenazine Versus Risperidone

Table 126 Evidence summary table: fluphenazine versus risperidone – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Withdrawals due to adverse events67 | 1 | 26 | NE | NE | ND

I^2^ = I–squared; ND = no difference; NE = not estimable

Table 127 Evidence summary table: fluphenazine versus risperidone – persistence and reversibility of adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Amenorrhea resolved by end of study67 | 1 | 26 | 0.33 (0.01, 7.50) | NE | ND
Gynecomastia resolved by end of study67 | 1 | 26 | 1.00 (0.07, 14.34) | NE | ND

I^2^ = I–squared; ND = no difference; NE = not estimable

Table 128 Evidence summary table: fluphenazine versus risperidone – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Anxiety67 | 1 | 26 | 0.50 (0.05, 4.86) | NE | ND
Cardiovascular
ECG abnormalities67 | 1 | 26 | NE | NE | ND
Orthostatic hypotension67 | 1 | 26 | 0.40 (0.09, 1.70) | NE | ND
Cholinergic and anticholinergic
Dry mouth67 | 1 | 26 | 1.00 (0.16, 6.07) | NE | ND
CNS
Dizziness67 | 1 | 26 | 0.33 (0.04, 2.80) | NE | ND
Lethargy67 | 1 | 26 | 0.75 (0.21, 2.71) | NE | ND
Somnolence67 | 1 | 26 | 0.80 (0.28, 2.32) | NE | ND
Endocrine (prolactin - thyroid)
Amenorrhea67 | 1 | 26 | 0.20 (0.01, 3.80) | NE | ND
Galactorrhea67 | 1 | 26 | 0.33 (0.01, 7.50) | NE | ND
EPS
Tremor67 | 1 | 26 | NE | NE | ND
Genital, urinary, and breast
Gynecomastia67 | 1 | 26 | 1.00 (0.07, 14.34) | NE | ND
Urinary hesitancy67 | 1 | 26 | 5.00 (0.26, 95.02) | NE | ND
Urinary frequency67 | 1 | 26 | 0.33 (0.01, 7.50) | NE | ND
GI
Constipation67 | 1 | 26 | 9.00 (0.53, 151.94) | NE | ND
Diarrhea67 | 1 | 26 | 0.20 (0.01, 3.80) | NE | ND
Dyspepsia67 | 1 | 26 | 3.00 (0.36, 25.21) | NE | ND
Increased appetite67 | 1 | 26 | 0.67 (0.13, 3.35) | NE | ND
Nausea67 | 1 | 26 | 0.67 (0.13, 3.35) | NE | ND
Ophthalmology
Blurry vision67 | 1 | 26 | 1.00 (0.16, 6.07) | NE | ND
Sleep
Insomnia67 | 1 | 26 | 1.67 (0.50, 5.57) | NE | ND
Systemic AE
Headache67 | 1 | 26 | 0.71 (0.30, 1.67) | NE | ND

AE = adverse event; CNS = central nervous system; ECG = electrocardiogram; EPS = extrapyramidal symptoms/syndrome; GI = gastrointestinal; I^2^ = I–squared; ND = no difference; NE = not estimable

## Haloperidol Versus Aripiprazole

Table 129 Evidence summary table: haloperidol versus aripiprazole – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Incidence of patients with AEs31,73,98 | 3 | 1713 | 1.11 (1.06, 1.17) | 0% | aripiprazole
Mortality31,44 | 2 | 655 | 0.77 (0.04, 15.91) | NE | ND
Serious AEs31–33,44,76,92 | 6 | 1741 | 0.84 (0.35, 2.03) | 58% | ND
Withdrawals due to AEs31–33,44,76,92,98 | 7 | 3035 | 1.25 (1.06, 1.47) | 0% | aripiprazole

AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 130 Evidence summary table: haloperidol versus aripiprazole – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Agitation31,44,74,98 | 4 | 2253 | 1.09 (0.80, 1.48) | 0% | ND
Anxiety33,74,92,98 | 4 | 2238 | 0.93 (0.73, 1.19) | 0% | ND
Depression32,33 | 2 | 679 | 0.85 (0.26, 2.76) | 82% | ND
Deterioration73 | 1 | 124 | 0.34 (0.01, 8.29) | NE | ND
Mania33 | 1 | 332 | 0.20 (0.05, 0.91) | NE | haloperidol
Psychosis98 | 1 | 1294 | 0.89 (0.69, 1.15) | NE | ND
BMI and weight
Weight gain33,92,98 | 3 | 1934 | 1.03 (0.54, 1.96) | 53% | ND
Cardiovascular
ECG abnormalities31,32,92 | 3 | 950 | 1.33 (0.42, 4.19) | 36% | ND
Orthostatic hypotension92 | 1 | 308 | 0.22 (0.03, 1.70) | NE | ND
Tachycardia31 | 1 | 295 | 1.57 (0.51, 4.82) | NE | ND
CNS
Dizziness31,44,92 | 3 | 963 | 0.53 (0.31, 0.90) | 0% | haloperidol
Seizure31 | 1 | 295 | 1.29 (0.05, 31.27) | NE | ND
Somnolence31,33,44,74,92,98 | 6 | 2893 | 1.39 (1.03, 1.87) | 0% | aripiprazole
Dermatology
Injection site reaction31,44 | 2 | 655 | 0.36 (0.09, 1.45) | 0% | ND
Endocrine (prolactin - thyroid)
Hyperprolactinemia32,33 | 2 | 679 | 3.67 (2.16, 6.24) | 70% | aripiprazole
EPS
Akathisia31–33,74,76,92,98 | 7 | 2979 | 2.04 (1.70, 2.44) | 0% | aripiprazole
Asthenia92 | 1 | 308 | 1.09 (0.37, 3.17) | NE | ND
Dystonia31 | 1 | 295 | 7.83 (1.47, 41.76) | NE | aripiprazole
EPS32,33,44,74,92,98 | 6 | 2945 | 2.22 (1.37, 3.59) | 83% | aripiprazole
Hypertonia92 | 1 | 308 | 0.59 (0.17, 2.09) | NE | ND
Rigidity33 | 1 | 332 | 8.10 (1.89, 34.66) | NE | aripiprazole
Tremor32,33,76,92,98 | 5 | 2380 | 1.99 (1.42, 2.78) | 4% | aripiprazole
GI
Abdominal pain92 | 1 | 308 | 0.78 (0.31, 1.96) | NE | ND
Diarrhea74 | 1 | 304 | 1.01 (0.26, 3.98) | NE | ND
Dyspepsia74 | 1 | 304 | 9.12 (1.17, 71.10) | NE | aripiprazole
Nausea/Vomiting31,44,74,92 | 4 | 1267 | 0.49 (0.28, 0.85) | 0% | haloperidol
Hepato-biliary
Liver Damage32 | 1 | 347 | 3.05 (0.13, 74.41) | NE | ND
Ophthalmology
Blurred vision92 | 1 | 308 | 5.23 (1.42, 19.30) | NE | aripiprazole
Sleep
Insomnia32,33,44,74,76,92,98 | 7 | 3044 | 0.85 (0.59, 1.23) | 65% | ND
Systemic AE
Headache31–33,44,74,92,98 | 7 | 3240 | 1.00 (0.81, 1.24) | 0% | ND

Significant results are in bold; AE = adverse event; BMI = body mass index; CNS = central nervous system; EPS = extrapyramidal symptoms/syndrome; GI = gastrointestinal; I^2^ = I–squared; ND = no difference; NE = not estimable

## Haloperidol Versus Asenapine

Table 131 Evidence summary table: haloperidol versus asenapine – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Incidence of patients with adverse events97 | 1 | 335 | 1.09 (0.96, 1.25) | NE | ND
Serious adverse events97 | 1 | 335 | 0.96 (0.42, 2.17) | NE | ND
Withdrawals due to adverse events97 | 1 | 335 | 1.53 (0.74, 3.16) | NE | ND

I^2^ = I–squared; ND = no difference; NE = not estimable

Table 132 Evidence summary table: haloperidol versus asenapine – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Agitation97 | 1 | 335 | 1.01 (0.47, 2.20) | NE | ND
Anxiety97 | 1 | 335 | 1.12 (0.45, 2.76) | NE | ND
Worse psychotic symptoms97 | 1 | 335 | 1.28 (0.54, 3.03) | NE | ND
BMI and weight
Weight gain97 | 1 | 335 | 0.96 (0.33, 2.73) | NE | ND
Weight loss97 | 1 | 335 | 0.27 (0.01, 5.22) | NE | ND
CNS
Oral hypoesthesia97 | 1 | 335 | 0.04 (0.00, 0.69) | NE | haloperidol
Sedation97 | 1 | 335 | 0.59 (0.20, 1.76) | NE | ND
Somnolence97 | 1 | 335 | 0.21 (0.05, 0.90) | NE | haloperidol
Endocrine (prolactin - thyroid)
Abnormal Fasting glucose97 | 1 | 335 | 1.91 (0.39, 9.33) | NE | ND
Hyperprolactinemia97 | 1 | 335 | 2.30 (1.02, 5.15) | NE | asenapine
EPS
Akathisia97 | 1 | 335 | 1.71 (0.93, 3.16) | NE | ND
Dystonia97 | 1 | 335 | 3.51 (1.33, 9.24) | NE | asenapine
EPS97 | 1 | 335 | 2.07 (1.40, 3.07) | NE | asenapine
Parkinsonism97 | 1 | 335 | 1.91 (0.99, 3.68) | NE | ND
Rigidity97 | 1 | 335 | 2.19 (0.81, 5.88) | NE | ND
GI
Nausea/Vomiting97 | 1 | 335 | 0.48 (0.10, 2.22) | NE | ND
Sleep
Insomnia97 | 1 | 335 | 0.75 (0.44, 1.27) | NE | ND
Systemic AE
Headache97 | 1 | 335 | 0.64 (0.24, 1.71) | NE | ND

Significant results are in bold; AE = adverse event; BMI = body mass index; CNS = central nervous system; EPS = extrapyramidal symptoms/syndrome; GI = gastrointestinal; I^2^ = I–squared; ND = no difference; NE = not estimable

## Haloperidol Versus Clozapine

Table 133 Evidence summary table: haloperidol versus clozapine – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Incidence of patients with adverse events126 | 1 | 423 | 0.81 (0.49, 1.34) | NE | ND
Mortality (Cohort)163 | 1 | 49625 | 1.98 (1.30, 3.00) | NE | clozapine
Withdrawals due to adverse events55,95,105,126,145 | 5 | 719 | 1.00 (0.66, 1.50) | 0% | ND

Significant results are in bold; AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 134 Evidence summary table: haloperidol versus clozapine – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Clinical deterioration conducive to termination145 | 1 | 77 | 3.24 (0.70, 15.08) | NE | ND
Irritability155 | 1 | 88 | 3.21 (1.26, 8.15) | NE | clozapine
Overt aggression145 | 1 | 77 | 1.66 (1.03, 2.66) | NE | clozapine
BMI and weight
Weight gain105,145 | 2 | 150 | 0.34 (0.01, 7.76) | 80% | ND
Cardiovascular
Hypertension55 | 1 | 75 | 2.57 (0.53, 12.42) | NE | ND
Hypertensive episodes145 | 1 | 77 | 0.22 (0.01, 4.35) | NE | ND
Intrathoracic oppression155 | 1 | 88 | 0.29 (0.06, 1.27) | NE | ND
Orthostatic hypotension155 | 1 | 88 | 0.48 (0.18, 1.24) | NE | ND
Palpitation155 | 1 | 88 | 0.29 (0.06, 1.27) | NE | ND
Cholinergic and anticholinergic
Dry mouth55,155 | 2 | 163 | 2.81 (1.61, 4.92) | 0% | clozapine
Hypersalivation55 | 1 | 75 | 0.23 (0.12, 0.46) | NE | haloperidol
CNS
Dizziness55,155 | 2 | 163 | 0.84 (0.18, 3.95) | 90% | ND
Drowsiness155 | 1 | 88 | 0.72 (0.40, 1.30) | NE | ND
Dysarthria155 | 1 | 88 | 1.72 (0.30, 9.79) | NE | ND
Sedation55 | 1 | 75 | 0.67 (0.39, 1.14) | NE | ND
Seizures145 | 1 | 77 | 0.12 (0.01, 2.15) | NE | ND
Seizures conducive to termination145 | 1 | 77 | 0.22 (0.01, 4.35) | NE | ND
Dermatology
Pruritus155 | 1 | 88 | 0.23 (0.01, 4.63) | NE | ND
Rash155 | 1 | 88 | 0.23 (0.01, 4.63) | NE | ND
Endocrine (prolactin - thyroid)
Abnormal menstruation155 | 1 | 88 | 3.44 (0.37, 31.79) | NE | ND
EPS
Hyperkinesia155 | 1 | 88 | 2.01 (1.13, 3.56) | NE | clozapine
Hypertonia155 | 1 | 88 | 1.59 (0.89, 2.83) | NE | ND
Tardive Dyskinesia (Cohort)162 | 1 | 333 | 34.50 (2.07, 573.55) | NE | clozapine
Genital, urinary, and breast
Enuresis55 | 1 | 75 | 0.15 (0.01, 2.74) | NE | ND
GI
Constipation55,155 | 2 | 163 | 1.10 (0.62, 1.95) | 0% | ND
Diarrhea55,155 | 2 | 163 | 0.75 (0.22, 2.55) | 0% | ND
Loss of Appetite155 | 1 | 88 | 1.02 (0.43, 2.40) | NE | ND
Nausea/Vomiting55,155 | 2 | 163 | 0.44 (0.21, 0.93) | 17% | haloperidol
Other GI155 | 1 | 88 | 0.46 (0.09, 2.24) | NE | ND
Hematology
Agranulocytosis126,145 | 2 | 500 | 0.21 (0.02, 1.85) | 0% | ND
Bruising55 | 1 | 75 | NE | NE | ND
Hematological problems conducive to termination145 | 1 | 77 | 0.15 (0.01, 2.89) | NE | ND
Leukopenia126 | 1 | 423 | 0.47 (0.09, 2.54) | NE | ND
Neutropenia126,145 | 2 | 500 | 0.97 (0.41, 2.30) | 0% | ND
Metabolic
Abnormal Glucose levels105 | 1 | 73 | 0.05 (0.00, 0.80) | NE | haloperidol
Hypercholesterolemia105 | 1 | 73 | 0.08 (0.00, 1.35) | NE | ND
Hypertriglyceridemia105 | 1 | 73 | 0.39 (0.11, 1.34) | NE | ND
Metabolic syndrome (emergent)105 | 1 | 73 | 0.27 (0.10, 0.75) | NE | haloperidol
Ophthalmology
Ophthalmic disturbances155 | 1 | 88 | 3.44 (0.37, 31.79) | NE | ND
Respiratory and airway
Cough155 | 1 | 88 | 0.57 (0.11, 2.97) | NE | ND
Nasal congestion155 | 1 | 88 | 0.23 (0.03, 1.88) | NE | ND
Sore throat55 | 1 | 75 | 1.37 (0.33, 5.70) | NE | ND
Sleep
Insomnia155 | 1 | 88 | 3.44 (1.51, 7.84) | NE | clozapine
Systemic AE
Headache155 | 1 | 88 | 0.53 (0.24, 1.18) | NE | ND
Fever55,155 | 2 | 163 | 0.65 (0.36, 1.15) | 0% | ND
Intercurrent illnesses conducive to termination145 | 1 | 77 | 0.36 (0.04, 3.31) | NE | ND
Malaise55 | 1 | 75 | 0.51 (0.23, 1.13) | NE | ND
Sweating155 | 1 | 88 | 0.13 (0.02, 0.96) | NE | ND
Weakness155 | 1 | 88 | 0.51 (0.17, 1.53) | NE | ND

Significant results are in bold; AE = adverse event; BMI = body mass index; CNS = central nervous system; EPS = extrapyramidal symptoms/syndrome; GI = gastrointestinal; I^2^ = I–squared; ND = no difference; NE = not estimable

## Haloperidol Versus Olanzapine

Table 135 Evidence summary table: haloperidol versus olanzapine – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Incidence of patients with adverse events73 | 1 | 119 | 10.47 (0.59, 185.18) | NE | ND
Persistence and reversibility of AE88 | 1 | 182 | 3.48 (0.99, 12.24) | NE | ND
Serious AEs91,104,147 | 3 | 741 | 1.41 (0.32, 6.21) | 54% | ND
Withdrawals due to adverse events43,49,50,54,71,78,84,88,91,101,104,105,108,110,124,127,140,141,145,147,159 | 21 | 5351 | 1.87 (1.55, 2.27) | 0% | olanzapine

Significant results are in bold; AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 136 Evidence summary table: haloperidol versus olanzapine – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Abnormal thinking101 | 1 | 256 | 0.98 (0.37, 2.62) | NE | ND
Accommodation disturbance159 | 1 | 27 | 8.18 (0.43, 155.12) | NE | ND
Agitation49,101 | 2 | 523 | 1.25 (0.85, 1.85) | 0% | ND
Anorexia88 | 1 | 182 | 3.66 (1.25, 10.69) | NE | olanzapine
Anxiety49,88,101,147 | 4 | 962 | 1.27 (0.90, 1.79) | 0% | ND
Appetite (decreased)141 | 1 | 1996 | 1.56 (1.25, 1.96) | NE | olanzapine
Appetite (excessive) 141 | 1 | 1996 | 0.51 (0.41, 0.64) | NE | haloperidol
Behavioral deterioration73,84 | 2 | 129 | 0.76 (0.05, 11.55) | 39% | ND
Conversion symptoms141 | 1 | 1996 | 2.34 (1.12, 4.88) | NE | olanzapine
Depression101 | 1 | 256 | 0.64 (0.34, 1.23) | NE | ND
Excitement88 | 1 | 182 | 1.04 (0.54, 2.01) | NE | ND
Hallucinations84,101 | 2 | 266 | 1.06 (0.53, 2.11) | 0% | ND
Nervousness49,101 | 2 | 523 | 1.45 (1.00, 2.11) | 0% | ND
Overt aggression/violent behavior49,110,145 | 3 | 378 | 1.22 (0.54, 2.73) | 52% | ND
Paranoia101 | 1 | 256 | 1.64 (0.71, 3.79) | NE | ND
Personality disorder49 | 1 | 267 | 0.51 (0.15, 1.68) | NE | ND
Suicidal ideation110 | 1 | 35 | 0.84 (0.06, 12.42) | NE | ND
Suicide88 | 1 | 182 | 3.13 (0.13, 75.92) | NE | ND
suicide (attempt)88 | 1 | 182 | 3.13 (0.13, 75.92) | NE | ND
BMI and weight
Overweight/Obese91,129 | 2 | 274 | 0.35 (0.21, 0.58) | 0% | haloperidol
Weight gain49,71,88,91,101,104,105,108,127,129,140–142,145,159 | 15 | 4600 | 0.47 (0.37, 0.61) | 75% | haloperidol
Weight loss88,141 | 2 | 2178 | 2.43 (0.74, 7.99) | 46% | ND
Cardiovascular
ECG abnormalities56,91 | 2 | 433 | 0.34 (0.04, 3.21) | NE | ND
Hypertensive episodes145 | 1 | 76 | NE | NE | ND
Hypotension56 | 1 | 225 | 0.30 (0.02, 5.19) | NE | ND
Palpitations141 | 1 | 1996 | 1.48 (1.09, 2.02) | NE | olanzapine
Cholinergic and anticholinergic
Dry mouth49,71,101,141,159 | 5 | 2657 | 0.75 (0.62, 0.91) | 0% | haloperidol
Hypersalivation50,71,88,140,141,159 | 6 | 3200 | 3.38 (1.79, 6.38) | 49% | olanzapine
CNS
Asthenia49,71,159 | 3 | 405 | 1.43 (1.00, 2.05) | 0% | ND
Concentration difficulty71 | 1 | 111 | 3.93 (0.87, 17.68) | NE | ND
Dizziness49,101,140 | 3 | 976 | 0.69 (0.22, 2.20) | 76% | ND
Drowsiness141 | 1 | 1996 | 1.19 (1.02, 1.38) | NE | olanzapine
Seizures145 | 1 | 76 | NE | NE | ND
Somnolence49,71,88,101,140,159 | 6 | 1296 | 0.84 (0.63, 1.12) | 35% | ND
Gait abnormalities88 | 1 | 182 | 8.36 (1.98, 35.32) | NE | olanzapine
Heaviness in extremities141 | 1 | 1996 | 1.40 (1.11, 1.77) | NE | olanzapine
Hypokinesia71,140,141,159 | 4 | 2587 | 3.01 (1.88, 4.82) | 7% | olanzapine
Hypotonia141 | 1 | 1996 | 1.68 (1.03, 2.72) | NE | olanzapine
Dermatology
Maculopapular rash147 | 1 | 257 | 0.35 (0.01, 8.43) | NE | ND
Endocrine (prolactin - thyroid)
Amenorrhea71 | 1 | 111 | 4.91 (0.24, 100.05) | NE | ND
Hot flashes141 | 1 | 1996 | 1.62 (1.06, 2.49) | NE | olanzapine
Hyperprolactinemia50,91,108 | 3 | 902 | NR | 97% | ND
EPS
Akathisia49–51,56,71,88,91,101,104,108,127,140,141,159 | 14 | 5031 | 3.11 (2.43, 3.98) | 38% | olanzapine
Ataxia141 | 1 | 1996 | 1.84 (1.01, 3.35) | NE | olanzapine
Bradykinesia88 | 1 | 182 | 8.36 (1.98, 35.32) | NE | olanzapine
Dyskinesia50,91,140,141 | 4 | 3088 | 3.55 (2.01, 6.27) | 10% | olanzapine
Dystonia49,50,56,91,104,140,147,159 | 8 | 2144 | 5.01 (2.70, 9.28) | 0% | olanzapine
EPS50,104,106,140,141,147 | 6 | 3445 | 3.88 (2.19, 6.85) | 69% | olanzapine
Hypertonia49,50,140,141 | 4 | 3147 | 2.54 (1.65, 3.91) | 55% | olanzapine
Neuroleptic malignant syndrome147 | 1 | 257 | 3.12 (0.13, 75.83) | NE | ND
Parkinsonism51,56,71,84,88,91,108,147 | 8 | 1283 | 4.28 (2.49, 7.35) | 50% | olanzapine
Rigidity71,159 | 2 | 138 | 10.65 (2.08, 54.50) | 0% | olanzapine
Tardive dyskinesia140 | 1 | 453 | 11.75 (0.65, 211.26) | NE | ND
Tremor49,50,71,88,101,104,140,141,159 | 9 | 3999 | 2.30 (1.59, 3.34) | 58% | olanzapine
Genital, urinary, and breast
Difficult micturition141 | 1 | 1996 | 1.68 (1.11, 2.54) | NE | olanzapine
Ejaculatory dysfunction71 | 1 | 111 | 4.91 (0.24, 100.05) | NE | ND
Erectile dysfunction71 | 1 | 111 | 4.91 (0.59, 40.69) | NE | ND
Micturition disturbances159 | 1 | 27 | 3.40 (0.35, 32.90) | NE | ND
GI
Constipation49,101,159 | 3 | 550 | 1.06 (0.43, 2.63) | 23% | ND
Diarrhea101 | 1 | 256 | 1.64 (0.84, 3.20) | NE | ND
Dyspepsia49 | 1 | 267 | 1.32 (0.68, 2.54) | NE | ND
Nausea/Vomiting49,88,101,141,141 | 5 | 4697 | 1.43 (1.06, 1.92) | 34% | olanzapine
Hematology
Agranulocytosis141,145 | 2 | 2072 | NE | NE | ND
Eosinophilia50 | 1 | 431 | 0.19 (0.01, 3.13) | NE | ND
Hematological problems conducive to termination145 | 1 | 76 | NE | NE | ND
Neutropenia145 | 1 | 76 | 3.16 (0.13, 75.16) | NE | ND
Hepato-biliary
Elevated ALT50 | 1 | 431 | 0.14 (0.02, 1.04) | NE | ND
Increased gGT50 | 1 | 431 | 0.33 (0.02, 5.79) | NE | ND
SGOT abnormality108 | 1 | 263 | 0.41 (0.28, 0.58) | NE | haloperidol
SGPT abnormality49,108 | 2 | 530 | 0.46 (0.35, 0.62) | 0% | haloperidol
Metabolic
Diabetes129 | 1 | 66 | 0.85 (0.21, 3.49) | NE | ND
Hypercholesterolemia91,105 | 2 | 281 | 0.43 (0.26, 0.72) | 0% | haloperidol
Hyperglycemia91,105 | 2 | 281 | 0.28 (0.12, 0.66) | 0% | haloperidol
Hypertriglyceridemia91,105 | 2 | 281 | 0.53 (0.30, 0.92) | 0% | haloperidol
HDL (low)91 | 1 | 208 | 0.38 (0.16, 0.94) | NE | haloperidol
Metabolic syndrome105,129 | 2 | 139 | 0.38 (0.06, 2.51) | 63% | ND
Ophthalmology
Blurred vision141 | 1 | 1996 | 1.40 (1.10, 1.78) | NE | olanzapine
Respiratory and airway
Rhinitis49,101 | 2 | 523 | 1.44 (0.90, 2.33) | 0% | ND
Sleep
Early awakening141 | 1 | 1996 | 1.49 (1.24, 1.79) | NE | olanzapine
Increased dreams/nightmares141 | 1 | 1996 | 1.31 (1.05, 1.63) | NE | olanzapine
Insomnia49,50,88,101,104,127,141 | 7 | 3717 | 1.36 (1.03, 1.80) | 49% | olanzapine
Systemic AE
Chills141 | 1 | 1996 | 1.74 (1.19, 2.52) | NE | olanzapine
Fever140 | 1 | 453 | 0.05 (0.00, 0.86) | NE | haloperidol
Headache49,50,101 | 3 | 954 | 1.19 (0.85, 1.65) | 0% | ND
Infection140 | 1 | 453 | 0.27 (0.08, 0.93) | NE | haloperidol
Increased perspiration141 | 1 | 1996 | 1.91 (1.44, 2.54) | NE | olanzapine
Injury49 | 1 | 267 | 0.86 (0.24, 3.04) | NE | ND
Intercurrent illnesses conducive to termination145 | 1 | 76 | 1.05 (0.07, 16.24) | NE | ND
Malaise88 | 1 | 182 | 0.94 (0.40, 2.21) | NE | ND
Pain49,101 | 2 | 523 | 0.81 (0.44, 1.50) | 22% | ND
Tension159 | 1 | 27 | 14.73 (0.87, 248.02) | NE | ND

Significant results are in bold; AE = adverse event; ALT = alanine transaminase; BMI = body mass index; CNS = central nervous system; ECG = electrocardiogram; EPS = extrapyramidal symptoms/syndrome; gGT = serum gamma-glutamyl transferase; GI = gastrointestinal; HDL = high density lipoprotein; I^2^ = I–squared; ND = no difference; NE = not estimable; SGOT = serum glutamic oxaloacetic transaminase; SGPT = serum glutamic pyruvic transaminase

## Haloperidol Versus Quetiapine

Table 137 Evidence summary table: haloperidol versus quetiapine – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Incidence of patients with AEs68,73,79 | 3 | 859 | 1.08 (0.93, 1.25) | 25% | ND
Serious AEs91 | 1 | 207 | 1.68 (0.41, 6.86) | NE | ND
Withdrawals due to AEs46,47,68,79,80,91,115,123 | 8 | 1559 | 1.98 (0.79, 4.96) | 73% | ND

AE = adverse event; I^2^ = I–squared; ND = no difference NE = not estimable

Table 138 Evidence summary table: haloperidol versus quetiapine – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Agitation46,68,115,123 | 4 | 984 | 0.83 (0.51, 1.36) | 0% | ND
Anxiety68 | 1 | 448 | 1.86 (0.92, 3.76) | NE | ND
Asthenia68 | 1 | 448 | 0.29 (0.12, 0.71) | NE | haloperidol
Depression115 | 1 | 201 | 2.75 (0.75, 10.06) | NE | ND
Deterioration73 | 1 | 123 | NE | NE | ND
Fatigue123 | 1 | 25 | 0.36 (0.02, 8.05) | NE | ND
Irritability123 | 1 | 25 | 3.23 (0.14, 72.46) | NE | ND
BMI and weight
Overweight91 | 1 | 207 | 0.65 (0.37, 1.14) | NE | ND
Weight gain46,91,123 | 3 | 542 | 0.59 (0.39, 0.89) | 0% | haloperidol
Cardiovascular
ECG abnormalities46,91 | 2 | 517 | 0.50 (0.05, 5.48) | NE | ND
Orthostatic hypotension46,68,115 | 3 | 959 | 0.49 (0.25, 0.94) | 0% | haloperidol
Cholinergic and anticholinergic
Dry mouth68,115,123 | 3 | 674 | 0.32 (0.15, 0.65) | 0% | haloperidol
Hypersalivation68,123 | 2 | 473 | 1.88 (0.22, 16.18) | 50% | ND
CNS
Dizziness46,68 | 2 | 758 | 0.68 (0.36, 1.28) | 0% | ND
Drowsiness123 | 1 | 25 | 0.36 (0.02, 8.05) | NE | ND
Sedation123 | 1 | 25 | 3.23 (0.14, 72.46) | NE | ND
Somnolence46,68,115,123 | 4 | 984 | 0.57 (0.39, 0.84) | 0% | haloperidol
Dermatology
Dry skin/rash123 | 1 | 25 | 3.23 (0.14, 72.46) | NE | ND
Endocrine (prolactin - thyroid)
Amenorrhea/Menstrual cycle irregularities123 | 1 | 25 | 0.36 (0.02, 8.05) | NE | ND
Cold flashes123 | 1 | 25 | 0.36 (0.02, 8.05) | NE | ND
Galactorrhea47 | 1 | 35 | 5.28 (0.27, 102.58) | NE | ND
Hyperprolactinemia68,79,91 | 3 | 943 | 2.24 (1.04, 4.80) | 89% | quetiapine
Thyroid function test abnormalities68 | 1 | 448 | 0.05 (0.00, 0.79) | NE | haloperidol
EPS
Akathisia46,68,79,91,115 | 5 | 1454 | 3.51 (1.84, 6.72) | 68% | quetiapine
Akinesia68 | 1 | 448 | 2.92 (0.12, 71.32) | NE | ND
Cogwheel rigidity68 | 1 | 448 | 2.92 (0.12, 71.32) | NE | ND
Dyskinesia91 | 1 | 207 | 5.05 (0.25, 103.88) | NE | ND
Dystonia46,68,91 | 3 | 965 | 3.94 (0.79, 19.70) | 29% | ND
EPS46,68,79,80,115 | 5 | 1292 | NR | 90% | ND
Fine tremors123 | 1 | 25 | 0.36 (0.02, 8.05) | NE | ND
Hypertonia68,79 | 2 | 736 | 2.05 (0.82, 5.10) | 60% | ND
Involuntary movement (jaw)123 | 1 | 25 | 0.36 (0.02, 8.05) | NE | ND
Neck rigidity68 | 1 | 448 | 2.92 (0.12, 71.32) | NE | ND
Oculogyric crisis68 | 1 | 448 | 6.82 (0.35, 131.19) | NE | ND
Parkinsonism46,91 | 2 | 517 | 4.04 (1.97, 8.26) | 53% | quetiapine
Stiffness123 | 1 | 25 | 3.23 (0.14, 72.46) | NE | ND
Tardive dyskinesia65 | 1 | 35 | NE | NE | ND
Tremor68,115 | 2 | 649 | 3.80 (2.12, 6.81) | 0% | quetiapine
Twitch in the extremities123 | 1 | 25 | 0.36 (0.02, 8.05) | NE | ND
GI
Constipation46,68 | 2 | 758 | 0.45 (0.22, 0.93) | 0% | haloperidol
Dyspepsia46 | 1 | 310 | 0.99 (0.35, 2.78) | NE | ND
Hematology
Agranulocytosis46 | 1 | 310 | NE | NE | ND
Leucopenia68 | 1 | 448 | 0.32 (0.03, 3.10) | NE | ND
Hepato-biliary
Elevated liver transaminases68 | 1 | 448 | 0.14 (0.02, 1.12) | NE | ND
Metabolic
HDL (low)91 | 1 | 207 | 0.76 (0.27, 2.11) | NE | ND
Hypercholesterolemia91 | 1 | 207 | 1.24 (0.63, 2.45) | NE | ND
Hyperglycemia91 | 1 | 207 | 0.67 (0.25, 1.82) | NE | ND
Hypertriglyceridemia91 | 1 | 207 | 1.19 (0.56, 2.54) | NE | ND
Ophthalmology
Blurred vision123 | 1 | 25 | 3.23 (0.14, 72.46) | NE | ND
Sleep
Insomnia46,68,115,123 | 4 | 984 | 1.12 (0.71, 1.76) | 29% | ND
Systemic AE
Headache46,68,115,123 | 4 | 984 | 1.31 (0.86, 1.98) | 5% | ND

Significant results are in bold; AE = adverse event; BMI = body mass index; CNS = central nervous system; ECG = electrocardiogram; EPS = extrapyramidal symptoms/syndrome; GI = gastrointestinal; HDL = high density lipoprotein; I^2^ = I–squared; ND = no difference; NE = not estimable

## Haloperidol Versus Risperidone

Table 139 Evidence summary table: haloperidol versus risperidone – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
AE resolved spontaneously by 24hrs151 | 1 | 124 | 1.06 (0.60, 1.86) | NE | ND
Incidence of patients with AEs72,73,81,85,117,128,136,151 | 8 | 1313 | 1.20 (1.01, 1.42) | 84% | risperidone
Mortality (Cohort)163 | 1 | 63352 | 1.70 (1.31, 2.20) | NE | risperidone
Serious AEs52 | 1 | 41 | NE | NE | ND
Withdrawals due to AEs52,59–61,64,71,72,81,82,85,90,101,118,120,124,128,132,138,145,146,149–151 | 23 | 4421 | 1.27 (1.04, 1.55) | 0% | risperidone

Significant results are in bold; AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 140 Evidence summary table: haloperidol versus risperidone – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Abnormal thinking101 | 1 | 255 | 0.61 (0.25, 1.51) | NE | ND
Accommodation disturbances120,149 | 2 | 1403 | 1.37 (0.99, 1.89) | 0% | ND
Agitation61,72,81,101 | 4 | 916 | 1.30 (0.96, 1.76) | 7% | ND
Anxiety61,81,101 | 3 | 551 | 0.95 (0.67, 1.34) | 67% | ND
Asthenia52,71,117,120,149 | 5 | 1596 | 1.20 (1.02, 1.41) | 0% | risperidone
Concentration difficulty64,71,117,120 | 4 | 1556 | 1.18 (0.97, 1.43) | 65% | ND
Decreased appetite64 | 1 | 42 | 0.55 (0.25, 1.20) | NE | ND
Depression101,118 | 2 | 544 | 0.63 (0.34, 1.16) | 0% | ND
Deterioration73 | 1 | 126 | NE | NE | ND
Drug overdose118 | 1 | 289 | 0.33 (0.01, 7.95) | NE | ND
Decreased sexual desire120,149 | 2 | 1403 | 1.07 (0.72, 1.59) | 0% | ND
Fatigue60,64 | 2 | 104 | 1.00 (0.63, 1.60) | 0% | ND
Hallucination101 | 1 | 255 | 1.00 (0.49, 2.02) | NE | ND
Increased appetite64 | 1 | 42 | 1.20 (0.43, 3.33) | NE | ND
Manic reaction128 | 1 | 105 | 6.87 (0.36, 129.81) | NE | ND
Nervousness101 | 1 | 255 | 1.20 (0.68, 2.14) | NE | ND
Paranoia101 | 1 | 255 | 1.16 (0.54, 2.52) | NE | ND
Sexual disturbances52 | 1 | 41 | 0.35 (0.02, 8.10) | NE | ND
BMI and weight
Weight gain101 | 1 | 255 | 0.19 (0.05, 0.81) | NE | haloperidol
Cardiovascular
ECG abnormalities128 | 1 | 105 | 1.31 (0.31, 5.56) | NE | ND
Hypotension61 | 1 | 113 | 1.41 (0.06, 33.44) | NE | ND
Orthostatic tachycardia61 | 1 | 113 | 0.60 (0.03, 11.27) | NE | ND
Orthostatic hypotension52,61,64 | 3 | 196 | 0.76 (0.39, 1.48) | 0% | ND
Palpitation52,64 | 2 | 83 | 1.18 (0.44, 3.13) | 0% | ND
Cholinergic and anticholinergic
Decreased salivation71 | 1 | 117 | 2.54 (0.69, 9.35) | NE | ND
Dry mouth52,60,64,101 | 4 | 400 | 1.44 (0.89, 2.33) | 0% | ND
Hypersalivation85 | 1 | 77 | 0.15 (0.01, 2.89) | NE | ND
CNS
Dizziness101,128,151 | 3 | 484 | 1.20 (0.72, 1.99) | 22% | ND
Sedation64 | 1 | 42 | 0.87 (0.56, 1.33) | NE | ND
Somnolence52,53,101,128,151 | 5 | 549 | 1.09 (0.79, 1.50) | 0% | ND
Vertigo52,64 | 2 | 83 | 0.56 (0.23, 1.38) | 63% | ND
Endocrine (prolactin - thyroid)
Amenorrhea64,71,120,149 | 4 | 1562 | 1.17 (0.80, 1.71) | 0% | ND
Galactorrhea132 | 1 | 555 | 0.08 (0.00, 1.36) | NE | ND
EPS
Akathisia52,60,71,101,139,146,149 | 7 | 619 | 1.79 (1.31, 2.44) | 0% | risperidone
Dystonia60,139,149 | 3 | 139 | 1.01 (0.41, 2.50) | 19% | ND
EPS61,117,128,138,151 | 5 | 675 | 1.86 (1.46, 2.36) | 0% | risperidone
Oculogyric crisis85 | 1 | 77 | 0.15 (0.01, 2.89) | NE | ND
Tremor52,85,101,128 | 4 | 478 | 2.09 (1.23, 3.53) | 0% | risperidone
Genital, urinary, and breast
Breast tension64 | 1 | 42 | 4.00 (0.49, 32.87) | NE | ND
Dry vagina149 | 1 | 41 | 0.53 (0.11, 2.56) | NE | ND
Ejaculatory dysfunction64,71,120,149 | 4 | 1562 | 0.68 (0.43, 1.07) | 0% | ND
Erectile dysfunction64,71,120 | 3 | 1521 | 1.19 (0.83, 1.70) | 18% | ND
Gynecomastia132 | 1 | 555 | 0.14 (0.01, 2.76) | NE | ND
Micturition disturbances52 | 1 | 41 | NE | NE | ND
GI
Constipation52,53,64,101,120,128,149 | 7 | 1870 | 1.04 (0.78, 1.38) | 35% | ND
Diarrhea101 | 1 | 255 | 1.36 (0.72, 2.57) | NE | ND
Dyspepsia128 | 1 | 105 | 0.98 (0.42, 2.27) | NE | ND
Nausea/Vomiting53,61,64,85,101 | 5 | 511 | 1.17 (0.74, 1.87) | 0% | ND
Hematology
Agranulocytosis145 | 1 | 78 | NE | NE | ND
Ophthalmology
Blurred vision60,64 | 2 | 104 | 0.47 (0.17, 1.30) | 40% | ND
Respiratory and airway
Rhinitis101 | 1 | 255 | 1.00 (0.60, 1.67) | NE | ND
Sleep
Insomnia52,61,81,101,120,151 | 6 | 2078 | 1.03 (0.85, 1.26) | 10% | ND
Sleep disorder52,85 | 2 | 118 | 2.47 (0.90, 6.76) | 33% | ND
Systemic AE
Headache52,53,61,64,81,85,101,128,151 | 9 | 964 | 0.83 (0.63, 1.08) | 0% | ND
Increased sweating52,64 | 2 | 83 | 1.54 (0.59, 3.99) | 41% | ND
Infection53 | 1 | 24 | 7.00 (0.40, 122.44) | NE | ND
Pain101 | 1 | 255 | 0.48 (0.21, 1.06) | NE | ND

Significant results are in bold; AE = adverse event; BMI = body mass index; CNS = central nervous system; ECG = electrocardiogram; EPS = extrapyramidal symptoms/syndrome; GI = gastrointestinal; I^2^ = I–squared; ND = no difference; NE = not estimable

## Haloperidol Versus Ziprasidone

Table 141 Evidence summary table: haloperidol versus ziprasidone – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Incidence of patients with AEs57,69,73,83,86,144 | 6 | 1448 | 1.13 (1.03, 1.23) | 31% | ziprasidone
Mortality116,144 | 2 | 408 | 3.10 (0.13, 75.68) | NE | ND
Serious AEs57,86,91,144 | 4 | 1403 | 1.02 (0.60, 1.75) | 0% | ND
Withdrawals due to AEs57,83,86,91,116,144 | 6 | 1551 | 1.73 (1.30, 2.32) | 0% | ziprasidone

Significant results are in bold; AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 142 Evidence summary table: haloperidol versus ziprasidone – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Agitation86,116 | 2 | 359 | 1.05 (0.66, 1.68) | 0% | ND
Anxiety86,116,144 | 3 | 709 | 1.42 (0.77, 2.61) | 15% | ND
Asthenia86,116 | 2 | 359 | 0.63 (0.29, 1.35) | 0% | ND
Depression86,144 | 2 | 651 | 1.52 (0.84, 2.76) | 0% | ND
Deterioration73 | 1 | 120 | 2.90 (0.12, 69.87) | NE | ND
Hallucinations86 | 1 | 301 | 1.29 (0.56, 2.97) | NE | ND
BMI and weight
Overweight91 | 1 | 185 | 0.91 (0.47, 1.75) | NE | ND
Weight gain91,144 | 2 | 535 | 0.86 (0.45, 1.67) | 47% | ND
Weight loss144 | 1 | 350 | 0.23 (0.05, 1.05) | NE | ND
Cardiovascular
Cardiovascular AEs116 | 1 | 58 | NE | NE | ND
ECG abnormalities57,86,91,116,122,144 | 6 | 2060 | 0.84 (0.53, 1.31) | 0% | ND
Hypertension116 | 1 | 58 | 3.43 (0.15, 80.83) | NE | ND
Hypotension116 | 1 | 58 | 0.57 (0.06, 5.99) | NE | ND
Syncope116 | 1 | 58 | NE | NE | ND

Table 143 Evidence summary table: haloperidol versus ziprasidone – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Cholinergic and anticholinergic
Dry mouth86,116 | 2 | 359 | 1.20 (0.38, 3.84) | 29% | ND
CNS
Dizziness86,116,144 | 3 | 709 | 1.19 (0.43, 3.34) | 55% | ND
Hypokinesia144 | 1 | 350 | 6.21 (1.41, 27.34) | NE | ziprasidone
Hypotonia144 | 1 | 350 | 5.86 (1.75, 19.65) | NE | ziprasidone
Somnolence57,86,116,122,144 | 5 | 1875 | 0.89 (0.70, 1.12) | 36% | ND
Dermatology
Injection-site pain116 | 1 | 58 | 0.57 (0.06, 5.99) | NE | ND
Endocrine (prolactin - thyroid)
Hyperprolactinemia57,91 | 2 | 752 | 1.53 (0.46, 5.05) | 89% | ND
EPS
Akathisia57,86,91,116,122,144 | 6 | 2060 | 1.58 (1.00, 2.50) | 80% | ND
Dyskinesia91 | 1 | 185 | 3.99 (0.19, 81.98) | NE | ND
Dystonia57,91,144 | 3 | 1102 | 2.19 (1.34, 3.60) | 15% | ziprasidone
EPS57,69,116,122,144 | 5 | 1594 | 2.34 (1.56, 3.53) | 63% | ziprasidone
Hypertonia57,86,116 | 3 | 926 | 2.45 (1.52, 3.94) | 0% | ziprasidone
Movement disorder86 | 1 | 301 | 2.73 (1.77, 4.19) | NE | ziprasidone
Parkinsonism91 | 1 | 185 | 1.81 (0.95, 3.46) | NE | ND
Psychosis86 | 1 | 301 | 0.48 (0.15, 1.57) | NE | ND
Tardive dyskinesia86 | 1 | 301 | 4.84 (0.23, 99.93) | NE | ND
Tremor57,86,116,122,144 | 5 | 1875 | 2.55 (1.79, 3.63) | 4% | ziprasidone
GI
Dyspepsia144 | 1 | 350 | 0.38 (0.12, 1.16) | NE | ND
Nausea/Vomiting86,116 | 2 | 359 | 0.55 (0.27, 1.11) | 0% | ND
Metabolic
HDL (low)91 | 1 | 185 | 0.96 (0.30, 3.02) | NE | ND
Hypercholesterolemia91 | 1 | 185 | 0.75 (0.40, 1.39) | NE | ND
Hyperglycemia91 | 1 | 185 | 0.68 (0.24, 1.95) | NE | ND
Hypertriglyceridemia91 | 1 | 185 | 1.03 (0.48, 2.24) | NE | ND
Ophthalmology
Abnormal vision116 | 1 | 58 | 5.71 (0.29, 114.05) | NE | ND
Sleep
Insomnia57,86,116,122 | 4 | 1525 | 0.81 (0.63, 1.04) | 0% | ND
Systemic AE
Headache86,116,144 | 3 | 709 | 0.49 (0.11, 2.18) | 82% | ND
Malaise116 | 1 | 58 | 0.38 (0.04, 3.47) | NE | ND
Sweating116 | 1 | 58 | 5.71 (0.29, 114.05) | NE | ND

Significant results are in bold; AE = adverse event; BMI = body mass index; CN = central nervous system; ECG = electrocardiogram; EPS = extrapyramidal symptoms/syndrome; GI = gastrointestinal; HDL = high density lipoprotein; I^2^ = I–squared; ND = no difference; NE = not estimable

## Perphenazine Versus Aripiprazole

Table 144 Evidence summary table: perphenazine versus aripiprazole – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Serious AEs93 | 1 | 300 | 0.79 (0.49, 1.28) | NE | ND
Withdrawals due to AEs93 | 1 | 300 | 0.53 (0.27, 1.05) | NE | ND

AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 145 Evidence summary table: perphenazine versus aripiprazole – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Agitation93 | 1 | 300 | 1.01 (0.61, 1.69) | NE | ND
Anxiety93 | 1 | 300 | 1.19 (0.63, 2.24) | NE | ND
Dizziness93 | 1 | 300 | 5.27 (1.18, 23.66) | NE | aripiprazole
Psychosis93 | 1 | 300 | 0.82 (0.42, 1.59) | NE | ND
Cardiovascular
ECG abnormalities93 | 1 | 300 | 15.82 (2.12, 118.27) | NE | aripiprazole
CNS
Somnolence93 | 1 | 300 | 2.64 (0.85, 8.22) | NE | ND
Endocrine (prolactin - thyroid)
Hyperprolactinemia93 | 1 | 300 | 13.89 (6.25, 30.86) | NE | aripiprazole
EPS
Akathisia93 | 1 | 300 | 2.29 (0.89, 5.85) | NE | ND
EPS93 | 1 | 300 | 1.90 (0.65, 5.53) | NE | ND
GI
Dyspepsia93 | 1 | 300 | 0.59 (0.27, 1.30) | NE | ND
Metabolic
Abnormal total creatinine phoshpokinase value93 | 1 | 300 | 0.62 (0.25, 1.52) | NE | ND
Increased creatinine phosphokinase93 | 1 | 300 | 0.47 (0.15, 1.49) | NE | ND
Sleep
Insomnia93 | 1 | 300 | 0.86 (0.56, 1.31) | NE | ND
Systemic AE
Headache93 | 1 | 300 | 0.55 (0.29, 1.03) | NE | ND
Injury93 | 1 | 300 | 4.75 (1.04, 21.60) | NE | aripiprazole

Significant results are in bold; AE = adverse event; CNS = central nervous system; ECG = electrocardiogram; EPS = extrapyramidal symptoms/syndrome; I2 = I–squared; ND = no difference; NE = not estimable

## Perphenazine Versus Olanzapine

Table 146 Evidence summary table: perphenazine versus olanzapine – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Incidence of patients with AEs23 | 1 | 597 | 0.93 (0.83, 1.04) | NE | ND
Serious AEs23 | 1 | 597 | 1.17 (0.72, 1.88) | NE | ND
Withdrawals due to AEs23 | 1 | 597 | 0.83 (0.58, 1.19) | NE | ND

AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 147 Evidence summary table: perphenazine versus olanzapine – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Suicide attempt23 | 1 | 597 | 0.64 (0.06, 7.06) | NE | ND
Suicidal ideation23 | 1 | 597 | 3.86 (0.40, 36.91) | NE | ND
BMI and weight
Weight gain23 | 1 | 597 | 0.41 (0.28, 0.60) | NE | perphenazine
Cardiovascular
ECG abnormalities23 | 1 | 597 | 6.43 (0.31, 133.39) | NE | ND
Hypertension23 | 1 | 597 | 0.85 (0.51, 1.40) | NE | ND
Orthostatic hypotension23 | 1 | 597 | 1.20 (0.75, 1.95) | NE | ND
Endocrine (prolactin - thyroid)
Menstrual irregularities23 | 1 | 597 | 0.82 (0.32, 2.08) | NE | ND
EPS
AIMS global severity score ≥2^23^ | 1 | 597 | 1.65 (1.07, 2.54) | NE | olanzapine
BARS global score ≥ 3^23^ | 1 | 597 | 1.37 (0.69, 2.73) | NE | ND
Dystonia23 | 1 | 597 | 1.29 (0.08, 20.48) | NE | ND
SAS mean score ≥1^23^ | 1 | 597 | 0.84 (0.45, 1.58) | NE | ND
Genital, urinary, and breast
Gynecomastia/galactorrhea23 | 1 | 597 | 0.74 (0.22, 2.49) | NE | ND
Incontinence, nocturia23 | 1 | 597 | 0.43 (0.17, 1.07) | NE | ND
Metabolic
Diabetes23 | 1 | 597 | 0.81 (0.45, 1.45) | NE | ND
Metabolic syndrome23 | 1 | 597 | 0.88 (0.63, 1.21) | NE | ND
Ophthalmology
Cataracts23 | 1 | 597 | 0.43 (0.04, 4.10) | NE | ND
Sleep
Hypersomnia23 | 1 | 597 | 0.92 (0.71, 1.18) | NE | ND
Insomnia23 | 1 | 597 | 1.54 (1.12, 2.13) | NE | olanzapine

Significant results are in bold; AIMS = Abnormal Involuntary Movement Scale; BARS = Barnes Akathisia Rating Scale; BMI = body mass index; ECG = electrocardiogram; EPS = extrapyramidal symptoms/syndrome; I^2^ = I–squared; ND = no difference; NE = not estimable; SAS = Simpson Angus Scale

## Perphenazine Versus Quetiapine

Table 148 Evidence summary table: perphenazine versus quetiapine – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Incidence of patients with AEs23 | 1 | 598 | 1.00 (0.89, 1.12) | NE | ND
Serious AEs23 | 1 | 598 | 1.17 (0.73, 1.88) | NE | ND
Withdrawals due to AEs23 | 1 | 598 | 1.05 (0.72, 1.55) | NE | ND

AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 149 Evidence summary table: perphenazine versus quetiapine – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Suicidal ideation23 | 1 | 598 | 1.94 (0.33, 11.51) | NE | ND
Suicide attempt23 | 1 | 598 | 1.29 (0.08, 20.55) | NE | ND
BMI and weight
Weight gain23 | 1 | 598 | 0.76 (0.50, 1.17) | NE | ND
Cardiovascular
ECG abnormalities23 | 1 | 598 | 0.43 (0.09, 2.12) | NE | ND
Hypertension23 | 1 | 598 | 0.80 (0.49, 1.32) | NE | ND
Orthostatic hypotension23 | 1 | 598 | 0.99 (0.62, 1.55) | NE | ND
Cholinergic and anticholinergic
Anticholinergic side-effects23 | 1 | 598 | 0.70 (0.53, 0.93) | NE | perphenazine
Endocrine (prolactin - thyroid)
Menstrual irregularities23 | 1 | 598 | 1.81 (0.58, 5.63) | NE | ND
EPS
AIMS global severity score ≥2^23^ | 1 | 598 | 1.76 (1.13, 2.75) | NE | quetiapine
BARS global score ≥3^23^ | 1 | 598 | 1.29 (0.66, 2.53) | NE | ND
Dystonia23 | 1 | 598 | 1.29 (0.08, 20.55) | NE | ND
SAS mean score ≥1^23^ | 1 | 598 | 1.61 (0.77, 3.39) | NE | ND
Genital, urinary, and breast
Gynecomastia/galactorrhea23 | 1 | 598 | 0.86 (0.25, 3.02) | NE | ND
Incontinence/nocturia23 | 1 | 598 | 0.52 (0.20, 1.31) | NE | ND
Metabolic
Diabetes23 | 1 | 598 | 1.57 (0.79, 3.12) | NE | ND
Metabolic syndrome23 | 1 | 598 | 1.19 (0.84, 1.70) | NE | ND
Ophthalmology
Cataracts23 | 1 | 598 | 1.29 (0.08, 20.55) | NE | ND
Sleep
Hypersomnia23 | 1 | 598 | 0.93 (0.72, 1.19) | NE | ND
Insomnia23 | 1 | 598 | 1.37 (1.01, 1.87) | NE | ND

Significant results are in bold; AIMS = Abnormal Involuntary Movement Scale; BARS = Barnes Akathisia Rating Scale; BMI = body mass index; ECG = electrocardiogram; EPS = extrapyramidal symptoms/syndrome; I^2^ = I–squared; ND = no difference; NE = not estimable; SAS = Simpson Angus Scale

## Perphenazine Versus Risperidone

Table 150 Evidence summary table: perphenazine versus risperidone – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Incidence of patients with AEs23 | 1 | 602 | 0.96 (0.85, 1.07) | NE | ND
Serious AEs23 | 1 | 602 | 1.15 (0.72, 1.84) | NE | ND
Withdrawals due to AEs23 | 1 | 602 | 1.54 (1.00, 2.36) | NE | ND

AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 151 Evidence summary table: perphenazine versus risperidone – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Suicidal ideation23 | 1 | 602 | 0.98 (0.22, 4.34) | NE | ND
Suicide attempt23 | 1 | 602 | 0.65 (0.06, 7.17) | NE | ND
BMI and weight
Weight gain23 | 1 | 602 | 0.90 (0.58, 1.41) | NE | ND
Cardiovascular
ECG abnormalities23 | 1 | 602 | 0.37 (0.08, 1.78) | NE | ND
Hypertension23 | 1 | 602 | 0.94 (0.56, 1.57) | NE | ND
Orthostatic hypotension23 | 1 | 602 | 1.02 (0.65, 1.62) | NE | ND
Cholinergic and anticholinergic
Anticholinergic side-effects23 | 1 | 602 | 0.89 (0.66, 1.19) | NE | ND
Endocrine (prolactin - thyroid)
Menstrual irregularities23 | 1 | 602 | 0.57 (0.24, 1.37) | NE | ND
EPS
AIMS global severity score ≥2^23^ | 1 | 602 | 1.41 (0.93, 2.13) | NE | ND
BARS global score ≥3^23^ | 1 | 602 | 1.05 (0.55, 1.98) | NE | ND
Dystonia23 | 1 | 602 | 0.65 (0.06, 7.17) | NE | ND
SAS mean score ≥1^23^ | 1 | 602 | 0.85 (0.45, 1.60) | NE | ND
Genital, urinary, and breast
Gynecomastia/galactorrhea23 | 1 | 602 | 0.37 (0.12, 1.12) | NE | ND
Incontinence/nocturia23 | 1 | 602 | 0.31 (0.13, 0.75) | NE | perphenazine
Metabolic
Diabetes23 | 1 | 602 | 1.06 (0.57, 1.96) | NE | ND
Metabolic syndrome23 | 1 | 602 | 1.42 (0.98, 2.06) | NE | ND
Ophthalmology
Cataracts23 | 1 | 602 | 0.65 (0.06, 7.17) | NE | ND
Sleep
Hypersomnia23 | 1 | 602 | 1.01 (0.78, 1.30) | NE | ND
Insomnia23 | 1 | 602 | 1.04 (0.79, 1.37) | NE | ND

Significant results are in bold; AIMS = Abnormal Involuntary Movement Scale; BARS = Barnes Akathisia Rating Scale; BMI = body mass index; ECG = electrocardiogram; EPS = extrapyramidal symptoms/syndrome; I^2^ = I–squared; ND = no difference; NE = not estimable; SAS = Simpson Angus Scale

## Perphenazine Versus Ziprasidone

Table 152 Evidence summary table: perphenazine versus ziprasidone – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Incidence of patients with AEs23 | 1 | 446 | 1.01 (0.88, 1.16) | NE | ND
Serious AEs23 | 1 | 446 | 1.08 (0.63, 1.87) | NE | ND
Withdrawals due to AEs23 | 1 | 446 | 1.01 (0.65, 1.58) | NE | ND

AE = adverse event; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 153 Evidence summary table: perphenazine versus ziprasidone – specific adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Behavior and psychosis
Suicidal ideation23 | 1 | 446 | 1.06 (0.18, 6.30) | NE | ND
Suicide attempt23 | 1 | 446 | 0.71 (0.04, 11.26) | NE | ND
BMI and weight
Weight gain23 | 1 | 446 | 1.71 (0.90, 3.27) | NE | ND
Cardiovascular
ECG abnormalities23 | 1 | 446 | 0.71 (0.10, 4.99) | NE | ND
Hypertension23 | 1 | 446 | 0.65 (0.38, 1.11) | NE | ND
Orthostatic hypotension23 | 1 | 446 | 0.86 (0.52, 1.42) | NE | ND
Cholinergic and anticholinergic
Anticholinergic side-effects23 | 1 | 446 | 1.09 (0.76, 1.58) | NE | ND
Endocrine (prolactin - thyroid)
Menstrual irregularities23 | 1 | 446 | 0.62 (0.23, 1.68) | NE | ND
EPS
AIMS global severity score ≥2^23^ | 1 | 446 | 1.61 (0.96, 2.72) | NE | ND
BARS global score ≥3^23^ | 1 | 446 | 0.81 (0.41, 1.62) | NE | ND
Dystonia23 | 1 | 446 | 0.24 (0.02, 2.25) | NE | ND
SAS mean score ≥1^23^ | 1 | 446 | 1.77 (0.70, 4.48) | NE | ND
Genital, urinary, and breast
Gynecomastia/galactorrhea23 | 1 | 446 | 0.47 (0.14, 1.65) | NE | ND
Incontinence/nocturia23 | 1 | 446 | 0.43 (0.16, 1.15) | NE | ND
Metabolic
Diabetes23 | 1 | 446 | 1.00 (0.49, 2.05) | NE | ND
Metabolic syndrome23 | 1 | 446 | 1.51 (0.96, 2.39) | NE | ND
Ophthalmology
Cataracts23 | 1 | 446 | 2.13 (0.09, 51.99) | NE | ND
Sleep
Hypersomnia23 | 1 | 446 | 1.17 (0.85, 1.60) | NE | ND
Insomnia23 | 1 | 446 | 0.84 (0.62, 1.13) | NE | ND

AIMS = Abnormal Involuntary Movement Scale; BARS = Barnes Akathisia Rating Scale; BMI = body mass index; ECG = electrocardiogram; EPS = extrapyramidal symptoms/syndrome; I^2^ = I–squared; ND = no difference; NE = not estimable; SAS = Simpson Angus Scale

## Thioridazine versus Clozapine

Table 154 Evidence summary table: thioridazine versus clozapine – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Mortality (Cohort)163 | 1 | 32280 | 2.12 (1.38, 3.26) | NE | clozapine

I2 = I–squared; NE = not estimable

## Thioridazine versus Risperidone

Table 155 Evidence summary table: thioridazine versus risperidone – general adverse events

Outcome | Studies | Participants | Effect Estimate | I^2^ | Less with
Mortality (Cohort)163 | 1 | 46007 | 1.82 (1.37, 2.40) | NE | risperidone

I2 = I–squared; NE = not estimable