# Subgroup and Sensitivity Analyses

Table 94 Subgroup and sensitivity analyses: chlorpromazine vs. clozapine – Total Score (BPRS)

Total Symptoms (BPRS) | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 6 | 535 | 8.40 (5.92, 10.88) | 20% | clozapine
Race
Asian | 2 | 80 | 4.73 (−0.39,9.85) | 0% | ND
Mixed | 4 | 455 | 9.57 (7.36,11.8) | 0% | clozapine
First time vs. other
Previous episodes | 4 | 474 | 9.63 (7.40,11.86) | 0% | clozapine
Mixed first and previous episodes | 2 | 61 | 4.77 (−0.17,9.71) | 0% | ND
Treatment resistance
Treatment resistant | 2 | 308 | 10.22 (7.12,13.33) | 10% | clozapine
Mixed | 4 | 227 | 6.96 (3.94,9.97) | 0% | clozapine
Duration of followup
>6weeks | 3 | 191 | 6.70 (3.55, 9.84) | 0% | clozapine
≤6weeks | 3 | 304 | 10.32 (7.66, 12.98) | 0% | clozapine
Dosage of FGA (chlorpromazine)
Up to 1800mg/d | 4 | 474 | 9.63 (7.40,11.9) | 0% | clozapine
Maximum 100 and 600mg/d | 2 | 61 | 4.77 (−0.17,9.71) | 0% | ND
Source of funding
Industry funding | 2 | 283 | 11.1 (8.13,14.0) | 0% | clozapine
No industry funding reported | 4 | 252 | 6.72 (3.89, 9.54) | 0% | clozapine
Risk of bias
Unclear | 4 | 363 | 8.23 (3.82, 12.6) | 45% | clozapine
High | 2 | 172 | 7.59 (4.20, 11.0) | 0% | clozapine
Imputations
Data imputed | 3 | 206 | 6.77 (2.39, 11.15) | 20% | clozapine
No data imputed | 3 | 329 | 9.70 (7.03, 12.37) | 5% | clozapine

Significant results are in bold. BPRS = Brief Psychiatric Rating Scale; d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference

Table 95 Subgroup and sensitivity analyses: haloperidol vs. aripiprazole – Response rates

Response Rates | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 6 | 2175 | 1.01 (0.76, 1.34) | 83% | ND
Disorder subtypes
Schizoaffective included | 3 | 531 | 0.93 (0.41, 2.11) | 87% | ND
Mixed or schizoaffective disorder excluded | 2 | 1654 | 0.94 (0.75, 1.16) | 74% | ND
Co-morbid drug/alcohol use
Excluded | 3 | 767 | 0.89 (0.57, 1.38) | 64% | ND
Mixed | 2 | 1418 | 1.13 (0.62, 2.06) | 94% | ND
First time vs. other
Mixed first and previous episodes | 4 | 891 | 1.06 (0.72, 1.57) | 79% | ND
Multiple episodes only | 1 | 1294 | 0.85 (0.75, 0.96) | NE | aripiprazole
Treatment resistance
Treatment resistant excluded | 3 | 1778 | 1.10 (0.80, 1.51) | 89% | ND
Mixed | 2 | 108 | 0.35 (0.03, 3.93) | 69% | ND
Duration of followup
>6weeks | 2 | 1393 | 0.37 (0.04, 3.76) | 68% | ND
≤6weeks | 3 | 792 | 1.12 (0.80, 1.57) | 80% | ND
Dosage of FGA (haloperidol)
<15mg/d | 4 | 2061 | 0.90 (0.73, 1.11) | 60% | ND
Up to 30mg/d | 1 | 124 | 1.55 (1.20, 2.00) | NE | haloperidol
Dosage of SGA (aripiprazole)
Up to 30mg/d | 4 | 2061 | 0.90 (0.73, 1.11) | 60% | ND
>30mg/d | 1 | 124 | 1.55 (1.20, 2.00) | NE | haloperidol
Source of funding
Industry funding | 4 | 2061 | 0.90 (0.73, 1.11) | 60% | ND
No industry funding reported | 1 | 124 | 1.55 (1.20, 2.00) | NE | haloperidol
Risk of bias
Unclear | 3 | 1654 | 0.94 (0.75, 1.16) | 74% | ND
High | 2 | 531 | 0.93 (0.41, 2.11) | 87% | ND

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; ND = no difference; NE = not estimable; mg = milligrams; SGA = second generation antipsychotic

Table 96 Subgroup and sensitivity analyses: haloperidol vs. olanzapine - Positive symptoms (PANSS Scale)

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 14 | 3742 | 0.43 (−0.22,1.08) | 36% | ND
Disorder subtypes
Schizoaffective disorder | 1 | 76 | 1.20 (−2.07, 4.47) | NE | ND
Mixed | 13 | 3666 | 0.38 (−0.30, 1.07) | 41% | ND
Co-morbid drug/alcohol use
Excluded | 4 | 527 | −0.44 (−2.75, 1.87) | 51% | ND
Included only | 1 | 31 | −2.00 (−4.82, 0.82) | NE | ND
Mixed | 9 | 3184 | 0.70 (0.15, 1.26) | 17% | olanzapine
Treatment resistance
Treatment resistant | 5 | 2207 | 0.26 (−1.26, 1.78) | 53% | ND
No treatment resistance | 1 | 44 | 2.18 (−0.59, 4.95) | NE | ND
Mixed | 8 | 1491 | 0.32 (−0.51, 1.15) | 30% | ND
Duration of followup
≤6 weeks | 2 | 58 | −2.08 (−4.59, 0.43) | 0% | ND
>6 weeks and <6 months | 7 | 694 | 0.21 (−1.19, 1.62) | 48% | ND
≥6 months | 5 | 2990 | 0.77 (0.30, 1.24) | 0% | olanzapine
Dosage of FGA (haloperidol)
≤20mg/d | 12 | 3593 | 0.62 (0.03, 1.21) | 23% | olanzapine
Upper limit >20mg/d | 2 | 149 | −0.62 (−3.62, 2.38) | 60% | ND
Dosage of SGA (olanzapine)
≤20mg/d | 12 | 3593 | 0.62 (0.03, 1.21) | 23% | olanzapine
>20mg/d | 2 | 149 | −0.62 (−3.62, 2.38) | 60% | ND
Source of funding
Industry funding | 13 | 3560 | 0.33 (−0.38, 1.05) | 40% | ND
No industry funding reported | 1 | 182 | 1.15 (−0.55, 2.85) | NE | ND
Risk of bias
Unclear | 11 | 1688 | 0.45 (−0.36, 1.25) | 36% | ND
High | 3 | 2054 | −0.12 (−2.21, 1.98) | 51% | ND
Race
Other | 13 | 3466 | 0.34 (−0.36, 1.04) | 39% | ND
Asian | 1 | 276 | 1.30 (−0.65, 3.25) | NE | ND
Data analysis
Imputed data | 2 | 336 | −0.66 (−2.68, 1.36) | 68% | ND
No imputed data | 12 | 3406 | 0.74 (0.11, 1.37) | 17% | olanzapine

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; PANSS = Positive and Negative Syndrome Scale; SGA = second generation antipsychotic

Table 97 Subgroup and sensitivity analyses: haloperidol vs. olanzapine – Negative symptoms (PANSS Scale)

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 14 | 3742 | 1.06 (0.46, 1.67) | 27% | olanzapine
Disorder subtypes
Schizoaffective disorder specifically included | 1 | 76 | 2.50 (−0.18, 5.18) | NE | ND
Mixed | 13 | 3666 | 0.99 (0.37, 1.62) | 29% | olanzapine
Co-morbid drug/alcohol use
Excluded | 4 | 527 | 0.88 (−0.63, 2.39) | 0% | ND
Included only | 1 | 31 | −3.20 (−6.03, −0.37) | NE | haloperidol
Mixed | 9 | 3184 | 1.27 (0.82, 1.72) | 2% | olanzapine
Treatment resistance
Treatment resistant | 5 | 2207 | 1.28 (0.11, 2.44) | 40% | olanzapine
Mixed | 8 | 1491 | 0.90 (−0.02, 1.81) | 35% | ND
No treatment resistance | 1 | 44 | 1.02 (−2.39, 4.43) | NE | ND
Duration of followup
≤6 weeks | 2 | 58 | −1.87 (−5.12, 1.39) | 42% | ND
>6 weeks and <6 months | 7 | 694 | 1.37 (0.25, 2.50) | 25% | olanzapine
≥6 months | 5 | 2990 | 1.26 (0.79, 1.73) | 0% | olanzapine
Dosage of FGA (haloperidol)
≤20mg/d | 12 | 3593 | 1.13 (0.51, 1.75) | 24% | olanzapine
Upper limit >20mg/d | 2 | 149 | 0.92 (−1.78, 3.62) | 65% | ND
Dosage of SGA (olanzapine)
≤20mg/d | 12 | 3593 | 1.13 (0.51, 1.75) | 24% | olanzapine
>20mg/d | 2 | 149 | 0.92 (−1.78, 3.62) | 65% | ND
Source of funding
Industry funding | 13 | 3560 | 1.08 (0.40, 1.76) | 32% | olanzapine
No industry funding reported | 1 | 182 | 0.82 (−0.69, 2.33) | NE | ND
Risk of bias
Unclear | 11 | 1688 | 1.18 (0.58, 1.78) | 0% | olanzapine
High | 3 | 2054 | −0.33 (−3.82, 3.16) | 79% | ND
Race
Other | 13 | 3466 | 0.97 (0.34, 1.59) | 27% | olanzapine
Asian | 1 | 276 | 2.40 (0.35, 4.45) | NE | olanzapine
Data analysis
Imputed data | 2 | 336 | 0.69 (−1.04, 2.41) | 56% | ND
No imputed data | 12 | 3406 | 1.14 (0.45, 1.83) | 28% | olanzapine

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; PANSS = Positive and Negative Syndrome Scale; SGA = second generation antipsychotic

Table 98 Subgroup and sensitivity analyses: haloperidol vs. olanzapine – General psychopathology (PANSS Scale)

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 10 | 1187 | 0.53 (−1.20, 2.25) | 52% | ND
Disorder subtypes
Schizoaffective disorder | 1 | 76 | 3.20 (−0.95, 7.35) | NE | ND
Mixed | 9 | 1111 | 0.24 (−1.60, 2.08) | 54% | ND
Co-morbid drug/alcohol use
Excluded | 3 | 500 | 0.02 (−2.77, 2.81) | 25% | ND
Included only | 1 | 31 | −6.10 (−10.90, −1.30) | NE | haloperidol
Mixed | 6 | 656 | 1.50 (−0.12, 3.12) | 25% | ND
Treatment resistance
Treatment resistant | 3 | 184 | 1.49 (−2.58, 5.56) | 68% | ND
Mixed | 6 | 959 | 0.05 (−2.23, 2.32) | 60% | ND
No treatment resistance | 1 | 44 | 1.35 (−4.82, 7.52) | NE | ND
Duration of followup
≤6 weeks | 1 | 31 | −6.10 (−10.90, −1.30) | NE | haloperidol
>6 weeks and <6 months | 6 | 418 | 0.79 (−1.48, 3.05) | 47% | ND
≥6 months | 3 | 738 | 1.71 (0.08, 3.35) | 0% | olanzapine
Dosage of FGA (haloperidol)
≤20mg/d | 8 | 1038 | 0.60 (−1.35, 2.55) | 51% | ND
Upper limit >20mg/d | 2 | 149 | 0.40 (−4.73, 5.54) | 74% | ND
Dosage of SGA (olanzapine)
≤20mg/d | 8 | 1038 | 0.60 (−1.35, 2.55) | 51% | ND
>20mg/d | 2 | 149 | 0.40 (−4.73, 5.54) | 74% | ND
Source of funding
Industry funding | 9 | 1005 | 0.32 (−1.64, 2.27) | 56% | ND
No industry funding reported | 1 | 182 | 1.93 (−1.17, 5.03) | NE | ND
Risk of bias
Unclear | 8 | 1129 | 1.08 (−0.43, 2.58) | 33% | ND
High | 2 | 58 | −2.54 (−9.93, 4.85) | 73% | ND
Data analysis
Imputed data | 8 | 851 | 0.65 (−1.56, 2.86) | 52% | ND
No imputed data | 2 | 336 | 0.10 (−3.67, 3.87) | 75% | ND

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; PANSS = Positive and Negative Syndrome Scale; SGA = second generation antipsychotic

Table 99 Subgroup and sensitivity analyses: haloperidol vs. olanzapine – Total scores (PANSS Scale)

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 15 | 4209 | 2.31 (0.44, 4.18) | 37% | olanzapine
Disorder subtypes
Paranoid schizophrenia | 1 | 28 | −0.65 (−4.77, 3.47) | NE | ND
Schizoaffective disorder | 3 | 593 | 2.13 (−0.91, 5.17) | 0% | ND
Mixed | 11 | 3588 | 2.65 (0.17, 5.12) | 42% | olanzapine
Co-morbid drug/alcohol use
Excluded | 3 | 483 | −0.73 (−5.83, 4.38) | 0% | ND
Mixed | 12 | 3726 | 2.71 (0.75, 4.67) | 40% | olanzapine
Treatment resistance
Treatment resistant | 6 | 2231 | 2.54 (−2.21, 7.29) | 56% | ND
Mixed | 8 | 1770 | 2.25 (0.00, 4.50) | 23% | ND
No treatment resistance | 1 | 208 | 0.90 (−3.81, 5.61) | NE | ND
Duration of followup
≤6 weeks | 2 | 51 | −4.88 (−17.94, 8.18) | 0% | ND
>6 weeks and <6 months | 7 | 695 | 2.26 (−1.85, 6.37) | 61% | ND
≥6 months | 6 | 3463 | 3.47 (1.99, 4.94) | 0% | olanzapine
Dosage of FGA (haloperidol)
≤20mg/d | 13 | 4060 | 2.74 (1.02, 4.46) | 23% | olanzapine
>20mg/d | 2 | 149 | 0.79 (−10.00, 11.58) | 77% | ND
Dosage of SGA (olanzapine)
≤20mg/d | 13 | 4060 | 2.74 (1.02, 4.46) | 23% | olanzapine
Upper limit >20mg/d | 2 | 149 | 0.79 (−10.00, 11.58) | 77% | ND
Source of funding
Industry funding | 13 | 4003 | 2.21 (0.15, 4.26) | 45% | olanzapine
No industry funding reported | 2 | 206 | 3.34 (−2.21, 8.90) | 0% | ND
Risk of bias
Unclear | 13 | 2005 | 2.01 (−0.30, 4.33) | 35% | ND
High | 2 | 2204 | 3.30 (0.27, 6.34) | 41% | olanzapine
Race
Other | 14 | 3933 | 2.01 (0.13, 3.89) | 36% | olanzapine
Asian | 1 | 276 | 7.90 (0.96, 14.84) | NE | olanzapine
Data analysis
Imputed data | 3 | 364 | −1.50 (−4.54, 1.54) | 0% | ND
No imputed data | 12 | 3845 | 3.68 (2.17, 5.18) | 5% | olanzapine

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; PANSS = Positive and Negative Syndrome Scale; SGA = second generation antipsychotic

Table 100 Subgroup and sensitivity analyses: haloperidol vs. olanzapine – Total scores (BPRS Scale)

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 13 | 4014 | 0.59 (−1.10, 2.28) | 82% | ND
Disorder subtypes
Paranoid schizophrenia | 1 | 28 | 8.85 (−3.92, 21.62) | NE | ND
Schizoaffective disorder | 2 | 182 | 0.99 (−2.19, 4.17) | 0% | ND
Mixed | 10 | 3804 | 0.33 (−1.56, 2.22) | 86% | ND
Co-morbid drug/alcohol use
Excluded | 6 | 1124 | −2.37 (−6.19, 1.44) | 90% | ND
Mixed | 7 | 2890 | 2.05 (0.55, 3.55) | 36% | olanzapine
Treatment resistance
Treatment resistant | 4 | 2205 | −5.50 (−14.1, 3.07) | 95% | ND
Mixed | 9 | 1809 | 1.10 (0.62, 1.58) | 0% | olanzapine
Duration of followup
≤6 weeks | 6 | 771 | −2.00 (−5.42, 1.42) | 90% | ND
>6 weeks and <6 months | 4 | 549 | 2.86 (0.50, 5.22) | 0% | olanzapine
≥6 months | 3 | 2694 | 1.63 (−0.72, 3.97) | 55% | ND
Dosage of FGA (haloperidol)
≤20mg/d | 11 | 3832 | 0.49 (−1.38, 2.37) | 85% | ND
>20mg/d | 2 | 182 | 0.99 (−2.19, 4.17) | 0% | ND
Dosage of SGA (olanzapine)
≤20mg/d | 10 | 3800 | 0.55 (−1.41, 2.52) | 86% | ND
Upper limit >20mg/d | 3 | 214 | 0.57 (−2.16, 3.30) | 0% | ND
Source of funding
Industry funding | 9 | 3570 | −0.42 (−3.48, 2.64) | 88% | ND
No industry funding reported | 4 | 444 | 1.12 (0.61, 1.63) | 0% | olanzapine
Risk of bias
Unclear | 9 | 1725 | −0.84 (−4.35, 2.67) | 86% | ND
High | 4 | 2289 | 1.78 (0.36, 3.21) | 66% | olanzapine
Race
Other | 12 | 3738 | 0.28 (−1.48, 2.04) | 83% | ND
Asian | 1 | 276 | 4.40 (0.33, 8.47) | NE | olanzapine

Significant results are in bold. BPRS = Brief Psychiatric Rating Scale; d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; SGA = second generation antipsychotic

Table 101 Subgroup and sensitivity analyses: haloperidol vs. olanzapine – Total scores (CGI–S Scale)

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 8 | 3564 | 0.14 (−0.05, 0.33) | 89% | ND
Disorder subtypes
Schizoaffective disorder | 2 | 271 | 0.20 (−0.35, 0.75) | 34% | ND
Mixed | 6 | 3293 | 0.13 (−0.08, 0.34) | 92% | ND
Co-morbid drug/alcohol use
Excluded | 5 | 1097 | 0.03 (−0.13, 0.20) | 61% | ND
Mixed | 3 | 2467 | 0.28 (0.19, 0.38) | 0% | olanzapine
Treatment resistance
Treatment resistant | 2 | 2059 | 0.24 (0.01, 0.47) | 32% | olanzapine
Mixed | 5 | 1297 | 0.07 (−0.10, 0.24) | 71% | ND
No treatment resistance | 1 | 208 | 0.60 (−0.23, 1.43) | NE | ND
Duration of followup
≤6 weeks | 2 | 336 | −0.06 (−0.19, 0.06) | 47% | ND
>6 weeks and <6 months | 1 | 63 | 0.00 (−0.47, 0.47) | NE | ND
≥6 months | 5 | 3165 | 0.26 (0.16, 0.37) | 7% | olanzapine
Dosage of FGA (haloperidol)
≤20mg/d | 7 | 3501 | 0.15 (−0.05, 0.36) | 90% | ND
Upper limit >20mg/d | 1 | 63 | 0.00 (−0.47, 0.47) | NE | ND
Dosage of SGA (olanzapine)
≤20mg/d | 7 | 3501 | 0.15 (−0.05, 0.36) | 90% | ND
>20mg/d | 1 | 63 | 0.00 (−0.47, 0.47) | NE | ND
Source of funding
Industry funding | 7 | 3453 | 0.20 (0.07, 0.32) | 33% | olanzapine
No industry funding reported | 1 | 111 | −0.10 (−0.14, −0.06) | NE | haloperidol
Risk of bias
Unclear | 4 | 1186 | 0.13 (−0.01, 0.27) | 11% | ND
High | 4 | 2378 | 0.13 (−0.19, 0.45) | 94% | ND
Data analysis
Imputed data | 1 | 263 | 0.17 (−0.08, 0.42) | NE | ND
No imputed data | 7 | 3301 | 0.13 (−0.08, 0.35) | 90% | ND

Significant results are in bold. CGI–S = Clinical Global Impression–Severity; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; SGA = second generation antipsychotic

Table 102 Subgroup and sensitivity analyses: haloperidol vs. olanzapine – Response rates

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 14 | 4099 | 0.86 (0.78, 0.96) | 55% | olanzapine
Disorder subtypes
Schizoaffective disorder | 2 | 327 | 0.73 (0.33, 1.63) | 95% | ND
Mixed | 12 | 3772 | 0.87 (0.80, 0.95) | 26% | olanzapine
Co-morbid drug/alcohol use
Only | 1 | 24 | 1.33 (0.38, 4.72) | NE | ND
Excluded | 2 | 378 | 1.02 (0.79, 1.32) | 29% | ND
Mixed | 11 | 3697 | 0.84 (0.75, 0.94) | 61% | olanzapine
Treatment resistance
Treatment resistant | 5 | 2247 | 0.81 (0.62, 1.04) | 70% | ND
Mixed | 8 | 1644 | 0.92 (0.85, 0.99) | 0% | olanzapine
No treatment resistance | 1 | 208 | 0.52 (0.37, 0.72) | NE | olanzapine
Duration of followup
≤6 weeks | 4 | 519 | 0.96 (0.87, 1.07) | 0% | ND
>6 weeks and <6 months | 5 | 590 | 0.83 (0.68, 1.01) | 22% | ND
≥6 months | 5 | 2990 | 0.83 (0.68, 1.01) | 74% | ND
Dosage of FGA (haloperidol)
≤20mg/d | 12 | 3907 | 0.86 (0.78, 0.96) | 48% | olanzapine
>20mg/d | 2 | 192 | 0.79 (0.42, 1.47) | 85% | ND
Dosage of SGA (olanzapine)
≤20mg/d | 11 | 3875 | 0.86 (0.77, 0.96) | 53% | olanzapine
Upper limit >20mg/d | 3 | 224 | 0.80 (0.50, 1.29) | 70% | ND
Source of funding
Industry funding | 9 | 3631 | 0.83 (0.73, 0.95) | 66% | olanzapine
No industry funding reported | 5 | 468 | 0.97 (0.85, 1.11) | 0% | ND
Risk of bias
Unclear | 9 | 1641 | 0.91 (0.83, 0.99) | 7% | olanzapine
High | 5 | 2458 | 0.81 (0.64, 1.02) | 78% | ND
Race
Other | 13 | 3823 | 0.86 (0.76, 0.97) | 59% | olanzapine
Asian | 1 | 276 | 0.87 (0.76, 1.00) | NE | ND
Data analysis
Imputed data | 3 | 360 | 0.80 (0.56, 1.13) | 42% | ND
No imputed data | 11 | 3739 | 0.87 (0.78, 0.98) | 61% | olanzapine

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; SGA = second generation antipsychotic

Table 103 Subgroup and sensitivity analyses: haloperidol vs. quetiapine – Negative symptoms (PANSS)^*^

Negative Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 4 | 393 | 1.36 (−0.41, 3.13) | 76% | ND
Disorder subtypes
Schizoaffective disorder | 1 | 45 | −1.20 (−4.49, 2.09) | NE | ND
Mixed | 3 | 348 | 1.87 (0.09, 3.65) | 77% | quetiapine
Co-morbid drug/alcohol use
Excluded | 1 | 25 | 3.10 (−1.60, 7.80) | NE | ND
Mixed | 3 | 368 | 1.12 (−0.86, 3.10) | 83% | ND
Treatment resistance
Treatment resistant | 1 | 288 | 0.61 (−0.57, 1.79) | NE | ND
Mixed | 3 | 105 | 1.65 (−0.93, 4.23) | 61% | ND
Duration of followup
≤6 months | 2 | 323 | 1.70 (−0.34, 3.75) | 88% | ND
>6 months | 2 | 70 | 0.61 (−3.55, 4.77) | 54% | ND
Dosage of FGA (haloperidol)
≤20mg/d | 4 | 393 | 1.36 (−0.41, 3.13) | 76% | ND
Upper limit >20mg/d | 0 | 0 | NE | NE | NE
Dosage of SGA (quetiapine)
Lower range ≤250mg/d | 1 | 45 | −1.20 (−4.49, 2.09) | NE | ND
Lower range >250mg/d | 3 | 348 | 1.87 (0.09, 3.65) | 77% | quetiapine
Risk of bias
Unclear | 3 | 358 | 0.53 (−0.81, 1.87) | 10% | ND
High | 1 | 35 | 2.70 (1.92, 3.48) | NE | quetiapine

* All studies were industry-funded.

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; PANSS = Positive and Negative Syndrome Scale; SGA = second generation antipsychotic

Table 104 Subgroup and sensitivity analyses: haloperidol vs. quetiapine – response rates^*^

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 6 | 1421 | 0.99 (0.76, 1.30) | 77% | ND
Disorder subtypes
Schizoaffective disorder | 1 | 45 | 0.64 (0.21, 1.96) | NE | ND
Mixed | 5 | 1376 | 1.01 (0.77, 1.34) | 81% | ND
Co-morbid drug/alcohol use
Excluded | 1 | 123 | 1.62 (1.24, 2.11) | NE | haloperidol
Mixed | 5 | 1298 | 0.90 (0.73, 1.10) | 47% | ND
Treatment resistance
Treatment resistant | 2 | 411 | 1.08 (0.49, 2.41) | 95% | ND
Mixed | 4 | 1010 | 1.00 (0.85, 1.17) | 6% | ND
Duration of followup
≤6 months | 3 | 881 | 1.22 (0.93, 1.61) | 71% | ND
>6 months | 3 | 540 | 0.74 (0.60, 0.91) | 0% | quetiapine
Dosage of FGA (haloperidol)
≤20mg/d | 5 | 1298 | 0.90 (0.73, 1.10) | 47% | ND
Upper limit >20mg/d | 1 | 123 | 1.62 (1.24, 2.11) | NE | haloperidol
Dosage of SGA (quetiapine)
Lower range ≤250mg/d | 5 | 1133 | 1.08 (0.82, 1.42) | 69% | ND
Lower range >250mg/d | 1 | 288 | 0.73 (0.56, 0.94) | NE | quetiapine
Risk of bias
Unclear | 3 | 663 | 0.85 (0.62, 1.15) | 44% | ND
High | 3 | 778 | 1.12 (0.76, 1.64) | 83% | ND

* All studies were industry-funded.

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; SGA = second generation antipsychotic

Table 105 Subgroup and sensitivity analyses: haloperidol vs. risperidone – Positive symptoms (PANSS Scale)

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 20 | 4043 | 0.64 (−0.06, 1.34) | 53% | ND
Disorder subtypes
Schizoaffective disorder | 4 | 1181 | 0.64 (−0.55, 1.83) | 47% | ND
Schizoaffective excluded | 2 | 363 | 2.70 (−1.10, 6.50) | 47% | ND
Mixed | 14 | 2499 | 0.48 (−0.42, 1.38) | 57% | ND
Co-morbid drug/alcohol use
Excluded | 14 | 3210 | 0.46 (−0.42, 1.34) | 58% | ND
Mixed | 6 | 833 | 1.24 (0.44, 2.03) | 0% | risperidone
First vs. multiple episodes
Mixed first and multiple episodes | 12 | 1876 | 1.04 (0.21, 1.86) | 30% | risperidone
Multiple episodes only | 7 | 1984 | 0.10 (−1.17, 1.36) | 70% | ND
First episode only | 1 | 183 | 0.10 (−1.98, 2.18) | NE | ND
Treatment resistance
No treatment resistant | 4 | 881 | 0.32 (−1.44, 2.08) | 80% | ND
Treatment resistant | 2 | 156 | −0.00 (−3.04, 3.03) | 56% | ND
Mixed | 14 | 3006 | 0.84 (0.07, 1.60) | 36% | risperidone
Duration of followup
≤6 weeks | 3 | 260 | 1.07 (−1.51, 3.64) | 41% | ND
>6 weeks and <6 months | 10 | 2147 | 0.26 (−0.44, 0.96) | 0% | ND
≥6 months | 7 | 1636 | 0.91 (−0.39, 2.21) | 81% | ND
Dosage of FGA (haloperidol)
≤20mg/d | 17 | 3881 | 0.48 (−0.21, 1.17) | 51% | ND
Upper limit >20mg/d | 2 | 106 | 3.28 (−0.33, 6.89) | 58% | ND
Dosage of SGA (risperidone)
Lower limit <4mg/d | 15 | 3754 | 0.68 (−0.08, 1.45) | 59% | ND
Upper range >6mg/d | 13 | 3394 | −0.01 (−0.67, 0.64) | 29% | ND
Source of funding
Industry funding | 10 | 2091 | 0.68 (−0.38, 1.74) | 66% | ND
No industry funding | 11 | 2317 | 0.85 (0.02, 1.67) | 34% | risperidone
Risk of bias
Unclear | 15 | 3488 | 0.46 (−0.34, 1.26) | 55% | ND
High | 5 | 555 | 1.52 (0.57, 2.47) | 0% | risperidone
Race
Other | 15 | 3813 | 0.74 (−0.06, 1.54) | 63% | ND
Asian | 5 | 230 | 0.18 (−1.32, 1.67) | 0% | ND
Data analysis
Imputed data | 3 | 1439 | 0.01 (−0.89, 0.90) | 0% | ND
No imputed data | 17 | 2604 | 0.77 (−0.05, 1.60) | 60% | ND

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; PANSS = Positive and Negative Syndrome Scale; SGA = second generation antipsychotic

Table 106 Subgroup and sensitivity analyses: haloperidol vs. risperidone – Negative symptoms (PANSS Scale)

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 20 | 4043 | 0.60 (0.01, 1.20) | 30% | risperidone
Disorder subtypes
Schizoaffective disorder | 4 | 1181 | 0.88 (0.12, 1.64) | 0% | risperidone
Schizoaffective excluded | 2 | 363 | 2.36 (0.39, 4.32) | 0% | risperidone
Mixed | 14 | 2499 | 0.32 (−0.51, 1.16) | 35% | ND
Co-morbid drug/alcohol use
Excluded | 14 | 3210 | 0.52 (−0.22, 1.26) | 31% | ND
Mixed | 6 | 833 | 0.77 (−0.37, 1.91) | 37% | ND
First vs. multiple episodes
Mixed first and multiple episodes | 13 | 2059 | 0.88 (0.30, 1.47) | 0% | risperidone
Multiple episodes only | 7 | 1984 | 0.05 (−1.19, 1.29) | 57% | ND
Treatment resistance
No treatment resistant | 4 | 881 | −0.04 (−1.78, 1.70) | 73% | ND
Treatment resistant | 2 | 156 | 1.00 (−1.74, 3.73) | 41% | ND
Mixed | 14 | 3006 | 0.71 (0.15, 1.27) | 3% | risperidone
Duration of followup
≤6 weeks | 3 | 260 | 1.05 (−0.84, 2.95) | 0% | ND
>6 weeks and <6 months | 10 | 2147 | 0.54 (−0.21, 1.29) | 0% | ND
≥6 months | 7 | 1636 | 0.54 (−0.49, 1.57) | 65% | ND
Dosage of FGA (haloperidol)
≤20mg/d | 18 | 3937 | 0.56 (−0.03, 1.15) | 28% | ND
Upper limit >20mg/d | 2 | 106 | 1.82 (−2.85, 6.49) | 71% | ND
Dosage of SGA (risperidone)
Lower limit <4mg/d | 15 | 3754 | 0.53 (−0.13, 1.19) | 40% | ND
Upper range >6mg/d | 10 | 3283 | 0.26 (−0.45, 0.96) | 38% | ND
Source of funding
Industry funding | 10 | 2091 | 0.43 (−0.54, 1.41) | 56% | ND
No industry funding not reported | 10 | 1952 | 0.76 (0.08, 1.45) | 0% | risperidone
Risk of bias
Unclear | 15 | 3488 | 0.39 (−0.30, 1.08) | 35% | ND
High | 5 | 555 | 1.47 (0.44, 2.51) | 0% | risperidone
Race
Other | 15 | 3813 | 0.60 (−0.08, 1.28) | 43% | ND
Asian | 5 | 230 | 0.78 (−1.03, 2.59) | 0% | ND
Data analysis
Imputed data | 3 | 1439 | −0.40 (−2.38, 1.58) | 18% | ND
No imputed data | 17 | 2604 | 0.74 (0.08, 1.41) | 32% | risperidone

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; PANSS = Positive and Negative Syndrome Scale; SGA = second generation antipsychotic

Table 107 Subgroup and sensitivity analyses: haloperidol vs. risperidone – General symptoms (PANSS Scale)

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 16 | 3073 | −2.54 (−6.39, 1.32) | 96% | ND
Disorder subtypes
Schizoaffective disorder | 3 | 816 | 0.60 (−1.08, 2.27) | 0% | ND
Schizoaffective excluded | 1 | 41 | 8.90 (−0.51, 18.31) | NE | ND
Mixed | 12 | 2216 | −4.18 (−9.09, 0.72) | 96% | ND
Co-morbid drug/alcohol use
Excluded | 12 | 2817 | 0.31 (−1.18, 1.80) | 43% | ND
Mixed | 4 | 256 | −12.2 (−26.8, 2.51) | 99% | ND
First vs. multiple episodes
Mixed first and multiple episodes | 8 | 906 | −4.07 (−14.33, 6.19) | 97% | ND
Multiple episodes only | 7 | 1984 | −1.24 (−5.05, 2.57) | 93% | ND
First episode only | 1 | 41 | 8.90 (−0.51, 18.31) | NE | ND
Treatment resistance
No treatment resistant | 3 | 516 | −1.13 (−3.95, 1.70) | 42% | ND
Treatment resistant | 2 | 156 | 1.51 (−1.22, 4.23) | 0% | ND
Mixed | 11 | 2401 | −3.82 (−9.26, 1.61) | 97% | ND
Duration of followup
≤6 weeks | 3 | 260 | −11.31 (−44.1, 21.5) | 99% | ND
>6 weeks and <6 months | 9 | 1825 | 0.98 (−0.25, 2.20) | 0% | ND
≥6 months | 4 | 988 | −2.76 (−7.19, 1.68) | 94% | ND
Dosage of FGA (haloperidol)
≤20mg/d | 13 | 2995 | −2.79 (−6.84, 1.27) | 96% | ND
Upper limit >20mg/d | 1 | 78 | 1.10 (−2.78, 4.98) | NE | ND
Dosage of SGA (risperidone)
Lower limit <4mg/d | 11 | 2784 | −0.36 (−3.30, 2.58) | 91% | ND
Upper range >6mg/d | 9 | 2704 | 0.62 (−0.90, 2.14) | 43% | ND
Source of funding
Industry funding | 6 | 1121 | −0.16 (−2.05, 1.73) | 37% | ND
No industry funding reported | 10 | 1952 | −4.41 (−10.45, 1.63) | 97% | ND
Risk of bias
Unclear | 12 | 2840 | 0.52 (−0.75, 1.78) | 28% | ND
High | 4 | 233 | −13.6 (−28.5, 1.41) | 98% | ND
Race
Other | 11 | 2843 | −3.44 (−8.34, 1.45) | 97% | ND
Asian | 5 | 230 | 0.01 (−2.83, 2.84) | 33% | ND
Data analysis
Imputed data | 3 | 1439 | 0.99 (−0.60, 2.58) | 0% | ND
No imputed data | 13 | 1634 | −3.07 (−7.73, 1.59) | 96% | ND

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; PANSS = Positive and Negative Syndrome Scale; SGA = second generation antipsychotic

Table 108 Subgroup and sensitivity analyses: haloperidol vs. risperidone – Total score (PANSS Scale)

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 20 | 4021 | 2.23 (−0.37, 4.83) | 75% | ND
Disorder subtypes
Schizoaffective disorder | 4 | 1181 | 3.08 (−0.19, 6.34) | 45% | ND
Schizoaffective excluded | 2 | 363 | 9.93 (0.77, 19.09) | 27% | risperidone
Mixed | 14 | 2477 | 1.04 (−1.82, 3.90) | 65% | ND
Co-morbid drug/alcohol use
Excluded | 14 | 3188 | 2.56 (0.65, 4.47) | 18% | risperidone
Mixed | 6 | 833 | 1.95 (−3.14, 7.04) | 82% | ND
First vs. multiple episodes
Mixed first and multiple episodes | 12 | 1854 | 3.78 (1.37, 6.18) | 32% | risperidone
Multiple episodes only | 7 | 1984 | −0.56 (−3.98, 2.86) | 65% | ND
First episode only | 1 | 183 | 1.60 (−5.61, 8.81) | NE | ND
Treatment resistance
No treatment resistant | 3 | 837 | 3.53 (−0.06, 7.13) | 46% | ND
Treatment resistant | 2 | 156 | 2.52 (−3.99, 9.02) | 0% | ND
Mixed | 15 | 3028 | 1.89 (−1.10, 4.89) | 71% | ND
Duration of followup
≤6 weeks | 4 | 280 | 5.89 (−0.00, 11.79) | 30% | ND
>6 weeks and <6 months | 10 | 2147 | 2.01 (−0.30, 4.32) | 0% | ND
≥6 months | 6 | 1594 | 1.06 (−3.29, 5.42) | 90% | ND
Dosage of FGA (haloperidol)
≤20mg/d | 19 | 3943 | 2.23 (−0.46, 4.93) | 76% | ND
Upper limit >20mg/d | 1 | 78 | 2.30 (−5.85, 10.45) | NE | ND
Dosage of SGA (risperidone)
Lower limit <4mg/d | 14 | 3702 | 1.83 (−1.14, 4.79) | 79% | ND
Upper range >6mg/d | 12 | 3646 | 2.95 (1.19, 4.70) | 20% | risperidone
Source of funding
Industry funding | 9 | 2049 | 3.11 (1.23, 5.00) | 13% | risperidone
No industry funding reported | 11 | 1972 | 1.67 (−2.15, 5.49) | 71% | ND
Risk of bias
Unclear | 13 | 3416 | 2.72 (1.17, 4.27) | 5% | risperidone
High | 7 | 605 | 1.91 (−3.47, 7.29) | 77% | ND
Race
Other | 15 | 3791 | 2.56 (−0.37, 5.48) | 81% | ND
Asian | 5 | 230 | 0.76 (−4.40, 5.92) | 6% | ND
Data analysis
Imputed data | 3 | 1439 | 1.11 (−1.91, 4.13) | 0% | ND
No imputed data | 17 | 2582 | 2.66 (−0.31, 5.63) | 79% | ND

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; PANSS = Positive and Negative Syndrome Scale; SGA = second generation antipsychotic

Table 109 Subgroup and sensitivity analyses: haloperidol vs. risperidone – Total score (BPRS)

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 13 | 2592 | 0.51 (−0.17, 1.20) | 44% | ND
Disorder subtypes
Schizoaffective disorder | 2 | 209 | 1.05 (−1.78, 3.87) | 0% | ND
Schizoaffective excluded | 2 | 363 | 4.88 (0.88, 8.89) | 0% | risperidone
Mixed | 9 | 1920 | 0.34 (−0.29, 0.98) | 46% | ND
Co-morbid drug/alcohol use
Excluded | 7 | 1875 | 0.84 (0.36, 1.32) | 0% | risperidone
Mixed | 6 | 717 | 0.23 (−1.44, 1.90) | 29% | ND
First vs. multiple episodes
Mixed first and multiple episodes | 7 | 805 | 0.98 (−1.14, 3.10) | 41% | ND
Multiple episodes only | 5 | 1604 | 0.00 (−0.11, 0.11) | 0% | ND
First episode only | 1 | 183 | 1.10 (−3.07, 5.27) | NE | ND
Treatment resistance
No treatment resistant | 1 | 183 | 1.10 (−3.07, 5.27) | NE | ND
Treatment resistant | 2 | 193 | 1.17 (−2.35, 4.68) | 0% | ND
Mixed | 10 | 2216 | 0.49 (−0.28, 1.27) | 57% | ND
Duration of followup
≤6 weeks | 5 | 491 | 0.82 (0.32, 1.32) | 0% | risperidone
>6 weeks and <6 months | 6 | 1961 | 0.80 (−1.63, 3.23) | 33% | ND
≥6 months | 1 | 63 | 0.00 (−0.11, 0.11) | NE | ND
Dosage of FGA (haloperidol)
≤20mg/d | 11 | 2389 | 0.52 (−0.23, 1.27) | 53% | ND
Upper limit >20mg/d | 2 | 203 | 0.91 (−2.57, 4.38) | 0% | ND
Dosage of SGA (risperidone)
Lower limit <4mg/d | 10 | 2421 | 0.80 (0.33, 1.28) | 0% | risperidone
Upper range >6mg/d | 9 | 2310 | 1.01 (−0.74, 2.75) | 22% | ND
Source of funding
Industry funding | 6 | 666 | 0.00 (−0.11, 0.11) | 0% | ND
No industry funding reported | 7 | 1926 | 0.71 (−0.29, 1.71) | 18% | ND
Risk of bias
Unclear | 10 | 2027 | 0.01 (−0.19, 0.21) | 0% | ND
High | 3 | 565 | 0.95 (0.04, 1.85) | 7% | risperidone
Race
Other | 12 | 2557 | 0.53 (−0.18, 1.24) | 49% | ND
Asian | 1 | 35 | −0.70 (−12.6, 11.2) | NE | ND
Data analysis
Imputed data | 5 | 1565 | 0.93 (−0.74, 2.60) | 0% | ND
No imputed data | 8 | 1027 | 0.49 (−0.36, 1.35) | 65% | ND

Significant results are in bold. BPRS = Brief Psychiatric Rating Scale; d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; SGA = second generation antipsychotic

Table 110 Subgroup and sensitivity analyses: haloperidol vs. risperidone – Total score (CGI–S)

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 8 | 2346 | 0.03 (−0.17, 0.23) | 63% | ND
Disorder subtypes
Schizoaffective excluded | 2 | 363 | 0.52 (−0.41, 1.46) | 75% | ND
Mixed | 6 | 1983 | −0.10 (−0.24, 0.05) | 30% | ND
Co-morbid drug/alcohol use
Excluded | 6 | 1957 | 0.01 (−0.23, 0.24) | 66% | ND
Mixed | 2 | 389 | 0.13 (−0.18, 0.45) | 0% | ND
First vs. multiple episodes
Mixed first and multiple episodes | 4 | 593 | 0.13 (−0.25, 0.50) | 78% | ND
Multiple episodes only | 4 | 1753 | 0.01 (−0.19, 0.21) | 0% | ND
Treatment resistance
No treatment resistant | 1 | 289 | −0.10 (−0.40, 0.20) | NE | ND
Treatment resistant | 1 | 67 | 0.20 (−0.72, 1.12) | NE | ND
Mixed | 6 | 1990 | 0.07 (−0.19, 0.34) | 72% | ND
Duration of followup
≤6 weeks | 2 | 158 | 0.37 (−0.89, 1.64) | 88% | ND
>6 weeks and <6 months | 5 | 1899 | 0.11 (−0.08, 0.30) | 0% | ND
≥6 months | 1 | 289 | −0.10 (−0.40, 0.20) | NE | ND
Dosage of SGA (risperidone)
Lower limit <4mg/d | 6 | 2238 | −0.05 (−0.22, 0.11) | 50% | ND
Upper range >6mg/d | 5 | 2127 | 0.11 (−0.11, 0.34) | 39% | ND
Source of funding
Industry funding | 4 | 791 | 0.03 (−0.17, 0.23) | 0% | ND
No industry funding reported | 4 | 1555 | 0.07 (−0.31, 0.45) | 76% | ND
Risk of bias
Unclear | 6 | 1907 | 0.10 (−0.14, 0.35) | 28% | ND
High | 2 | 439 | −0.08 (−0.39, 0.23) | 73% | ND
Race
Other | 7 | 2311 | 0.04 (−0.17, 0.26) | 68% | ND
Asian | 1 | 35 | −0.30 (−1.58, 0.98) | NE | ND
Data analysis
Imputed data | 3 | 1464 | 0.09 (−0.17, 0.35) | 0% | ND
No imputed data | 5 | 882 | 0.03 (−0.23, 0.29) | 71% | ND

Significant results are in bold. CGI–S = Clinical Global Impression–Severity; d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; SGA = second generation antipsychotic

Table 111 Subgroup and sensitivity analyses: haloperidol vs. risperidone – Response rates

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 16 | 3453 | 0.94 (0.87, 1.02) | 29% | ND
Disorder subtypes
Schizoaffective included | 3 | 864 | 1.03 (0.95, 1.12) | 0% | ND
Schizoaffective excluded | 2 | 363 | 0.78 (0.56, 1.07) | 42% | ND
Mixed | 11 | 2226 | 0.93 (0.83, 1.03) | 16% | ND
Co-morbid drug/alcohol use
Excluded | 10 | 1586 | 0.97 (0.91, 1.05) | 0% | ND
Mixed | 6 | 913 | 0.86 (0.68, 1.10) | 66% | ND
First vs. multiple episodes
Mixed first and multiple episodes | 8 | 1553 | 0.93 (0.81, 1.07) | 48% | ND
Multiple episodes only | 7 | 1717 | 0.95 (0.84, 1.07) | 14% | ND
First episodes only | 1 | 183 | 0.89 (0.70, 1.14) | NE | ND
Treatment resistance
No treatment resistant | 1 | 183 | 0.89 (0.70, 1.14) | NE | ND
Treatment resistant | 3 | 271 | 0.82 (0.52, 1.29) | 75% | ND
Mixed | 12 | 2999 | 0.96 (0.88, 1.04) | 18% | ND
Duration of followup
≤6 weeks | 6 | 524 | 0.97 (0.85, 1.11) | 16% | ND
>6 weeks and <6 months | 7 | 2019 | 0.86 (0.72, 1.03) | 33% | ND
≥6 months | 3 | 910 | 0.98 (0.85, 1.13) | 48% | ND
Dosage of FGA (haloperidol)
≤20mg/d | 15 | 3327 | 0.93 (0.85, 1.01) | 26% | ND
Upper limit >20mg/d | 1 | 126 | 1.09 (0.91, 1.29) | NE | ND
Dosage of SGA (risperidone)
Lower limit <4mg/d | 13 | 3267 | 0.97 (0.90, 1.05) | 21% | ND
Upper range >6mg/d | 11 | 3056 | 0.94 (0.86, 1.03) | 31% | ND
Source of funding
Industry funding | 8 | 1411 | 0.79 (0.63, 1.00) | 53% | ND
No industry funding | 8 | 2042 | 0.98 (0.91, 1.06) | 0% | ND
Risk of bias
Unclear | 12 | 2788 | 0.93 (0.84, 1.01) | 20% | ND
High | 4 | 665 | 0.99 (0.82, 1.19) | 56% | ND
Race
Other | 14 | 3340 | 0.96 (0.88, 1.04) | 25% | ND
Asian | 2 | 113 | 0.90 (0.55, 1.46) | 65% | ND
Data analysis
Imputed data | 5 | 1530 | 0.92 (0.71, 1.18) | 23% | ND
No imputed data | 11 | 1923 | 0.94 (0.85, 1.03) | 38% | ND

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; SGA = second generation antipsychotic

Table 112 Subgroup and sensitivity analyses: haloperidol vs. ziprasidone – Response rates

Total Symptoms | Studies | Participants | Effect Estimate | I^2^ | Favors
OVERALL POOLED RESULTS | 6 | 1283 | 0.98 (0.74,1.30) | 80% | ND
Co-morbid drug/alcohol use
Excluded | 3 | 677 | 1.03 (0.92, 1.15) | 0% | ND
Mixed | 3 | 606 | 0.90 (0.49, 1.62) | 91% | ND
Treatment resistance
Treatment resistant | 1 | 120 | 1.54 (1.19, 2.00) | NE | ziprasidone
No treatment resistance | 3 | 1053 | 0.79 (0.56, 1.13) | 84% | ND
Mixed | 2 | 110 | 1.21 (0.74, 1.98) | 0% | ND
Mixed and treatment resistant | 3 | 230 | 1.46 (1.16, 1.84) | 0% | ziprasidone
Duration of followup
≤6 weeks | 4 | 797 | 1.22 (0.91, 1.62) | 66% | ND
>6 months | 2 | 486 | 0.68 (0.54, 0.85) | 0% | haloperidol
Dosage of FGA (haloperidol)
≤20mg/d | 5 | 1163 | 0.87 (0.66, 1.15) | 70% | ND
Upper limit >20mg/d | 1 | 120 | 1.54 (1.19, 2.00) | NE | ziprasidone
Dosage of SGA (ziprasidone)
Lower limit <120mg/d | 6 | 1283 | 0.98 (0.74,1.30) | 80% | ND
Upper range >160mg/d | 1 | 120 | 1.54 (1.19, 2.00) | NE | ziprasidone
Risk of bias
Unclear | 1 | 120 | 1.54 (1.19, 2.00) | NE | ziprasidone
High | 5 | 1163 | 0.87 (0.66, 1.15) | 70% | ND
Source of funding
Industry-funded | 4 | 1073 | 0.82 (0.59, 1.12) | 76% | ND
Funding not reported | 2 | 210 | 1.50 (1.19, 1.91) | 0% | ziprasidone
Imputed Data
Data imputed | 3 | 958 | 0.93 (0.66, 1.31) | 77% | ND
Data not imputed | 3 | 325 | 1.02 (0.53, 1.97) | 86% | ND

Significant results are in bold. d = day; FGA = first generation antipsychotic; I^2^ = I–squared; mg = milligrams; ND = no difference; NE = not estimable; SGA = second generation antipsychotic