# Subscales, Composite Outcomes, and Functional Capacity

## A Schizophrenia and Related Psychoses

Table 81 Evidence summary table: chlorpromazine versus clozapine

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive symptoms
BPRS - cluster of four key items94 | 1 | 268 | 3.00 (1.91, 4.09) | NE | clozapine
BPRS - hostility subscale63,109,154,158 | 4 | 355 | 0.25 (−0.43, 0.94) | 43% | ND
BPRS - psychotic subscale152 | 1 | 64 | 0.11 (−0.26, 0.48) | NE | ND
NOSIE - Irritability subscale152 | 1 | 64 | 0.59 (0.26, 0.92) | NE | clozapine
NOSIE - Volitional Lack/Hallucination subscale152 | 1 | 64 | −0.09 (−0.60, 0.42) | NE | ND
Negative symptoms
BPRS - Anergia subscale63,109,154,160 | 4 | 374 | 0.30 (−0.65, 1.25) | 0% | ND
NOSIE - Depression subscale152 | 1 | 64 | 0.81 (0.36, 1.26) | NE | clozapine
SANS - Affective blunting subscale109 | 1 | 164 | 1.20 (0.00, 2.40) | NE | ND
SANS - Alogia subscale109 | 1 | 164 | 0.30 (−0.46, 1.06) | NE | ND
SANS - Apathy subscale109 | 1 | 164 | −0.10 (−0.87, 0.67) | NE | ND
SANS - Avolition subscale109 | 1 | 164 | 0.50 (−0.66, 1.66) | NE | ND
SANS - Disturbance of attention subscale109 | 1 | 164 | 0.10 (−0.22, 0.42) | NE | ND
General psychopathology
BPRS - Agitation/Activation63,109 | 2 | 315 | −0.17 (−0.71, 0.37) | 77% | ND
BPRS - Anxiety/Depression subscale63,152 | 2 | 215 | 0.07 (−0.45, 0.60) | 70% | ND
BPRS - Thought Disorder63,109,154,160 | 4 | 374 | 0.26 (−0.27, 0.78) | 32% | ND
NOSIE - Autistic152 | 1 | 64 | 0.39 (−0.12, 0.90) | NE | ND
NOSIE - Social competence152,160 | 2 | 108 | 0.36 (−1.10, 1.82) | 89% | ND
NOSIE - Social interest152,160 | 2 | 108 | −0.17 (−1.43, 1.10) | 67% | ND

Note: bolded results are statistically significant; BPRS = Brief Psychiatric Rating Scale; I^2^ = I–squared; ND = no difference; NE = not estimable; NOSIE = Nurses’ Observation Scale for Inpatient Evaluation; SANS = Scale for the Assessment of Negative Symptoms

Table 82 Evidence summary table: chlorpromazine versus olanzapine

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive symptoms
BPRS - cluster of four key items66 | 1 | 84 | 1.30 (−0.28, 2.88) | NE | ND
BPRS - hostility subscale66 | 1 | 84 | 0.20 (−1.43, 1.83) | NE | ND
Negative symptoms
BPRS - anergia66 | 1 | 84 | 0.60 (−1.05, 2.25) | NE | ND
General psychopathology
BPRS - activation66 | 1 | 84 | 0.40 (−1.10, 1.90) | NE | ND
BPRS - anxiety/depression66 | 1 | 84 | 1.30 (−0.37, 2.97) | NE | ND

BPRS = Brief Psychiatric Rating Scale; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 83 Evidence summary table: fluphenazine versus olanzapine

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
General psychopathology
PANSS - mood subscale89 | 1 | 60 | 1.60 (−0.32, 3.52) | NE | ND
Functional capacity
Auditory verbal learning (# words recalled)112 | 1 | 18 | 2.30 (−1.73, 6.33) | NE | ND
Finger tapping test dominant hand112 | 1 | 18 | 34.70 (−38.87, 108.27) | NE | ND
Finger tapping test non-dominant hand112 | 1 | 18 | 47.10 (−13.64, 107.84) | NE | ND
LSEQ awakening score89 | 1 | 60 | −2.70 (−9.76, 4.36) | NE | ND
LSEQ behavior following wakefulness89 | 1 | 60 | −6.60 (−13.50, 0.30) | NE | ND
LSEQ getting to sleep89 | 1 | 60 | −6.10 (−15.37, 3.17) | NE | ND
LSEQ quality of sleep89 | 1 | 60 | −4.40 (−13.59, 4.79) | NE | ND
Serial digital learning112 | 1 | 18 | −2.30 (−9.72, 5.12) | NE | ND
SNST color task (# of errors)112 | 1 | 18 | −0.40 (−2.83, 2.03) | NE | ND
SNST color task (# of words)112 | 1 | 18 | −4.50 (−50.60, 41.60) | NE | ND
SNST word task (# of errors)112 | 1 | 18 | −1.80 (−4.97, 1.37) | NE | ND
SNST word task (# of words)112 | 1 | 18 | 6.80 (−24.02, 37.62) | NE | ND
WAIS overall function112 | 1 | 18 | 0.70 (−16.08, 17.48) | NE | ND
WCST total correct112 | 1 | 18 | −0.50 (−27.56, 26.56) | NE | ND

I^2^ = I–squared; LSEQ = Listening Self-Efficacy Questionnaire; ND = no difference; NE = not estimable; PANSS = Positive and negative symptom scale; SNST = Stroop Neuropsychological Screening Test; WAIS = Wechsler Adult Intelligence Scale; WCST = Wisconsin Card Sorting Test

Table 84 Evidence summary table: fluphenazine versus quetiapine

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive symptoms
BPRS - hostility subscale67 | 1 | 25 | 0.79 (−2.37, 3.95) | NE | ND
General psychopathology
BPRS - activation67 | 1 | 25 | −0.33 (−2.89, 2.23) | NE | ND
BPRS - anxiety/depression67 | 1 | 25 | 0.13 (−3.39, 3.65) | NE | ND

BPRS = Brief Psychiatric Rating Scale; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 85 Evidence summary table: fluphenazine versus risperidone

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive symptoms
BPRS - hostility subscale67 | 1 | 26 | 0.92 (−2.12, 3.96) | NE | ND
General psychopathology
BPRS - Activation subscale67 | 1 | 26 | 0.00 (−2.62, 2.62) | NE | ND
BPRS - Anxiety/depression subscale67 | 1 | 26 | 1.07 (−3.21, 5.35) | NE | ND

BPRS = Brief Psychiatric Rating Scale; I^2^ = I–squared; ND = no difference; NE = not estimable

Table 86 Evidence summary table: haloperidol versus asenapine

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive symptoms
PANSS - hostility/excitement subscale97 | 1 | 335 | −0.70 (−1.54, 0.14) | NE | ND
General psychopathology
PANSS - anxiety/depression subscale97 | 1 | 335 | 0.26 (−0.51, 1.04) | NE | ND
PANSS - disorganized thought subscale97 | 1 | 335 | 0.01 (−0.95, 0.97) | NE | ND

I^2^ = I–squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Syndrome Scale

Table 87 Evidence summary table: haloperidol versus clozapine

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive symptoms
BPRS - hostile/suspiciousness subscale95 | 1 | 71 | 1.40 (0.29, 2.51) | NE | clozapine
BPRS - psychosis cluster subscale95 | 1 | 71 | 2.70 (0.48, 4.92) | NE | clozapine
PANSS - hostility subscale62 | 1 | 77 | 0.71 (0.07, 1.35) | NE | clozapine
PANSS - excitement factor145 | 1 | 77 | −0.60 (−1.20, 0.00) | NE | ND
PANSS - positive factor145 | 1 | 77 | 0.06 (−0.38, 0.50) | NE | ND
Negative symptoms
PANSS - negative factor145 | 1 | 77 | −0.41 (−0.80, −0.02) | NE | haloperidol
SANS - affective flattening subscale95 | 1 | 71 | −0.30 (−0.84, 0.24) | NE | ND
SANS - alogia subscale95 | 1 | 71 | 0.10 (−0.44, 0.64) | NE | ND
SANS - anhedonia/sociality subscale95 | 1 | 71 | −0.30 (−0.89, 0.29) | NE | ND
SANS - avolition/apathy subscale95 | 1 | 71 | 0.20 (−0.36, 0.76) | NE | ND
General psychopathology
BPRS - activation95 | 1 | 71 | 0.60 (−0.26, 1.46) | NE | ND
BPRS - anergia95 | 1 | 71 | −0.70 (−2.55, 1.15) | NE | ND
BPRS - anxiety/depression95 | 1 | 71 | 1.10 (−0.65, 2.85) | NE | ND
BPRS - thought disorder95 | 1 | 71 | 0.30 (−1.68, 2.28) | NE | ND
PANSS - cognitive factor145 | 1 | 77 | −0.03 (−0.36, 0.30) | NE | ND
PANSS - depression/anxiety factor145 | 1 | 77 | −0.05 (−0.46, 0.36) | NE | ND
Functional capacity
Block Design55,105 | 2 | 148 | −0.89 (−2.44, 0.67) | 80% | ND
Cat. Fluency55 | 1 | 75 | −11.50 (−17.71, −5.29) | NE | clozapine
Declarative verbal learning and memory - Neurocognitive testing145 | 1 | 77 | 0.06 (−0.40, 0.52) | NE | ND
Disorientation105 | 1 | 73 | 0.19 (−0.28, 0.66) | NE | ND
Executive function105 | 1 | 73 | 0.15 (−0.12, 0.42) | NE | ND
GCI105 | 1 | 73 | −0.07 (−0.35, 0.21) | NE | ND
General intelligence103 | 1 | 34 | −9.00 (−17.87, −0.13) | NE | clozapine
Judgment of Lines55 | 1 | 75 | −5.00 (−11.96, 1.96) | NE | ND
Memory: Figural55 | 1 | 75 | 0.17 (−0.67, 1.01) | NE | ND
Memory: Logical55 | 1 | 75 | 5.80 (−2.67, 14.27) | NE | ND
Memory: Verbal pairs55 | 1 | 75 | −0.60 (−2.94, 1.74) | NE | ND
Memory: Visual pairs55 | 1 | 75 | −0.90 (−3.09, 1.29) | NE | ND
Memory: Visual Reprod.55 | 1 | 75 | −0.80 (−4.70, 3.10) | NE | ND
Motor function105 | 1 | 73 | −0.29 (−0.60, 0.02) | NE | ND
Neurocognitive Global Score145 | 1 | 77 | −0.19 (−0.43, 0.05) | NE | ND
Neurocognitive testing - General executive and perceptual organization145 | 1 | 77 | −0.19 (−0.46, 0.08) | NE | ND
Neurocognitive testing - Processing speed and attention145 | 1 | 77 | −0.29 (−0.74, 0.16) | NE | ND
Neurocognitive testing - Simple motor Functioning145 | 1 | 77 | −0.55 (−1.00, −0.10) | NE | clozapine
Mooney Faces55 | 1 | 75 | −0.80 (−1.70, 0.10) | NE | ND
MMSE55 | 1 | 75 | −1.14 (−3.56, 1.28) | NE | ND
Poor attention105 | 1 | 75 | 0.21 (−0.25, 0.67) | NE | ND
Stroop55 | 1 | 75 | −1.00 (−5.08, 3.08) | NE | ND
Syndrome short test103 | 1 | 34 | −28.70 (−31.51, −25.89) | NE | clozapine
Trail Making Test A105 | 1 | 73 | −0.27 (−0.78, 0.24) | NE | ND
Trail Making Test B55 | 1 | 75 | 0.00 (−0.10, 0.10) | NE | ND
Verbal fluency55 | 1 | 75 | −1.50 (−7.42, 4.42) | NE | ND
Verbal Memory105 | 1 | 73 | 0.01 (−0.44, 0.46) | NE | ND
Visual Memory105 | 1 | 73 | 0.23 (−0.36, 0.82) | NE | ND
WCST55 | 1 | 75 | 0.40 (−8.02, 8.82) | NE | ND

BPRS = Brief Psychiatric Rating Scale; GCI = General Cognitive Index; I^2^ = I–squared; MMSE = Mini–Mental State Examination; ND = no difference; NE = not estimable; PANSS = Positive and Negative Syndrome Scale; SANS = Scale for the Assessment of Negative Symptoms; WCST = Wisconsin Card Sorting Test

Table 88 Evidence summary table: haloperidol versus olanzapine

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive symptoms
BPRS - anxiety159 | 1 | 27 | 1.40 (−0.54, 3.34) | NE | ND
BPRS - hostility subscale88 | 1 | 182 | 1.75 (1.04, 2.46) | NE | olanzapine
PANSS - hostility subscale62 | 1 | 76 | 0.71 (−0.02, 1.44) | NE | ND
PANSS - PEC56,147 | 2 | 482 | 0.07 (−1.54, 1.67) | 69% | ND
PANSS - excitement factor145 | 1 | 76 | −0.25 (−0.81, 0.31) | NE | ND
PANSS - positive factor145 | 1 | 76 | −0.21 (−0.66, 0.24) | NE | ND
Negative symptoms
BPRS - activation88 | 1 | 182 | 0.74 (−0.19, 1.67) | NE | ND
BPRS - anergia88 | 1 | 182 | 0.33 (−0.60, 1.26) | NE | ND
PANSS - negative factor145 | 1 | 76 | −0.37 (−0.74, 0.00) | NE | ND
SANS - Affective flattening subscale159 | 1 | 27 | 0.38 (−0.48, 1.24) | NE | ND
SANS - Alogia subscale159 | 1 | 27 | 0.08 (−0.84, 1.00) | NE | ND
SANS - Anhedonia subscale159 | 1 | 27 | 0.76 (−0.49, 2.01) | NE | ND
SANS - Attention subscale159 | 1 | 27 | 0.77 (−0.41, 1.95) | NE | ND
SANS - Avoilition subscale159 | 1 | 27 | 0.07 (−0.94, 1.08) | NE | ND
SANS - composite49 | 1 | 267 | 2.93 (−1.35, 7.21) | NE | ND
General psychopathology
BPRS - Psychosis106 | 1 | 32 | −1.10 (−2.59, 0.39) | NE | ND
BPRS - anxiety/depression88 | 1 | 182 | 0.72 (−0.28, 1.72) | NE | ND
PANSS - Cognitive factor145 | 1 | 76 | −0.26 (−0.57, 0.05) | NE | ND
PANSS - Depression/anxiety factor145 | 1 | 76 | −0.19 (−0.56, 0.18) | NE | ND
BPRS - thought disorder88 | 1 | 182 | 0.25 (−0.72, 1.22) | NE | ND
Subjective well-being - emotional regulation subscale78 | 1 | 24 | 1.70 (−1.07, 4.47) | NE | ND
Subjective well-being - mental functioning subscale78 | 1 | 24 | 0.80 (−2.92, 4.52) | NE | ND
Subjective well-being - physical functioning subscale78 | 1 | 24 | 1.80 (−0.62, 4.22) | NE | ND
Subjective well-being - self-control subscale78 | 1 | 24 | 3.20 (0.75, 5.65) | NE | olanzapine
Functional capacity
Attention Span124 | 1 | 44 | −0.22 (−0.59, 0.15) | NE | ND
Block Design105 | 1 | 73 | −0.61 (−1.15, −0.07) | NE | olanzapine
Brief test of attention (correct responses)71 | 1 | 111 | −0.76 (−1.88, 0.36) | NE | ND
COWAT, category/semantic110 | 1 | 35 | −5.13 (−10.50, 0.24) | NE | ND
continuous performance test (correct responses)71 | 1 | 111 | −2.78 (−7.30, 1.74) | NE | ND
Cognitive composite score75 | 1 | 208 | −0.10 (−0.28, 0.08) | NE | ND
COWAT71,110,124,134 | 4 | 250 | −2.64 (−8.48, 3.19) | 78% | ND
CRT54 | 1 | 25 | −50.00 (−163.48, 63.48) | NE | ND
CVLT134 | 1 | 60 | 4.60 (−1.91, 11.11) | NE | ND
D2 Test of Attention54 | 1 | 25 | −1.71 (−37.40, 33.98) | NE | ND
Declarative verbal learning and memory145 | 1 | 76 | −0.34 (−0.74, 0.06) | NE | ND
Design List Learning124 | 1 | 44 | −4.68 (−9.30, −0.06) | NE | olanzapine
Digit Span124 | 1 | 44 | −0.70 (−2.80, 1.40) | NE | ND
Digit Span Backward54 | 1 | 25 | 0.82 (−0.82, 2.46) | NE | ND
Digit Span Distractibility Test54 | 1 | 25 | 7.99 (−13.85, 29.83) | NE | ND
Digit Symbol Subtest124 | 1 | 44 | −4.20 (−9.76, 1.36) | NE | ND
Discrimination of self-generated words101 | 1 | 256 | 0.07 (−0.06, 0.20) | NE | ND
Disorientation105 | 1 | 73 | −0.41 (−0.87, 0.05) | NE | ND
Distractibility task, no. correct110 | 1 | 35 | −2.33 (−7.97, 3.31) | NE | ND
DSC CPT134 | 1 | 60 | 0.05 (−0.01, 0.11) | NE | ND
DSC134 | 1 | 60 | 2.60 (−4.01, 9.21) | NE | ND
Executive function105 | 1 | 73 | −0.03 (−0.29, 0.23) | NE | ND
Executive Skills124 | 1 | 44 | −0.33 (−0.96, 0.30) | NE | ND
Fagerstrom Tolerance Questionnaire102 | 1 | 67 | 2.60 (1.52, 3.68) | NE | haloperidol
Finger Tapping54,124 | 2 | 69 | −4.02 (−10.66, 2.62) | 36% | ND
Finger tapping left, no. taps110 | 1 | 35 | −8.43 (−16.57, −0.29) | NE | ND
Finger tapping right, no. taps110 | 1 | 35 | −7.59 (−18.35, 3.17) | NE | ND
Finger tapping test (mean taps/10 ses)71 | 1 | 111 | 0.27 (−3.15, 3.69) | NE | ND
GCI105 | 1 | 73 | −0.49 (−0.77, −0.21) | NE | olanzapine
General executive and perceptual organization - Neurocognitive testing145 | 1 | 76 | −0.45 (−0.76, −0.14) | NE | olanzapine
GPT134 | 1 | 60 | −14.80 (−42.36, 12.76) | NE | ND
Pegboard54,71,75,124 | 4 | 388 | 3.14 (−2.03, 8.31) | 76% | ND
Hooper Visual Organization Test124 | 1 | 44 | −0.85 (−1.84, 0.14) | NE | ND
Immediate Recall124 | 1 | 44 | −0.63 (−1.03, −0.23) | NE | olanzapine
IOWA gambling71 | 1 | 111 | −16.02 (−31.31, −0.73) | NE | olanzapine
Level of Functioning Scale58 | 1 | 63 | 0.00 (−2.87, 2.87) | NE | ND
LNS54,110,134 | 3 | 120 | 0.56 (−1.99, 3.11) | 63% | ND
memory: Z mean score127 | 1 | 309 | −0.19 (−0.39, 0.01) | NE | ND
MMSE105 | 1 | 73 | −3.89 (−6.32, −1.46) | NE | olanzapine
Motor function105,124,127,145 | 4 | 502 | −0.39 (−0.76, −0.02) | 74% | olanzapine
neurocognitive composite score101,108,145 | 3 | 595 | −0.06 (−0.44, 0.32) | 86% | ND
Nonverbal Fluency124 | 1 | 44 | −3.40 (−6.52, −0.28) | NE | olanzapine
Nonverbal Fluency and Construction124 | 1 | 44 | −0.66 (−1.36, 0.04) | NE | ND
Peabody Picture Vocabulary Test124 | 1 | 44 | −2.68 (−9.54, 4.18) | NE | ND
Poor attention105 | 1 | 73 | −0.59 (−1.05, −0.13) | NE | olanzapine
Processing speed and attention145 | 1 | 76 | −0.49 (−0.87, −0.11) | NE | olanzapine
Rey auditory verbal learning (# words recalled)71 | 1 | 111 | −3.09 (−7.35, 1.17) | NE | ND
Rey auditory verbal learning LTR (# words recalled from list after delay)71 | 1 | 111 | −1.40 (−2.69, −0.11) | NE | olanzapine
Rey complex figure test (long term recall)71 | 1 | 111 | 0.10 (−2.60, 2.80) | NE | ND
Rey Auditory Verbal Learning Test, recognition form75,110 | 2 | 243 | −0.20 (−0.35, −0.06) | 0% | olanzapine
Rey Auditory Verbal Learning Test, sum of trials 1–5^110^ | 1 | 35 | −19.61 (−28.53, −10.69) | NE | olanzapine
Rey-Taylor Complex Figure Copy124 | 1 | 44 | −1.92 (−5.53, 1.69) | NE | ND
Rey-Taylor Complex Figure Immediate Recall124 | 1 | 44 | −0.08 (−3.89, 3.73) | NE | ND
Similarities Subtest124 | 1 | 44 | 0.50 (−1.47, 2.47) | NE | ND
SRT54,124 | 2 | 69 | −2.98 (−8.21, 2.24) | 0% | ND
Stoop54 | 1 | 25 | 0.22 (−4.48, 4.92) | NE | ND
Trail Making Test A75,105,110 | 3 | 316 | −0.38 (−1.17, 0.41) | 79% | ND
Trail Making Test B71,75,110,124 | 4 | 398 | 8.79 (−6.26, 23.85) | 66% | ND
Unweighted Neurocognitive Composite Score based on Z score (change score)108 | 1 | 263 | 0.16 (0.04, 0.28) | NE | haloperidol
VCCQ-intensity score136 | 1 | 31 | −5.90 (−12.36, 0.56) | NE | ND
VCCQ-mood score136 | 1 | 31 | 8.20 (−1.79, 18.19) | NE | ND
VCCQ-sick136 | 1 | 31 | 11.20 (0.85, 21.55) | NE | haloperidol
Verbal STM54 | 1 | 25 | −4.22 (−11.62, 3.18) | NE | ND
Verbal Memory105 | 1 | 73 | −0.82 (−1.26, −0.38) | NE | Olanzapine
Verbal Fluency and Reasoning124 | 1 | 44 | −0.32 (−0.61, −0.03) | NE | olanzapine
Verbal List Learning124 | 1 | 44 | −8.52 (−14.18, −2.86) | NE | olanzapine
Visual Memory Span Backward54 | 1 | 25 | 0.11 (−1.64, 1.86) | NE | ND
Visual Memory Span Forward54 | 1 | 25 | 0.54 (−1.11, 2.19) | NE | ND
Visual Memory105 | 1 | 73 | 0.21 (−0.37, 0.79) | NE | ND
Visual Digit Coding Task110 | 1 | 35 | −10.57 (−17.24, −3.90) | NE | olanzapine
Visual Reproduction124 | 1 | 44 | −0.90 (−2.78, 0.98) | NE | ND
Visual Span124 | 1 | 44 | −0.78 (−2.70, 1.14) | NE | ND
WAIS III backwards digits (total score)71 | 1 | 111 | 0.41 (−0.34, 1.16) | NE | ND
WAIS III digit symbol (total score)71,75 | 2 | 319 | −0.29 (−0.83, 0.24) | 28% | ND
WCST134 | 1 | 60 | 0.80 (−0.15, 1.75) | NE | ND
VCCQ-energy score136 | 1 | 31 | 11.50 (3.69, 19.31) | NE | haloperidol
WCS Test total errors137 | 1 | 29 | 9.32 (2.63, 16.01) | NE | haloperidol
WCST, perseverative errors110,124 | 2 | 79 | 0.05 (−0.07, 0.17) | 0% | ND
Social relatedness/functioning
Subjective well-being, social functioning subscale78 | 1 | 24 | −0.90 (−4.23, 2.43) | NE | ND

Note: bolded results are statistically significant; BPRS = Brief Psychiatric Rating Scale; COWA = Controlled Oral Word Association; COWAT = Controlled Oral Word Association Test; CRT = Clinical Global Impressions; CVLT = California Verbal Learning Test; DS CPT = Degraded Stimuli–Continuous Performance Test; DSC = Degraded Stimuli–Continuous; GCI = General Cognitive Index; GPT = Grooved Pegboard Test; I^2^ = I–squared; LNS = Letter–Number Sequencing; ND = no difference; NE = not estimable; PANSS = Positive and Negative Syndrome Scale; SANS = Scale for the Assessment of Negative Symptoms; SRT = Simple Reaction Time; STM = short-term memory; VCCQ = Voris Cocaine Craving Questionnaire; WAIS = Wechsler Adult; Intelligence Scale; WCST = Wisconsin Card Sorting Test

Table 89 Evidence summary table: haloperidol versus quetiapine

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive symptoms
BPRS - elated mood subscale79 | 1 | 288 | 0.53 (−0.17, 1.23) | NE | ND
Negative symptoms
PANSS - Depressive subscale79 | 1 | 288 | 1.06 (0.32, 1.80) | NE | quetiapine
Functional capacity
Cognition - Attention Span123 | 1 | 25 | −0.20 (−0.68, 0.28) | NE | ND
Cognition - Executive skills/visuomotor tracking123 | 1 | 25 | 0.10 (−0.42, 0.62) | NE | ND
Cognition - General123 | 1 | 25 | −0.10 (−0.49, 0.29) | NE | ND
Cognition - Immediate recall123 | 1 | 25 | −0.20 (−0.67, 0.27) | NE | ND
Cognition - Motor speed/dexterity123 | 1 | 25 | 0.10 (−1.04, 1.24) | NE | ND
Cognition - Verbal reasoning/fluency123 | 1 | 25 | −0.20 (−0.58, 0.18) | NE | ND
Cognition - Visuospatial fluency/construction123 | 1 | 25 | −0.60 (−1.29, 0.09) | NE | ND
Cognitive - composite score75 | 1 | 207 | −0.14 (−0.33, 0.05) | NE | ND
Cognitive - Summary Score143 | 1 | 58 | −0.11 (−0.61, 0.39) | NE | ND
Complex Figure Copy Test123 | 1 | 25 | −1.30 (−3.09, 0.49) | NE | ND
Complex Figure Recall Test123 | 1 | 25 | 1.00 (0.10, 1.90) | NE | haloperidol
Design Learning Test123 | 1 | 25 | −0.40 (−1.35, 0.55) | NE | ND
Finger Tapping123 | 1 | 25 | −0.40 (−1.56, 0.76) | NE | ND
Grooved Pegboard75,123 | 2 | 232 | −0.02 (−0.25, 0.21) | 0% | ND
Hopkins Verbal Learning143 | 1 | 58 | −1.52 (−5.84, 2.80) | NE | ND
Nonverbal fluency123 | 1 | 25 | −0.10 (−0.46, 0.26) | NE | ND
Paragraph Recall143 | 1 | 58 | −0.72 (−3.05, 1.60) | NE | ND
Rey Auditory Verbal Learning Test75 | 1 | 207 | 0.00 (−0.26, 0.26) | NE | ND
Story Recall Test123 | 1 | 25 | −1.00 (−1.91, −0.09) | NE
Stroop Color-Word143 | 1 | 58 | −2.57 (−13.52, 8.37) | NE | ND
Symbol Digit143 | 1 | 58 | 1.14 (−7.55, 9.83) | NE | ND
Trail Making Test A75 | 1 | 207 | −0.04 (−0.22, 0.14) | NE | ND
Trail Making Test B75,123 | 2 | 232 | −0.12 (−0.24, −0.01) | 0% | quetiapine
Trails B-A143 | 1 | 58 | −1.00 (−33.10, 31.10) | NE | ND
Verbal Fluency123,143 | 2 | 83 | −0.42 (−1.02, 0.17) | 0% | ND
Verbal Learning Test123 | 1 | 25 | 0.00 (−0.91, 0.91) | NE | ND
Visual Organization Test123 | 1 | 25 | 0.00 (−0.48, 0.48) | NE | ND
WAIS-III Digit Symbol75 | 1 | 207 | −0.26 (−0.46, −0.06) | NE | ND
WAIS-R Digit Symbol Test123 | 1 | 25 | 0.00 (−0.36, 0.36) | NE | ND
WAIS-R Similarities123 | 1 | 25 | −0.30 (−0.77, 0.17) | NE | ND
WCST (perseverations)123 | 1 | 25 | 0.50 (−0.53, 1.53) | NE | ND
WMS Digit Span123 | 1 | 25 | −0.10 (−0.53, 0.33) | NE | ND
WMS Visual Reproduction123 | 1 | 25 | −0.10 (−1.44, 1.24) | NE | ND
WMS Visual Span123 | 1 | 25 | −0.50 (−1.23, 0.23) | NE | ND

Note: bolded results are statistically significant; BPRS = Brief Psychiatric Rating Scale; PANSS = Positive and Negative Syndrome Scale; WAIS = Wechsler Adult Intelligence Scale; WCST = Wisconsin Card Sorting Test; WMS = Wechsler Memory Scale

Table 90 Evidence summary table: haloperidol versus risperidone

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive symptoms
BPRS - Hostility/suspiciousness subscale113 | 1 | 63 | 0.05 (−0.13, 0.23) | NE | ND
PANSS-derived BPRS - activity subscale120 | 1 | 1362 | 0.30 (−0.11, 0.71) | NE | ND
PANSS-derived BPRS - hostility subscale120 | 1 | 1362 | 0.08 (−0.38, 0.54) | NE | ND
PANSS - hostility subscale62,72 | 2 | 443 | 0.47 (−0.13, 1.06) | 0% | ND
PANSS - excitement factor145 | 1 | 78 | −0.15 (−0.73, 0.43) | NE | ND
PANSS - positive factor145 | 1 | 78 | 0.03 (−0.38, 0.44) | NE | ND
PANSS - Uncontrolled hostility/excitement MADRS118 | 1 | 289 | −0.70 (−1.18, −0.22) | NE | haloperidol
SCL-90-R - Anger/hostility subscale113 | 1 | 63 | 0.22 (0.04, 0.40) | NE | risperidone
SCL-90-R - Obsessive/compulsive subscale113 | 1 | 63 | 0.35 (0.13, 0.57) | NE | risperidone
SCL-90-R - Paranoid ideation subscale113 | 1 | 63 | 0.16 (−0.16, 0.48) | NE | ND
SCL-90-R - Psychotiscism subscale113 | 1 | 63 | 0.17 (−0.09, 0.43) | NE | ND
Negative symptoms
BPRS - emotional withdrawal subscale113 | 1 | 63 | 0.00 (−0.17, 0.17) | NE | ND
CDS-S - depression subscale45 | 1 | 20 | 2.30 (−0.42, 5.02) | NE | ND
PANSS - 5-factor solution118 | 1 | 289 | −1.40 (−2.93, 0.13) | NE | ND
PANSS - negative factor145 | 1 | 78 | −0.14 (−0.53, 0.25) | NE | ND
PANSS-derived BPRS - Anergia120 | 1 | 1362 | 0.36 (−0.12, 0.84) | NE | ND
SANS - Affective Flattening113 | 1 | 63 | −0.02 (−0.35, 0.31) | NE | ND
SANS - Alogia113 | 1 | 63 | −0.01 (−0.29, 0.27) | NE | ND
SANS - Anhedonia113 | 1 | 63 | 0.11 (−0.24, 0.46) | NE | ND
SANS - Attentional impairment score118 | 1 | 289 | −0.20 (−0.47, 0.07) | NE | ND
SANS - Avolition113 | 1 | 63 | 0.06 (−0.26, 0.38) | NE | ND
SANS - Global113 | 1 | 63 | 0.04 (−0.21, 0.29) | NE | ND
SCL-90 - Depression subscale113 | 1 | 63 | 0.46 (0.22, 0.70) | NE | risperidone
General psychopathology
BPRS - Factor I60 | 1 | 62 | −0.52 (−0.84, −0.20) | NE | haloperidol
BPRS - anxiety/depression subscale113,117 | 2 | 98 | 0.18 (−0.13, 0.49) | 51% | ND
BPRS - Factor II60 | 1 | 62 | −0.17 (−0.46, 0.12) | NE | ND
BPRS - Factor III60 | 1 | 62 | −0.11 (−0.51, 0.29) | NE | ND
BPRS - Factor IV60 | 1 | 62 | −0.09 (−0.22, 0.04) | NE | ND
BPRS - Factor V60 | 1 | 62 | −0.13 (−0.45, 0.19) | NE | ND
BPRS - Thought disturbances subscale113,117 | 2 | 98 | −0.10 (−0.33, 0.12) | 0% | ND
PANSS - anxiety/depression subscale72,118,145 | 3 | 732 | 0.25 (−0.26, 0.77) | 50% | ND
PANSS - Cognitive subscale145 | 1 | 78 | −0.13 (−0.42, 0.16) | NE | ND
PANSS - disorganized thought subscale72,118 | 2 | 654 | −0.25 (−2.91, 2.41) | 93% | ND
PANSS-derived BPRS - Anxiety/depression subscale120 | 1 | 1362 | 0.33 (−0.15, 0.81) | NE | ND
PANSS-derived BPRS - Thought disturbances subscale120 | 1 | 1362 | −0.06 (−0.62, 0.50) | NE | ND
Total score
SCL–9–R - Anxiety subscale113 | 1 | 63 | 0.35 (0.13, 0.57) | NE | risperidone
SCL–90–R - Interpersonal sensitivity subsclae113 | 1 | 63 | 0.33 (0.05, 0.61) | NE | risperidone
SCL–90–R - Phobic Anxiety subscale113 | 1 | 63 | 0.33 (0.09, 0.57) | NE | risperidone
SCL–90–R - Somatization subscale113 | 1 | 63 | 0.21 (−0.01, 0.43) | NE | ND
Functional capacity
Attention Span124 | 1 | 44 | 0.08 (−0.24, 0.40) | NE | ND
Brief test of attention (correct responses)71 | 1 | 117 | −0.51 (−1.54, 0.52) | NE | ND
Continuous performance test (correct responses)71 | 1 | 117 | −2.45 (−6.83, 1.93) | NE | ND
COWAT71,124,132,134 | 4 | 776 | −0.95 (−4.20, 2.31) | 62% | ND
CVLT134 | 1 | 60 | 6.20 (−0.31, 12.71) | NE | ND
Design List Learning124 | 1 | 44 | −3.78 (−9.34, 1.78) | NE | ND
Digit Span124 | 1 | 44 | 0.20 (−1.42, 1.82) | NE | ND
Digit Symbol Subtest124 | 1 | 44 | 0.20 (−4.34, 4.74) | NE | ND
Discrimination of self-generated words100 | 1 | 9 | −0.01 (−0.12, 0.10) | NE | ND
DS CPT134 | 1 | 60 | −0.01 (−0.06, 0.04) | NE | ND
DSC134 | 1 | 60 | 0.40 (−6.41, 7.21) | NE | ND
Early night45 | 1 | 20 | 244.45 (−49.52, 538.42) | NE | ND
Executive Skills124 | 1 | 44 | 0.11 (−0.51, 0.73) | NE | ND
Fagerstrom Tolerance Questionnaire102 | 1 | 76 | 1.90 (0.94, 2.86) | NE | haloperidol
Finger Tapping71,124 | 2 | 161 | 0.44 (−6.66, 7.54) | 65% | ND
GAF118 | 1 | 289 | −2.20 (−5.64, 1.24) | NE | ND
GPT134 | 1 | 60 | −1.40 (−25.41, 22.61) | NE | ND
Grooved Pegboard71,124 | 2 | 161 | −0.48 (−17.58, 16.61) | 64% | ND
Hooper Visual Organization Test124 | 1 | 44 | 0.38 (−0.47, 1.23) | NE | ND
Immediate Recall124 | 1 | 44 | −0.22 (−0.58, 0.14) | NE | ND
IOWA gambling71 | 1 | 117 | −11.99 (−26.45, 2.47) | NE | ND
Late night45 | 1 | 20 | 88.89 (−1.54, 179.32) | NE | ND
LNS134 | 1 | 60 | 0.20 (−2.40, 2.80) | NE | ND
Maze tasks CM velocity107 | 1 | 20 | −41.70 (−81.21, −2.19) | NE | risperidone
Maze tasks SM velocity107 | 1 | 20 | −48.00 (−94.88, −1.12) | NE | risperidone
Morning45 | 1 | 20 | −200.00 (−561.65, 161.65) | NE | ND
Motor Skills124 | 1 | 44 | −0.48 (−1.10, 0.14) | NE | ND
Neurocognitive composite score101 | 1 | 255 | −0.06 (−0.27, 0.15) | NE | ND
Neurocognitive Global Score145 | 1 | 78 | −0.46 (−0.73, −0.19) | NE | risperidone
Neurocognitive testing - Declarative verbal learning and memory145 | 1 | 78 | −0.66 (−1.08, −0.24) | NE | risperidone
Neurocognitive testing - General executive and perceptual organization145 | 1 | 78 | −0.44 (−0.77, −0.11) | NE | risperidone
Neurocognitive testing - Simple motor Functioning145 | 1 | 78 | −0.24 (−0.72, 0.24) | NE | ND
Nonverbal Fluency124 | 1 | 44 | −3.60 (−6.17, −1.03) | NE | risperidone
Nonverbal Fluency and Construction124 | 1 | 44 | 0.24 (−0.24, 0.72) | NE | ND
Peabody Picture Vocabulary Test124 | 1 | 44 | 1.02 (−4.41, 6.45) | NE | ND
Perception of emotion99 | 1 | 18 | −6.93 (−10.32, −3.54) | NE | risperidone
Neurocognitive testing - Processing speed and attention145 | 1 | 78 | −0.21 (−0.63, 0.21) | NE | ND
Processing speed: WAIS-R Digit Symbol age-corrected score132 | 1 | 555 | −0.35 (−0.67, −0.03) | NE | risperidone
Rey auditory verbal learning (# words recalled)71 | 1 | 117 | −1.26 (−5.18, 2.66) | NE | ND
Rey auditory verbal learning LTR (# words recalled from list after delay)71 | 1 | 117 | −0.98 (−2.36, 0.40) | NE | ND
Rey complex figure test (long term recall)71 | 1 | 117 | −0.46 (−2.97, 2.05) | NE | ND
Rey Verbal Learning Test: trials 1–5^132^ | 1 | 555 | −1.47 (−3.08, 0.14) | NE | ND
Rey-Taylor Complex Figure Copy124 | 1 | 44 | 2.31 (−0.36, 4.98) | NE | ND
Rey-Taylor Complex Figure Immediate Recall124 | 1 | 44 | −0.08 (−4.15, 3.99) | NE | ND
RVLT: Long-delay free recall132 | 1 | 555 | −0.63 (−1.12, −0.14) | NE | risperidone
RVLT: Recognition discriminability132 | 1 | 555 | −0.78 (−2.85, 1.29) | NE | ND
Similarities Subtest124 | 1 | 44 | −0.65 (−2.11, 0.81) | NE | ND
Sleep time (hrs)45 | 1 | 20 | −0.46 (−2.22, 1.30) | NE | ND
SRM 5 s146 | 1 | 67 | 1.60 (−0.20, 3.40) | NE | ND
SRM 15 s146 | 1 | 67 | 1.50 (−0.20, 3.20) | NE | ND
Story Recall Test124 | 1 | 44 | −2.45 (−7.44, 2.54) | NE | ND
SWM 5 s146 | 1 | 67 | −1.50 (−4.69, 1.69) | NE | ND
SWM 15s146 | 1 | 67 | −2.90 (−5.92, 0.12) | NE | ND
Trail Making Test B71,124 | 2 | 161 | 2.64 (−9.02, 14.30) | 0% | ND
Verbal Fluency and Reasoning124 | 1 | 44 | −0.30 (−0.49, −0.11) | NE | risperidone
Verbal List Learning124 | 1 | 44 | −2.27 (−7.50, 2.96) | NE | ND
Vigilance: Continuous Performance Test d’ total132 | 1 | 555 | 0.08 (−0.01, 0.17) | NE | ND
Visual Reproduction124 | 1 | 44 | 0.45 (−1.33, 2.23) | NE | ND
Visual Span124 | 1 | 44 | 0.47 (−1.31, 2.25) | NE | ND
Waking bouts45 | 1 | 20 | 7.26 (−1.46, 15.98) | NE | ND
WAIS III backwards digits (total score)71 | 1 | 117 | −0.07 (−0.84, 0.70) | NE | ND
WAIS III digit symbol (total score)71 | 1 | 117 | −0.30 (−1.42, 0.82) | NE | ND
WCST Categories107,132,134 | 3 | 635 | −0.21 (−0.84, 0.41) | 37% | ND
WCST Nonperseverative errors107 | 1 | 20 | 19.10 (−10.11, 48.31) | NE | ND
WCST Perseverative errors107,124,132 | 3 | 619 | 0.58 (−2.92, 4.08) | 12% | ND
WCST Perseverative responses107 | 1 | 20 | 5.10 (−16.83, 27.03) | NE | ND
WMS_RVR: Delayed recall total132 | 1 | 555 | −0.81 (−2.15, 0.53) | NE | ND
WMS_RVR: Immediate recall total score132 | 1 | 555 | −0.05 (−1.07, 0.97) | NE | ND
Functional deterioration
Deterioration (Csernasky criterion)118 | 1 | 289 | 0.87 (0.46, 1.64) | NE | haloperidol
Marked clinical deterioration118 | 1 | 289 | 0.84 (0.29, 2.44) | NE | haloperidol
Social relatedness/functioning
Improvement135 | 1 | 100 | 0.65 (0.45, 0.93) * | NE | risperidone
Social Adjustment Scale II- Instrumental role113 | 1 | 63 | −0.01 (−0.55, 0.53) | NE | ND
Social Adjustment Scale II- Intimate relationship113 | 1 | 63 | 0.47 (0.01, 0.93) | NE | haloperidol
Social Adjustment Scale II- Overall Social functioning113 | 1 | 63 | 0.18 (−0.18, 0.54) | NE | ND
Social Adjustment Scale II- Sense of wellbeing113 | 1 | 63 | 0.12 (−0.20, 0.44) | NE | ND
Social Adjustment Scale II - Total Social relatedness/functioning113 | 1 | 63 | 0.05 (−0.25, 0.35) | NE | ND
Social Adjustment Scale II- Social/leisure113 | 1 | 63 | −0.06 (−0.42, 0.30) | NE | ND
SOFAS118 | 1 | 289 | −1.80 (−5.14, 1.54) | NE | ND
Total score118 | 1 | 289 | −1.10 (−4.45, 2.25) | NE | ND
Facial Emotion Identification Test134 | 1 | 60 | −0.50 (−2.26, 1.26) | NE | ND
Half profile nonverbal sensitivity134 | 1 | 60 | 5.20 (0.45, 9.95) | NE | haloperidol
Interpersonal Perception Task - 15^134^ | 1 | 60 | 0.30 (−0.62, 1.22) | NE | ND
Voice Emotion Identification Test134 | 1 | 60 | 0.50 (−1.51, 2.51) | NE | ND

Note: bold = statistically significant;

* binary outcome;

BPRS = Brief Psychiatric Rating Scale; CARS–M = Clinician-Administered Rating Scale for Mania; CDS–S = Calgary Depression Scale for Schizophrenia; CGI–I = Clinical Global Impression–Improvement; CGI–S = Clinical Global Impression–Severity; CI = confidence intervals; CM = Complex Maze; COWAT = Controlled Word Association Test; CVLT = California Verbal Learning Test; DSC–CPT = Degraded Stimuli–Continuous Performance Test; GAF = Global Assessment of Functioning; GPT = Grooved Pegboard Test; HAM–A = Hamilton Rating Scale for Anxiety; HAM–D = Hamilton Rating Scale for Depression; I^2^ = I–squared; LNS = Letter–Number Sequencing; LQLP = Lancashire Quality of Life Profile; MADRS = Montgomery-Asberg Depression Rating Scale; ND = no difference; NE = not estimable; NOSIE = Nurses’ Observation Scale for Inpatient Evaluation; NR = not reported; PANSS = Positive and Negative Syndrome Scale; PPI = Prepulse Inhibition; QLS = Quality of Life Scale; QoL = quality of life; RVLT = Rey Verbal Learning Test; SADS–C = Schedule for Affective Disorders and Schizophrenia–Change; SANS = Scale for the Assessment of Negative Symptoms; SAPS = Scale for the Assessment of Positive Symptoms; SCL = Symptom Check Lis; SM = simple maze; SOFAS = Social and Occupational Functioning Scale; SRM = Spatial Recognition Memory; SWM = Spatial Working Memory; WAIS–R = Wechsler Adult Intelligence Scale–Revised; WCST = Wisconsin Card Sort Test; WMS-RVR = Wechsler Memory Scale - Revised Visual Reproduction; YMRS = Young Mania Rating Scale

Table 91 Evidence summary table: haloperidol versus ziprasidone

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
Functional capacity
Cognitive composite score75 | 1 | 185 | −0.08 (−0.28, 0.12) | NE | ND
Purdue Pegboard Test75 | 1 | 185 | 0.30 (0.05, 0.55) | NE | haloperidol
RVLT75 | 1 | 185 | −0.24 (−0.48, 0.00) | NE | ND
Trail Making Test A75 | 1 | 185 | −0.06 (−0.27, 0.15) | NE | ND
Trail Making Test B75 | 1 | 185 | −0.19 (−0.39, 0.01) | NE | ND
WAIS-III Digit Symbol75 | 1 | 185 | −0.19 (−0.41, 0.03) | NE | ND

Note: bold = statistically significant;

* binary outcome;

I^2^ = I–squared; ND = no difference; NE = not estimable; RVLT = Rey’s Auditory Verbal Learning Test; WAIS = Wechsler Adult Intelligence Scale

## B Bipolar Disorder

Table 92 Evidence summary table: haloperidol versus aripiprazole

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive symptoms
PANSS - Hostility subscale33 | 1 | 332 | −0.50 (−1.09, 0.09) | NE | ND
Mood-Mania
CGI-BP - Mania subscale32,33 | 2 | 679 | 0.13 (−0.17, 0.43) | 44% | ND
Mood-Depression
CGI-BP - Depression subscale32,33 | 2 | 679 | 0.01 (−0.16, 0.18) | 0% | ND
General psychopathology
PANSS - cognitive subscale33 | 1 | 332 | −0.70 (−1.81, 0.41) | NE | ND

Note: bold = statistically significant;

* binary outcome;

CGI—BP = Clinical Global Impressions—Bipolar; I^2^ = I–squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale

Table 93 Evidence summary table: haloperidol versus risperidone

Outcome | Studies | Participants | Effect Estimate | I^2^ | Favors
Positive symptoms
PANSS - hostility subscale90 | 1 | 62 | 0.70 (−1.35, 2.75) | NE | ND
Mood-Mania
CARS-M - Mania subscale90 | 1 | 62 | 4.00 (−1.66, 9.66) | NE | ND
Mood-Depression
HAM-D - core depression90 | 1 | 62 | 1.70 (−1.13, 4.53) | NE | ND
HAM-D - Secondary symptoms90 | 1 | 62 | 1.00 (−0.62, 2.62) | NE | ND
HAM-D - sleep disturbance90 | 1 | 62 | 1.80 (0.20, 3.40) | NE | olanzapine
HAM-D - Somatic symptoms90 | 1 | 62 | 0.70 (−0.44, 1.84) | NE | ND
General psychopathology
PANSS - anxiety/depression subscale90 | 1 | 62 | −0.30 (−2.64, 2.04) | NE | ND
PANSS - disorganized thought subscale90 | 1 | 62 | 0.10 (−2.31, 2.51) | NE | ND

Note: bold = statistically significant;

* binary outcome;

CARS-M = Clinician-Administered Rating Scale for Mania; HAM-D = Hamilton Rating Scale for Depression; I2 = I–squared; ND = no difference; NE = not estimable; PANSS = Positive and Negative Symptom Scale