# Funnel Plots

Funnel plot 1 Haloperidol versus olanzapine–Core symptoms (Sz)–Positive symptoms–PANSS (positive) scale

PANSS = Positive and Negative Syndrome Scale; MD = Mean Difference; SE = Standard Error; Sz = schizophrenia

Begg and Mazumdar rank correlation: p = 0.19; Egger’s regression intercept: p = 0.17

Funnel plot 1 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus olanzapine for core symptoms and positive symptoms on the PANSS scale. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of the PANSS scale for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 0.43 on the mean difference scale. The funnel plot is slightly asymmetrical, with studies showing larger effects for haloperidol.

Funnel plot 2 Haloperidol versus olanzapine–Core symptoms (Sz)–Negative symptoms–PANSS (negative) scale

PANSS = Positive and Negative Syndrome Scale; MD = Mean Difference; SE = Standard Error; Sz = schizophrenia

Begg and Mazumdar rank correlation: p = 1.00; Egger’s regression intercept: p = 0.64

Funnel plot 2 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus olanzapine for core symptoms and negative symptoms on the PANSS scale. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of the PANSS scale for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 1.06 on the mean difference scale. The funnel plot is symmetrical, indicating no publication bias.

Funnel plot 3 Haloperidol versus olanzapine–Core symptoms (Sz)–General psychopathology–PANSS (general psychopathology) scale

PANSS = Positive and Negative Syndrome Scale; MD = Mean Difference; SE = Standard Error; Sz = schizophrenia

Begg and Mazumdar rank correlation: p = 0.59; Egger’s regression intercept: p = 0.55

Funnel plot 3 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus olanzapine for core symptoms and general psychopathology on the PANSS scale. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of the PANSS scale for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 0.53 on mean difference scale. The funnel plot is symmetrical, indicating no publication bias.

Funnel plot 4 Haloperidol versus olanzapine–Core symptoms (Sz)–Total score–PANSS scale

PANSS = Positive and Negative Syndrome Scale; MD = Mean Difference; SE = Standard Error; Sz = schizophrenia

Begg and Mazumdar rank correlation: p = 0.55; Egger’s regression intercept: p = 0.24

Funnel plot 4 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus olanzapine for core symptoms and total score on the PANSS scale. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of the PANSS scale for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 2.31 on the mean difference scale. The funnel plot is symmetrical, indicating no publication bias.

Funnel plot 5 Haloperidol versus olanzapine–Core symptoms (Sz)–Total score–BPRS scale

BPRS = Brief Psychiatric Rating Scale; MD = Mean Difference; SE = Standard Error; Sz = schizophrenia

Begg and Mazumdar rank correlation: p = 0.86; Egger’s regression intercept: p = 0.49

Funnel plot 5 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus olanzapine for core symptoms and total score on the BPRS scale. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of the BPRS scale for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 0.59 on the mean difference scale. The funnel plot is symmetrical, indicating no publication bias.

Funnel plot 6 Haloperidol versus olanzapine–response rates (Sz)

Log = Log Scale; RR = Relative Risk; SE = Standard Error; Sz = schizophrenia

Begg and Mazumdar rank correlation: p = 0.74; Egger’s regression intercept: p = 0.74

Funnel plot 6 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus olanzapine for response rates. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of the response rate for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 0.86 on the relative risk scale. The funnel plot is symmetrical, indicating no publication bias.

Funnel plot 7 Haloperidol versus risperidone–Core symptoms (Sz)–positive score–PANSS (positive) scale

PANSS = Positive and Negative Syndrome Scale; MD = Mean Difference; SE = Standard Error; Sz = schizophrenia

Begg and Mazumdar rank correlation: p = 0.63; Egger’s regression intercept: p = 0.11

Funnel plot 7 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus risperidone for core symptoms and positive score on the PANSS scale. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of the PANSS scale for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 0.64 on the mean difference scale. Tests for publication bias were not significant, although the funnel plot shows some asymmetry due to the two small studies that showed large effects for risperidone.

Funnel plot 8 Haloperidol versus risperidone–Core symptoms (Sz)–negative score–PANSS (negative) scale

PANSS = Positive and Negative Syndrome Scale; MD = Mean Difference; SE = Standard Error; Sz = schizophrenia

Begg and Mazumdar rank correlation: p = 0.97; Egger’s regression intercept: p = 0.69

Funnel plot 8 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus risperidone for core symptoms and negative score on the PANSS scale. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of the PANSS scale for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 0.60 on the mean difference scale. The funnel plot is symmetrical indicating no publication bias.

Funnel plot 9 Haloperidol versus risperidone–Core symptoms (Sz)–General symptoms–PANSS (general psychopathology) scale

PANSS = Positive and Negative Syndrome Scale; MD = Mean Difference; SE = Standard Error; Sz = schizophrenia

Begg and Mazumdar rank correlation: p = 0.26; Egger’s regression intercept: p = 0.61

Funnel plot 9 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus risperidone for core symptoms and positive score on the PANSS scale. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of the PANSS scale for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at negative two on the mean difference scale. Tests for publication bias were not significant, although the funnel plot shows some asymmetry due to the two small studies that showed large effects for risperidone.

Funnel plot 10 Haloperidol versus risperidone–Core symptoms (Sz)–Total score–PANSS scale

PANSS = Positive and Negative Syndrome Scale; MD = Mean Difference; SE = Standard Error; Sz = schizophrenia

Begg and Mazumdar rank correlation: p = 0.35; Egger’s regression intercept: p = 0.01

Funnel plot 10 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus risperidone for core symptoms and total score on the PANSS scale. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of the PANSS scale for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 2.23 on the mean difference scale. There was some suggestion of publication bias based on visual inspection of the funnel plot, with one small study showing a large effect for risperidone.

Funnel plot 11 Haloperidol versus risperidone–Core symptoms (Sz)–Total score–BPRS scale

BPRS = Brief Psychiatric Rating Scale; MD = Mean Difference; SE = Standard Error; Sz = schizophrenia

Begg and Mazumdar rank correlation: p = 0.50; Egger’s regression intercept: p = 0.14

Funnel plot 11 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus risperidone for core symptoms and total score on the BPRS scale. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of the BPRS scale for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 0.51 on the mean difference scale. The funnel plot is symmetrical indicating no publication bias.

Funnel plot 12 Haloperidol versus risperidone–response rates (Sz)

Log = Log Scale; RR = Relative Risk; SE = Standard Error; Sz = schizophrenia

Begg and Mazumdar rank correlation: p = 0.03; Egger’s regression intercept: p = 0.006

Funnel plot 12 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus risperidone for response rates. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of the response rates for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 0.94 on the mean difference scale. There was a suggestion of publication bias as the funnel was asymmetrical with more small trials favoring risperidone.

Funnel plot 13 Haloperidol versus olanzapine–withdrawals due to adverse events

Log = Log Scale; RR = Relative Risk; SE = Standard Error

Begg and Mazumdar rank correlation: p = 0.17; Egger’s regression intercept: p = 0.02

Funnel plot 13 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus olanzapine for rates of withdrawals due to adverse events. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of withdrawals due to adverse events for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 1.87 on the mean difference scale. The funnel plot shows some asymmetry.

Funnel plot 14 Haloperidol versus risperidone–withdrawals due to adverse events

Log = Log Scale; RR = Relative Risk; SE = Standard Error

Begg and Mazumdar rank correlation: p = 0.26; Egger’s regression intercept: p = 0.28

Funnel plot 14 is a scatterplot that explores potential publication bias for studies comparing haloperidol versus risperidone for rates of withdrawals due to adverse events. The mean difference is plotted along the X-axis and standard error is plotted along the Y-axis. The point estimate of withdrawals due to adverse events for each study is represented by a square dot. A broken line, which represents the point estimate of the meta-analysis is positioned at 1.27 on the mean difference scale. The funnel plot is symmetrical indicating no publication bias.