# Forest Plots for Adverse Events

Forest plot 1 Chlorpromazine versus clozapine–Withdrawal due to adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 1 is a metagraph comparing the rate of withdrawal due to adverse events between patients receiving chlorpromazine and clozapine. Five trials with 463 patients contributing data were pooled and found no difference between groups (MD=1.70, 95 percent CI, 0.65, 4.45); however there was moderate statistical heterogeneity (p=0.19, I2=34%) between studies.

Forest plot 2 Chlorpromazine versus clozapine–Specific adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 2 is a metagraph comparing specific adverse events between patients receiving chlorpromazine and clozapine. Five studies, (n=563) reported dry mouth, which occurred significantly less with clozapine (MD=3.00, 95 percent CI, 1.67, 5.40); slight heterogeneity was present between studies (p=0.34, I2=11%). Six studies (n=451) reported EPS, and found they occurred significantly less with clozapine (MD=2.75, 95 percent CI, 1.48, 5.12). Hypersalivation was reported in nine trials (n=674) and it occurred significantly less with chlorpromazine (MD=0.25, 95 percent CI, 0.14, 0.45); slight heterogeneity was present between studies (p=0.33, I2=13%). Five studies (n=543) reported on hypotension and found no difference between groups (MD=1.94, 95 percent CI, 0.91, 4.13); moderate heterogeneity existed between studies (p=0.10, I2=49%).

Forest plot 3 Haloperidol versus aripiprazole–Withdrawal due to adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 3 is a metagraph comparing the rate of withdrawal due to adverse events between patients receiving haloperidol versus aripiprazole. The data from seven studies (n=3,035) was pooled and found that withdrawals occurred less in haloperidol (MD=1.25, 95 percent CI, 1.06, 1.47).

Forest plot 4 Haloperidol versus aripiprazole–Specific adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 4 is a metagraph comparing the specific adverse events between patients receiving haloperidol versus aripiprazole. Seven studies (2,979) found that akathisia occurred significantly less with aripiprazole (MD=2.04, 95 percent CI, 1.70, 2.44). Six studies (n=2,945) provided data for EPS and found they occurred significantly less with aripiprazole (MD=2.22, 95 percent CI, 1.37, 3.59); heterogeneity was considerable (p<0.0001, I2 = 83%). Seven studies (n=3,240) reported on headache and found no difference between groups (MD=1.00, 95 percent CI, 0.81, 1.24). Seven studies (n=3,044) found no difference between groups for insomnia (MD=0.85, 95 percent CI, 0.59, 1.23); heterogeneity was substantial (p=0.009, I2=65%). Serious adverse events were reported in six studies (n=1,741), but no difference was found between groups (0.84, 95 percent CI, 0.35, 2.03); heterogeneity was substantial (p=0.03, I2=58%). Six trials (n=2,893) found that somnolence occurred significantly less with aripiprazole (MD=1.39, 95 percent CI, 1.03, 1.87). Five trials (n=2,380) reported that tremor occurred significantly less with aripiprazole (MD=1.99, 95 percent CI, 1.42, 2.78); heterogeneity was minimal (p=0.38, I2=4%).

Forest plot 5 Haloperidol versus clozapine– Withdrawal due to adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 5 is a metagraph comparing the rate of withdrawal due to adverse events between patients receiving haloperidol versus clozapine. Five studies contributed data from 719 patients and found no difference between treatment groups (MD=1.00, 95 percent CI, 0.66, 1.50).

Forest plot 6 Haloperidol versus olanzapine–Withdrawal due to adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 6 is a metagraph comparing the rate of withdrawal due to adverse events between patients receiving haloperidol versus olanzapine. When the findings of twenty-one studies (n=5,351) were pooled, olanzapine was shown to cause significantly fewer withdrawals due to adverse events (MD=1.87, 95 percent CI, 1.55, 2.27).

Forest plot 7 Haloperidol versus olanzapine–Specific adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plots 7 and 8 are metagraphs comparing the specific adverse events between patients receiving haloperidol versus olanzapine. Fourteen studies (n=5,031) reported that akathisia occurred significantly less with olanzapine (MD=3.11, 95 percent CI, 2.43, 3.98); statistical heterogeneity was moderate (p=0.08, I2=38%). Eight studies (n=2,144) reported that dystonia occurred significantly less with olanzapine (MD=5.01, 95 percent CI, 2.70, 9.28). Five studies (n=2,657) reported on dry mouth and found that it occurred significantly less with haloperidol (MD=0.75, 95 percent CI, 0.62, 0.91). EPS were reported in six studies (n=3,445) and found they occurred significantly less with olanzapine (MD=3.88, 95 percent CI, 2.19, 6.85); statistical heterogeneity was substantial (p=0.007, I2=69%). Six studies (n=3,200) reported on hypersalivation and found it occurred significantly less with olanzapine (MD=3.38, 95 percent CI, 1.79, 6.38); heterogeneity was moderate (p=0.08, I2=49%). Seven studies (n=3,717) reported on insomnia and found it occurred significantly less with olanzapine (MD=1.36, 95 percent CI, 1.03, 1.80); heterogeneity was moderate (p=0.07, I2=49%). Eight studies (n=1,283) reported on parkinsonism and found it occurred significantly less in olanzapine (MD=4.28, 95 percent CI, 2.49, 7.35); heterogeneity was moderate (p=0.05, I2=50%). Six studies (n=1,296) provided data for somnolence and found no difference (MD=0.84, 95 percent CI, 0.63, 1.12); heterogeneity was moderate (p=0.17, I2=35%). Tremor was reported in nine studies (n=3,999) and was found to occur significantly less in olanzapine (MD=2.30, 95 percent CI, 1.59, 3.34); heterogeneity was substantial (p=0.01, I2=58%). Fifteen studies (n=4,600) reported on weight gain and found it to occur significantly less with haloperidol (MD=0.47, 95 percent CI, 0.37, 0.61); heterogeneity was substantial (p<0.00001, I2=75%).

Forest plot 8 Haloperidol versus olanzapine–Specific adverse events (continued)

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plots 7 and 8 are metagraphs comparing the specific adverse events between patients receiving haloperidol versus olanzapine. Fourteen studies (n=5,031) reported that akathisia occurred significantly less with olanzapine (MD=3.11, 95 percent CI, 2.43, 3.98); statistical heterogeneity was moderate (p=0.08, I2=38%). Eight studies (n=2,144) reported that dystonia occurred significantly less with olanzapine (MD=5.01, 95 percent CI, 2.70, 9.28). Five studies (n=2,657) reported on dry mouth and found that it occurred significantly less with haloperidol (MD=0.75, 95 percent CI, 0.62, 0.91). EPS were reported in six studies (n=3,445) and found they occurred significantly less with olanzapine (MD=3.88, 95 percent CI, 2.19, 6.85); statistical heterogeneity was substantial (p=0.007, I2=69%). Six studies (n=3,200) reported on hypersalivation and found it occurred significantly less with olanzapine (MD=3.38, 95 percent CI, 1.79, 6.38); heterogeneity was moderate (p=0.08, I2=49%). Seven studies (n=3,717) reported on insomnia and found it occurred significantly less with olanzapine (MD=1.36, 95 percent CI, 1.03, 1.80); heterogeneity was moderate (p=0.07, I2=49%). Eight studies (n=1,283) reported on parkinsonism and found it occurred significantly less in olanzapine (MD=4.28, 95 percent CI, 2.49, 7.35); heterogeneity was moderate (p=0.05, I2=50%). Six studies (n=1,296) provided data for somnolence and found no difference (MD=0.84, 95 percent CI, 0.63, 1.12); heterogeneity was moderate (p=0.17, I2=35%). Tremor was reported in nine studies (n=3,999) and was found to occur significantly less in olanzapine (MD=2.30, 95 percent CI, 1.59, 3.34); heterogeneity was substantial (p=0.01, I2=58%). Fifteen studies (n=4,600) reported on weight gain and found it to occur significantly less with haloperidol (MD=0.47, 95 percent CI, 0.37, 0.61); heterogeneity was substantial (p<0.00001, I2=75%).

Forest plot 9 Haloperidol versus quetiapine–Withdrawal due to adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 9 is a metagraph comparing the rates of withdrawal due to adverse events between patients receiving haloperidol versus quetiapine. Eight studies (n=1,559) were pooled and no difference between groups was found (MD=1.98, 95 percent CI, 0.79, 4.96); however heterogeneity was substantial (p=0.001. I2=73%).

Forest plot 10 Haloperidol versus quetiapine–Specific adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 10 is a metagraph comparing the specific adverse events between patients receiving haloperidol versus quetiapine. For rates of akathisia five trials contributed 1,454 patients, which when pooled showed that rates were significantly less with quetiapine (MD=3.51, 95 percent CI, 1.84, 6.72); however heterogeneity was substantial (p=0.01, I2=68%). Five studies (n=1,292) reported on EPS and found they occurred significantly less in quetiapine (MD=2.49, 95 percent CI, 1.15, 5.39); however heterogeneity was considerable (p<0.00001, I2=90%).

Forest plot 11 Haloperidol versus risperidone–Incidence of patients with adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 11 is a metagraph comparing the adverse events between patients receiving haloperidol versus risperidone. Eight studies (n=1,313) were pooled together and found that adverse events occurred significantly less with risperidone (MD=1.20, 95 percent CI, 1.01, 1.42); however statistical heterogeneity was considerable (p<0.00001, I2=84%).

Forest plot 12 Haloperidol versus risperidone–Withdrawal due to adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 12 is a metagraph comparing the rates of withdrawal due to adverse events between patients receiving haloperidol versus risperidone. Twenty-three studies with 4,421 patients provided data for this comparison and found that significantly fewer withdrawals occurred with risperidone (MD=1.27, 95 percent CI, 1.04, 1.55).

Forest plot 13 Haloperidol versus risperidone–Specific adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 13 is a metagraph comparing the specific adverse events between patients receiving haloperidol versus risperidone. Seven studies (n=619) found that akathisia occurred significantly less with risperidone (MD=1.78, 95 percent CI, 1.30, 2.43). Five studies contributed data from 1,596 patients and reported significantly fewer events of asthenia with risperidone (MD=1.19, 95 percent CI, 1.01, 1.40). Seven studies (n=1,870) reported on rates of constipation and no difference was found (MD=1.04, 95 percent CI, 0.61, 1.78); moderate statistical heterogeneity was present (p=0.16, I2=35%). Five studies (n=675) were pooled and found no difference in rates of EPS (MD=1.88, 95 percent CI, 1.49. 2.37). Nine studies (n=964) reported no significant difference for rates of headache (MD=0.83, 95 percent CI, 0.65, 1.06). Insomnia was reported in six studies (n=2,078) and found no difference (MD=1.08, 95 percent CI, 0.87, 1.34). Five studies (n=511) reported no difference on nausea/vomiting (MD=1.14, 95 percent CI, 0.72, 1.82). Five studies (n=549) reported somnolence and found no difference between groups (MD=1.09, 95 percent CI, 0.79, 1.49).

Forest plot 14 Haloperidol versus ziprasidone–Incidence of patients with adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 14 is a metagraph comparing the incidence of adverse events in patients receiving haloperidol versus ziprasidone. Six trials (n=1,448) were pooled and reported that significantly fewer adverse events occurred with ziprasidone (MD=1.13, 95 percent CI, 1.03, 1.23); statistical heterogeneity was moderate (p=0.20, I2=31%).

Forest plot 15 Haloperidol versus ziprasidone–Withdrawal due to adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 15 is a metagraph comparing the incidence of withdrawals due to adverse events between patients receiving haloperidol versus ziprasidone. Six trials pooled data from 1,551 patients and found that withdrawals due to adverse events occurred significantly less with ziprasidone (MD=1.73, 95 percent CI, 1.30, 2.32).

Forest plot 16 Haloperidol versus ziprasidone–Specific adverse events

CI = confidence intervals; df = degrees of freedom; I^2^ = I–squared; IV = inverse variance; M-H = Mantel-Haenszel

Forest plot 16 is a metagraph comparing the incidence of specific adverse events between patients receiving haloperidol versus ziprasidone. Akathisia was reported in six studies (n=2,060) and found no difference between groups (MD=1.58, 95 percent CI, 1.00, 2.50); however considerable heterogeneity was present (p=0.0001, I2=80%). Six studies (n=2,060) found no difference between groups for ECG abnormalities (MD=0.84, 95 percent CI, 0.53, 1.31). Five studies (n=1,594) found that EPS occurred significantly less with ziprasidone (MD=2.34, 95 percent CI, 1.56, 3.53); however heterogeneity was substantial (p=0.03, I2=63%). Five studies (n=1,875) reported no difference between groups for somnolence (MD=0.89, 95 percent CI, 0.70, 1.12); heterogeneity was slight (p=0.18, I2=36). Tremor was reported in five studies (n=1,875), which showed significantly fewer occurrences with ziprasidone (MD=2.55, 95 percent, 1.79, 1.63); slight heterogeneity was found (p=0.39, I2=4%).